# Appendix G: Excluded Studies

Executive summary of the clinical guidelines on the identification, evaluation, and treatment of overweight and obesity in adults. Arch Intern Med 1998;158(17):1855–67. [Rec#: 545]
Excluded. Topic unrelated.
Prevention of obesity in American Indian children: the Pathways study. American journal of clinical nutrition 1999;69(4 Suppl):745S–824S. [Rec#: 233]
Excluded. Topic unrelated.
Abramson R, Garg M, Cioffari A, Rotman P A. An evaluation of behavioral techniques reinforced with an anorectic drug in a double-blind weight loss study. J Clin Psychiatry. 1980;41(7):234-7. [Rec#: 546]. [pmid: 6993445].
Excluded. Duration of treatment < 6 months.
Agurs-Collins T D, Kumanyika S K, Ten Have T R, Adams-Campbell L L. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20(10):1503-11. [Rec#: 827]. [pmid: 9314625].
Excluded. Duration of treatment < 6 months.
Albach E, Gianoli A C. [Therapy of obesity. The initial and continued effectiveness of tenuate in intermittent therapy of moderately and severely obese patients. Double-blind study]. Fortschr Med. 1977;95(33):2040-4. [Rec#: 886]. [pmid: 334650].
Excluded. Topic unrelated.
Alford B B, Blankenship A C, Hagen R D. The effects of variations in carbohydrate, protein, and fat content of the diet upon weight loss, blood values, and nutrient intake of adult obese women. J Am Diet Assoc. 1990;90(4):534-40. [Rec#: 828]. [pmid: 2319073].
Excluded. Diet, not reviewed further.
Allen G S. A double-blind clinical trail of diethylpropion hydrochloride, mazindol, and placebo inthe treatment of exogenous obesity. Curr Ther Res. 1997;22:678-685. [Rec#: 547].
Excluded. Mazindol, not reviewed.
Allison D B, Fontaine K R, Heshka S, Mentore J L, Heymsfield S B. Alternative treatments for weight loss: a critical review. Critical Reviews in Food Science and Nutrition. 2001;41(1):1-28. [Rec#: 505]. [pmid: 11152041].
Excluded. Subject unrelated.
Amador M, Ramos L T, Morono M, Hermelo M P. Growth rate reduction during energy restriction in obese adolescents. Exp Clin Endocrinol. 1990;96(1):73-82. [Rec#: 548]. [pmid: 2279528].
Excluded. Subject unrelated.
Andelman M B, Jones C, Nathan S. Treatment of obesity in underprivileged adolescents. Comparison of diethylpropion hydrochloride with placebo in a double-blind study. Clin Pediatr (Phila). 1967;6(6):327-30. [Rec#: 399]. [pmcid: 358331]. [pmid: 12490205].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Andersen T, Fogh J. Weight loss and delayed gastric emptying following a South Americanherbal preparation in overweight patients. Journal of Human Nutrition and Dietetics. 2001;14(3):243-250. [Rec#: 506]. [pmid: 11424516].
Excluded. Subject unrelated.
Andersen T, Hyldstrup L, Quaade F. [Pre-meal satiation, meal replacement and conventional diet compared in a randomized clinical trial. Protein powder in the treatment of moderate obesity]: <Original> Proteinpulver i behandlingen af moderat adipositas. Nordisk medicin. 1983;98(6–7):180-3. [Rec#: 254]. [pmid: 6878025].
Excluded. Duration of treatment < 6 months.
Anderson J W, Hamilton C C, Crown-Weber E, Riddlemoser M, Gustafson N J. Safety and effectiveness of a multidisciplinary very-low-calorie diet program for selected obese individuals. J Am Diet Assoc. 1991;91(12):1582-4. [Rec#: 976]. [pmid: 1960353].
Excluded. Diet, not reviewed further.
Anderson J W, Konz E C, Frederich R C, Wood C L. Long-term weight-loss maintenance: a meta-analysis of US studies. Am J Clin Nutr. 2001;74(5):579-84. [Rec#: 957]. [pmid: 11684524].
Excluded. Diet, not reviewed further.
Anderson J W, Brinkman V L, Hamilton C C. Weight loss and 2-yr follow-up for 80 morbidly obese patients treated with intensive very-low-calorie diet and an education program. Am J Clin Nutr. 1992;56:244S-246S. [Rec#: 1018]. [pmid: 1615891].
Excluded. Diet, not reviewed further.
Anderson J W, Hamilton C C, Brinkman-Kaplan V. Benefits and risks of an intensive very-low-calorie diet program for severe obesity. Am J Gastroenterol. 1992;87(1):6-15. [Rec#: 1019]. [pmid: 1728126].
Excluded. Diet, not reviewed further.
Anderson J W, Vichitbandra S, Qian W, Kryscio R J. Long-term weight maintenance after an intensive weight-loss program. J Am Coll Nutr. 1999;18(6):620-7. [Rec#: 1020]. [pmid: 10613414].
Excluded. Diet, not reviewed further.
Anderson R T, Hogan P, Appel L, Rosen R, Shumaker S A. Baseline correlates with quality of life among men and women with medication-controlled hypertension. The trial of nonpharmacologic interventions in the elderly (TONE). J Am Geriatr Soc. 1997;45(9):1080-5. [Rec#: 12]. [pmid: 9288015].
Excluded. Topic unrelated.
Andersen T, Backer O G, Stokholm K H, et al. Randomized trial of diet and gastroplasty compared with diet alone in morbid obesity. New England journal of medicine. 1984;310(6):352-6. [pmid: 6690963].
Notes: Quality Reviewed for Surgery Analyses. Reports on Diethylproprion; no analysis performed, summary of recent meta-analysis provided.
Andersen T, Stokholm K H, Backer O G, et al. Long-term (5-year) results after either horizontal gastroplasty or very- low-calorie diet for morbid obesity. Int J Obes. 1988;12(4):277-84. [pmid: 3058614].
Notes: Quality Reviewed for Surgery Analyses. Reports on Diethylproprion; no analysis performed, summary of recent meta-analysis provided.
Anderssen S, Holme I, Urdal P, Hjermann I. Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4(6):343-9. [Rec#: 13]. [pmid: 8746601].
Excluded. Diet, not reviewed further.
Anderssen S A, Haaland A, Hjermann I, Urdal P, Gjesdal K, Holme I. Oslo Diet and Exercise Study: a one-year randomized intervention trial. Effect on hemostatic variables and other coronary risk factors. Nutrition Metabolism & Cardiovascular Diseases. 1995;5(3):189-200. [Rec#: 16].
Excluded. Rejected at abstract.
Anderssen S A, Hjermann I, Urdal P, Torjesen P A, Holme I. Improved carbohydrate metabolism after physical training and dietary intervention in individuals with the "atherothrombogenic syndrome'. Oslo Diet and Exercise Study (ODES). A randomized trial. J Intern Med. 1996;240(4):203-9. [Rec#: 14]. [pmid: 8918511].
Excluded. Diet, not reviewed further.
Anderssen S A, Holme I, Urdal P, Hjermann I. Associations between central obesity and indexes of hemostatic, carbohydrate and lipid metabolism. Results of a 1-year intervention from the Oslo Diet and Exercise Study. Scand J Med Sci Sports. 1998;8(2):109-15. [Rec#: 15]. [pmid: 9564716].
Excluded. Diet, not reviewed further.
Andersson I, Adolfsson B, Apelman J, Bengtsson B, Rossner S, Thorne A. Prospective randomised controlled study with a 3 year follow-up-behaviour modification + adjustable gastric banding (AGB) vs AGB. Int J Obes Relat Metab Disord. 2001;25(Supplement 2):S27. [Rec#: 446]. [pmid: 11933881].
Excluded. Topic unrelated.
Angrisani L, Alkilani M, Basso N, et al. Laparoscopic Italian experience with the Lap-Band. Obes Surg. 2001;11(3):307-10. [pmid: 11433906].
Excluded. Topic: not on weight loss or surgery complication.
Apfelbaum M, Vague P, Ziegler O, Hanotin C, Thomas F, Leutenegger E. Long-term maintenance of weight loss after a very-low-calorie diet: a randomized blinded trial of the efficacy and tolerability of sibutramine. Am J Med. 1999;106(2):179-84. [Rec#: 17]. [pmid: 10230747].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Appel L J, Moore T J, Obarzanek E, Vollmer W M, Svetkey L P, Sacks F M, et al. A clinical trial of the effects of dietary patterns on blood pressure. DASH Collaborative Research Group. N Engl J Med. 1997;336(16):1117-24. [Rec#: 829]. [pmid: 9099655].
Excluded. Topic unrelated.
Appel L J, Espeland M, Whelton P K, Dolecek T, Kumanyika S, Applegate W B, et al. Trial of Nonpharmacologic Intervention in the Elderly (TONE). Design and rationale of a blood pressure control trial. Ann Epidemiol. 1995;5(2):119-29. [Rec#: 18]. [pmid: 7795830].
Excluded. Topic unrelated.
Appel L J, Espeland M A, Easter L, Wilson A C, Folmar S, Lacy C R. Effects of reduced sodium intake on hypertension control in older individuals: results from the Trial of Nonpharmacologic Interventions in the Elderly (TONE). Arch Intern Med. 2001;161(5):685-93. [Rec#: 19]. [pmid: 11231700].
Excluded. Topic unrelated.
Appel L J, Hebert P R, Cohen J D, Obarzanek E, Yamamoto M, Buring J, et al. Baseline characteristics of participants in phase II of the Trials of Hypertension Prevention (TOHP II). Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):149-55. [Rec#: 20]. [pmid: 7795833].
Excluded. Topic unrelated.
Appolinario Jose C, Godoy-Matos Amelio, Fontenelle Leonardo F, CarraroLucia, Cabral Monica, Vieira Andrea, et al. An open-label trial of sibutramine in obese patients with binge-eating disorder. Journal of Clinical Psychiatry. 2002;63(1):28-30. [Rec#: 447]. [pmid: 11838622].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Aro A, Uusitupa M, Voutilainen E, Hersio K, Korhonen T, Siitonen O. Improved diabetic control and hypocholesterolaemic effect induced by long-term dietary supplementation with guar gum in type 2 (insulin- independent) diabetes. Diabetologia. 1981;21(1):29-33. [Rec#: 550]. [pmid: 6268475].
Excluded. Subject unrelated.
Aro A, Uusitupa M, Voutilainen E, Korhonen T. Effects of guar gum in male subjects with hypercholesterolemia. Am J Clin Nutr. 1984;39(6):911-6. [Rec#: 551]. [pmid: 6326562].
Excluded. Subject unrelated.
Arterburn D, Noel PH. Effects of drug treatment for obesity in adults. Clin Evid 2001;412–419. [Rec#: 698]
Excluded. Study design, review or meta-analysis.
Ash S, Reeves M M, Yeo S, Morrison G, Carey D, Capra S. Effect of intensive dietetic interventions on weight and glycaemic control in overweight men with Type II diabetes: a randomised trial. Int J Obes Relat Metab Disord. 2003;27(7):797-802. [Rec#: 974]. [pmid: 12821964].
Excluded. Subject unrelated.
Ashley J M, St Jeor S T, Schrage J P, Perumean-Chaney S E, Gilbertson M C, McCall N L, et al. Weight control in the physician's office. Archives of Internal Medicine. 2001;161(13):1599-1604. [Rec#: 508]. [pmid: 11434791].
Excluded. Subject unrelated.
Ashley J M, StJeor S T, Perumean-Chaney S, Schrage J, Bovee V. Meal replacements in weight intervention. Obesity Research. 2001;9(Suppl. 4):312S-320S. [Rec#: 507]. [pmid: 11918343].
Excluded. Subject unrelated.
Ashutosh K, Methrotra K, Fragale-Jackson J. Effects of sustained weight loss and exercise on aerobic fitness in obese women. J Sports Med Phys Fitness. 1997;37(4):252-7. [Rec#: 21]. [pmid: 9509823].
Excluded. Subject unrelated.
Astrup A, <Editors> Herpetz S, Saller B. The role of dietary fat in the prevention and treatment of obesity.Efficacy and safety of low-fat diets. Int J Obes Relat Metab Disord 2001;25(Supplement 1):S46–S50. [Rec#: 509]
Excluded. Diet, not reviewed further.
Astrup A, Grunwald G K, Melanson E L, Saris W H, Hill J O. The role of low-fat diets in body weight control: a meta-analysis of ad libitum dietary intervention studies. Int J Obes Relat Metab Disord. 2000;24(12):1545-52. [Rec#: 830]. [pmid: 11126204].
Excluded. Diet, not reviewed further.
Astrup A, Ryan L, Grunwald G K, Storgaard M, Saris W, Melanson E, et al. The role of dietary fat in body fatness: evidence from a preliminary meta-analysis of ad libitum low-fat dietary intervention studies. Br J Nutr. 2000;83 Suppl 1:S25-32. [Rec#: 831]. [pmid: 10889789].
Excluded. Diet, not reviewed further.
Astrup A, Toubro S. When, for whom and how to use sibutramine?. Int J Obes Relat Metab Disord. 2001;25 Suppl 4:S2-7. [Rec#: 819]. [pmid: 11916101].
Excluded. Study design, review or meta-analysis.
Atkinson R L, Greenway F L, Bray G A, Dahms W T, Molitch M, HamiltonK N A ;, et al. Treatment of obesity: comparison of physician and nonphysician therapists using placebo and anorectic drugs in a double-blind trial. Int J Obes. 1977;1(2):113-20. [Rec#: 261]. [pmid: 363629].
Excluded. Mazindol, not reviewed.
Atomi Y, Miyashita M. Influences of weight reduction on aerobic power and body composition of middle-aged women. J Sports Med Phys Fitness. 1987;27(4):501-9. [Rec#: 977]. [pmid: 3444336].
Excluded. Diet, not reviewed further.
Bach D S, Rissanen A M, Mendel C M, Shepherd G, Weinstein S P, Kelly F, et al. Absence of cardiac valve dysfunction in obese patients treated with sibutramine. Obes Res. 1999;7(4):363-9. [Rec#: 887]. [pmid: 10440592].
Excluded. Topic unrelated.
Baird I M, Howard A N. A double-blind trial of mazindol using a very low calorie formula diet. Int J Obes. 1977;1(3):271-8. [Rec#: 400]. [pmid: 363631].
Excluded. Mazindol, not reviewed.
Bakhoj S, Nielsen C, Toubro S, Astrup A. A randomised trial on weight maintenance including a low-fat aromatic gastronomy course. Int J Obes Relat Metab Disord. 2001;25(Supplement 2):S113. [Rec#: 448]. [pmid: 11933881].
Excluded. Subject unrelated.
Ball GDC, Marshall DJ, McCargar LJ. A comparison of two weight management programs for obese children. Obes Res. 2000 8:45(Abstract) [Rec#: 978]
Excluded. Subject unrelated.
Ballinger Anne, Peikin Steven R. Orlistat: Its current status as an anti-obesity drug. European Journal of Pharmacology. 2002;440(2–3):109-117. [Rec#: 449]. [pmid: 12007542].
Excluded. Study design, review or meta-analysis.
Ballor D L, Katch V L, Becque M D, Marks C R. Resistance weight training during caloric restriction enhances lean body weight maintenance. Am J Clin Nutr. 1988;47(1):19-25. [Rec#: 979]. [pmid: 3337037].
Excluded. Diet, not reviewed further.
Bandisode M S, Boshell B R. Double-blind clinical evaluation of mazindol (42–548) in obese diabetics. Curr Ther Res Clin Exp. 1975;18(6):816-24. [Rec#: 552]. [pmid: 813947].
Excluded. Mazindol, not reviewed.
Baranowski T, Baranowski J C, Cullen K W, Thompson D I, Nicklas T, Zakeri I E, et al. The Fun, Food, and Fitness Project (FFFP): the Baylor GEMS pilot study. Ethn Dis. 2003;13(1 Suppl 1):S30-9. [Rec#: 869]. [pmid: 14964185].
Excluded. Duration of treatment < 6 months.
Bard J M, Charles M A, Juhan-Vague I, Vague P, Andre P, Safar M, et al. Accumulation of triglyceride-rich lipoprotein in subjects with abdominal obesity: the biguanides and the prevention of the risk of obesity (BIGPRO) 1 study. Arterioscler Thromb Vasc Biol. 2001;21(3):407-14. [Rec#: 22]. [pmid: 11231921].
Excluded. Topic unrelated.
Barkeling B, Elfhag K, Rooth P, Rossner S. Short-term effects of sibutramine (Reductil) on appetite and eating behaviour and the long-term therapeutic outcome. Int J Obes Relat Metab Disord. 2003;27(6):693-700. [Rec#: 975]. [pmid: 12833113].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Barlow S E, Dietz W H. Obesity evaluation and treatment: Expert Committee recommendations. The Maternal and Child Health Bureau, Health Resources and Services Administration and the Department of Health and Human Services. Pediatrics. 1998;102(3):E29. [pmid: 9724677].
Excluded. Reporting on diet only.
Barlow Sarah E, Dietz William H, Klish William J, Trowbridge Frederick L. Medical evaluation of overweight children and adolescents: reports from pediatricians, pediatric nurse practitioners, and registered dietitians. Pediatrics. 2002;110(1 Pt 2):222-8. [Rec#: 363]. [pmcid: 487903]. [pmid: 12462238].
Excluded. Topic unrelated.
Barlow S E, Trowbridge F L, Klish W J, Dietz W H. Treatment of child and adolescent obesity: reports from pediatricians,pediatric nurse practitioners, and registered dietitians. Pediatrics. 2002;110(1 part2):229-235. [Rec#: 510]. [pmcid: 487903]. [pmid: 12462238].
Excluded. Topic unrelated.
Baron J A, Schori A, Crow B, Carter R, Mann J I. A randomized controlled trial of low carbohydrate and low fat/high fiber diets for weight loss. Am J Public Health. 1986;76(11):1293-6. [Rec#: 663]. [pmid: 3021006]. [pmcid: 1646726].
Excluded. Subject unrelated.
Bauta H P. Evaluation of a new anorexic agent in adolescence. Conn Med. 1974;38(9):460-3. [Rec#: 401]. [pmid: 4606529].
Excluded. Duration of treatment < 6 months.
Beasley J W. Obesity and years of life lost. JAMA. 2003;289(14):1777. [Rec#: 654]. [pmid: 12684350].
Excluded. Topic unrelated.
Becque M D, Katch V L, Rocchini A P, Marks C R, Moorehead C. Coronary risk incidence of obese adolescents: reduction by exercise plus diet intervention. Pediatrics. 1988;81(5):605-12. [Rec#: 553]. [pmid: 3357722].
Excluded. Duration of treatment < 6 months.
Beech B M, Klesges R C, Kumanyika S K, Murray D M, Klesges L, McClanahan B, et al. Child- and parent-targeted interventions: the Memphis GEMS pilot study. Ethn Dis. 2003;13(1 Suppl 1):S40-53. [Rec#: 870]. [pmid: 14964185].
Excluded. Duration of treatment < 6 months.
Beermann B, Melander H, Sawe J, Ulleryd C, Dahlqvist R. Incorrect use and limited weight reduction of orlistat (Xenical) in clinical practice. European Journal of Clinical Pharmacology. 2001;57(4):309-311. [Rec#: 450]. [pmid: 11549209].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Belko A Z, Van Loan M, Barbieri T F, Mayclin P. Diet, exercise, weight loss, and energy expenditure in moderately overweight women. Int J Obes. 1987;11(2):93-104. [Rec#: 980]. [pmid: 3301712].
Excluded. Subject unrelated.
Ben-Menachem E, Axelsen M, Johanson E H, Stagge A, Smith U. Predictors of weight loss in adults with topiramate-treated epilepsy. Obes Res. 2003;11(4):556-62. [Rec#: 796]. [pmid: 12690085].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Benjamin S B, Maher K A, Cattau E L, Collen M J, Fleischer D E, Lewis J H, et al. Double-blind controlled trial of the Garren-Edwards gastric bubble: an adjunctive treatment for exogenous obesity. Gastroenterology. 1988;95(3):581-8. [Rec#: 250]. [pmid: 3294079].
Excluded. Subject unrelated.
Birkenfeld A L, Schroeder C, Boschmann M, Tank J, Franke G, Luft F C, et al. Paradoxical effect of sibutramine on autonomic cardiovascular regulation. Circulation. 2002;106(19):2459-65. [Rec#: 797]. [pmid: 12417543].
Excluded. Topic unrelated.
Bitsch M, Skrumsager B K. Femoxetine in the treatment of obese patients in general practice. A randomized group comparative study with placebo. Int J Obes. 1987;11(2):183-90. [Rec#: 23]. [pmid: 3301710].
Excluded. Subject unrelated.
Black D R, Lantz C E. Spouse involvement and a possible long-term follow-up trap in weight loss. Behav Res Ther. 1984;22(5):557-62. [Rec#: 24]. [pmid: 6508706].
Excluded. Subject unrelated.
Blake D E, Hamblett C J, Frost P G, Judd P A, Ellis P R. Wheat bread supplemented with depolymerized guar gum reduces the plasma cholesterol concentration in hypercholesterolemic human subjects. Am J Clin Nutr. 1997;65(1):107-13. [Rec#: 554]. [pmid: 8988921].
Excluded. Subject unrelated.
Blaufox M D, Langford H G, Oberman A, Hawkins C M, Wassertheil-Smoller S W, Cutter G R. Effect of dietary change on the return of hypertension after withdrawal of prolonged antihypertensive therapy (DISH). Dietary Intervention Study of Hypertension. J Hypertens Suppl. 1984;2(3):S179-81. [Rec#: 25]. [pmid: 6599665].
Excluded. Subject unrelated.
Blonk M C, Jacobs M A, Biesheuvel E H, Weeda-Mannak W L, Heine R J. Influences on weight loss in type 2 diabetic patients: little long-term benefit from group behaviour therapy and exercise training. Diabet Med. 1994;11(5):449-57. [Rec#: 26]. [pmid: 8088122].
Excluded. Diet, not reviewed further.
Bolding O T. Diethylpropion hydrochloride: an effective appetite suppressant. Curr Ther Res Clin Exp. 1974;16(1):40-8. [Rec#: 402]. [pmid: 4203847].
Excluded. Duration of treatment < 6 months.
Bondi M, Menozzi R, Bertolini M, Venneri M G, Del Rio G. Metabolic effects of fluoxetine in obese menopausal women. J Endocrinol Invest. 2000;23(5):280-6. [Rec#: 888]. [pmid: 10882145].
Excluded. Duration of treatment < 6 months.
Boozer Carol Neely, Daly Patricia A, Solomon Janis L, Blanchard Deanna, Nasser Jennifer A, Homel Peter. Herbal ephedra/caffeine for weight loss: A 6-mo trial. FASEB Journal. 2001;15(4):A403. [Rec#: 451]. [pmid: 11156956].
Excluded. Subject unrelated.
Boozer C N, Daly P A, Homel P, Solomon J L, Blanchard D, Nasser J A, et al. Herbal ephedra/caffeine for weight loss: a 6-month randomized safetyand efficacy trial. Int J Obes Relat Metab Disord. 2002;26(5):593-604. [Rec#: 511]. [pmid: 12032741].
Excluded. Subject unrelated.
Boozer C N, Nasser J A, Heymsfield S B, Wang V, Chen G, Solomon J L. An herbal supplement containing Ma Huang-Guarana for weight loss: arandomized, double-blind trial. Int J Obes Relat Metab Disord. 2001;25(3):316-324. [Rec#: 512]. [pmid: 11319627].
Excluded. Subject unrelated.
Borys J M, Lafay L. [Nutritional information for children to modify the food habits of the whole family]. Rev Med Suisse Romande. 2000;120(3):207-9. [Rec#: 981]. [pmid: 10815450].
Excluded. Subject unrelated.
Boyd N F, Cousins M, Beaton M, Kriukov V, Lockwood G, Tritchler D. Quantitative changes in dietary fat intake and serum cholesterol in women: results from a randomized, controlled trial. Am J Clin Nutr. 1990;52(3):470-6. [Rec#: 982]. [pmid: 2203251].
Excluded. Diet, not reviewed further.
Braet C, Van Winckel M, Van Leeuwen K. Follow-up results of different treatment programs for obese children. Acta Paediatr. 1997;86(4):397-402. [Rec#: 403]. [pmid: 9174227].
Excluded. Subject unrelated.
Brandou F, Dumortier M, Garandeau P, Mercier J, Brun J F. Effects of a two-month rehabilitation program on substrate utilization during exercise in obese adolescents. Diabetes Metab. 2003;29(1):20-7. [Rec#: 871]. [pmid: 12629444].
Excluded. Diet, not reviewed further.
Bratusch-Marrain P, Dudczak R, Waldhausl W. [Weight reduction in obese diabetics: a double-blind study of diethylpropionate (author's transl)]. Wien Klin Wochenschr. 1979;91(13):455-8. [Rec#: 889]. [pmid: 380178].
Excluded. Duration of treatment < 6 months.
Bravata D M, Sanders L, Huang J, Krumholz H M, Olkin I, Gardner C D, et al. Efficacy and safety of low-carbohydrate diets: a systematic review. JAMA. 2003;289(14):1837-50. [Rec#: 642]. [pmid: 12684364].
Excluded. Diet, not reviewed further.
Bray G A. Low-carbohydrate diets and realities of weight loss. JAMA. 2003;289(14):1853-5. [Rec#: 640]. [pmid: 12684366].
Excluded. Diet, not reviewed further.
Bray G A, Blackburn G L, Ferguson J M, Greenway F L, Jain A K, Mendel C M, et al. Sibutramine produces dose-related weight loss. Obes Res. 1999;7(2):189-98. [Rec#: 890]. [pmid: 10102256].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Bray G A, Blackburn G L, Ferguson J M, et al. Sibutramine—dose response and long-term efficacy in weight loss, a double-blind study. Int J Obes Relat Metab Disord. 1994;18:60. [Rec#: 555].
Excluded. Duration of treatment < 6 months.
Bray G A, Ryan D, Gordon D, Heidingsfelder S, Cerise F, Wilson K. A double-blind randomized placebo-controlled trial of sibutramine. Obesity research. 1996;4(3):263-70. [Rec#: 239]. [pmid: 8732960].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Brightwell D R, Naylor C S. Effects of a combined behavioral and pharmacological program on weight loss. Int J Obes. 1979;3(2):141-8. [Rec#: 556]. [pmid: 528125].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Bross R, Hoffer L J. Fluoxetine increases resting energy expenditure and basal body temperature in humans. Am J Clin Nutr. 1995;61(5):1020-5. [Rec#: 891]. [pmid: 7733022].
Excluded. Duration of treatment < 6 months.
Brown R C, Cox C M, Goulding A. High-carbohydrate versus high-fat diets: effect on body composition in trained cyclists. Med Sci Sports Exerc. 2000;32(3):690-4. [Rec#: 757]. [pmid: 10731014].
Excluded. Subject unrelated.
Brun L D, Bielmann P, Gagne C, Moorjani S, Nadeau A, Lupien P J. Effects of fenfluramine in hypertriglyceridemic obese subjects. Int J Obes. 1988;12(5):423-31. [Rec#: 664]. [pmid: 3069765].
Excluded. Subject unrelated.
Brussaard J H, Katan M B, Groot P H, Havekes L M, Hautvast J G. Serum lipoproteins of healthy persons fed a low-fat diet or a polyunsaturated fat diet for three months. A comparison of two cholesterol-lowering diets. Atherosclerosis. 1982;42(2–3):205-19. [Rec#: 758]. [pmid: 7159502].
Excluded. Subject unrelated.
Buchwald H, Varco RL, Moore RB, Schwartz MZ. Intestinal bypass procedures. Partial ileal bypass for hyperlipidemai and jejunoileal bypass for obesity. Curr Probl Surg 1975;1–51. [Rec#: 832]
Excluded. Study design, review or meta-analysis.
Burke V, Giangiulio N, Gillam H F, Beilin L J, Houghton S. Physical activity and nutrition programs for couples: A randomized controlled trial. J Clin Epidemiol. 2003;56(5):421-32. [Rec#: 965]. [pmid: 12812815].
Excluded. Diet, not reviewed further.
Bustos Lozano G, Moreno Martin F, Calderin Marrero M A, Martinez Quesada J J, Diaz Martinez E, Arana Canedo C. [Comparative study of medical advice and cognitive-behavioral group therapy in the treatment of child-adolescent obesity]. An Esp Pediatr. 1997;47(2):135-43. [Rec#: 404]. [pmid: 9382344].
Excluded. Diet, not reviewed further.
Buzzard IM, Asp EH, Chlebowski RT, Boyar AP, Jeffery RW, Nixon DW, et al. Diet intervention methods to reduce fat intake: nutrient and food group composition of self-selected low-fat diets. J Am Diet Assoc 1990;90(1):42–50, 53. [Rec#: 983]
Excluded. Subject unrelated.
Cairella G, Romagnoli F, Cantarelli P, Valentini P, Tarsitani G. School oriented intervention on dietary education: results of phase 1. Int J Obes. 1998 22:(S254)(Abstract) [Rec#: 984]
Excluded. Subject unrelated.
Campbell C J, Bhalla I P, Steel J M, et al. A controlled trial of phentermine in obese diabetic patients. Practitioner. 1977;218(1308):851-5. [pmid: 329259].
Excluded. Reports on Phentermine; no analysis performed, summary of recent meta-analysis provided.
Campbell K, Waters E, O'Meara S, Summerbell C. Interventions for preventing obesity in childhood. A systematic review. Obes Rev. 2001;2(3):149-57. [Rec#: 213]. [pmid: 12120100].
Excluded. Diet only.
Canlorbe P, Borniche P, Toublanc J E. [Controled trial of an anorectic (An 448) in the treatment, of childhood obesity]: <Original> Essai controle d'un anorexigene (An 448) dans le traitement de l'obesite de l'enfant. La Nouvelle presse medicale. 1976;5(16):1061-2. [Rec#: 265]. [pmid: 775433].
Excluded. Duration of treatment < 6 months.
Cannella M, Scarpelli P T, Vailati G. [The role of anorexic drugs in the treatment of obesity. Clinical data on the use of a new anorexic drug (Ro 6–1343)]. Minerva Med. 1968;59(67):3472-83. [Rec#: 405]. [pmid: 5695367].
Excluded. Subject unrelated.
Canner P L, Borhani N O, Oberman A, Cutler J, Prineas R J, Langford H, et al. The Hypertension Prevention Trial: assessment of the quality of blood pressure measurements. Am J Epidemiol. 1991;134(4):379-92. [Rec#: 31]. [pmid: 1877599].
Excluded. Topic unrelated.
Carey A L, Staudacher H M, Cummings N K, Stepto N K, Nikolopoulos V, Burke L M, et al. Effects of fat adaptation and carbohydrate restoration on prolonged endurance exercise. J Appl Physiol. 2001;91(1):115-22. [Rec#: 759]. [pmid: 11408421].
Excluded. Topic unrelated.
Carney D E, Tweddell E D. Double blind evaluation of long acting diethylpropion hydrochloride in obese patients from a general practice. Med J Aust. 1975;1(1):13-5. [Rec#: 406]. [pmid: 1092973].
Excluded. Duration of treatment < 6 months.
Casado Martinez JJ, Mora Moreno F, Gonzalez Tapia M C, Vera Perez P, MunozBarata M J. [A clinical trial on the efficacy of an alternative diet in obese patients]: <Original> Ensayo clinico sobre la eficacia de una dieta alternativa en pacientes obesos. Atencion primaria / Sociedad Espanola de Medicina de Familia y Comunitaria 1993;11(9):407–1, 473–4. [Rec#: 364]
Excluded. Duration of treatment < 6 months.
Chao D, Espeland M A, Farmer D, Register T C, Lenchik L, Applegate W B, et al. Effect of voluntary weight loss on bone mineral density in older overweight women. J Am Geriatr Soc. 2000;48(7):753-9. [Rec#: 32]. [pmid: 10894313].
Excluded. Diet, not reviewed further.
Charles M A, Morange P, Eschwege E, Andre P, Vague P, Juhan-Vague I. Effect of weight change and metformin on fibrinolysis and the von Willebrand factor in obese nondiabetic subjects: the BIGPRO1 Study. Biguanides and the Prevention of the Risk of Obesity. Diabetes Care. 1998;21(11):1967-72. [Rec#: 33]. [pmid: 9802752].
Excluded. Subject unrelated.
Chiasson J L, Josse R G, Hunt J A, Palmason C, Rodger N W, Ross S A, et al. The efficacy of acarbose in the treatment of patients with non-insulin- dependent diabetes mellitus. A multicenter controlled clinical trial. Ann Intern Med. 1994;121(12):928-35. [Rec#: 34]. [pmid: 7734015].
Excluded. Topic unrelated.
Chism Salli E, Mahabir Deepak, Modlesky Christopher M, Lewis Richard D. Overweight and obesity in Trinidadian adolescents. FASEB Journal. 2002;16(4):A279. [Rec#: 453].
Excluded. Topic unrelated.
Christakis G, Sajecki S, Hillman R W, Miller E, Blumenthal S, Archer M. Effect of a combined nutrition education and physical fitness program on the weight status of obese high school boys. Fed Proc. 1966;25(1):15-9. [Rec#: 833]. [pmid: 5006567].
Excluded. Diet, not reviewed further.
Chuang L M, Jou T S, Yang W S, Wu H P, Huang S H, Tai T Y, et al. Therapeutic effect of guar gum in patients with non-insulin-dependent diabetes mellitus. J Formos Med Assoc. 1992;91(1):15-9. [Rec#: 559]. [pmid: 1352328].
Excluded. Topic unrelated.
Clarke P, Gray A, Adler A, Stevens R, Raikou M, Cull C, et al. Cost-effectiveness analysis of intensive blood-glucose control with metformin in overweight patients with type II diabetes (UKPDS No. 51). Diabetologia. 2001;44(3):298-304. [Rec#: 35]. [pmid: 11317659].
Excluded. Topic unrelated.
Coates T J, Thoresen C E. Treating obesity in children and adolescents: a review. Am J Public Health. 1978;68(2):143-51. [Rec#: 560]. [pmid: 626257]. [pmcid: 1653865].
Excluded. Study design, review or meta-analysis.
Coates T J, Jeffery R W, Slinkard L A, Killen J D, Danaher B G. Frequency of contact and monetary reward in weight loss, lipid change and blood pressure reduction with adolescents. Behav Ther. 1982;13:175-185. [Rec#: 561].
Excluded. Subject unrelated.
Cohen A, De Felice E A, Leb S M, Fuentes J G, Rothwell K G, Truant A P. Double-blind comparison of efficacy, safety, and side effects of Bionamin, phentermine compound, and placebo in the treatment of exogenous obesity. Curr Ther Res Clin Exp. 1968;10(7):323-34. [Rec#: 562]. [pmid: 4969672].
Excluded. Duration of treatment < 6 months.
Cohen M D, D'Amico F J, Merenstein J H. Weight reduction in obese hypertensive patients. Fam Med. 1991;23(1):25-8. [Rec#: 36]. [pmid: 2001777].
Excluded. Diet, not reviewed further.
Colquitt J, Clegg A, Sidhu M, Royle P. Surgery for morbid obesity (Cochrane Review). Cochrane Database Syst Rev 2003;(2):CD003641. [Rec#: 966]
Excluded. Study design, review or meta-analysis.
Conte A. Evaluation of Sanorex-a new appetite suppresant. J Obes Bariat Med. 1973;2:104-107. [Rec#: 564].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Cousins J H, Rubovits D S, Dunn J K, Reeves R S, Ramirez A G, Foreyt J P. Family versus individually oriented intervention for weight loss in Mexican American women. Public Health Rep. 1992;107(5):549-55. [Rec#: 37]. [pmid: 1410236]. [pmcid: 1403697].
Excluded. Subject unrelated.
Coyle E F, Jeukendrup A E, Oseto M C, Hodgkinson B J, Zderic T W. Low-fat diet alters intramuscular substrates and reduces lipolysis and fat oxidation during exercise. Am J Physiol Endocrinol Metab. 2001;280(3):E391-8. [Rec#: 760]. [pmid: 11171592].
Excluded. Diet, not reviewed further.
Crommelin R M. Nonamphetamine, anorectic medication for obese diabetic patients: controlled and open investigations of mazindol. Clin Med. 1974;81:20-24. [Rec#: 565].
Excluded. Mazindol, not reviewed.
Cuellar G E, Ruiz A M, Monsalve M C, et al. Six-month treatment of obesity with sibutramine 15 mg; a double-blind, placebo-controlled monocenter clinical trial in a Hispanic population. Obesity research. 2000;8(1):71-82. [pmid: 10678261].
Excluded. Reports on Sibutramine; no analysis performed, summary of recent meta-analysis provided.
Cutler J A. Randomized clinical trials of weight reduction in nonhypertensive persons. Ann Epidemiol. 1991;1(4):363-70. [Rec#: 834]. [pmid: 1669517].
Excluded. Diet, not reviewed further.
Dahms W T, Molitch M E, Bray G A, Greenway F L, Atkinson R L, Hamilton K. Treatment of obesity: cost-benefit assessment of behavioral therapy, placebo, and two anorectic drugs. Am J Clin Nutr. 1978;31(5):774-8. [Rec#: 566]. [pmid: 417615].
Excluded. Mazindol, not reviewed.
Daniels S. Pharmacological treatment of obesity in paediatric patients. Paediatr Drugs. 2001;3(6):405-10. [Rec#: 407]. [pmid: 11437185].
Excluded. Rejected at abstract.
Dargent J. Laparoscopic adjustable gastric banding: lessons from the first 500 patients in a single institution. Obes Surg. 1999;9(5):446-52. [Rec#: 946]. [pmid: 10605901].
Excluded. Duplicate article.
Dargent J. [Laparoscopic surgery in morbid obesity: adjustable-ring gastroplasty. 320 cases]. Ann Chir. 1999;53(6):467-71. [Rec#: 945]. [pmid: 10427837].
Excluded. Not found.
Daubresse J C, Kolanowski J, Krzentowski G, Kutnowski M, Scheen A, Van GaalL. Usefulness of fluoxetine in obese non-insulin-dependent diabetics: a multicenter study. Obesity research. 1996;4(4):391-6. [Rec#: 238 ]. [pmid: 8822764].
Excluded. Duration of treatment < 6 months.
Davis B R, Blaufox M D, Hawkins C M, Langford H G, Oberman A, Swencionis C, et al. Trial of antihypertensive interventions and management. Design, methods, and selected baseline results. Control Clin Trials. 1989;10(1):11-30. [Rec#: 744]. [pmid: 2649308].
Excluded. Topic unrelated.
Davis B R, Blaufox M D, Oberman A, Wassertheil-Smoller S, Zimbaldi N, Cutler J A, et al. Reduction in long-term antihypertensive medication requirements. Effects of weight reduction by dietary intervention in overweight persons with mild hypertension. Arch Intern Med. 1993;153(15):1773-82. [Rec#: 40]. [pmid: 8333814].
Excluded. Subject unrelated.
Davis B R, Hawkins C M, et al. Trial Antihypertensive Interventions and Management: design, methods, and selected baseline results. Controlled Clin Trials. 1989;10:11-30. [Rec#: 567]. [pmid: 2649308].
Excluded. Topic unrelated.
Davis B R, Oberman A, Blaufox M D, Wassertheil-Smoller S, Hawkins C M, Cutler J A, et al. Effect of antihypertensive therapy on weight loss. The Trial of Antihypertensive Interventions and Management Research Group. Hypertension. 1992;19(4):393-9. [Rec#: 41]. [pmid: 1555871].
Excluded. Subject unrelated.
Davis B R, Oberman A, Blaufox M D, Wassertheil-Smoller S, Zimbaldi N, Kirchner K, et al. Lack of effectiveness of a low-sodium/high-potassium diet in reducing antihypertensive medication requirements in overweight persons with mild hypertension. TAIM Research Group. Trial of Antihypertensive Interventions and Management. Am J Hypertens. 1994;7(10 Pt 1):926-32. [Rec#: 42]. [pmid: 7702809].
Excluded. Topic unrelated.
Davis K, Christoffel K K. Obesity in preschool and school-age children. Treatment early and often may be best. Archives of pediatrics & adolescent medicine. 1994;148(12):1257-61. [Rec#: 366]. [pmid: 7951803].
Excluded. Diet, not reviewed further.
Davis S M, Going S B, Helizer D L, Teufel N I, Snyder P, Gittlesohn J, et al. Pathways: a culturally appropriate obesity-prevention program for American Indian schoolchildren. Am J Clin Nutr. 1999;69(suppl):796S-802S. [Rec#: 537]. [pmid: 10584048].
Excluded. Topic unrelated.
de Bont A J, Baker I A, St Leger A S, Sweetnam P M, Wragg K G, Stephens S M, et al. A randomised controlled trial of the effect of low fat diet advice on dietary response in insulin independent diabetic women. Diabetologia. 1981;21(6):529-33. [Rec#: 835]. [pmid: 7040142].
Excluded. Subject unrelated.
De Felice E A, Bronstein S, Cohen A. Double-blind comparison of placebo and 42–548, a new appetite suppressant, in obese volunteers. Curr Ther Res Clin Exp. 1969;11(5):256-62. [Rec#: 667]. [pmid: 4977396].
Excluded. Subject unrelated.
de Waard F, Ramlau R, Mulders Y, de Vries T, van Waveren S. A feasibility study on weight reduction in obese postmenopausal breast cancer patients. Eur J Cancer Prev. 1993;2(3):233-8. [Rec#: 43]. [pmid: 8490542].
Excluded. Diet, not reviewed further.
Defelice E A, Chaykin L B, Cohen A. Double-blind clinical evaluation of mazindol, dextroamphetamine, and placebo in treatment of exogenous obesity. Curr Ther Res Clin Exp. 1973;15(7):358-66. [Rec#: 568]. [pmid: 4198296].
Excluded. Mazindol, not reviewed.
Deitel M, Shikora S A. The development of the surgical treatment of morbid obesity. J Am Coll Nutr. 2002;21(5):365-71. [Rec#: 2]. [pmid: 12356776].
Excluded. Study design, descriptive.
Desideri G, Ferri C. Effects of Obesity and Weight Loss on Soluble CD40L Levels. JAMA. 2003;289(14):1781-2. [Rec#: 651]. [pmid: 12684355].
Excluded. Diet, not reviewed further.
DeWolfe J A, Jack E. Weight control in adolescent girls: a comparison of the effectiveness of three approaches to follow-up. Journal of school health. 1984;54(9):347-9. [Rec#: 367]. [pmid: 6568354].
Excluded. Diet, not reviewed further.
Ditschuneit H H, Flechtner-Mors M, Johnson T D, Adler G. Metabolic and weight-loss effects of a long-term dietary intervention in obese patients. Am J Clin Nutr. 1999;69(2):198-204. [Rec#: 958]. [pmid: 9989680].
Excluded. Subject unrelated.
Djuric Z, Lababidi S, Heilbrun L K, Depper J B, Poore K M, Uhley V E. Effect of low-fat and/or low-energy diets on anthropometric measures inparticipants of the women's diet study. Journal of the American College of Nutrition. 2002;21(1):38-46. [Rec#: 513]. [pmid: 11838886].
Excluded. Duration of treatment < 6 months.
Donnelly J E, Pronk N P, Jacobsen D J, Pronk S J, Jakicic J M. Effects of a very-low-calorie diet and physical-training regimens on body composition and resting metabolic rate in obese females. Am J Clin Nutr. 1991;54(1):56-61. [Rec#: 985]. [pmid: 2058588].
Excluded. Subject unrelated.
Drent M L, Larsson I, William-Olsson T, Quaade F, Czubayko F, von Bergmann K, et al. Orlistat (Ro 18–0647), a lipase inhibitor, in the treatment of human obesity: a multiple dose study. Int J Obes Relat Metab Disord. 1995;19(4):221-6. [Rec#: 569]. [pmid: 7627244].
Excluded. Duration of treatment < 6 months.
Drent M L, Popp-Snijders C, Ader H J, Jansen J B, van der Veen E A. Lipase inhibition and hormonal status, body composition and gastrointestinal processing of a liquid high-fat mixed meal in moderately obese subjects. Obes Res. 1995;3(6):573-81. [Rec#: 709]. [pmid: 8653534].
Excluded. Duration of treatment < 6 months.
Drent M L, van der Veen E A. Lipase inhibition: a novel concept in the treatment of obesity. Int J Obes Relat Metab Disord. 1993;17(4):241-4. [Rec#: 893]. [pmid: 8387973].
Excluded. Duration of treatment < 6 months.
Dubbert P M, Wilson G T. Goal-setting and spouse involvement in the treatment of obesity. Behav Res Ther. 1984;22(3):227-42. [Rec#: 1021]. [pmid: 6466273].
Excluded. Subject unrelated.
Duell P B. Bariatric surgery for morbid obesity. JAMA. 2003;289(14):1779. [Rec#: 653]. [pmid: 12684352].
Excluded. Topic unrelated.
Duffy G, Spence S H. The effectiveness of cognitive self-management as an adjunct to a behavioural intervention for childhood obesity: a research note. J Child Psychol Psychiatry. 1993;34(6):1043-50. [Rec#: 570]. [pmid: 8408368].
Excluded. Subject unrelated.
Dujovne C A, Zavoral J H, Rowe E, Mendel C M. Effects of sibutramine on body weight and serum lipids: a double-blind, randomized, placebo-controlled study in 322 overweight and obese patients with dyslipidemia. American heart journal. 2001;142(3):489-97. [Rec#: 220]. [pmid: 11526363].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Dykes M H. Evaluation of three anorexiants. Clortermine hydrochloride (voranil), fenfluramine hydrochloride (pondimin), and mazindol (sanorex). JAMA. 1974;230(2):270-2. [Rec#: 409]. [pmid: 4606535].
Excluded. Mazindol, not reviewed.
Ebbeling C B, Rodriguez N R. Effects of exercise combined with diet therapy on protein utilization in obese children. Med Sci Sports Exerc. 1999;31(3):378-85. [Rec#: 410]. [pmid: 10188741].
Excluded. Diet, not reviewed further.
Ebeling P, Yki-Jarvinen H, Aro A, Helve E, Sinisalo M, Koivisto V A. Glucose and lipid metabolism and insulin sensitivity in type 1 diabetes: the effect of guar gum. Am J Clin Nutr. 1988;48(1):98-103. [Rec#: 571]. [pmid: 3291601].
Excluded. Subject unrelated.
Eliakim Alon, Kaven Galit, Berger Isaac, Friedland Orit, WolachBaruch, Nemet Dan. The effect of a combined intervention on body mass index and fitness in obese children and adolescents - a clinical experience. European journal of pediatrics. 2002;161(8):449-54. [Rec#: 368]. [pmid: 12172831].
Excluded. Diet, not reviewed further.
Elmaleh M K, Miller J. Controlled clinical evaluation of a new anorectic agent in obese adults. Pa Med. 1974;77(9):46-50. [Rec#: 572]. [pmid: 4609056].
Excluded. Duration of treatment < 6 months.
Enzi G, Baritussio A, Marchiori E, Crepaldi G. Short-term and long-term clinical evaluation of a non-amphetaminic anorexiant (mazindol) in the treatment of obesity. Journal of international medical research. 1976;4(5):305-18. [Rec#: 369]. [pmid: 1028632].
Excluded. Mazindol, not reviewed.
Epstein L H, McKenzie S J, Valoski A, Klein K R, Wing R R. Effects of mastery criteria and contingent reinforcement for family- based child weight control. Addict Behav. 1994;19(2):135-45. [Rec#: 573]. [pmid: 8036961].
Excluded. Subject unrelated.
Epstein L H, Valoski A, Wing R R, McCurley J. Ten-year outcomes of behavioral family-based treatment for childhood obesity. Health Psychol. 1994;13(5):373-83. [Rec#: 574]. [pmid: 7805631].
Excluded. Diet, not reviewed further.
Epstein L H, Valoski A M, Vara L S, McCurley J, Wisniewski L, Kalarchian M A, et al. Effects of decreasing sedentary behavior and increasing activity on weight change in obese children. Health Psychol. 1995;14(2):109-15. [Rec#: 575]. [pmid: 7789345].
Excluded. Subject unrelated.
Epstein L H, Wing R R, Koeske R, Andrasik F, Ossip D J. Child and parent weight loss in family-based behavior modification programs. J Consult Clin Psychol. 1981;49(5):674-85. [Rec#: 576]. [pmid: 7287977].
Excluded. Subject unrelated.
Epstein L H, Wing R R, Koeske R, Valoski A. Effect of parent weight on weight loss in obese children. J Consult Clin Psychol. 1986;54(3):400-1. [Rec#: 577]. [pmid: 3722572].
Excluded. Subject unrelated.
Epstein L H, Gordy C C, Raynor H A, Beddome M, Kilanowski C K, Paluch R. Increasing fruit and vegetable intake and decreasing fat and sugarintake in families at risk for childhood obesity. Obesity Research. 2001;9(3):171-178. [Rec#: 514]. [pmid: 11323442].
Excluded. Subject unrelated.
Epstein L H, Myers M D, Raynor H A, Saelens B E. Treatment of pediatric obesity. Pediatrics. 1998;101(3 Pt 2):554-70. [Rec#: 212]. [pmid: 12224663].
Excluded. Diet, not reviewed further.
Epstein L H, Paluch R A, Gordy C C, Dorn J. Decreasing sedentary behaviors in treating pediatric obesity. Archives of pediatrics & adolescent medicine. 2000;154(3):220-6. [Rec#: 370]. [pmid: 10710017].
Excluded. Duration of treatment < 6 months.
Epstein L H, Paluch R A, Gordy C C, Saelens B E, Ernst M M. Problem solving in the treatment of childhood obesity. Journal of consulting and clinical psychology. 2000;68(4):717-21. [Rec#: 371]. [pmid: 10965646].
Excluded. Subject unrelated.
Epstein L H, Paluch R A, Saelens B E, Ernst M M, Wilfley D E. Changes in eating disorder symptoms with pediatric obesity treatment. Journal of pediatrics. 2001;139(1):58-65. [Rec#: 372]. [pmid: 11445795].
Excluded. Duration of treatment < 6 months.
Epstein L H, Paluch R A, Raynor H A. Sex differences in obese children and siblings in family-based obesitytreatment. Obesity Research. 2001;9(12):746-753. [Rec#: 515]. [pmid: 11743058].
Excluded. Diet, not reviewed further.
Epstein L H, Wing R R, Koeske R, Valoski A. Effects of diet plus exercise on weight change in parents and children. Journal of consulting and clinical psychology. 1984;52(3):429-37. [Rec#: 373]. [pmid: 6747061].
Excluded. Diet, not reviewed further.
Epstein L H, Wing R R, Penner B C, Kress M J. Effect of diet and controlled exercise on weight loss in obese children. Journal of pediatrics. 1985;107(3):358-61. [Rec#: 252]. [pmid: 4032130].
Excluded. Subject unrelated.
Epstein L H, Wing R R, Koeske R, Ossip D J, Beck S. A comparison of lifestyle change and programmed aerobic exercise on weight and fitness changes in obese children. Behav Ther. 1982;13:651-665. [Rec#: 579].
Excluded. Duration of treatment < 6 months.
Epstein L H, Wing R R, Koeske R, Valoski A. A comparison of lifestyle exercise, aerobic exercise and calisthenics on weight loss in obese children. Behav Ther. 1985;16:345-356. [Rec#: 580].
Excluded. Subject unrelated.
Epstein L H, Wing R R, Steranchak L, Dickson B, Michelson J. Comparison of family-based behavior modification and nutrition education for childhood obesity. J Pediatr Psychol. 1980;5(1):25-36. [Rec#: 578]. [pmid: 7452420].
Excluded. Subject unrelated.
Epstein L H, Wing R R, Woodall K, Penner B C, Kress M J, Koeske R. Effects of family-based behavioral treatment on obest 5–8 year old children. Behav Ther. 1985;16:205-212. [Rec#: 581].
Excluded. Subject unrelated.
Eriksson J, Lindstrom J, Valle T, Aunola S, Hamalainen H, Ilanne-Parikka P, et al. Prevention of Type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42(7):793-801. [Rec#: 44]. [pmid: 10440120].
Excluded. Diet, not reviewed further.
Espeland M A, Kumanyika S, Wilson A C, Wilcox S, Chao D, Bahnson J, et al. Lifestyle interventions influence relative errors in self-reported diet intake of sodium and potassium. Ann Epidemiol. 2001;11(2):85-93. [Rec#: 45]. [pmid: 11164124].
Excluded. Topic unrelated.
Espeland M A, Whelton P K, Kostis J B, Bahnson J L, Ettinger W H, Cutler J A, et al. Predictors and mediators of successful long-term withdrawal from antihypertensive medications. TONE Cooperative Research Group. Trial of Nonpharmacologic Interventions in the Elderly. Arch Fam Med. 1999;8(3):228-36. [Rec#: 46]. [pmid: 10333818].
Excluded. Subject unrelated.
Esposito K, Pontillo A, Di Palo C, Giugliano G, Masella M, Marfella R, et al. Effect of weight loss and lifestyle changes on vascular inflammatory markers in obese women: a randomized trial. JAMA. 2003;289(14):1799-804. [Rec#: 648]. [pmid: 12684358].
Excluded. Diet, not reviewed further.
Ettinger M P, Littlejohn T W, Schwartz S L, Weiss S R, McIlwain H H, Heymsfield S B, et al. Recombinant variant of ciliary neurotrophic factor for weight loss in obese adults: a randomized, dose-ranging study. JAMA. 2003;289(14):1826-32. [Rec#: 644]. [pmid: 12684362].
Excluded. Subject unrelated.
Ewbank P P, Darga L L, Lucas C P. Physical activity as a predictor of weight maintenance in previously obese subjects. Obes Res. 1995;3(3):257-63. [Rec#: 1022]. [pmid: 7627774].
Excluded. Diet, not reviewed further.
Fagerberg B, Andersson O, Nilsson U, Hedner T, Isaksson B, Bjorntorp P. Weight-reducing diets: role of carbohydrates on sympathetic nervous activity and hypotensive response. Int J Obes. 1984;8(3):237-43. [Rec#: 761]. [pmid: 6746191].
Excluded. Subject unrelated.
Fanghanel G, Cortinas L, Sanchez-Reyes L, et al. A clinical trial of the use of sibutramine for the treatment of patients suffering essential obesity. Int J Obes Relat Metab Disord. 2000;24(2):144-50. [pmid: 10702763].
Excluded. Reports on Sibutramine; no analysis performed, summary of recent meta-analysis provided.
Fanghanel G, Cortinas L, Sanchez-Reyes L, Berber A. Second phase of a double-blind study clinical trial on Sibutramine for the treatment of patients suffering essential obesity: 6 months after treatment cross-over. Int J Obes Relat Metab Disord. 2001;25(5):741-7. [Rec#: 219]. [pmid: 11360159].
Excluded. Study design: not appropriate.
Fanghanel G, Cortinas L, Sanchez-Reyes L, Gomez-Santos R, Campos-Franco E, Berber A. Safety and efficacy of sibutramine in overweight Hispanic patients with hypertension. Adv Ther. 2003;20(2):101-13. [Rec#: 970]. [pmid: 12836810].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Faria A N, Ribeiro Filho F F, Lerario D D, Kohlmann N, Ferreira S R, Zanella M T. Effects of sibutramine on the treatment of obesity in patients with arterial hypertension. Arq Bras Cardiol. 2002;78(2):172-80. [Rec#: 894]. [pmid: 11887193].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Favretti F, Cadiere G B, Segato G, et al. Laparoscopic adjustable silicone gastric banding (Lap-Band): how to avoid complications. Obes Surg. 1997;7(4):352-8. [pmid: 9730523].
Excluded. Topic: not on weight loss or surgery complication.
Feese M, Franklin F, Murdock M, Harrington K, Brown-Binns M, Nicklas T, et al. Prevalence of obesity in children in alabama and Texas participating in social programs. JAMA. 2003;289(14):1780-1. [Rec#: 652]. [pmid: 12684354].
Excluded. Topic unrelated.
Feng JJ, Gagner M, Pomp A, Korgaonkar NM, Jacob BP, Chu CA, et al. Effect of standard vs extended Roux limb length on weight loss outcomes after laparoscopic Roux-en-Y gastric bypass. Surg Endosc 2003 [Rec#: 1048]
Excluded. Not found.
Ferguson J M, Feighner J P. Fluoxetine-induced weight loss in overweight non-depressed humans. Int J Obes. 1987;11 Suppl 3:163-70. [Rec#: 582]. [pmid: 3501992].
Excluded. Duration of treatment < 6 months.
Ferguson J M. Fluoxetine-induced weight loss in overweight, nondepressed subjects. Am J Psychiatry. 1986;143(11):1496. [Rec#: 411]. [pmid: 3535547].
Excluded. Duration of treatment < 6 months.
Fernandez-Soto M L, Gonzalez-Jimenez A, Barredo-Acedo F, Luna del Castillo J D, Escobar-Jimenez F. Comparison of fluoxetine and placebo in the treatment of obesity. Ann Nutr Metab. 1995;39(3):159-63. [Rec#: 836]. [pmid: 7486842].
Excluded. Duration of treatment < 6 months.
Figueroa-Colon R, Franklin F A, Lee J Y, von Almen T K, Suskind R M. Feasibility of a clinic-based hypocaloric dietary intervention implemented in a school setting for obese children. Obesity research. 1996;4(5):419-29. [Rec#: 237]. [pmid: 8885206].
Excluded. Duration of treatment < 6 months.
Figueroa-Colon R, von Almen T K, Franklin F A, Schuftan C, Suskind R M. Comparison of two hypocaloric diets in obese children. American journal of diseases of children (1960). 1993;147(2):160-6. [Rec#: 243]. [pmid: 12085871].
Excluded. Subject unrelated.
Finer N. Pharmacotherapy of obesity. Best Pract Res Clin Endocrinol Metab. 2002;16(4):717-42. [Rec#: 837]. [pmid: 12468417].
Excluded. Study design, review or meta-analysis.
Finer N. Sibutramine: its mode of action and efficacy. Int J Obes Relat Metab Disord. 2002;26 Suppl 4:S29-33. [Rec#: 820]. [pmid: 12457297].
Excluded. Study design, review or meta-analysis.
Finer N, Bloom S R, Frost G S, Banks L M, Griffiths J. Sibutramine is effective for weight loss and diabetic control in obesity with type 2 diabetes: a randomised, double-blind, placebo- controlled study. Diabetes Obes Metab. 2000;2(2):105-12. [Rec#: 710]. [pmid: 11220522].
Excluded. Duration of treatment < 6 months.
Finer N, Finer S, Naoumova R P. Prolonged use of a very low calorie diet (Cambridge diet) in massively obese patients attending an obesity clinic: safety, efficacy and additional benefit from dexfenfluramine. Int J Obes. 1989;13 Suppl 2:91-3. [Rec#: 583]. [pmid: 2613434].
Excluded. Subject unrelated.
Fitzgibbon Marian L, Stolley Melinda R, Dyer Alan R, Van Horn Linda, Kaufer Christoffel Katherine. A community-based obesity prevention program for minority children: Rationale and study design for Hip-Hop to Health Jr. Preventive Medicine. 2002;34(2):289-297. [Rec#: 458]. [pmid: 11817926].
Excluded. Topic unrelated.
Fitzwater S L, Weinsier R L, Wooldridge N H, Birch R, Liu C, Bartolucci A A. Evaluation of long-term weight changes after a multidisciplinary weight control program. J Am Diet Assoc. 1991;91(4):421-6. [Rec#: 1023]. [pmid: 2016489].
Excluded. Diet, not reviewed further.
Flechtner-Mors M, Ditschuneit H H, Johnson T D, Suchard M A, Adler G. Metabolic and weight loss effects of long-term dietary intervention in obese patients: four-year results. Obes Res. 2000;8(5):399-402. [Rec#: 959]. [pmid: 10968732].
Excluded. Subject unrelated.
Flodmark C E, Ohlsson T, Ryden O, Sveger T. Prevention of progression to severe obesity in a group of obese schoolchildren treated with family therapy. Pediatrics. 1993;91(5):880-4. [Rec#: 584]. [pmid: 8474806].
Excluded. Subject unrelated.
Flynn Mary M. A Mediterranean diet may improve weight loss and weight loss maintenance. FASEB Journal. 2002;16(4):A369. [Rec#: 459].
Excluded. Subject unrelated.
Flynn T J, Walsh M F. Thirty-month evaluation of a popular very-low-calorie diet program. Arch Fam Med. 1993;2(10):1042-8. [Rec#: 1024]. [pmid: 8111485].
Excluded. Diet, not reviewed further.
Fogelholm M, Kukkonen-Harjula K, Nenonen A, Pasanen M. Effects of walking training on weight maintenance after a very-low- energy diet in premenopausal obese women: a randomized controlled trial. Arch Intern Med. 2000;160(14):2177-84. [Rec#: 711]. [pmid: 10904461].
Excluded. Subject unrelated.
Foger M, Bart G, Rathner G, Jager B, Fischer H, Zollner-Neussl D. [Physical activity, nutritional counseling and psychological guidance in treatment of obese children. A controlled follow-up study over six months]: <Original> Korperliche Aktivitat, Ernahrungsberatung und psychologische Fuhrung in der Behandlung adiposer Kinder. Eine kontrollierte Verlaufsstudie uber sechs Monate. Monatsschrift Kinderheilkunde : Organ der Deutschen Gesellschaft fur Kinderheilkunde. 1993;141(6):491-7. [Rec#: 242]. [pmid: 8336746].
Excluded. Rejected at abstract.
Fontbonne A, Andre P, Eschwege E. BIGPRO (biguanides and the prevention of the risk of obesity): study design. A randomized trial of metformin versus placebo in the correction of the metabolic abnormalities associated with insulin resistance. Diabete Metab. 1991;17(1 Pt 2):249-54. [Rec#: 49]. [pmid: 1809602].
Excluded. Topic unrelated.
Fontbonne A, Charles M A, Juhan-Vague I, Bard J M, Andre P, Isnard F, et al. The effect of metformin on the metabolic abnormalities associated with upper-body fat distribution. BIGPRO Study Group. Diabetes Care. 1996;19(9):920-6. [Rec#: 50]. [pmid: 8875083].
Excluded. Subject unrelated.
Foreyt J P, Godrick G K, Reeves R S, Raynaud A S, Darnell L, Brown A H, et al. Response of free-living adults to behavioral treament of obesity: Attrition and compliance to exercise. Behavior Therapy. 1993;24(4):659-69. [Rec#: 52].
Excluded. Diet, not reviewed further.
Forster J L, Jeffery R W, VanNatta M, Pirie P. Hypertension prevention trial: do 24-h food records capture usual eating behavior in a dietary change study?. Am J Clin Nutr. 1990;51(2):253-7. [Rec#: 53]. [pmid: 2407098].
Excluded. Diet, not reviewed further.
Fortmann S P, Haskell W L, Wood P D. Effects of weight loss on clinic and ambulatory blood pressure in normotensive men. Am J Cardiol. 1988;62(1):89-93. [Rec#: 54]. [pmid: 3381757].
Excluded. Diet, not reviewed further.
Foster G D, Wadden T A, Brownell K D. Peer-led program for the treatment and prevention of obesity in the schools. J Consult Clin Psychol. 1985;53(4):538-40. [Rec#: 986]. [pmid: 4031211].
Excluded. Diet, not reviewed further.
Foster G D, Wadden T A, Vogt R A, Brewer G. What is a reasonable weight loss? Patients' expectations and evaluations of obesity treatment outcomes. J Consult Clin Psychol. 1997;65(1):79-85. [Rec#: 821]. [pmid: 9103737].
Excluded. Diet, not reviewed further.
Foster G D, Wyatt H R, Hill J O, McGuckin B G, Brill C, Mohammed B S, et al. A randomized trial of a low-carbohydrate diet for obesity. N Engl J Med. 2003;348(21):2082-90. [Rec#: 872]. [pmid: 12761365].
Excluded. Subject unrelated.
Foster G D, Wadden T A, Kendall P C, Stunkard A J, Vogt R A. Psychological effects of weight loss and regain: a prospective evaluation. J Consult Clin Psychol. 1996;64(4):752-7. [Rec#: 55]. [pmid: 8803365].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Foster G D, Wadden T A, Peterson F J, Letizia K A, Bartlett S J, Conill A M. A controlled comparison of three very-low-calorie diets: effects on weight, body composition, and symptoms. Am J Clin Nutr. 1992;55(4):811-7. [Rec#: 56]. [pmid: 1550063].
Excluded. Duration of treatment < 6 months.
Foxcroft D R, Milne R. Orlistat for the treatment of obesity: rapid review and cost-effectiveness model. Obes Rev. 2000;1(2):121-6. [Rec#: 895]. [pmid: 12119985].
Excluded. Study design, review or meta-analysis.
Frank Guido K, Kaye Walter H, Marcus Marsha D. Sertraline in underweight binge eating/purging-type eating disorders: Five case reports. International Journal of Eating Disorders. 2001;29(4):495-498. [Rec#: 460]. [pmid: 11285589].
Excluded. Topic unrelated.
Franz M J, Monk A, Barry B, McClain K, Weaver T, Cooper N, et al. Effectiveness of medical nutrition therapy provided by dietitians in the management of non-insulin-dependent diabetes mellitus: a randomized, controlled clinical trial. J Am Diet Assoc. 1995;95(9):1009-17. [Rec#: 839]. [pmid: 7657902].
Excluded. Subject unrelated.
Freedman M R, King J, Kennedy E. Popular diets: a scientific review. Obes Res. 2001;9 Suppl 1:1S-40S. [Rec#: 743]. [pmid: 11374180].
Excluded. Diet, not reviewed further.
Freeman R, Sheiham A. Understanding decision-making processes for sugar consumption in adolescence. Community dentistry and oral epidemiology. 1997;25(3):228-32. [Rec#: 374]. [pmid: 9192152].
Excluded. Topic unrelated.
Freemark M, Bursey D. The effects of metformin on body mass index and glucose tolerance in obese adolescents with fasting hyperinsulinemia and a family history of type 2 diabetes. Pediatrics. 2001;107(4):E55. [Rec#: 375]. [pmid: 11335776].
Excluded. Subject unrelated.
Frey-Hewitt B, Vranizan K M, Dreon D M, Wood P D. The effect of weight loss by dieting or exercise on resting metabolic rate in overweight men. Int J Obes. 1990;14(4):327-34. [Rec#: 58]. [pmid: 2361810].
Excluded. Diet, not reviewed further.
Frostfeldt G, Ahlberg G, Gustafsson G, Helmius G, Lindahl B, Nygren A, et al. Low molecular weight heparin (dalteparin) as adjuvant treatment of thrombolysis in acute myocardial infarction—a pilot study: biochemical markers in acute coronary syndromes (BIOMACS II). J Am Coll Cardiol. 1999;33(3):627-33. [Rec#: 59]. [pmid: 10080461].
Excluded. Topic unrelated.
Fujioka K. Management of obesity as a chronic disease: nonpharmacologic, pharmacologic, and surgical options. Obes Res. 2002;10 Suppl 2:116S-23S. [Rec#: 840]. [pmid: 12490660].
Excluded. Study design, review or meta-analysis.
Fujioka K, Seaton T B, Rowe E, Jelinek C A, Raskin P, Lebovitz H E, et al. Weight loss with sibutramine improves glycaemic control and other metabolic parameters in obese patients with type 2 diabetes mellitus. Diabetes Obes Metab. 2000;2(3):175-87. [Rec#: 825]. [pmid: 11220553].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Fulton J E, McGuire M T, Caspersen C J, Dietz W H. Interventions for weight loss and weight gain prevention among youth:current issues. Sports Medicine. 2001;31(3):153-165. [Rec#: 516]. [pmid: 11286354].
Excluded. Rejected at abstract.
Garrow J S, Summerbell C D. Meta-analysis: effect of exercise, with or without dieting, on the body composition of overweight subjects. Eur J Clin Nutr. 1995;49:1-10. [Rec#: 841]. [pmid: 7713045].
Excluded. Diet, not reviewed further.
Gittelsohn J, Evans M, Story M, Davis S M, Metcalfe L, Helitzer D L, et al. Multisite formative assessment for the Pathways study to prevent obesity in American Indian schoolchildren. AM J Clin Nutr. 1999;69(suppl):767S-72S. [Rec#: 538]. [pmid: 10584048].
Excluded. Topic unrelated.
Gladis M M, Wadden T A, Vogt R, Foster G, Kuehnel R H, Bartlett S J. Behavioral treatment of obese binge eaters: do they need different care?. J Psychosom Res. 1998;44(3–4):375-84. [Rec#: 60]. [pmid: 9678750].
Excluded. Subject unrelated.
Glazer G. Long-term pharmacotherapy of obesity 2000: a review of efficacy and safety. Arch Intern Med. 2001;161(15):1814-24. [Rec#: 3]. [pmid: 11493122].
Excluded. Mazindol, not reviewed.
Glenny A M, O'Meara S, Melville A, Sheldon T A, Wilson C. The treatment and prevention of obesity: a systematic review of the literature. Int J Obes Relat Metab Disord. 1997;21(9):715-37. [Rec#: 235]. [pmid: 9376884].
Excluded. Study design, review or meta-analysis.
Going S B, Levin S, Harrell J, Stewart D, Kushi L, Cornell C E, et al. Physical activity assessment in American Indian schoolchildren in the Pathways study. Am J Clin Nutr. 1999;69(suppl):788S-95S. [Rec#: 539]. [pmid: 10584048].
Excluded. Topic unrelated.
Gokcel A, Gumurdulu Y, Karakose H, Ertorer E M, Tanaci N, Tutuncu N B, et al. Evaluation of the safety and efficacy of sibutramine, orlistat andmetformin in the treatment of obesity. Diabetes, Obesity and Metabolism. 2002;4(1):49-55. [Rec#: 517]. [pmid: 11874442].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Gokcel A, Gumurdulu Y, Karakose H, Karademir B, Anarat R. Effects of sibutramine in non-dieting obese women. Journal of Endocrinological Investigation. 2002;25(2):101-105. [Rec#: 462]. [pmid: 11929078].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Gokcel A, Karakose H, Ertorer E M, Tanaci N, Tutuncu N B, Guvener N. Effects of sibutramine in obese female subjects with type 2 diabetes and poor blood glucose control. Diabetes Care. 2001;24(11):1957-60. [Rec#: 822]. [pmid: 11679464].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Golan M, Fainaru M, Weizman A. Role of behaviour modification in the treatment of childhood obesity with the parents as the exclusive agents of change. Int J Obes Relat Metab Disord. 1998;22(12):1217-24. [Rec#: 376]. [pmid: 9877257].
Excluded. Subject unrelated.
Goldfield G S, Kalakanis L E, Ernst M M, Epstein L H. Open-loop feedback to increase physical activity in obese children. Int J Obes Relat Metab Disord. 2000;24(7):888-92. [Rec#: 377]. [pmid: 10918536].
Excluded. Topic unrelated.
Goldstein D J, Rampey Ah, Potvin J H, Fludzinski L A. Fluoxetine in obese patients with noninsulin-dependent diabetes mellitus. Clin Res. 1992;40:240A. [Rec#: 586].
Excluded. Rejected at abstract.
Golebiowska M, Chlebna-Sokol D, Kobierska I, Konopinska A, Malek M, Mastalska A, et al. [Clinical evaluation of Teronac (mazindol) in the treatment of obesity in children. Part II. Anorectic properties and side effects (author's transl)]. Przegl Lek. 1981;38(3):355-8. [Rec#: 413]. [pmid: 7017827].
Excluded. Unable to find translator.
Golebiowska M, Chlebna-Sokol D, Mastalska A, Zwaigzne-Raczynska J. [The clinical evaluation of teronac (Mazindol) in the treatment of children with obesity. Part I. Effect of the drug on somatic patterns and exercise capacity (author's transl)]. Przegl Lek. 1981;38(2):311-4. [Rec#: 414]. [pmid: 7017826].
Excluded. Unable to find translator.
Gordon A, Price L H. Mood stabilization and weight loss with topiramate. Am J Psychiatry. 1999;156(6):968-9. [Rec#: 749]. [pmid: 10360144].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Gortmaker S L, Cheung L W, Peterson K E, Chomitz G, Cradle J H, Dart H, et al. Impact of a school-based interdisciplinary intervention on diet and physical activity among urban primary school children: eat well and keep moving. Arch Pediatr Adolesc Med. 1999;153(9):975-83. [Rec#: 987]. [pmid: 10482216].
Excluded. Topic unrelated.
Gortmaker S L, Peterson K, Wiecha J, Sobol A M, Dixit S, Fox M K, et al. Reducing obesity via a school-based interdisciplinary intervention among youth: Planet Health. Arch Pediatr Adolesc Med. 1999;153(4):409-18. [Rec#: 988]. [pmid: 10201726].
Excluded. Diet, not reviewed further.
Graham L E, Taylor C B, Hovell M F, Siegel W. Five-year follow-up to a behavioral weight-loss program. J Consult Clin Psychol. 1983;51(2):322-3. [Rec#: 1025]. [pmid: 6841782].
Excluded. Subject unrelated.
Graves T, Meyers A W, Clark L. An evaluation of parental problem-solving training in the behavioral treatment of childhood obesity. J Consult Clin Psychol. 1988;56(2):246-50. [Rec#: 587]. [pmid: 3372833].
Excluded. Diet, not reviewed further.
Gray D S, Fujioka K, Devine W, Bray G A. A randomized double-blind clinical trial of fluoxetine in obese diabetics. Int J Obes Relat Metab Disord. 1992;16 Suppl 4:S67-72. [Rec#: 588]. [pmid: 1338389].
Excluded at meta-analysis.
Greenberg Danielle, Harris Rosemarie, Komorowski James R. Nutritional supplement products containing chromium picolinate and hydroxycitric acid lead to weight loss in randomized controlled study. FASEB Journal. 2001;15(4):A75. [Rec#: 463].
Excluded. Subject unrelated.
Greeno C G, Wing R R. A double-blind, placebo-controlled trial of the effect of fluoxetine on dietary intake in overweight women with and without binge-eating disorder. Am J Clin Nutr. 1996;64(3):267-73. [Rec#: 898]. [pmid: 8780333].
Excluded. Duration of treatment < 6 months.
Greenstein R J, Martin L, MacDonald K J, Chapman W, McIntyre R, Witgrove A C, et al. The LAP-band system as surgical therapy for morbid obesity: Intermediate results of the USA Multicenter Prospective Study. Surg Endosc. 1999;13:S1. [Rec#: 947]. [pmid: 10333873].
Excluded. Not found.
Greenway F, Herber D, Raum W, Herber D, Morales S. Double-blind, randomized, placebo-controlled clinical trials with non-prescription medications for the treatment of obesity. Obesity research. 1999;7(4):370-8. [Rec#: 378]. [pmid: 10440593].
Excluded. Subject unrelated.
Gropper S S, Acosta P B. The therapeutic effect of fiber in treating obesity. J Am Coll Nutr. 1987;6(6):533-5. [Rec#: 589]. [pmid: 2826563].
Excluded. Subject unrelated.
Guessl H S, Williams G, Adrian T E, Bloom S R. Guar sprinkled on food: effect on glycaemic control, plasma lipids and gut hormones in non-insulin dependent diabetic patients. Diabet Med. 1987;4(5):463-8. [Rec#: 585]. [pmid: 2959439].
Excluded. Not found.
Guillaume M, Lapidus L, Lambert A. Obesity and nutrition in children. The Belgian Luxembourg Child Study IV. European journal of clinical nutrition. 1998;52(5):323-8. [Rec#: 379]. [pmid: 9630381].
Excluded. Topic unrelated.
Gwinup G. Effect of diet and exercise in the treatment of obesity. In: Bray GA, Bethune JE. Behavioral treatment of obesity: two year follow-up. 1974: [Rec#: 590]
Excluded. Diet, not reviewed further.
Haddock C K, Poston W S, Dill P L, Foreyt J P, Ericsson M. Pharmacotherapy for obesity: a quantitative analysis of four decades of published randomized clinical trials. Int J Obes Relat Metab Disord. 2002;26(2):262-73. [Rec#: 4]. [pmid: 11850760].
Excluded. Study design, review or meta-analysis.
Hagan R D, Upton S J, Wong L, Whittam J. The effects of aerobic conditioning and/or caloric restriction in overweight men and women. Med Sci Sports Exerc. 1986;18(1):87-94. [Rec#: 989]. [pmid: 3457234].
Excluded. Diet, not reviewed further.
Hainer V. Czech trial of sibutramine in the treatment of obesity: Multicentric randomized study. Int J Obes Relat Metab Disord. 2001;25(Supplement 2):S107. [Rec#: 465]. [pmid: 11933881].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Hakala P. Weight reduction programme based on dietary and behavioural counselling - a 2-year follow-up study. Int J Obes Relat Metab Disord 1993;(17):49. [Rec#: 62]
Excluded. Subject unrelated.
Hakala P, Karvetti R L. Weight reduction on lactovegetarian and mixed diets. Changes in weight, nutrient intake, skinfold thicknesses and blood pressure. Eur J Clin Nutr. 1989;43(6):421-30. [Rec#: 63]. [pmid: 2743965].
Excluded. Duration of treatment < 6 months.
Hakala P, Karvetti R L, Ronnemaa T. Group vs. individual weight reduction programmes in the treatment of severe obesity—a five year follow-up study. Int J Obes Relat Metab Disord. 1993;17(2):97-102. [Rec#: 64]. [pmid: 8384171].
Excluded. Subject unrelated.
Hall S M. Behavioral treatment of obesity: a two-year follow-up. Behav Res Ther. 1973;11(4):647-8. [Rec#: 1026]. [pmid: 4777656].
Excluded. Subject unrelated.
Halpern A, Mancini M C. Treatment of obesity: an update on anti-obesity medications. Obes Rev. 2003;4(1):25-42. [Rec#: 842]. [pmid: 12608525].
Excluded. Mazindol, not reviewed.
Halpern Alfredo, Leite Claudia Cozer, Herszkowicz Nathan, BarbatoAlfonso, Costa Ana Paula Arruda. Evaluation of efficacy, reliability, and tolerability of sibutramine in obese patients, with an echocardiographic study. Revista do Hospital das Clinicas. 2002;57(3):98-102. [Rec#: 209]. [pmid: 12118266].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Hammer R L, Barrier C A, Roundy E S, Bradford J M, Fisher A G. Calorie-restricted low-fat diet and exercise in obese women. Am J Clin Nutr. 1989;49(1):77-85. [Rec#: 762]. [pmid: 2912014].
Excluded. Duration of treatment < 6 months.
Hanif M W, Kumar S. Pharmacological management of obesity. Expert Opin Pharmacother. 2002;3(12):1711-8. [Rec#: 843]. [pmid: 12472368].
Excluded. Not found.
Hankey CR, Leslie WS, Lean MEJ. An energy deficit approach to weight management during nutritional counselling post myocardial infarction. Proceedings of the Nutrition Society 2001;(60):33A. [Rec#: 65]
Excluded. Duration of treatment < 6 months.
Hanotin C, Thomas F, Jones S P, Leutenegger E, Drouin P. A comparison of sibutramine and dexfenfluramine in the treatment of obesity. Obes Res. 1998;6(4):285-91. [Rec#: 591]. [pmid: 9688105].
Excluded. Duration of treatment < 6 months.
Hanotin C, Thomas F, Jones S P, Leutenegger E, Drouin P. Efficacy and tolerability of sibutramine in obese patients: a dose- ranging study. Int J Obes Relat Metab Disord. 1998;22(1):32-8. [Rec#: 592]. [pmid: 9481597].
Excluded. Duration of treatment < 6 months.
Hansen D, Astrup A, Toubro S, Finer N, Kopelman P, Hilsted J, et al. Predictors of weight loss and maintenance during 2 years of treatment by sibutramine in obesity. Results from the European multi-centre STORM trial. Sibutramine Trial of Obesity Reduction and Maintenance. Int J Obes Relat Metab Disord. 2001;25(4):496-501. [Rec#: 66]. [pmid: 11319653].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Hansen D L, Toubro S, Stock M J, Macdonald I A, Astrup A. The effect of sibutramine on energy expenditure and appetite during chronic treatment without dietary restriction. Int J Obes Relat Metab Disord. 1999;23(10):1016-24. [Rec#: 900]. [pmid: 10557021].
Excluded. Duration of treatment < 6 months.
Hansen D L, Toubro S, Stock M J, Macdonald I A, Astrup A. Thermogenic effects of sibutramine in humans. Am J Clin Nutr. 1998;68(6):1180-6. [Rec#: 899]. [pmid: 9846844].
Excluded. Topic unrelated.
Harfvey-Berino J. Calorie restriction is more effective for obesity treatment than dietary fat restriction. Ann Behav Med 1999;21(35–39). [Rec#: 1027]
Excluded. Subject unrelated.
Hartman W M, Stroud M, Sweet D M, Saxton J. Long-term maintenance of weight loss following supplemented fasting. Int J Eat Disord. 1993;14(1):87-93. [Rec#: 1028]. [pmid: 8339104].
Excluded. Diet, not reviewed further.
Hartmann D, Guzelhan C, Zuiderwijk P B, Odink J. Lack of interaction between orlistat and oral contraceptives. Eur J Clin Pharmacol. 1996;50(5):421-4. [Rec#: 901]. [pmid: 8839667].
Excluded. Duration of treatment < 6 months.
Harto-Truax N, Stern W C, Miller L L, Sato T L, Cato A E. Effects of bupropion on body weight. J Clin Psychiatry. 1983;44 (5 Pt 2):183-6. [Rec#: 750]. [pmid: 11658760].
Excluded. Duration of treatment < 6 months.
Harvey-Berino J. The efficacy of dietary fat vs total energy restriction for wieght loss. Obes Res. 1998;6:202-207. [Rec#: 1029]. [pmid: 9618124].
Excluded. Diet, not reviewed further.
Hasik J, Gawlak E, Tycowa M. [Treatment of simple obesity with mazindol under sanatorium conditions]. Pol Tyg Lek. 1980;35(45):1729-31. [Rec#: 415]. [pmid: 7012806].
Excluded. Unable to find translator.
Haugen H N. Double blind cross-over study of a new appetite suppressant AN 448. Eur J Clin Pharmacol. 1975;8(1):71-4. [Rec#: 902]. [pmid: 786676].
Excluded. Mazindol, not reviewed.
Haulrik N, Toubro S, Dyerberg J, Stender S, Skov A R, Astrup A. Effect of protein and methionine intakes on plasma homocysteine concentrations: a 6-mo randomized controlled trial in overweight subjects. Am J Clin Nutr. 2002;76(6):1202-6. [Rec#: 1069]. [pmid: 12450883].
Excluded. Diet, not reviewed further.
Hauptman J. Orlistat: selective inhibition of caloric absorption can affect long-term body weight. Endocrine. 2000;13(2):201-6. [Rec#: 903]. [pmid: 11186221].
Excluded. Study design, review or meta-analysis.
Haus G, Hoerr S L, Mavis B, Robison J. Key modifiable factors in weight maintenance: fat intake, exercise, and weight cycling. J Am Diet Assoc. 1994;94(4):409-13. [Rec#: 1030]. [pmid: 8144808].
Excluded. Diet, not reviewed further.
Haynes R B, Harper A C, Costley S R, Johnston M, Logan A G, Flanagan P T, et al. Failure of weight reduction to reduce mildly elevated blood pressure: a randomized trial. J Hypertens. 1984;2(5):535-9. [Rec#: 844]. [pmid: 6397541].
Excluded. Duration of treatment < 6 months.
Haynes R B, Kris-Etherton P, McCarron D A, Oparil S, Chait A, Resnick L M, et al. Nutritionally complete prepared meal plan to reduce cardiovascular risk factors: a randomized clinical trial. J Am Diet Assoc. 1999;99(9):1077-83. [Rec#: 960]. [pmid: 10491676].
Excluded. Subject unrelated.
Haynes William G, Mark Allyn L. Pharmacotherapy of obesity: Lessons from clinical trials in hypertension. Journal of Hypertension. 2002;20(9):1731-1735. [Rec#: 469]. [pmid: 12195112].
Excluded. Study design, review or meta-analysis.
Hays Nicholas P, Starling Raymond D, Liu Xiaolan, Sullivan Dennis H, Trappe Todd A, Evans William J. Effects of an ad libitum high carbohydrate diet on body weight and composition in older men and women. FASEB Journal. 2002;16(4):A369. [Rec#: 470].
Excluded. Duration of treatment < 6 months.
Hazenberg B P. Randomized, double-blind, placebo-controlled, multicenter study of sibutramine in obese hypertensive patients. Cardiology. 2000;94(3):152-8. [Rec#: 223 ]. [pmid: 11279320].
Excluded. Duration of treatment < 6 months.
He J, Whelton P K, Appel L J, Charleston J, Klag M J. Long-term effects of weight loss and dietary sodium reduction on incidence of hypertension. Hypertension. 2000;35(2):544-9. [Rec#: 68]. [pmid: 10679495].
Excluded. Diet, not reviewed further.
Health Education Authority. Obesity in primary health care. A literature review. London: Health Education Authority; 1995. [Rec#: 671]
Excluded. Rejected at abstract.
Heber K R. Double-blind trial of mazindol in overweight patients. Med J Aust. 1975;2(14):566-7. [Rec#: 593]. [pmid: 1105106].
Excluded. Mazindol, not reviewed.
Hebert P R, Bolt R J, Borhani N O, Cook N R, Cohen J D, Cutler J A, et al. Design of a multicenter trial to evaluate long-term life-style intervention in adults with high-normal blood pressure levels. Trials of Hypertension Prevention (phase II). Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):130-9. [Rec#: 69]. [pmid: 7795831].
Excluded. Topic unrelated.
Heiat A, Vaccarino V, Krumholz H M. An evidence-based assessment of federal guidelines for overweight and obesity as they apply to elderly persons. Arch Intern Med. 2001;161(9):1194-203. [Rec#: 717]. [pmid: 11343442].
Excluded. Topic unrelated.
Heilbronn L K, Noakes M, Clifton P M. The effect of high- and low-glycemic index energy restricted diets on plasma lipid and glucose profiles in type 2 diabetic subjects with varying glycemic control. J Am Coll Nutr. 2002;21(2):120-7. [Rec#: 1070]. [pmid: 11999539].
Excluded. Subject unrelated.
Heini A F, Lara-Castro C, Schneider H, Kirk K A, Considine R V, Weinsier R L. Effect of hydrolyzed guar fiber on fasting and postprandial satiety and satiety hormones: a double-blind, placebo-controlled trial during controlled weight loss. Int J Obes Relat Metab Disord. 1998;22(9):906-9. [Rec#: 594]. [pmid: 9756250].
Excluded. Topic unrelated.
Helge J W. Long-term fat diet adaptation effects on performance, training capacity, and fat utilization. Med Sci Sports Exerc. 2002;34(9):1499-504. [Rec#: 764]. [pmid: 12218745].
Excluded. Topic unrelated.
Helge J W. Prolonged adaptation to fat-rich diet and training; effects on body fat stores and insulin resistance in man. Int J Obes Relat Metab Disord. 2002;26(8):1118-24. [Rec#: 763]. [pmid: 12119578].
Excluded. Subject unrelated.
Helitzer D L, Davis S M, Gittelsohn J, Going S B, Murray D M, Snyder P, et al. Process evaluation in a multisite, primary obesity-prevention trial in American Indian schoolchildren. Am J Clin Nutr. 1999;69(suppl):816S-24S. [Rec#: 540]. [pmid: 10584048].
Excluded. Topic unrelated.
Hellenius M L, de Faire U, Berglund B, Hamsten A, Krakau I. Diet and exercise are equally effective in reducing risk for cardiovascular disease. Results of a randomized controlled study in men with slightly to moderately raised cardiovascular risk factors. Atherosclerosis. 1993;103(1):81-91. [Rec#: 845]. [pmid: 8280188].
Excluded. Diet, not reviewed further.
Hensrud D D. Dietary treatment and long-term weight loss and maintenance in type 2 diabetes. Obes Res. 2001;9 Suppl 4:348S-353S. [Rec#: 961]. [pmid: 11707564].
Excluded. Diet, not reviewed further.
Hensrud D D, Weinsier R L, Darnell B E, Hunter G R. A prospective study of weight maintenance in obese subjects reduced to normal body weight without weight-loss training. Am J Clin Nutr. 1994;60(5):688-94. [Rec#: 1031]. [pmid: 7942574].
Excluded. Diet, not reviewed further.
Hernandez-Estefania R, Gonzalez-Lamuno D, Garcia-Ribes M, et al. Variables affecting BMI evolution at 2 and 5 years after vertical banded gastroplasty. Obes Surg. 2000;10(2):160-6. [pmid: 10782178].
Excluded. Not retrieved by cut-off date.
Heshka S, Anderson J W, Atkinson R L, Greenway F, Hill J O, Phinney S D, et al. Two-year randomized controlled study of self-help weight loss vs a structured commercial program. FASEB Journal. 2001;15(4):A623. [Rec#: 471].
Excluded. Subject unrelated.
Heshka S, Anderson J W, Atkinson R L, Greenway F L, Hill J O, Phinney S D, et al. Weight Loss With Self-help Compared With a Structured Commercial Program: A Randomized Trial. JAMA. 2003;289(14):1792-8. [Rec#: 649]. [pmid: 12684357].
Excluded. Diet, not reviewed further.
Heymsfield S B, Segal K R, Hauptman J, Lucas C P, Boldrin M N, Rissanen A, et al. Effects of weight loss with orlistat on glucose tolerance and progression to type 2 diabetes in obese adults. Arch Intern Med. 2000;160(9):1321-6. [Rec#: 904]. [pmid: 10809036].
Excluded. Study design, review or meta-analysis.
Heymsfield S B, van Mierlo C A, van der Knaap H C, Heo M, Frier H I. Weight management using a meal replacement strategy: meta and pooling analysis from six studies. Int J Obes Relat Metab Disord. 2003;27(5):537-49. [Rec#: 814]. [pmid: 12704397].
Excluded. Diet, not reviewed further.
Hill J O, Schlundt D G, Sbrocco T, Sharp T, Pope-Cordle J, Stetson B, et al. Evaluation of an alternating-calorie diet with and without exercise in the treatment of obesity. Am J Clin Nutr. 1989;50(2):248-54. [Rec#: 990]. [pmid: 2667313].
Excluded. Subject unrelated.
Hill J O, Sparling P B, Shields T W, Heller P A. Effects of exercise and food restriction on body composition and metabolic rate in obese women. Am J Clin Nutr. 1987;46(4):622-30. [Rec#: 991]. [pmid: 3661479].
Excluded. Subject unrelated.
Hills A P, Parker A W. Obesity management via diet and exercise intervention. Child Care Health Dev. 1988;14(6):409-16. [Rec#: 595]. [pmid: 3228964].
Excluded. Subject unrelated.
Ho G Y, Blaufox M D, Wassertheil-Smoller S, Oberman A, Langford H. Plasma renin predicts success of antihypertensive drug withdrawal. Am J Hypertens. 1994;7(8):679-84. [Rec#: 71]. [pmid: 7986457].
Excluded. Topic unrelated.
Hockaday T D, Hockaday J M, Mann J I, Turner R C. Prospective comparison of modified fat-high-carbohydrate with standard low-carbohydrate dietary advice in the treatment of diabetes: one year follow-up study. Br J Nutr. 1978;39(2):357-62. [Rec#: 765]. [pmid: 629924].
Excluded. Subject unrelated.
Hogan R B, Johnston J H, Long B W, Sones J Q, Hinton L A, Bunge J, et al. A double-blind, randomized, sham-controlled trial of the gastric bubble for obesity. Gastrointest Endosc. 1989;35(5):381-5. [Rec#: 672]. [pmid: 2792672].
Excluded. Subject unrelated.
Hoie L H, Bruusgaard D. Compliance, clinical effects, and factors predicting weight reduction during a very low calorie diet regime. Scand J Prim Health Care. 1995;13(1):13-20. [Rec#: 416]. [pmid: 7777729].
Excluded. Diet, not reviewed further.
Hollis J F, Satterfield S, Smith F, Fouad M, Allender P S, Borhani N, et al. Recruitment for phase II of the Trials of Hypertension Prevention. Effective strategies and predictors of randomization. Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):140-8. [Rec#: 73]. [pmid: 7795832].
Excluded. Topic unrelated.
Holman S L, Goldstein D J, Enas G G. Pattern analysis method for assessing successful weight reduction. Int J Obes Relat Metab Disord. 1994;18(5):281-5. [Rec#: 673]. [pmid: 8061720].
Excluded. Topic unrelated.
Holmback U, Forslund A, Forslund J, Hambraeus L, Lennernas M, Lowden A, et al. Metabolic responses to nocturnal eating in men are affected by sources of dietary energy. J Nutr. 2002;132(7):1892-9. [Rec#: 766]. [pmid: 12097665].
Excluded. Diet, not reviewed further.
Hovell M F, Koch A, Hofstetter C R, Sipan C, Faucher P, Dellinger A, et al. Long-term weight loss maintenance: assessment of a behavioral and supplemented fasting regimen. Am J Public Health. 1988;78(6):663-6. [Rec#: 1032]. [pmid: 3369597]. [pmcid: 1350278].
Excluded. Diet, not reviewed further.
Hu F B, Li T Y, Colditz G A, Willett W C, Manson J E. Television watching and other sedentary behaviors in relation to risk of obesity and type 2 diabetes mellitus in women. JAMA. 2003;289(14):1785-91. [Rec#: 650]. [pmid: 12684356].
Excluded. Topic unrelated.
Huang C C, Chian C Y, Lin J D. Short-term treatment of obesity with fluoxetine as a supplement to a low calorie diet. Changgeng Yi Xue Za Zhi. 1998;21(1):50-6. [Rec#: 905]. [pmid: 9607264].
Excluded. Not found.
Hussain Y, Guzelhan C, Odink J, van der Beek E J, Hartmann D. Comparison of the inhibition of dietary fat absorption by full versus divided doses of orlistat. J Clin Pharmacol. 1994;34(11):1121-5. [Rec#: 906]. [pmid: 7876405].
Excluded. Topic unrelated.
Hypertension Prevention Trial Research Group. Hypertension Prevention Trial 3 Year Results. Circulation. 1988;78(4 suppl 2):568. [Rec#: 74].
Excluded. Diet, not reviewed further.
Inoue S. Clinical studies with mazindol. Obes Res. 1995;3(suppl):549S-552S. [Rec#: 596]. [pmid: 8653567].
Excluded. Mazindol, not reviewed.
Iselin H U, Burckhardt P. Balanced hypocaloric diet versus protein-sparing modified fast in the treatment of obesity: a comparative study. Int J Obes. 1982;6(2):175-81. [Rec#: 417]. [pmid: 7095973].
Excluded. Subject unrelated.
Israsena T, Israngkura M, Srivuthana S. Treatment of childhood obesity. J Med Assoc Thai. 1980;63(8):433-7. [Rec#: 418]. [pmid: 7000948].
Excluded. Subject unrelated.
Jalkanen L. The effect of a weight reduction program on cardiovascular risk factors among overweight hypertensives in primary health care. Scand J Soc Med. 1991;19(1):66-71. [Rec#: 75]. [pmid: 1925430].
Excluded. Diet, not reviewed further.
James P, Astrup A, Finer N, Hilsted J, Kopelman P, Rossner S, et al. Sibutramine trial in obesity reduction and maintenance (STORM). Obesity Research 1999;(7):50. [Rec#: 76]
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
James W P, Avenell A, Broom J, Whitehead J. A one-year trial to assess the value of orlistat in the management of obesity. Int J Obes Relat Metab Disord. 1997;21(Suppl 3):S24-30. [Rec#: 78]. [pmid: 9426390].
Excluded at meta-analysis.
Jeffery R W, Gerber W M, Rosenthal B S, Lindquist R A. Monetary contracts in weight control: effectiveness of group and individual contracts of varying size. J Consult Clin Psychol. 1983;51(2):242-8. [Rec#: 745]. [pmid: 6841768].
Excluded. Subject unrelated.
Jeffery R W, Gray C W, French S A, Hellerstedt W L, Murray D, Luepker R V, et al. Evaluation of weight reduction in a community intervention for cardiovascular disease risk: changes in body mass index in the Minnesota Heart Health Program. Int J Obes Relat Metab Disord. 1995;19(1):30-9. [Rec#: 675]. [pmid: 7719388].
Excluded. Rejected at abstract.
Jeffery R W, Hellerstedt W L, French S A, Baxter J E. A randomized trial of counseling for fat restriction versus calorie restriction in the treatment of obesity. Int J Obes Relat Metab Disord. 1995;19(2):132-7. [Rec#: 676]. [pmid: 7735340].
Excluded. Subject unrelated.
Jeffery R W, Bjornson-Benson W M, Rosenthal B S, Lindquist R A, Kurth C L, Johnson S L. Correlates of weight loss and its maintenance over two years of follow- up among middle-aged men. Prev Med. 1984;13(2):155-68. [Rec#: 273]. [pmid: 6739444].
Excluded. Subject unrelated.
Jeffery R W, French S A, Schmid T L. Attributions for dietary failures: problems reported by participants in the Hypertension Prevention Trial. Health Psychol. 1990;9(3):315-29. [Rec#: 79]. [pmid: 2187695].
Excluded. Topic unrelated.
Jeffery R W, Wing R R. Long-term effects of interventions for weight loss using food provision and monetary incentives. J Consult Clin Psychol. 1995;63(5):793-6. [Rec#: 80]. [pmid: 7593872].
Excluded. Diet, not reviewed further.
Jeffery R W, Wing R R, Mayer R R. Are smaller weight losses or more achievable weight loss goals better in the long term for obese patients?. J Consult Clin Psychol. 1998;66(4):641-5. [Rec#: 81]. [pmid: 9735580].
Excluded. Diet, not reviewed further.
Jeffery R W, Wing R R, Thorson C, Burton L R, Raether C, Harvey J, et al. Strengthening behavioral interventions for weight loss: a randomized trial of food provision and monetary incentives. J Consult Clin Psychol. 1993;61(6):1038-45. [Rec#: 82]. [pmid: 8113481].
Excluded. Diet, not reviewed further.
Jenkins D J, Kendall C W, Vidgen E, Augustin L S, van Erk M, Geelen A, et al. High-protein diets in hyperlipidemia: effect of wheat gluten on serum lipids, uric acid, and renal function. Am J Clin Nutr. 2001;74(1):57-63. [Rec#: 767]. [pmid: 11451718].
Excluded. Subject unrelated.
Jernberg T, Lindahl B, Wallentin L. ST-segment monitoring with continuous 12-lead ECG improves early risk stratification in patients with chest pain and ECG nondiagnostic of acute myocardial infarction. J Am Coll Cardiol. 1999;34(5):1413-9. [Rec#: 83]. [pmid: 10551686].
Excluded. Topic unrelated.
Jimenez-Cruz A, Bacardi-Gascon M, Turnbull W H, Rosales-Garay P, Severino-Lugo I. A flexible, low-glycemic index mexican-style diet in overweight and obese subjects with type 2 diabetes improves metabolic parameters during a 6-week treatment period. Diabetes Care. 2003;26(7):1967-70. [Rec#: 971]. [pmid: 12832297].
Excluded. Subject unrelated.
Johnson W G, Hughes J R. Mazindol: its efficacy and mode of action in generating weight loss. Addict Behav. 1979;4(3):237-44. [Rec#: 597]. [pmid: 495247].
Excluded. Mazindol, not reviewed.
Johnson W G, Hinkle L K, Carr R E, Anderson D A, Lemmon C R, Engler L B, et al. Dietary and exercise interventions for juvenile obesity: long-term effect of behavioral and public health models. Obesity research. 1997;5(3):257-61. [Rec#: 236]. [pmid: 9192400].
Excluded. Subject unrelated.
Johnston Carol S, Day Carol S, Swan Pamela D. Postprandial thermogenesis is increased 100% on a high-protein, low-fat diet versus a high-carbohydrate, low-fat diet in healthy, young women. Journal of the American College of Nutrition. 2002;21(1):55-61. [Rec#: 211]. [pmid: 11838888].
Excluded. Topic unrelated.
Jones D W, Miller M E, Wofford M R, Anderson DC D C Jr, Cameron M E, Willoughby D L, et al. The effect of weight loss intervention on antihypertensive medication requirements in the hypertension Optimal Treatment (HOT) study. Am J Hypertens. 1999;12(12 Pt 1–2):1175-80. [Rec#: 84]. [pmid: 10619579].
Excluded. Diet, not reviewed further.
Jones K B Jr. Roux-en-Y gastric bypass: an effective antireflux procedure in the less than morbidly obese. Obes Surg. 1998;8(1):35-8. [Rec#: 720]. [pmid: 9562484].
Excluded. Population inappropriate.
Jones S E, Owens H M, Bennett G A. Does behaviour therapy work for dietitians? An experimental evaluation of the effects of three procedures in a weight reduction clinic. Hum Nutr Appl Nutr. 1986;40(4):272-81. [Rec#: 85]. [pmid: 3759500].
Excluded. Subject unrelated.
Jones SP, Smith IG, Kelly F, Gray JA. Long term weight loss with sibutramine. Int J Obes Relat Metab Disord 1995;(19):41. [Rec#: 86]
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Jordan H A, Canavan A J, Steer R A. Patterns of weight change: the interval 6 to 10 years after initial weight loss in a cognitive-behavioral treatment program. Psychol Rep. 1985;57(1):195-203. [Rec#: 1033]. [pmid: 4048335].
Excluded. Subject unrelated.
Kalman D, Incledon T, Gaunaurd I, Schwartz H, Krieger D. An acute clinical trial evaluating the cardiovascular effects of an herbal ephedra-caffeine weight loss product in healthy overweight adults. Int J Obes Relat Metab Disord. 2002;26(10):1363-6. [Rec#: 846]. [pmid: 12355332].
Excluded. Topic unrelated.
Kaplan R M, Hartwell S L, Wilson D K, Wallace J P. Effects of diet and exercise interventions on control and quality of life in non-insulin-dependent diabetes mellitus. J Gen Intern Med. 1987;2(4):220-8. [Rec#: 87]. [pmid: 3302144].
Excluded. Duration of treatment < 6 months.
Karvetti R L, Hakala P. A seven-year follow-up of a weight reduction programme in Finnish primary health care. Eur J Clin Nutr. 1992;46(10):743-52. [Rec#: 88]. [pmid: 1425528].
Excluded. Diet, not reviewed further.
Karvetti R L, Knuts L R. Effects of comprehensive rehabilitation on weight reduction in myocardial infarction patients. Scand J Rehabil Med. 1983;15(1):11-6. [Rec#: 338]. [pmid: 6828828].
Excluded. Diet, not reviewed further.
Kasim S E, Martino S, Kim P N, Khilnani S, Boomer A, Depper J, et al. Dietary and anthropometric determinants of plasma lipoproteins during a long-term low-fat diet in healthy women. Am J Clin Nutr. 1993;57(2):146-53. [Rec#: 992]. [pmid: 8424382].
Excluded. Diet, not reviewed further.
Katzel L I, Bleecker E R, Colman E G, Rogus E M, Sorkin J D, Goldberg A P. Effects of weight loss vs aerobic exercise training on risk factors for coronary disease in healthy, obese, middle-aged and older men. A randomized controlled trial. JAMA. 1995;274(24):1915-21. [Rec#: 847]. [pmid: 8568984].
Excluded. Diet, not reviewed further.
Kaukua J, Pekkarinen T, Rissanen A. Quality of life in obese type 2 diabetics in a randomised controlled weight loss trial comparing sibutramine to placebo. Int J Obes Relat Metab Disord. 2002;26(Supplement 1):S184. [Rec#: 472]. [pmid: 12461680].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Kaukua J, Pekkarinen T, Sane T, Mustajoki P. Health-related quality of life in WHO class II-III obese men losing weight with very-low-energy diet and behaviour modification: a randomised clinical trial. Int J Obes Relat Metab Disord. 2002;26(4):487-95. [Rec#: 214]. [pmid: 12075575].
Excluded. Diet, not reviewed further.
Kay J P, Alemzadeh R, Langley G, D'Angelo L, Smith P, Holshouser S. Beneficial effects of metformin in normoglycemic morbidly obese adolescents. Metabolism: clinical and experimental. 2001;50(12):1457-61. [Rec#: 380]. [pmid: 11735093].
Excluded. Rejected at abstract.
Kaye Walter H, Nagata Toshihiko, Weltzin Theodore E, Hsu L, George K, Sokol Mae S, McConaha Claire, et al. Double-blind placebo-controlled administration of fluoxetine in restricting- and restricting-purging-type anorexia nervosa. Biological Psychiatry. 2001;49(7):644-652. [Rec#: 473]. [pmid: 11297722].
Excluded. Rejected at abstract.
Kazdin A E, Weisz J R. Identifying and developing empirically supported child and adolescent treatments. Journal of consulting and clinical psychology. 1998;66(1):19-36. [Rec#: 381]. [pmid: 9489260].
Excluded. Diet, not reviewed further.
Keating GM, Jarvis B. Orlistat: in the prevention and treatment of type 2 diabetes mellitus. Drugs 2001;61(14):2107–19; discussion 2120–1. [Rec#: 907]
Excluded. Study design, review or meta-analysis.
Keim N L, Barbieri T F, Van Loan M D, Anderson B L. Energy expenditure and physical performance in overweight women: response to training with and without caloric restriction. Metabolism. 1990;39(6):651-8. [Rec#: 993]. [pmid: 2352481].
Excluded. Subject unrelated.
Kern P A, Trozzolino L, Wolfe G, Purdy L. Combined use of behavior modification and very low-calorie diet in weight loss and weight maintenance. Am J Med Sci. 1994;307(5):325-8. [Rec#: 272]. [pmid: 8172224].
Excluded. Rejected at abstract.
Khan A R, Khan G Y, Mitchel A, Qadeer M A. Effect of guar gum on blood lipids. Am J Clin Nutr. 1981;34(11):2446-9. [Rec#: 598]. [pmid: 7304485].
Excluded. Subject unrelated.
Kiernan M, King A C, Kraemer H C, Stefanick M L, Killen J D. Characteristics of successful and unsuccessful dieters: an application of signal detection methodology. Ann Behav Med. 1998;20(1):1-6. [Rec#: 90]. [pmid: 9755345].
Excluded. Topic unrelated.
King A C, Frey-Hewitt B, Dreon D M, Wood P D. Diet vs exercise in weight maintenance. The effects of minimal intervention strategies on long-term outcomes in men. Arch Intern Med. 1989;149(12):2741-6. [Rec#: 91]. [pmid: 2596943].
Excluded. Diet, not reviewed further.
Kirschenbaum D S, Stalonas P M, Zastowny T R, Tomarken A J. Behavioral treatment of adult obesity: attentional controls and a 2-year follow-up. Behav Res Ther. 1985;23(7):675-82. [Rec#: 1034]. [pmid: 4074283].
Excluded. Subject unrelated.
Kirschner M A, Schneider G, Ertel N H, Gorman J. An eight-year experience with a very-low-calorie formula diet for control of major obesity. Int J Obes. 1988;12(1):69-80. [Rec#: 274]. [pmid: 3360564].
Excluded. Diet, not reviewed further.
Klein S. Outcome success in obesity. Obesity Research. 2001;9(Suppl. 4):354S-358S. [Rec#: 520]. [pmid: 11918343].
Excluded. Study design, review or meta-analysis.
Klem M L, Wing R R, Simkin-Silverman L, Kuller L H. The psychological consequences of weight gain prevention in healthy, premenopausal women. Int J Eat Disord. 1997;21(2):167-74. [Rec#: 340]. [pmid: 9062840].
Excluded. Duration of treatment < 6 months.
Kogon M M, Krauchi K, Van der Velde P, Van der Werf H, Keller U. Psychological and metabolic effects of dietary carbohydrates and dexfenfluramine during a low-energy diet in obese women. Am J Clin Nutr. 1994;60(4):488-93. [Rec#: 768]. [pmid: 8092082].
Excluded. Subject unrelated.
Kohrt W M, Ehsani A A, Birge S J Jr. Effects of exercise involving predominantly either joint-reaction or ground-reaction forces on bone mineral density in older women. J Bone Miner Res. 1997;12(8):1253-61. [Rec#: 341]. [pmid: 9258756].
Excluded. Subject unrelated.
Kornhaber A. Obesity-depression: clinical evaluation with a new anorexigenic agent. Psychosomatics. 1973;14(3):162-7. [Rec#: 599]. [pmid: 4604838].
Excluded. Duration of treatment < 6 months.
Korsten-Reck Ulrike, Wolfarth B, Kromeyer-Hauschild K, Rudloff C, Berg A. FITOC (Freiburg intervention trial for obese children); short-term and long-term results. Int J Obes Relat Metab Disord. 2002;26(Supplement 1):S10. [Rec#: 474]. [pmid: 12461680].
Excluded. Subject unrelated.
Kostis J B, Wilson A C, Shindler D M, Cosgrove N M, Lacy C R. Non-drug therapy for hypertension: do effects on weight and sodium intake persist after discontinuation of intervention?. Am J Med. 2000;109(9):734-6. [Rec#: 92]. [pmid: 11137490].
Excluded. Subject unrelated.
Kral J G. Selection of patients for anti-obesity surgery. Int J Obes Relat Metab Disord. 2001;25(Supplement 1):S107-S112. [Rec#: 475]. [pmid: 11933881].
Kramer F M, Jeffery R W, Forster J L, Snell M K. Long-term follow-up of behavioral treatment for obesity: patterns of weight regain among men and women. Int J Obes. 1989;13(2):123-36. [Rec#: 1035]. [pmid: 2663745].
Excluded. Subject unrelated.
Krassas G, Panotopoulos G, Thalassinos N, Avramides A, Katsilambros N. The efficacy and safety of orlistat in Greek obese patients: A multicentre study. Int J Obes Relat Metab Disord. 2002;26(Supplement 1):S14. [Rec#: 476]. [pmid: 12461680].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Kratz M, von Eckardstein A, Fobker M, Buyken A, Posny N, Schulte H, et al. The impact of dietary fat composition on serum leptin concentrations in healthy nonobese men and women. J Clin Endocrinol Metab. 2002;87(11):5008-14. [Rec#: 1075]. [pmid: 12414865].
Excluded. Subject unrelated.
Krejs G J. Metabolic benefits associated with sibutramine therapy. Int J Obes Relat Metab Disord. 2002;26 Suppl 4:S34-7. [Rec#: 823 ]. [pmid: 12457298].
Excluded. Study design, review or meta-analysis.
Kremen A J, Linner J H. An Experimental evaluation of the nutritional imortance of proximal and distal small intestine. Ann Surg. 1954;140:439-48. [Rec#: 951]. [pmid: 13198079].
Excluded. Population inappropriate.
Krotkiewski M, Toss L, Bjorntorp P, Holm G. The effect of a very-low-calorie diet with and without chronic exercise on thyroid and sex hormones, plasma proteins, oxygen uptake, insulin and c peptide concentrations in obese women. Int J Obes. 1981;5(3):287-93. [Rec#: 994]. [pmid: 7024157].
Excluded. Diet, not reviewed further.
Kuller L H. Obesity and years of life lost. JAMA. 2003;289(14):1777. [Rec#: 655]. [pmid: 12684349].
Excluded. Topic unrelated.
Kuller L H, Simkin-Silverman L R, Wing R R, Meilahn E N, Ives D G. Women's Healthy Lifestyle Project: A randomized clinical trial: results at 54 months. Circulation. 2001;103(1):32-7. [Rec#: 722]. [pmid: 11136682].
Excluded. Diet, not reviewed further.
Kumanyika S K, Obarzanek E, Robinson T N, Beech B M. Phase 1 of the Girls health Enrichment Multi-site Studies (GEMS): conclusion. Ethn Dis. 2003;13(1 Suppl 1):S88-91. [Rec#: 873]. [pmid: 14964185].
Excluded. Diet, not reviewed further.
Kumanyika SK, Brancato J, Brewer A, Carnaghi M, Doroshenko L, Rosen R, et al. Interventions in the trials of nonpharmacologic intervention in the elderly: an effective approach to weight and sodium reduction among older adults. Circulation 1996;(94):I-690. [Rec#: 93]
Excluded. Subject unrelated.
Kutnowski M, Daubresse J C, Friedman H, Kolanowski J, Krzentowski G, Scheen A, et al. Fluoxetine therapy in obese diabetic and glucose intolerant patients. Int J Obes Relat Metab Disord. 1992;16 Suppl 4:S63-6. [Rec#: 600]. [pmid: 1338388].
Excluded. Duration of treatment < 6 months.
Kylov VI. Efficacy and safety of fluoxetine treatment of obesity. 10th European College of Neuropsychopharmacology Congress. September 13th – 17th, 1997; Vienna, Austria. 1997.
Excluded. Not found.
Laessle R G, Wurmser H, Pirke K M. Restrained eating and leptin levels in overweight preadolescent girls. Physiol Behav. 2000;70(1–2):45-7. [Rec#: 420]. [pmid: 11239674].
Excluded. Topic unrelated.
Laitinen J, Uusitupa M, Ahola I, Laakso M, Siitonen O. Metabolic and dietary variables associated with glycaemic control in patients with recently diagnosed Type II diabetes mellitus. Diabetes, Nutrition & Metabolism. 1994;7(2):77-87. [Rec#: 94].
Excluded. Diet, not reviewed further.
Laitinen J, Uusitupa M, Ahola I, Siitonen O. Metabolic and dietary determinants of serum lipids in obese patients with recently diagnosed non-insulin-dependent diabetes. Ann Med. 1994;26(2):119-24. [Rec#: 95]. [pmid: 8024729].
Excluded. Diet, not reviewed further.
Laitinen J H, Ahola I E, Sarkkinen E S, Winberg R L, Harmaakorpi-Iivonen P A, Uusitupa M I. Impact of intensified dietary therapy on energy and nutrient intakes and fatty acid composition of serum lipids in patients with recently diagnosed non-insulin-dependent diabetes mellitus. J Am Diet Assoc. 1993;93(3):276-83. [Rec#: 96]. [pmid: 8382712].
Excluded. Diet, not reviewed further.
Lalor B C, Bhatnagar D, Winocour P H, Ishola M, Arrol S, Brading M, et al. Placebo-controlled trial of the effects of guar gum and metformin on fasting blood glucose and serum lipids in obese, type 2 diabetic patients. Diabet Med. 1990;7(3):242-5. [Rec#: 601]. [pmid: 2158410].
Excluded. Subject unrelated.
Lampman R M, Santinga J T, Bassett D R, Block W D, Mercer N, Hook D A, et al. Type IV hyperlipoproteinemia: effects of a caloric restricted type IV diet versus physical training plus isocaloric type IV diet. Am J Clin Nutr. 1980;33(6):1233-43. [Rec#: 995]. [pmid: 6992559].
Excluded. Subject unrelated.
Landin K, Holm G, Tengborn L, Smith U. Guar gum improves insulin sensitivity, blood lipids, blood pressure, and fibrinolysis in healthy men. Am J Clin Nutr. 1992;56(6):1061-5. [Rec#: 602]. [pmid: 1442658].
Excluded. Subject unrelated.
Langford H G, Blaufox M D, Oberman A, Hawkins C M, Curb J D, Cutter G R, et al. Dietary therapy slows the return of hypertension after stopping prolonged medication. JAMA. 1985;253(5):657-64. [Rec#: 97]. [pmid: 3881608].
Excluded. Diet, not reviewed further.
Langford H G, Davis B R, Blaufox D, Oberman A, Wassertheil-Smoller S, Hawkins M, et al. Effect of drug and diet treatment of mild hypertension on diastolic blood pressure. The TAIM Research Group. Hypertension. 1991;17(2):210-7. [Rec#: 98]. [pmid: 1671380].
Excluded. Subject unrelated.
Langlois K J, Forbes J A, Bell G W, Grant G F Jr. A double-blind clinical evaluation of the safety and efficacy of phentermine hydrochloride (Fastin) in the treatment of exogenous obesity. Curr Ther Res Clin Exp. 1974;16(4):289-96. [Rec#: 603]. [pmid: 4208343].
Excluded. Duration of treatment < 6 months.
Lantz H, Peltonen M, Agren L, Torgerson J S. Intermittent versus on-demand use of a very low calorie diet: a randomized 2-year clinical trial. J Intern Med. 2003;253(4):463-71. [Rec#: 874]. [pmid: 12653876].
Excluded. Subject unrelated.
Lasser V I, Raczynski J M, Stevens V J, Mattfeldt-Beman M K, Kumanyika S, Evans M, et al. Trials of Hypertension Prevention, phase II. Structure and content of the weight loss and dietary sodium reduction interventions. Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):156-64. [Rec#: 99 ]. [pmid: 7795834].
Excluded. Topic unrelated.
Latner J D, Stunkard A J, Wilson G T, Jackson M L, Zelitch D S, Labouvie E. Effective long-term treatment of obesity: a continuing care model. Int J Obes Relat Metab Disord. 2000;24(7):893-8. [Rec#: 275]. [pmid: 10918537].
Excluded. Subject unrelated.
Lavery M A, Loewy J W. Identifying predictive variables for long-term weight change after participation in a weight loss program. J Am Diet Assoc. 1993;93(9):1017-24. [Rec#: 1036]. [pmid: 8360406].
Excluded. Subject unrelated.
Lawton C L, Wales J K, Hill A J, Blundell J E. Serotoninergic manipulation, meal-induced satiety and eating pattern: effect of fluoxetine in obese female subjects. Obes Res. 1995;3(4):345-56. [Rec#: 908]. [pmid: 8521151].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Lean M E, Han T S, Prvan T, Richmond P R, Avenell A. Weight loss with high and low carbohydrate 1200 kcal diets in free living women. Eur J Clin Nutr. 1997;51(4):243-8. [Rec#: 769]. [pmid: 9104574].
Excluded. Subject unrelated.
Leiser J P, Gunning K. What is the long-term efficacy and tolerability of orlistat, a gastrointestinal lipase inhibitor, for the treatment of obesity in primary care?. J Fam Pract. 2000;49(6):572-3. [Rec#: 100]. [pmid: 10923560].
Excluded. Study design, review or meta-analysis.
Leung W Y, Neil Thomas G, Chan J C, Tomlinson B. Weight management and current options in pharmacotherapy: Orlistat and sibutramine. Clin Ther. 2003;25(1):58-80. [Rec#: 802]. [pmid: 12637112].
Excluded. Study design, review or meta-analysis.
Levine L R, Enas G G, Thompson W L, Byyny R L, Dauer A D, Kirby R W, et al. Use of fluoxetine, a selective serotonin-uptake inhibitor, in the treatment of obesity: a dose-response study (with a commentary by Michael Weintraub). Int J Obes. 1989;13(5):635-45. [Rec#: 248]. [pmid: 2583918].
Excluded. Duration of treatment < 6 months.
Levine L R, Rosenblatt S, Bosomworth J. Use of a serotonin re-uptake inhibitor, fluoxetine, in the treatment of obesity. Int J Obes. 1987;11 ( Suppl 3):185-90. [Rec#: 421]. [pmid: 3667070].
Excluded. Duration of treatment < 6 months.
Levine M D, Ringham R M, Kalarchian M A, Wisniewski L, Marcus M D. Is family-based behavioral weight control appropriate for severe pediatric obesity?. International journal of eating disorders. 2001;30(3):318-28. [Rec#: 382]. [pmid: 11746293].
Excluded. Diet, not reviewed further.
Levy E, Margolese H C, Chouinard G. Topiramate produced weight loss following olanzapine-induced weight gain in schizophrenia. J Clin Psychiatry. 2002;63(11):1045. [Rec#: 752]. [pmid: 12469686].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Li Qi-fu, Li Rong, Luo Rong, Wang Zhihong, Liu Zhi-ping, He Jun, et al. Sibutramine capsules for treatment of simple obesity. Zhongguo Xinyao yu Linchuang ZANhi. 2002;21(7):401-404. [Rec#: 478].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Lijesen G K, Theeuwen I, Assendelft W J, Van Der Wal G. The effect of human chorionic gonadotropin (HCG) in the treatment of obesity by means of the Simeons therapy: a criteria-based meta-analysis. Br J Clin Pharmacol. 1995;40(3):237-43. [Rec#: 276]. [pmid: 8527285]. [pmcid: 1365103].
Excluded. Subject unrelated.
Lindahl B. More is worse—ST-segment deviation in unstable coronary artery disease. Eur Heart J. 1999;20(22):1611-2. [Rec#: 102]. [pmid: 10543920].
Excluded. Topic unrelated.
Lindahl B. Therapeutic implications of the use of cardiac markers in acute coronary syndromes. Scand J Clin Lab Invest Suppl. 1999;230:43-9. [Rec#: 101]. [pmid: 10389201].
Excluded. Topic unrelated.
Lindahl B, Dinesen B, Eliasson M, Roder M, Jansson J H, Huhtasaari F, et al. High proinsulin concentration precedes acute myocardial infarction in a nondiabetic population. Metabolism. 1999;48(9):1197-202. [Rec#: 103]. [pmid: 10484064].
Excluded. Topic unrelated.
Lindahl B, Nilsson T K, Jansson J H, Asplund K, Hallmans G. Improved fibrinolysis by intense lifestyle intervention. A randomized trial in subjects with impaired glucose tolerance. J Intern Med. 1999;246(1):105-12. [Rec#: 104]. [pmid: 10447232].
Excluded. Diet, not reviewed further.
Lindahl B, Weinehall L, Asplund K, Hallmans G. Screening for impaired glucose tolerance. Results from a population- based study in 21,057 individuals. Diabetes Care. 1999;22(12):1988-92. [Rec#: 105]. [pmid: 10587831].
Excluded. Topic unrelated.
Lindahl B, Westling C, Gimenez-Gallego G, Lindahl U, Salmivirta M. Common binding sites for beta-amyloid fibrils and fibroblast growth factor-2 in heparan sulfate from human cerebral cortex. J Biol Chem. 1999;274(43):30631-5. [Rec#: 106]. [pmid: 10521448].
Excluded. Topic unrelated.
Lindeberg S, Eliasson M, Lindahl B, Ahren B. Low serum insulin in traditional Pacific Islanders—the Kitava Study. Metabolism. 1999;48(10):1216-9. [Rec#: 107]. [pmid: 10535381].
Excluded. Topic unrelated.
Lindstrom J, Tuomilehto J, Louheranta A, Mannelin M, Rastas M, Salminen V, et al. Prevention of type 2 diabetes by lifestle intervention - the finnish diabetes prevention study. Int J Obes Relat Metab Disord. 2001;25 (suppl 2):S21. [Rec#: 110]. [pmid: 11933881].
Excluded. Diet, not reviewed further.
Linfors E W, Feussner J R, Blessing C L, Starmer C F, Neelon F A, McKee P A. Spurious hypertension in the obese patient. Effect of sphygmomanometer cuff size on prevalence of hypertension. Archives of internal medicine. 1984;144(7):1482-5. [Rec#: 383]. [pmid: 6732409].
Excluded. Topic unrelated.
Littrell K H, Petty R G, Hiligoss N M, Peabody C D, Johnson C G. Weight loss with topiramate. Ann Pharmacother. 2001;35(9):1141-2. [Rec#: 753]. [pmid: 11573869].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Liu Hong, Ouyang Ling-li, Luo Zuo-jie, Zhou Yan-wen, LinJian, Shen Han-lei. Effect of sex on weight loss with sibutramine. Zhongguo Xinyao yu Linchuang Zazhi. 2002;21(4):234-236. [Rec#: 479].
Exclude. Duration of treatment < 6 months.
Liu M Y, Yeh S L, Chen W J. Effects of weight reduction on body composition and plasma lipids in obese women. Nutritional Sciences Journal. 1998;23(1):83-93. [Rec#: 343].
Excluded. Diet, not reviewed further.
Lohman T G, Caballero B, Himes J H, Hunsberger R R, Stewart D, Skipper B. Body composition assessment in American Indian children. Am J Clin Nutr. 1999;69 (suppl):764S-6S. [Rec#: 541]. [pmid: 10584048].
Excluded. Topic unrelated.
Loke Y K, Derry S, Pritchard-Copley A. Appetite suppressants and valvular heart disease - a systematic review. BMC Clin Pharmacol. 2002;2(1):6. [Rec#: 909]. [pmcid: 126245]. [pmid: 12194699].
Excluded. Study design, review or meta-analysis.
London A M, Schreiber E D. A controlled study of the effects of group discussions and an anorexiant in outpatient treatment of obesity. With attention to the psychological aspects of dieting. Ann Intern Med. 1966;65(1):80-92. [Rec#: 422]. [pmid: 5327947].
Excluded. Subject unrelated.
Long C G, Simpson C M, Allott E A. Psychological and dietetic counselling combined in the treatment of obesity: a comparative study in a hospital outpatient clinic. Hum Nutr Appl Nutr. 1983;37(2):94-102. [Rec#: 111]. [pmid: 6408031].
Excluded. Subject unrelated.
Lorber J. Obesity in childhood. A controlled trial of anorectic drugs. Arch Dis Child. 1966;41(217):309-12. [Rec#: 423]. [pmid: 5328625].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Lousley S E, Jones D B, Slaughter P, Carter R D, Jelfs R, Mann J I. High carbohydrate-high fibre diets in poorly controlled diabetes. Diabet Med. 1984;1(1):21-5. [Rec#: 770]. [pmid: 6100938].
Excluded. Topic unrelated.
Lowe M R, Annunziato R, Riddell L, Butryn M, CrerandC, Didie L, et al. Controlled trial of a nutrition-focused treatment for weight loss maintenance. Int J Obes Relat Metab Disord. 2002;26 (Supplement 1):S24. [Rec#: 480]. [pmid: 12461680].
Excluded. Diet, not reviewed further.
Lucas Kristy H, Kaplan-Machlis Barbara. Orlistat: A novel weight loss therapy. Annals of Pharmacotherapy. 2001;35(3):314-328. [Rec#: 481]. [pmid: 11261530].
Excluded. Study design, review or meta-analysis.
Luepker R V, Perry C L, McKinlay S M, Nader P R, Parcel G S, Stone E J, et al. Outcomes of a field trial to improve children's dietary patterns and physical activity. The Child and Adolescent Trial for Cardiovascular Health. CATCH collaborative group. JAMA. 1996;275(10):768-76. [Rec#: 996]. [pmid: 8598593].
Excluded. Diet, not reviewed further.
Luscombe N D, Clifton P M, Noakes M, Parker B, Wittert G. Effects of energy-restricted diets containing increased protein on weight loss, resting energy expenditure, and the thermic effect of feeding in type 2 diabetes. Diabetes Care. 2002;25(4):652-7. [Rec#: 771]. [pmid: 11919120].
Excluded. Subject unrelated.
Luscombe N D, Noakes M, Clifton P M. Diets high and low in glycemic index versus high monounsaturated fat diets: effects on glucose and lipid metabolism in NIDDM. Eur J Clin Nutr. 1999;53(6):473-8. [Rec#: 772]. [pmid: 10403584].
Excluded. Diet, not reviewed further.
Maclay W P, Wallace M G. A multi-centre general practice trial of mazindol in the treatment of obesity. Practitioner. 1977;218(1305):431-4. [Rec#: 263]. [pmid: 322112].
Excluded. Mazindol, not reviewed.
MacMahon S W, Macdonald G J, Bernstein L, Andrews G, Blacket R B. A randomized controlled trial of weight reduction and metoprolol in the treatment of hypertension in young overweight patients. Clin Exp Pharmacol Physiol. 1985;12(3):267-71. [Rec#: 848]. [pmid: 3896595].
Excluded. Duration of treatment < 6 months.
Maetzel A, Ruof J, Covington M, Wolf A. Economic evaluation of orlistat in overweight and obese patients with type 2 diabetes mellitus. Pharmacoeconomics. 2003;21(7):501-12. [Rec#: 849]. [pmid: 12696990].
Excluded. Study design, review or meta-analysis.
Maheux P, Ducros F, Bourque J, Garon J, Chiasson J L. Fluoxetine improves insulin sensitivity in obese patients with non-insulin-dependent diabetes mellitus independently of weight loss. Int J Obes Relat Metab Disord. 1997;21(2):97-102. [Rec#: 910]. [pmid: 9043962].
Excluded. Duration of treatment < 6 months.
Makkonen M, Simpanen A L, Saarikoski S, Uusitupa M, Penttila I, Silvasti M, et al. Endocrine and metabolic effects of guar gum in menopausal women. Gynecol Endocrinol. 1993;7(2):135-41. [Rec#: 605]. [pmid: 8213228].
Excluded. Subject unrelated.
Manios Y, Moschandreas J, Hatzis C, Kafatos A. Evaluation of a health and nutrition education program in primary school children of Crete over a three-year period. Prev Med. 1999;28(2):149-59. [Rec#: 997]. [pmid: 10048106].
Excluded. Diet, not reviewed further.
Manning R M, Jung R T, Leese G P, Newton R W. The comparison of four weight reduction strategies aimed at overweight diabetic patients. Diabet Med. 1995;12(5):409-15. [Rec#: 724]. [pmid: 7648803].
Excluded. Diet, not reviewed further.
Marchini J S, Lambertini C R, Ferriolli E, Oliveira JEDde. Obese women on a low energy rice and bean diet: effects of leucine,arginine or glycine supplementation on protein turnover. Brazilian Journal of Medical and Biological Research. 2001;34(10):1277-1283. [Rec#: 521]. [pmid: 11593302].
Excluded. Subject unrelated.
Marckmann P, Toubro S, Astrup A. Sustained improvement in blood lipids, coagulation, and fibrinolysis after major weight loss in obese subjects. Eur J Clin Nutr. 1998;52(5):329-33. [Rec#: 278]. [pmid: 9630382].
Excluded. Subject unrelated.
Marcus M D, Wing R R, Guare J, Blair E H, Jawad A. Lifetime prevalence of major depression and its effect on treatment outcome in obese type II diabetic patients. Diabetes Care. 1992;15(2):253-5. [Rec#: 113]. [pmid: 1547681].
Excluded. Diet, not reviewed further.
Margraf J. Weight loss and long-term weight maintenance with orlistat: an 18-month patient support program. Int J Obes Relat Metab Disord. 2001;25 (Suppl 2):s1033. [Rec#: 344]. [pmid: 11933881].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Marniemi J, Seppanen A, Hakala P. Long-term effects on lipid metabolism of weight reduction on lactovegetarian and mixed diet. Int J Obes. 1990;14(2):113-25. [Rec#: 114]. [pmid: 2111292].
Excluded. Diet, not reviewed further.
Marsoobian V, Grosvenor M, Jacob M, Ipp E. Very-low-energy diets alter the counterregulatory response to falling plasma glucose concentrations. American journal of clinical nutrition. 1995;61(2):373-8. [Rec#: 384]. [pmid: 7840077].
Excluded. Subject unrelated.
Mason E E. Gastric surgery for morbid obesity. Surg Clin North Am. 1992;72(2):501-13. [pmid: 1549806].
Excluded. Not retrieved by cut-off date.
Mason E E, Scott D H, Doherty C, et al. Vertical Banded Gastroplasty in the Severely Obese under Age Twenty-One. Obes Surg. 1995;5(1):23-33. [pmid: 10733790].
Excluded. Not retrieved by cut-off date.
Mathieson R A, Walberg J L, Gwazdauskas F C, Hinkle D E, Gregg J M. The effect of varying carbohydrate content of a very-low-caloric diet on resting metabolic rate and thyroid hormones. Metabolism. 1986;35(5):394-8. [Rec#: 1076]. [pmid: 3702673].
Excluded. Subject unrelated.
Mattfeldt-Beman M K, Corrigan S A, Stevens V J, Sugars C P, Dalcin A T, Givi M J, et al. Participants' evaluation of a weight-loss program. J Am Diet Assoc. 1999;99(1):66-71. [Rec#: 115]. [pmid: 9917734].
Excluded. Topic unrelated.
Mazzoni R, Mannucci E, Rizzello S M, Ricca V, Rotella C M. Failure of acupuncture in the treatment of obesity: a pilot study. Eating and weight disorders : EWD. 1999;4(4):198-202. [Rec#: 385]. [pmid: 10728182].
Excluded. Subject unrelated.
McCallum Z, Wake M, Waters E, Gunn J, Gibbons K, Baur L. Methodology of a randomised controlled trial of a primary care intervention for childhood overweight/mild obesity. Int J Obes Relat Metab Disord. 2002;26 (Supplement 1):S194. [Rec#: 482]. [pmid: 12461680].
Excluded. Topic unrelated.
McElroy S L, Arnold L M, Shapira N A, Keck P E Jr, Rosenthal N R, Karim M R, et al. Topiramate in the treatment of binge eating disorder associated with obesity: a randomized, placebo-controlled trial. Am J Psychiatry. 2003;160(2):255-61. [Rec#: 804]. [pmid: 12562571].
Excluded. Duration of treatment < 6 months.
McIvor M E, Cummings C C, Van Duyn M A, Leo T A, Margolis S, Behall K M, et al. Long-term effects of guar gum on blood lipids. Atherosclerosis. 1986;60(1):7-13. [Rec#: 606]. [pmid: 3011023].
Excluded. Subject unrelated.
McKay R H. Long-term use of diethylpropion in obesity. Curr Med Res Opin. 1973;1(8):489-93. [pmid: 4589633].
Excluded. Reports on Diethylproprion; no analysis performed, summary of recent meta-analysis provided.
McMahon F G, Weinstein S P, Rowe E, Ernst K R, Johnson F, Fujioka K. Sibutramine is safe and effective for weight loss in obese patients whose hypertension is well controlled with angiotensin-converting enzyme inhibitors. J Hum Hypertens. 2002;16(1):5-11. [Rec#: 911]. [pmid: 11840224].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
McMahon F G, Fujioka K, Singh B N, Mendel C M, Rowe E, Rolston K, et al. Efficacy and safety of sibutramine in obese white and African American patients with hypertension: a 1-year, double-blind, placebo-controlled, multicenter trial. Arch Intern Med. 2000;160(14):2185-91. [Rec#: 116]. [pmid: 10904462].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
McManus K, Antinoro L, Sacks F. A randomized controlled trial of a moderate-fat, low-energy diet compared with a low fat, low-energy diet for weight loss in overweight adults. Int J Obes Relat Metab Disord. 2001;25(10):1503-1511. [Rec#: 483]. [pmid: 11673773].
Excluded. Subject unrelated.
McNulty S J, Ur E, Williams G. A randomized trial of sibutramine in the management of obese type 2 diabetic patients treated with metformin. Diabetes Care. 2003;26(1):125-31. [Rec#: 805]. [pmid: 12502668].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
McQuarrie H G. Clinical assessment of the use of an anorectic drug in a total weight reduction program. Curr Ther Res Clin Exp. 1975;17(5):437-43. [Rec#: 608]. [pmid: 805027].
Excluded. Duration of treatment < 6 months.
Melanson K, Gootman J, Myrdal A, Kline G, Rippe J M. Weight loss and total lipid profile changes in overweight women consuming beef or chicken as the primary protein source. Nutrition. 2003;19(5):409-14. [Rec#: 815]. [pmid: 12714091].
Excluded. Subject unrelated.
Melia A T, Koss-Twardy S G, Zhi J. The effect of orlistat, an inhibitor of dietary fat absorption, on the absorption of vitamins A and E in healthy volunteers. J Clin Pharmacol. 1996;36(7):647-53. [Rec#: 912]. [pmid: 8844448].
Excluded. Topic unrelated.
Mellin L M, Slinkard L A, Irwin C E. Adolescent obesity intervention: validation of the SHAPEDOWN program. Journal of the American Dietetic Association. 1987;87(3):333-8. [Rec#: 251]. [pmid: 3819254].
Excluded. Subject unrelated.
Menghetti E, Di Feo G, Mucedola G, Montaleone M, Carratelli T J, Agolini D, et al. Follow-up of obese child. Riv Eur Sci Med Farmacol. 1995;17(2–3):77-80. [Rec#: 424]. [pmid: 8766480].
Excluded. Rejected at abstract.
Mertens I, Wauters M, Peiffer F, Van de Sompel M, Van der Planken B, Corthouts B, et al. A 2 year combined weight loss program with a hypocaloric diet, sibutramine and physical activity increase antithrombin III levels in obese subjects. Obesity Research 1999;(7):125.[Rec#: 117]
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Miach P J, Thomson W, Doyle A E, Louis W J. Double-blind cross-over evaluation of mazindol in the treatment of obese hypertensive patients. Med J Aust. 1976;2(10):378-80. [Rec#: 609]. [pmid: 792640].
Excluded. Mazindol, not reviewed.
Michelson D, Amsterdam J D, Quitkin F M, Reimherr F W, Rosenbaum J F, Zajecka J, et al. Changes in weight during a 1-year trial of fluoxetine. Am J Psychiatry. 1999;156(8):1170-6. [Rec#: 277]. [pmid: 10450256].
Excluded. Duplicate article.
Mies R. [Comparative trial on the effects of diet, mazindol, and placebo in the treatment of exogenous obesity (author's transl)]. Med Klin. 1976;71(46):2013-6. [Rec#: 425]. [pmid: 995040].
Excluded. Rejected at abstract.
Miles P, Kerr D. Very low calorie diets in diabetes: the Bournemouth experience. Journal of Diabetes Nursing. 2000;4(4):108-111. [Rec#: 346].
Excluded. Diet, not reviewed further.
Miller E R 3rd, Erlinger T P, Young D R, Jehn M, Charleston J, Rhodes D, et al. Results of the Diet, Exercise, and Weight Loss Intervention Trial (DEW- IT). Hypertension. 2002;40(5):612-8. [Rec#: 773]. [pmid: 12411452].
Excluded. Duration of treatment < 6 months.
Miller Edgar R III, Young Deborah R, Erlinger Thomas P, Jehn Megan L, Charleston Jeanne, Appel Lawrence J. The diet, exercise and weight loss intervention trial (DEW-IT). Circulation. 2001;103(9):1345. [Rec#: 484].
Excluded. Duration of treatment < 6 months.
Mirouze J, Mary P, Schmouker Y, Lapinski H, Chauchard C, Prunac N. [Alternating low calory diets (200 to 1000 calories), their value in the treatment of resistant obesity]. Sem Hop. 1976;52(40):2255-61. [Rec#: 280]. [pmid: 188176].
Excluded. Diet, not reviewed further.
Mitka M. Surgery for obesity: demand soars amid scientific, ethical questions. JAMA. 2003;289(14):1761-2. [Rec#: 659]. [pmid: 12684340].
Excluded. Topic unrelated.
Miura J, Arai K, Tsukahara S, Ohno M, Ikeda Y. The long term effectiveness of combined therapy by behavior modification and very low calorie diet: 2 years follow-up. Int J Obes. 1989;13 (Suppl 2):73-7. [Rec#: 284]. [pmid: 2793305].
Excluded. Diet, not reviewed further.
Mo-suwan L, Pongprapai S, Junjana C, Puetpaiboon A. Effects of a controlled trial of a school-based exercise program on the obesity indexes of preschool children. Am J Clin Nutr. 1998;68(5):1006-11. [Rec#: 998]. [pmid: 9808215].
Excluded. Subject unrelated.
Molokhia M. Obesity wars: a pilot study of very low calorie diets in obese patients in general practice. Br J Gen Pract. 1998;48(430):1251-2. [Rec#: 281]. [pmid: 9692287]. [pmcid: 1410173].
Excluded. Diet, not reviewed further.
Moore DB. Obesity clinical trials in youth: concepts and challenges. Ethn Dis 2002 ;12(4)S3-40-3.[Rec#: 742]
Excluded. Diet, not reviewed further.
Morrison J A, Cottingham E M, Barton B A. Metformin for weight loss in pediatric patients taking psychotropic drugs. Am J Psychiatry. 2002;159(4):655-7. [pmid: 11925306].
Excluded. Subject: not on diet, surgery, or medication.
Msika S. [Surgery for morbid obesity: 2. Complications. Results of a Technologic Evaluation by the ANAES]. J Chir (Paris). 2003;140(1):4-21. [Rec#: 875]. [pmcid: 358319]. [pmid: 15314698].
Excluded. Subject unrelated.
Muller H, Lindman A S, Brantsaeter A L, Pedersen J I. The serum LDL/HDL cholesterol ratio is influenced more favorably by exchanging saturated with unsaturated fat than by reducing saturated fat in the diet of women. J Nutr. 2003;133(1):78-83. [Rec#: 774]. [pmid: 12514271].
Excluded. Diet, not reviewed further.
Muller M J, Asbeck I, Mast M, Langnase K, Grund A. Prevention of obesity—more than an intention. Concept and first results of the Kiel Obesity Prevention Study (KOPS). Int J Obes Relat Metab Disord. 2001;25 Suppl 1:S66-74. [Rec#: 999]. [pmid: 11466593].
Excluded. Subject unrelated.
Muller M J, Wiechmann M, Helms C, Wulff C, Kolenda K D. [Nutrient intake with low-fat diets in rehabilitation of patients with coronary heart disease]. Z Kardiol. 2000;89(5):454-63. [Rec#: 285]. [pmid: 10900676].
Excluded. Diet, not reviewed further.
Munnelly P, Feehan S. An obesity clinic model. Proceedings of the Nutrition Society. 2002;61(1):9-10. [Rec#: 522]. [pmid: 12002800].
Excluded. Subject unrelated.
Murphy J E, Donald J F, Molla A L, Crowder D. A comparison of mazindol (Teronac) with diethylpropion in the treatment of exogenous obesity. J Int Med Res. 1975;3(3):202-6. [Rec#: 610]. [pmid: 162676].
Excluded. Mazindol, not reviewed.
Murphy J K, Burce B K, Williamson D A. A comparison of measured and self-reported weights in a 4-year follow-up of spouse involvement in obesity treatment. Behav Ther. 1985;16:524-30. [Rec#: 1037].
Excluded. Subject unrelated.
Murphy JK, Williamson DA, Buxton AE, Moody SC, Absher N, Warner M. The long-term effects of spouse involvement upon weight loss and maintenance. Behavior Therapy 1982;(13):681–93.[Rec#: 118]
Excluded. Subject unrelated.
Muscelli E, Camastra S, Catalano C, Galvan A Q, Ciociaro D, Baldi S, et al. Metabolic and cardiovascular assessment in moderate obesity: effect of weight loss. J Clin Endocrinol Metab. 1997;82(9):2937-43. [Rec#: 283]. [pmid: 9284723].
Excluded. Diet, not reviewed further.
Narayan K M, Hoskin M, Kozak D, Kriska A M, Hanson R L, Pettitt D J, et al. Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. 1998;15(1):66-72. [Rec#: 119]. [pmid: 9472866].
Excluded. Diet, not reviewed further.
Naslund E, Backman L, Granstrom L, et al. Seven year results of vertical banded gastroplasty for morbid obesity. Eur J Surg. 1997;163(4):281-6. [pmid: 9161826].
Excluded. Not retrieved by cut-off date.
National Institutes of Health. Clinical Guidelines on the Identification, Evaluation, and Treatment of Overweight and Obesity in Adults—The Evidence Report. Obes Res. 1998;6 Suppl 2:51S-209S. [Rec#: 694]. [pmid: 9813653].
Excluded. Study design, review or meta-analysis.
National Institutes of Health. Gastrointestinal surgery for severe obesity. Proceedings of a National Institutes of Health Consensus Development Conference. March 25–27, 1991, Bethesda, MD. Am J Clin Nutr. 1992;55(2 Suppl):487S-619S. [pmid: 1733116].
Excluded. Study design: descriptive.
National Institutes of Health. Very low-calorie diets. National Task Force on the Prevention and Treatment of Obesity. JAMA. 1993;270(8):967-74. [Rec#: 1]. [pmid: 8345648].
Excluded. Diet, not reviewed further.
NHS. CRD. A systematic review of the interventions for the prevention and treatment of obesity, and the maintenance of weight loss. In: University of York: CRD Report; 1997. [Rec#: 681]
Excluded. Rejected at abstract.
NHS Centre for Reviews and Dissemination. The prevention and treatment of childhood obesity. Effective Health Care. 2002;7(6):1-11. [Rec#: 682].
Excluded. Diet, not reviewed further.
Nieman D C, Haig J L, Fairchild K S, De Guia E D, Dizon G P, Register U D. Reducing-diet and exercise-training effects on serum lipids and lipoproteins in mildly obese women. Am J Clin Nutr. 1990;52(4):640-5. [Rec#: 1000]. [pmid: 2403058].
Excluded. Subject unrelated.
Noble R E. A controlled study of a weight reduction regimen. Curr Ther Res Clin Exp. 1971;13(11):685-91. [Rec#: 611]. [pmid: 5000715].
Excluded. Duration of treatment < 6 months.
Nolan G R. Use of an anorexic drug in a total weight reduction program in private practice. Curr Ther Res Clin Exp. 1975;18(2):332-7. [Rec#: 612]. [pmid: 809245].
Excluded. Duration of treatment < 6 months.
Nordmann A. [What is the evidence with regard to the effectiveness of orlistat?]. Schweiz Med Wochenschr. 2000;130(17):629-34. [Rec#: 917]. [pmid: 10829301].
Excluded. Study design, review or meta-analysis.
Nova A, Russo A, Sala E. Long-term management of obesity in pediatric office practice: experimental evaluation of two different types of intervention. Ambul Child Health. 2001;7:239-47. [Rec#: 1001].
Excluded. Diet, not reviewed further.
Nunn R G, Newton K S, Faucher P. 2.5 years follow-up of weight and Body Mass Index values in the Weight Control for Life! program: a descriptive analysis. Addict Behav. 1992;17(6):579-85. [Rec#: 286]. [pmid: 1488938].
Excluded. Diet, not reviewed further.
Nuutinen O, Knip M. Predictors of weight reduction in obese children. Eur J Clin Nutr. 1992;46(11):785-94. [Rec#: 428]. [pmid: 1425532].
Excluded. Subject unrelated.
O'Meara S, Riemsma R, Shirran L, Mather L, ter Riet G. The clinical effectiveness and cost-effectiveness of sibutramine in the management of obesity: a technology assessment. Health Technol Assess. 2002;6(6):1-97. [Rec#: 806]. [pmid: 12583816].
Excluded. Study design, review or meta-analysis.
O'Meara S, Riemsma R, Shirran L, Mather L, ter Riet G. A rapid and systematic review of the lcinical effectiveness and cost-effectiveness of orlistat in the management of obesity. Health Technol Assess. 2001;5(18):1-81. [Rec#: 883]. [pmid: 11701100].
Excluded. Study design, review or meta-analysis.
Obarzanek E, Hunsberger S A, Van Horn L, Hartmuller V V, Barton B A, Stevens V J, et al. Safety of a fat-reduced diet: the Dietary Intervention Study in Children (DISC). Pediatrics. 1997;100(1):51-9. [Rec#: 1002]. [pmid: 9200359].
Excluded. Diet, not reviewed further.
Okonkwo P O, Akpala C O, Okafor H U, Mbah A U, Nwaiwu O. Compliance to correct dose of chloroquine in uncomplicated malariacorrelates with improvement in the condition of rural Nigerianchildren. Transactions of the Royal Society of Tropical Medicine and Hygiene. 2001;95(3):320-324. [Rec#: 523]. [pmid: 11491007].
Excluded. Topic unrelated.
Oslo Diet and Exercise Study. The Oslo Diet and Exercise Study (ODES): design and objectives.Control Clin Trials 1993;14(3):229–43. [Rec#: 5]
Excluded. Topic unrelated.
Ost L G, Gotestam K G. Behavioral and pharmacological treatments for obesity: an experimental comparison. Addict Behav. 1976;1(4):331-8. [Rec#: 121]. [pmid: 998364].
Excluded. Subject unrelated.
Pace D G, Blotner S, Guerciolini R. Short-term orlistat treatment does not affect mineral balance and bone turnover in obese men. J Nutr. 2001;131(6):1694-9. [Rec#: 918]. [pmid: 11385055].
Excluded. Topic unrelated.
Paisey R B, Harvey P, Rice S, Belka I, Bower L, Dunn M, et al. An intensive weight loss programme in established type 2 diabetes and controls: effects on weight and atherosclerosis risk factors at 1 year. Diabet Med. 1998;15(1):73-9. [Rec#: 288]. [pmid: 9472867].
Excluded. Diet, not reviewed further.
Palgi A, Read J L, Greenberg I, Hoefer M A, Bistrian B R, Blackburn G L. Multidisciplinary treatment of obesity with a protein-sparing modified fast: results in 668 outpatients. Am J Public Health. 1985;75(10):1190-4. [Rec#: 289]. [pmid: 4037162]. [pmcid: 1646394].
Excluded. Diet, not reviewed further.
Pan X R, Li G W, Hu Y H, Wang J X, Yang W Y, An Z X, et al. Effects of diet and exercise in preventing NIDDM in people with impaired glucose tolerance. The Da Qing IGT and Diabetes Study. Diabetes Care. 1997;20(4):537-44. [Rec#: 850]. [pmid: 9096977].
Excluded. Diet, not reviewed further.
Panz V R, van der Merwe M T, Wilson R, Ali A, Crowther N J, Goldburgh S, et al. Efficacy of long term weight loss trial: Clinical and biochemical indices. Int J Obes Relat Metab Disord. 2002;26 (Supplement 1):S48. [Rec#: 485]. [pmid: 12461680].
Excluded. Subject unrelated.
Park TL. Two minimal intervention programs for weight loss in heart transplant candidates. Dissertation Abstracts International: Section B: The Sciences and Engineering: 1999.[Rec #: 347]
Excluded. Subject unrelated.
Parker B, Noakes M, Luscombe N, Clifton P. Effect of a high-protein, high-monounsaturated fat weight loss diet on glycemic control and lipid levels in type 2 diabetes. Diabetes Care. 2002;25(3):425-30. [Rec#: 775]. [pmid: 11874925].
Excluded. Subject unrelated.
Pascale R W, Wing R R, Butler B A, Mullen M, Bononi P. Effects of a behavioral weight loss program stressing calorie restriction versus calorie plus fat restriction in obese individuals with NIDDM or a family history of diabetes. Diabetes Care. 1995;18(9):1241-8. [Rec#: 1038]. [pmid: 8612437].
Excluded. Subject unrelated.
Pasquali R, Cesari M P, Melchionda N, Boschi S, Munarini A, Barbara L. Erythrocyte Na-K-ATPase membrane activity in obese patients fed over a long-term period with a very-low-calorie diet. Metabolism. 1988;37(1):86-90. [Rec#: 291]. [pmid: 2826967].
Excluded. Topic unrelated.
Pavlou K N, Steffee W P, Lerman R H, Burrows B A. Effects of dieting and exercise on lean body mass, oxygen uptake, and strength. Med Sci Sports Exerc. 1985;17(4):466-71. [Rec#: 1003]. [pmid: 4033403].
Excluded. Subject unrelated.
Pavlou K N, Whatley J E, Jannace P W, DiBartolomeo J J, Burrows B A, Duthie E A, et al. Physical activity as a supplement to a weight-loss dietary regimen. Am J Clin Nutr. 1989;49 (5 Suppl):1110-4. [Rec#: 1004]. [pmid: 2801582].
Excluded. Subject unrelated.
Pavlou K N, Krey S, Steffee W P. Exercise as an adjunct to weight loss and maintenance in moderately obese subjects. Am J Clin Nutr. 1989;49 (5 Suppl):1115-23. [Rec#: 122]. [pmid: 2801582].
Excluded. Duration of treatment < 6 months.
Pearce J W, LeBow M D, Orchard J. Role of spouse involvement in the behavioral treatment of overweight women. J Consult Clin Psychol. 1981;49(2):236-44. [Rec#: 123]. [pmid: 7217490].
Excluded. Duration of treatment < 6 months.
Pedro-Botet P J, Roca M A. Efficacy of weight loss in the treatment of obstructive sleep apnea syndrome. Experience in 135 patients. Medicina Clinica. 1992;98(2):45-48. [Rec#: 348]. [pmid: 1545619].
Excluded. Diet, not reviewed further.
Pekkarinen T, Mustajoki P. Comparison of behavior therapy with and without very-low-energy diet in the treatment of morbid obesity. A 5-year outcome. Arch Intern Med. 1997;157(14):1581-5. [Rec#: 293]. [pmid: 9236560].
Excluded. Diet, not reviewed further.
Pekkarinen T, Takala I, Mustajoki P. Weight loss with very-low-calorie diet and cardiovascular risk factors in moderately obese women: one-year follow-up study including ambulatory blood pressure monitoring. Int J Obes Relat Metab Disord. 1998;22(7):661-6. [Rec#: 292]. [pmid: 9705026].
Excluded. Diet, not reviewed further.
Pena L, Pena M, Gonzalez J, Claro A. A comparative study of two diets in the treatment of primary exogenous obesity in children. Acta paediatrica Academiae Scientiarum Hungaricae. 1979;20(1):99-103. [Rec#: 258]. [pmid: 532631].
Excluded. Subject unrelated.
Perri M G, Shapiro R M, Ludwig W W, Twentyman C T, McAdoo W G. Maintenance strategies for the treatment of obesity: an evaluation of relapse prevention training and posttreatment contact by mail and telephone. J Consult Clin Psychol. 1984;52(3):404-13. [Rec#: 683]. [pmid: 6747059].
Excluded. Subject unrelated.
Peterson C M, Jovanovic-Peterson L. Randomized crossover study of 40% vs. 55% carbohydrate weight loss strategies in women with previous gestational diabetes mellitus and non- diabetic women of 130–200% ideal body weight. J Am Coll Nutr. 1995;14(4):369-75. [Rec#: 776]. [pmid: 8568114].
Excluded. Subject unrelated.
Pi-Sunyer F X, Maggio C A, McCarron D A, Reusser M E, Stern J S, Haynes R B, et al. Multicenter randomized trial of a comprehensive prepared meal program in type 2 diabetes. Diabetes Care. 1999;22(2):191-7. [Rec#: 962]. [pmid: 10333932].
Excluded. Subject unrelated.
Pidlich J, Pfeffel F, Zwiauer K, Schneider B, Schmidinger H. The effect of weight reduction on the surface electrocardiogram: a prospective trial in obese children and adolescents. Int J Obes Relat Metab Disord. 1997;21(11):1018-23. [Rec#: 429]. [pmid: 9368825].
Excluded. Diet, not reviewed further.
Pijl H, Koppeschaar H P, Cohen A F, Iestra J A, Schoemaker H C, Frolich M, et al. Evidence for brain serotonin-mediated control of carbohydrate consumption in normal weight and obese humans. Int J Obes Relat Metab Disord. 1993;17(9):513-20. [Rec#: 920]. [pmid: 8220653].
Excluded. Topic unrelated.
Pijl H, Koppeschaar H P, Willekens F L, Op de Kamp I, Veldhuis H D, Meinders A E. Effect of serotonin re-uptake inhibition by fluoxetine on body weight and spontaneous food choice in obesity. Int J Obes. 1991;15(3):237-42. [Rec#: 613]. [pmid: 1646182].
Excluded. Duration of treatment < 6 months.
Pirozzo S, Summerbell C, Cameron C, Glasziou P. Should we recommend low-fat diets for obesity?. Obes Rev. 2003;4(2):83-90. [Rec#: 876]. [pmid: 12760443].
Excluded. Diet, not reviewed further.
Pittler M H. Positive findings for a herbal preparation for weight loss. Focus Alternat Complement Ther. 2001;6(3):194-5. [Rec#: 503].
Excluded. Subject unrelated.
Pittler M H, Ernst E. Guar gum for body weight reduction: meta-analysis of randomized trials. American Journal of Medicine. 2001;110(9):724-730. [Rec#: 524]. [pmid: 11403757].
Excluded. Subject unrelated.
Polley B A, Jakicic J M, Venditti E M, Barr S, Wing R R. The effects of health beliefs on weight loss in individuals at high risk for NIDDM. Diabetes Care. 1997;20(10):1533-8. [Rec#: 124]. [pmid: 9314630].
Excluded. Diet, not reviewed further.
Pomerleau J, Verdy M, Garrel D R, Nadeau M H. Effect of protein intake on glycaemic control and renal function in type 2 (non-insulin-dependent) diabetes mellitus. Diabetologia. 1993;36(9):829-34. [Rec#: 777]. [pmid: 8405754].
Excluded. Subject unrelated.
Poston W S C, Haddock C K, Dill P L, Thayer B, Foreyt J P. Lifestyle treatments in randomized clinical trials of pharmacotherapiesfor obesity. Obesity Research. 2001;9(9):552-563. [Rec#: 525]. [pmid: 11557836].
Excluded. Study design, review or meta-analysis.
Potter van Loon B J, Radder J K, Frolich M, Krans H M, Zwinderman A H, Meinders A E. Fluoxetine increases insulin action in obese type II (non-insulin dependent) diabetic patients. Int J Obes Relat Metab Disord. 1992;16 Suppl 4:S55-61. [Rec#: 922]. [pmid: 1338387].
Excluded. Duration of treatment < 6 months.
Potter van Loon B J, Radder J K, Frolich M, Krans H M, Zwinderman A H, Meinders A E. Fluoxetine increases insulin action in obese nondiabetic and in obese non-insulin-dependent diabetic individuals. Int J Obes Relat Metab Disord. 1992;16(2):79-85. [Rec#: 921]. [pmid: 1316330].
Excluded. Duration of treatment < 6 months.
Poyurovsky M, Pashinian A, Gil-Ad I, Maayan R, Schneidman M, Fuchs C, et al. Olanzapine-induced weight gain in patients with first-episode schizophrenia: a double-blind, placebo-controlled study of fluoxetine addition. Am J Psychiatry. 2002;159(6):1058-60. [Rec#: 923]. [pmid: 12042201].
Excluded. Duration of treatment < 6 months.
Prewitt T E, Schmeisser D, Bowen P E, Aye P, Dolecek T A, Langenberg P, et al. Changes in body weight, body composition, and energy intake in women fed high- and low-fat diets. Am J Clin Nutr. 1991;54(2):304-10. [Rec#: 294]. [pmid: 1858694].
Excluded. Diet, not reviewed further.
Price J H, Desmond S M, Ruppert E S, Stelzer C M. Pediatricians' perceptions and practices regarding childhood obesity. American journal of preventive medicine. 1989;5(2):95-103. [Rec#: 386]. [pmid: 2730797].
Excluded. Topic unrelated.
Pritchard J E, Nowson C A, Wark J D. Bone loss accompanying diet-induced or exercise-induced weight loss: a randomised controlled study. Int J Obes Relat Metab Disord. 1996;20(6):513-20. [Rec#: 125]. [pmid: 8782726].
Excluded. Diet, not reviewed further.
Pritchard J E, Nowson C A, Wark J D. A worksite program for overweight middle-aged men achieves lesser weight loss with exercise than with dietary change. J Am Diet Assoc. 1997;97(1):37-42. [Rec#: 126]. [pmid: 8990415].
Excluded. Diet, not reviewed further.
Pritchard JE, Saul ALF, Nowson CA, Wark JD. Body composition following diet-induced and/or exercise-indusced weight loss: A randomised controlled study. Int J Obes Relat Metab Disord 1995;(19):212.[Rec#: 127]
Excluded. Subject unrelated.
Pritchard JE Nowson CA Wark JD. Bone loss accompanying weight loss: a randomised controlled weight loss study using diet and exercise. Proceedings of the Nutrition Society of Australia 1995;(19):57.[Rec#: 128]
Excluded. Subject unrelated.
Puska P, Iacono J M, Nissinen A, Korhonen H J, Vartianinen E, Pietinen P, et al. Controlled, randomised trial of the effect of dietary fat on blood pressure. Lancet. 1983;1(83145):1-5. [Rec#: 852]. [pmid: 6129364].
Excluded. Duration of treatment < 6 months.
Quaade F. [Jejunoileostomy in the treatment of obesity - on the way out. A randomized clinical trial compared with a review of the literature]: <Original> Jejunoileostomi som adipositasbehandling - pa vej ud. En randomiseret klinisk undersogelse sammenholdt med en litteraturopgorelse. Ugeskrift for laeger. 1981;143(10):599-603. [Rec#: 256]. [pmid: 7025403].
Excluded. Population inappropriate.
Quaade F, Hyldstrup L, Andersen T. The Copenhagen PRODI project: preliminary results. Int J Obes. 1981;5(3):263-6. [Rec#: 924]. [pmid: 7024155].
Excluded. Topic unrelated.
Rabast U, Kasper H, Schonborn J. Comparative studies in obese subjects fed carbohydrate-restricted and high carbohydrate 1,000-calorie formula diets. Nutr Metab. 1978;22(5):269-77. [Rec#: 853]. [pmid: 662209].
Excluded. Diet, not reviewed further.
Rabast U, Schonborn J, Kasper H. Dietetic treatment of obesity with low and high-carbohydrate diets: comparative studies and clinical results. Int J Obes. 1979;3(3):201-11. [Rec#: 854]. [pmid: 395115].
Excluded. Diet, not reviewed further.
Raben A, Jensen N D, Marckmann P, Sandstrom B, Astrup A. Spontaneous weight loss during 11 weeks' ad libitum intake of a low fat/high fiber diet in young, normal weight subjects. Int J Obes Relat Metab Disord. 1995;19(12):916-23. [Rec#: 1005]. [pmid: 8963361].
Excluded. Diet, not reviewed further.
Racette S B, Schoeller D A, Kushner R F, Neil K M, Herling-Iaffaldano K. Effects of aerobic exercise and dietary carbohydrate on energy expenditure and body composition during weight reduction in obese women. Am J Clin Nutr. 1995;61(3):486-94. [Rec#: 778]. [pmid: 7872211].
Excluded. Subject unrelated.
Rae A, Bond D, Evans S, North F, Roberman B, Walters B. A randomised controlled trial of dietary energy restriction in the management of obese women with gestational diabetes. Aust N Z J Obstet Gynaecol. 2000;40(4):416-22. [Rec#: 295]. [pmid: 11194427].
Excluded. Topic unrelated.
Raeburn J M, Atkinson J M. A low-cost community approach to weight control: initial results from an evaluated trial. Prev Med. 1986;15(4):391-402. [Rec#: 296]. [pmid: 3763562].
Excluded. Diet, not reviewed further.
Ramhamadany E M, Fowler J, Baird I M. Effect of the gastric balloon versus sham procedure on weight loss in obese subjects. Gut. 1989;30(8):1054-7. [Rec#: 430]. [pmid: 2767500]. [pmcid: 1434178].
Excluded. Subject unrelated.
Ramirez E M, Rosen J C. A comparison of weight control and weight control plus body image therapy for obese men and women. J Consult Clin Psychol. 2001;69(3):440-6. [Rec#: 504]Excluded. Subject unrelated. [pmid: 11495173].
Ramsay L E, Ramsay M H, Hettiarachchi J, Davies D L, Winchester J. Weight reduction in a blood pressure clinic. Br Med J. 1978;2(6132):244-5. [Rec#: 297]. [pmid: 678886]. [pmcid: 1606357].
Excluded. Diet, not reviewed further.
Ramsey-Stewart G. Vertical banded gastroplasty for morbid obesity: weight loss at short and long-term follow up. Aust N Z J Surg. 1995;65(1):4-7. [pmid: 7818421].
Excluded. Not retrieved by cut-off date.
Rauh J L, Lipp R. Chlorphentermine as an anorexigenic agent in adolescent obesity. Report of its efficacy in a double-blind study of 30 teen-agers. Clin Pediatr (Phila). 1968;7(3):138-40. [Rec#: 431]. [pmcid: 358331]. [pmid: 12490205].
Excluded. Subject unrelated.
Renjilian DA. Individual vresus group therapy for obesity: matching clients with treatments. Dissertation Abstracts International. V 51. Is. 5-B. Pg. 2633: 1990.[Rec #: 349]
Excluded. Subject unrelated.
Requejo F, Uttenthal L O, Bloom S R. Effects of alpha-glucosidase inhibition and viscous fibre on diabetic control and postprandial gut hormone responses. Diabet Med. 1990;7(6):515-20. [Rec#: 614]. [pmid: 2163805].
Excluded. Subject unrelated.
Resch. Adjuvant weight control by means of aquaresis. Zeitschrift fur Phytotherapie 1994;15:(5)297. [Rec#: 350]
Excluded. Subject unrelated.
Reseland J E, Anderssen S A, Solvoll K, Hjermann I, Urdal P, Holme I, et al. Effect of long-term changes in diet and exercise on plasma leptin concentrations. Am J Clin Nutr. 2001;73(2):240-5. [Rec#: 129]. [pmid: 11157319].
Excluded. Diet, not reviewed further.
Resnick M, Joubert L. A double-blind evaluation of an anorexiant, a placebo and diet alone in obese subjects. Can Med Assoc J. 1967;97(17):1011-5. [Rec#: 432]. [pmid: 6052899]. [pmcid: 1923471].
Excluded. Subject unrelated.
Ricca V, Mannucci E, Di Bernardo M, Rizzello S M, Cabras P L, Rotella C M. Sertraline enhances the effects of cognitive-behavioral treatment on weight reduction of obese patients. J Endocrinol Invest. 1996;19(11):727-33. [Rec#: 298]. [pmid: 9061505].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Richman R M, Steinbeck K S, Caterson I D. Severe obesity: the use of very low energy diets or standard kilojoule restriction diets. Med J Aust. 1992;156(11):768-70. [Rec#: 299]. [pmid: 1630346].
Excluded. Diet, not reviewed further.
Richman R M, Webster P, Salgo A R, Mira M, Steinbeck K S, Caterson I D. A shared care approach in obesity management: the general practitioner and a hospital based service. Int J Obes Relat Metab Disord. 1996;20(5):413-9. [Rec#: 300]. [pmid: 8696419].
Excluded. Diet, not reviewed further.
Riesco J, Troncoso G, Costamaillere L, Rodriguez J. [Treatment of obesity with a non-amphetamine anorexigenic agent (author's transl)]. Rev Med Chil. 1977;105(6):375-9. [Rec#: 301]. [pmid: 331428].
Excluded. Mazindol, not reviewed.
Rissanen A. Pharmacological intervention: the antiobesity approach. Eur J Clin Invest. 1998;28 Suppl 2:27-30. [Rec#: 730]. [pmid: 9777325].
Excluded. Rejected at abstract.
Rissanen A, Lean M, Rossner S, Segal K R, Sjostrom L. Predictive value of early weight loss in obesity management with orlistat: an evidence-based assessment of prescribing guidelines. Int J Obes Relat Metab Disord. 2003;27(1):103-9. [Rec#: 807]. [pmid: 12532161].
Excluded. Study design, review or meta-analysis.
Robinson T N, Killen J D, Kraemer H C, Wilson D M, Matheson D M, Haskell W L, et al. Dance and reducing television viewing to prevent weight gain in African-American girls: the Stanford GEMS pilot study. Ethn Dis. 2003;13 (1 Suppl 1):S65-77. [Rec#: 877]. [pmid: 14964185].
Excluded. Duration of treatment < 6 months.
Rocchini A P, Katch V, Anderson J, Hinderliter J, Becque D, Martin M, et al. Blood pressure in obese adolescents: effect of weight loss. Pediatrics. 1988;82(1):16-23. [Rec#: 615]. [pmid: 3288957].
Excluded. Duration of treatment < 6 months.
Rock C L, Thomson C, Caan B J, Flatt S W, Newman V, Ritenbaugh C, et al. Reduction in fat intake is not associated with weight loss in most women after breast cancer diagnosis: evidence from a randomized controlled trial. Cancer. 2001;91(1):25-34. [Rec#: 303]. [pmid: 11148556].
Excluded. Diet, not reviewed further.
Roderick P, Ruddock A, Hunt P, Miller G. A randomized trial to evaluate the effectiveness of dietary advice by practice nurses in lowering diet-related coronary heart disease risk. British Journal of General Practice. 1997;47(414):7-12. [Rec#: 351]. [pmid: 9115804]. [pmcid: 1312885].
Excluded. Diet, not reviewed further.
Rodger N W, Chiasson J L, Josse R G, Hunt J A, Palmason C, Ross S A, et al. Clinical experience with acarbose: results of a Canadian multicentre study. Clin Invest Med. 1995;18(4):318-24. [Rec#: 131]. [pmid: 8549019].
Excluded. Subject unrelated.
Roginsky M S, Sandler J. Phenformin in human obesity. Ann N Y Acad Sci. 1968;148(3):892-6. [Rec#: 302]. [pmid: 4872313].
Excluded. Subject unrelated.
Rolls B J, Shide D J, Thorwart M L, Ulbrecht J S. Sibutramine reduces food intake in non-dieting women with obesity. Obes Res. 1998;6(1):1-11. [Rec#: 926]. [pmid: 9526964].
Excluded. Duration of treatment < 6 months.
Rosalinda T. Change in weight during a one-year trial with fluoxetine. J Clin Psychiatry. 1992;53:59058. [Rec#: 857].
Excluded. Not found.
Rosen J C, Gross J, Loew D, Sims E A. Mood and appetite during minimal-carbohydrate and carbohydrate- supplemented hypocaloric diets. Am J Clin Nutr. 1985;42(3):371-9. [Rec#: 779]. [pmid: 4036844].
Excluded. Subject unrelated.
Rosenthal B, Allen G J, Winter C. Husband involvement in the behavioral treatment of overweight women: initial effects and long-term follow-up. Int J Obes. 1980;4(2):165-73. [Rec#: 132]. [pmid: 7399805].
Excluded. Subject unrelated.
Rossner S. [Sibutramine—antidepressive agent tested against obesity]. Lakartidningen. 2001;98(15):1802-3. [Rec#: 928]. [pmid: 11374008].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Rothacker D Q, Staniszewski B A, Ellis P K. Liquid meal replacement vs traditional food: a potential model for women who cannot maintain eating habit change. Journal of the American Dietetic Association. 2001;101(3):345-7. [Rec#: 387]. [pmid: 11269616].
Excluded. Subject unrelated.
Ryan D H, Kaiser P, Bray G A. Sibutramine: a novel new agent for obesity treatment. Obesity research. 1995;3 (Suppl 4):553S-559S. [Rec#: 388]. [pmid: 8653567].
Excluded. Duration of treatment < 6 months.
Ryan Donna H. The role of sibutramine in the clinical management of obesity. Int J Obes Relat Metab Disord. 2002;26 (Supplement 1):S218. [Rec#: 487]. [pmid: 12461680].
Excluded. Study design, descriptive.
Ryttig K R, Rossner S. Weight maintenance after a very low calorie diet (VLCD) weight reduction period and the effects of VLCD supplementation. A prospective, randomized, comparative, controlled long-term trial. J Intern Med. 1995;238(4):299-306. [Rec#: 684]. [pmid: 7595165].
Excluded. Subject unrelated.
Ryttig K R, Tellnes G, Haegh L, Boe E, Fagerthun H. A dietary fibre supplement and weight maintenance after weight reduction: a randomized, double-blind, placebo-controlled long-term trial. Int J Obes. 1989;13(2):165-71. [Rec#: 249]. [pmid: 2545640].
Excluded. Diet, not reviewed further.
Saelens Brian E, Sallis James F, Wilfley Denise E, Patrick Kevin, CellaJohn A, Buchta Richard. Behavioral weight control for overweight adolescents initiated in primary care. Obesity research. 2002;10(1):22-32. [Rec#: 389]. [pmid: 11786598].
Excluded. Duration of treatment < 6 months.
Sahota P, Rudolf M C, Dixey R, Hill A J, Barth J H, Cade J. Evaluation of implementation and effect of primary school based intervention to reduce risk factors for obesity. BMJ. 2001;323(7320):1027-9. [Rec#: 1006]. [pmcid: 59380]. [pmid: 11691758].
Excluded. Topic unrelated.
Sahota P, Rudolf M C, Dixey R, Hill A J, Barth J H, Cade J. Randomised controlled trial of primary school based intervention to reduce risk factors for obesity. BMJ (Clinical research ed). 2001;323(7320):1029-32. [Rec#: 218]. [pmcid: 117638]. [pmid: 15339831].
Excluded. Diet, not reviewed further.
Saito K, Tatsumi M. [Effect of dietary therapy in a school health program for obese children]. Nippon Koshu Eisei Zasshi. 1994;41(8):693-705. [Rec#: 433]. [pmid: 7949281].
Excluded. Diet, not reviewed further.
Salenius J P, Harju E, Jokela H, Riekkinen H, Silvasti M. Long term effects of guar gum on lipid metabolism after carotid endarterectomy. BMJ. 1995;310(6972):95-6. [Rec#: 616]. [pmid: 7833735].
Excluded. Subject unrelated.
Saltzman E, Das S K, Lichtenstein A H, Dallal G E, Corrales A, Schaefer E J, et al. An oat-containing hypocaloric diet reduces systolic blood pressure and improves lipid profile beyond effects of weight loss in men and women. J Nutr. 2001;131(5):1465-70. [Rec#: 780]. [pmid: 11340101].
Excluded. Diet, not reviewed further.
Saltzman E, Moriguti J C, Das S K, Corrales A, Fuss P, Greenberg A S, et al. Effects of a cereal rich in soluble fiber on body composition and dietary compliance during consumption of a hypocaloric diet. J Am Coll Nutr. 2001;20(1):50-7. [Rec#: 310]. [pmid: 11293468].
Excluded. Subject unrelated.
Samaha F F, Iqbal N, Seshadri P, Chicano K L, Daily D A, McGrory J, et al. A low-carbohydrate as compared with a low-fat diet in severe obesity. N Engl J Med. 2003;348(21):2074-81. [Rec#: 878]. [pmid: 12761364].
Excluded. Subject unrelated.
Samsa G P, Kolotkin R L, Williams G R, Nguyen M H, Mendel C M. Effect of moderate weight loss on health-related quality of life: an analysis of combined data from 4 randomized trials of sibutramine vs placebo. Am J Manag Care. 2001;7(9):875-83. [Rec#: 929]. [pmid: 11570021].
Excluded. Study design, review or meta-analysis.
Saris W H, Astrup A, Prentice A M, Zunft H J, Formiguera X, Verboeket-van de Venne W P, et al. Randomized controlled trial of changes in dietary carbohydrate/fat ratio and simple vs complex carbohydrates on body weight and blood lipids: the CARMEN study. The Carbohydrate Ratio Management in European National diets. Int J Obes Relat Metab Disord. 2000;24(10):1310-8. [Rec#: 1007]. [pmid: 11093293].
Excluded. Diet, not reviewed further.
Saris WH M. Very-low-calorie diets and sustained weight loss. Obesity Research. 2001;9 (Suppl. 4):295S-301S. [Rec#: 526]. [pmid: 11918343].
Excluded. Diet, not reviewed further.
Sash S F. Letter: Treating obesity in schoolboys. South African medical journal. Suid-Afrikaanse tydskrif vir geneeskunde. 1976;50(21):797. [Rec#: 390]. [pmid: 935959].
Excluded. Subject unrelated.
Sato Y, Miyao M, Watanabe T, Shimaoka K, Sakai E, Kumazawa A, et al. Follow-up studies of group behavior therapy for obese Japanese patients. Scandinavian Journal of Medicine and Science in Sports. 1992;2(4):212-217. [Rec#: 352].
Excluded. Diet, not reviewed further.
Satre H, Holmvang L, Wagner G S, Lindahl B, Wallentin L. Reduction of myocardial damage by prolonged treatment with subcutaneous low molecular weight heparin in unstable coronary artery disease. FRISC study group. Fragmin during Instability in Coronary Artery Disease. Eur Heart J. 1999;20(9):645-52. [Rec#: 134]. [pmid: 10208784].
Excluded. Topic unrelated.
Satterfield S, Cutler J A, Langford H G, Applegate W B, Borhani N O, Brittain E, et al. Trials of hypertension prevention. Phase I design. Ann Epidemiol. 1991;1(5):455-71. [Rec#: 135]. [pmid: 1669525].
Excluded. Topic unrelated.
Saunders J T, Green J A. Effect on weight maintenance of weight control programs varying in degree of structure. Int J Obes. 1989;13:404. [Rec#: 353].
Excluded. Subject unrelated.
Sayler M E, Goldstein D, Roback P, Atkinson R. Evaluating success of weight loss programs, with an application to fluoxetine weight reduction clinical trial data. Int J Obes Relat Metab Disord. 1994;18(11):742-51. [Rec#: 391]. [pmid: 7866474].
Excluded. Study design, review or meta-analysis.
Schaefer E J, Lichtenstein A H, Lamon-Fava S, McNamara J R, Schaefer M M, Rasmussen H, et al. Body weight and low-density lipoprotein cholesterol changes after consumption of a low-fat ad libitum diet. JAMA. 1995;274(18):1450-5. [Rec#: 305]. [pmid: 7474191].
Excluded. Diet, not reviewed further.
Scheen A J. Results of obesity treatment. Annales d'Endocrinologie. 2002;63(2 Cahier 1):163-170. [Rec#: 488]. [pmid: 12737145].
Excluded. Study design, review or meta-analysis.
Scheen A J. [Study of the month. Long-term (1–2 years) clinical trials with orlistat, a new drug for the treatment of obesity]. Rev Med Liege. 1999;54(8):707-9. [Rec#: 930]. [pmid: 10548902].
Excluded. Study design, review or meta-analysis.
Scheen A J, Ernest P. New antiobesity agents in type 2 diabetes: overview of clinical trials with sibutramine and orlistat. Diabetes Metab. 2002;28(6 Pt 1):437-45. [Rec#: 810]. [pmid: 12703063].
Excluded. Study design, review or meta-analysis.
Schlundt D G, Hill J O, Pope-Cordle J, Arnold D, Virts K L, Katahn M. Randomized evaluation of a low fat ad libitum carbohydrate diet for weight reduction. Int J Obes Relat Metab Disord. 1993;17(11):623-9. [Rec#: 685]. [pmid: 8281220].
Excluded. Subject unrelated.
Schmid T L, Jeffery R W, Onstad L, Corrigan S A. Demographic, knowledge, physiological, and behavioral variables as predictors of compliance with dietary treatment goals in hypertension. Addict Behav. 1991;16 (3–4):151-60. [Rec#: 136]. [pmid: 1801564].
Excluded. Subject unrelated.
Schwartz L N. A non-amphetamine anorectic agent: preclinical background and a double-blind clinical trial. J Int Med Res. 1975;3:328-332. [Rec#: 617].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Schwartz R S, Jaeger L F, Veith R C, Lakshminarayan S. The effect of diet or exercise on plasma norepinephrine kinetics in moderately obese young men. Int J Obes. 1990;14(1):1-11. [Rec#: 1008]. [pmid: 2179146].
Excluded. Diet, not reviewed further.
Schwimmer J B, Burwinkle T M, Varni J W. Health-related quality of life of severely obese children and adolescents. JAMA. 2003;289(14):1813-9. [Rec#: 646]. [pmid: 12684360].
Excluded. Topic unrelated.
Scott C B, Carpenter R, Taylor A, Gordon N F. Effect of macronutrient composition of an energy-restrictive diet on maximal physical performance. Med Sci Sports Exerc. 1992;24(7):814-8. [Rec#: 781]. [pmid: 1501567].
Excluded. Subject unrelated.
Scott H W Jr, Dean R H, Shull H J, Gluck F W. Metabolic complications of jejunoileal bypass operations for morbid obesity. Annu Rev Med. 1976;27:397-405. [Rec#: 858]. [pmid: 938008].
Excluded. Topic unrelated.
Seagle H M, Bessesen D H, Hill J O. Effects of sibutramine on resting metabolic rate and weight loss in overweight women. Obesity research. 1998;6(2):115-21. [Rec#: 392]. [pmid: 9545017].
Excluded. Duration of treatment < 6 months.
Sedgwick J P. Maziniol in the treatment of obesity. Practitioner. 1975;214(1281):418-20. [Rec#: 618]. [pmid: 1096123].
Excluded. Mazindol, not reviewed.
Self M, Brewer A, Kumanyika S, Doroshenko L, Carnaghi M, Brancato J. Pilot study to enhance start-up of a multicenter nutrition intervention trial. J Am Diet Assoc. 1998;98(3):322-5. [Rec#: 137]. [pmid: 9508016].
Excluded. Subject unrelated.
Seltzer C C, Mayer J. An effective weight control program in a public school system. Am J Public Health Nations Health. 1970;60(4):679-89. [Rec#: 859]. [pmid: 5461722]. [pmcid: 1348859].
Excluded. Subject unrelated.
Senediak C, Spence S H. Rapid versus gradual scheduling of therapeutic contact in a family based behavioral weight control programme for children. Behav Psychother. 1985;13:265-287. [Rec#: 619].
Excluded. Subject unrelated.
Serdula M K, Khan L K, Dietz W H. Weight loss counseling revisited. JAMA. 2003;289(14):1747-50. [Rec#: 660]. [pmid: 12684339].
Excluded. Topic unrelated.
Serrano-Rios M, Melchionda N, Moreno-Carretero E. Role of sibutramine in the treatment of obese Type 2 diabetic patients receiving sulphonylurea therapy. Diabet Med. 2002;19(2):119-24. [Rec#: 931]. [pmid: 11874427].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Shah M, Baxter J E, McGovern P G, Garg A. Nutrient and food intake in obese women on a low-fat or low-calorie diet. Am J Health Promot. 1996;10(3):179-82. [Rec#: 138]. [pmid: 10163296].
Excluded. Subject unrelated.
Shah M, Jeffery R W, Laing B, Savre S G, Van Natta M, Strickland D. Hypertension Prevention Trial (HPT): food pattern changes resulting from intervention on sodium, potassium, and energy intake. Hypertension Prevention Trial Research Group. J Am Diet Assoc. 1990;90(1):69-76. [Rec#: 139]. [pmid: 2404050].
Excluded. Diet, not reviewed further.
Shah M, McGovern P, French S, Baxter J. Comparison of a low-fat, ad libitum complex-carbohydrate diet with a low-energy diet in moderately obese women. Am J Clin Nutr. 1994;59(5):980-4. [Rec#: 782]. [pmid: 8172104].
Excluded. Diet, not reviewed further.
Shah Meena, Kavanaugh Arthur, Coyle Yvonne, Adams-Huet Beverley, Lipsky Peter E. Effect of a culturally sensitive cholesterol lowering diet program on lipid and lipoproteins, body weight, nutrient intakes, and quality of life in patients with systemic lupus erythematosus. Journal of Rheumatology. 2002;29(10):2122-2128. [Rec#: 490]. [pmid: 12375321].
Excluded. Duration of treatment < 6 months.
Sharma A M. Sibutramine in overweight/obese hypertensive patients. Int J Obes Relat Metab Disord. 2001;25 Suppl 4:S20-3. [Rec#: 824 ]. [pmid: 11916102].
Excluded. Study design, review or meta-analysis.
Sharma A M, Golay A. Effect of orlistat-induced weight loss on blood pressure and heart rate in obese patients with hypertension. J Hypertens. 2002;20(9):1873-8. [Rec#: 811]. [pmid: 12195131].
Excluded. Study design, review or meta-analysis.
Shekelle P G, Hardy M L, Morton S C, Maglione M, Mojica W A, Suttorp M J, et al. Efficacy and safety of ephedra and ephedrine for weight loss and athletic performance: a meta-analysis. JAMA. 2003;289(12):1537-45. [Rec#: 860]. [pmid: 12672771].
Excluded. Subject unrelated.
Shepard T Y, Jensen D R, Blotner S, Zhi J, Guerciolini R, Pace D, et al. Orlistat fails to alter postprandial plasma lipid excursions or plasma lipases in normal-weight male volunteers. Int J Obes Relat Metab Disord. 2000;24(2):187-94. [Rec#: 932] Excluded. Topic unrelated. [pmid: 10702769].
Sheppard L, Kristal A R, Kushi L H. Weight loss in women participating in a randomized trial of low-fat diets. Am J Clin Nutr. 1991;54(5):821-8. [Rec#: 306]. [pmid: 1951152].
Excluded. Diet, not reviewed further.
Shorey R L, Sewell B, O'Brien M. Efficacy of diet and exercise in the reduction of serum cholesterol and triglyceride in free-living adult males. Am J Clin Nutr. 1976;29(5):512-21. [Rec#: 620]. [pmid: 1266792].
Excluded. Subject unrelated.
Shutter L, Garell D C. Obesity in children and adolescents: a double-blind study with cross-over. J Sch Health. 1966;36(6):273-5. [Rec#: 434]. [pmid: 5326984].
Excluded. Subject unrelated.
Siao M S, Wing RR/ Klem M L, McGuire M T, Hill J O, Seagle H. Persons successful at long-term weight loss and maintenance continue to consume a low-energy, low-fat diet. Journal of the American Dietetic Association. 1998;98(4):408-413. [Rec#: 354]. [pmid: 9550162].
Excluded. Topic unrelated.
Siggaard R, Raben A, Astrup A. Weight loss during 12 week's ad libitum carbohydrate-rich diet in overweight and normal-weight subjects at a Danish work site. Obes Res. 1996;4(4):347-56. [Rec#: 1009]. [pmid: 8822759].
Excluded. Diet, not reviewed further.
Sikand G, Kondo A, Foreyt J P, Jones P H Jr, Gotto AM. Two-year follow-up of patients treated with a very-low-calorie diet and exercise training. J Am Diet Assoc. 1988;88(4):487-8. [Rec#: 140]. [pmid: 3351170].
Excluded. Subject unrelated.
Silverman M, Okun R. The use of an appetite suppressant (diethylpropion hydrochloride) during pregnancy. Curr Ther Res Clin Exp. 1971;13(10):648-53. [Rec#: 307]. [pmid: 5004802].
Excluded. Duration of treatment < 6 months.
Silverstone J T, Solomon T. The long-term management of obesity in general practice. Brit J Clin Pract. 1965;19:395-8. [Rec#: 686 ]. [pmid: 14308191].
Excluded. Duration of treatment < 6 months.
Simon M S, Heilbrun L K, Boomer A, Kresge C, Depper J, Kim P N, et al. A randomized trial of a low-fat dietary intervention in women at high risk for breast cancer. Nutr Cancer. 1997;27(2):136-42. [Rec#: 1010]. [pmid: 9121940].
Excluded. Diet, not reviewed further.
Simonen P, Gylling H, Howard A N, Miettinen T A. Introducing a new component of the metabolic syndrome: low cholesterol absorption. Am J Clin Nutr. 2000;72(1):82-8. [Rec#: 141]. [pmid: 10871565].
Excluded. Duration of treatment < 6 months.
Simonetti D'Arca A, Tarsitani G, Cairella M, Siani V, De Filippis S, Mancinelli S, et al. Prevention of obesity in elementary and nursery school children. Public Health. 1986;100(3):166-73. [Rec#: 1011]. [pmid: 3737864].
Excluded. Subject unrelated.
Simpson R W, Mann J I, Eaton J, Moore R A, Carter R, Hockaday T D. Improved glucose control in maturity-onset diabetes treated with high- carbohydrate-modified fat diet. Br Med J. 1979;1(6180):1753-6. [Rec#: 783]. [pmid: 466210]. [pmcid: 1599386].
Excluded. Subject unrelated.
Singh R B, Rastogi S S, Verma R, Laxmi B, Singh R, Ghosh S, et al. Randomised controlled trial of cardioprotective diet in patients with recent acute myocardial infarction: results of one year follow up. BMJ. 1992;304(6833):1015-9. [Rec#: 732]. [pmid: 1586782]. [pmcid: 1881705].
Excluded. Subject unrelated.
Sirtori C, Hurwitz A, Azarnoff D L. Hyperinsulinemia secondary to chronic administration of mazindol and d- amphetamine. Am J Med Sci. 1971;261(6):341-9. [Rec#: 687]. [pmid: 4948438].
Excluded. Mazindol, not reviewed.
Skender M L, Goodrick G K, Del Junco D J, Reeves R S, Darnell L, Gotto A M, et al. Comparison of 2-year weight loss trends in behavioral treatments of obesity: diet, exercise, and combination interventions. J Am Diet Assoc. 1996;96(4):342-6. [Rec#: 143]. [pmid: 8598434].
Excluded. Diet, not reviewed further.
Skov A R, Haulrik N, Toubro S, Molgaard C, Astrup A. Effect of protein intake on bone mineralization during weight loss: a 6- month trial. Obes Res. 2002;10(6):432-8. [Rec#: 784]. [pmid: 12055318].
Excluded. Subject unrelated.
Skov A R, Toubro S, Bulow J, Krabbe K, Parving H, Astrup A. Changes in renal function during weight loss induced by high vs low-protein low-fat diets in overweight subjects. Int J Obes Relat Metab Disord. 1999;23(11):1170-7. [Rec#: 393]. [pmid: 10578207].
Excluded. Duration of treatment < 6 months.
Skov A R, Toubro S, Ronn B, Holm L, Astrup A. Randomized trial on protein vs carbohydrate in ad libitum fat reduced diet for the treatment of obesity. Int J Obes Relat Metab Disord. 1999;23(5):528-36. [Rec#: 232]. [pmid: 10375057].
Excluded. Duration of treatment < 6 months.
Smith IG. Long-term weight loss with sibutramine, a once-daily serotonin and norephinephrine reuptake inhibitor. Obesity Research 1997;(5):80.[Rec#: 145]
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Smith I G. On behalf of the members of the sibutramine clinical study 1047 Goulder MA Randomized placebo-controlled trial of long-term treatment with sibutramine in mild to moderate obesity. J Fam Pract. 2001;50:505-12. [Rec#: 621]. [pmid: 11407998].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Smith I G, Goulder M A. Randomized placebo-controlled trial of long-term treatment with sibutramine in mild to moderate obesity. J Fam Pract. 2001;50(6):505-12. [Rec#: 144]. [pmid: 11407998].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Smith R G, Innes J A, Munro J F. Double-blind evaluation of mazindol in refractory obesity. Br Med J. 1975;3(5978):284. [Rec#: 933]. [pmid: 1097046]. [pmcid: 1674216].
Excluded. Mazindol, not reviewed.
Smith R B, Katzin D B. Clinical assessment of a novel weight control programme. Journal of Drug Assessment. 1998;1(Part 3):415-422. [Rec#: 355].
Excluded. Subject unrelated.
Smith-Warner S A, Elmer P J, Tharp T M, Fosdick L, Randall B, Gross M, et al. Increasing vegetable and fruit intake: randomized intervention and monitoring in an at-risk population. Cancer Epidemiol Biomarkers Prev. 2000;9(3):307-17. [Rec#: 308]. [pmid: 10750670].
Excluded. Subject unrelated.
Snider Laura J, Malone Margaret. Orlistat use in type 2 diabetes. Annals of Pharmacotherapy. 2002;36(78):1210-1218. [Rec#: 492]. [pmid: 12086556].
Excluded. Study design, review or meta-analysis.
Snyder P, Anliker J, Cunningham-Sabo L, Dixon L B, Altaha J, Chamberlain A, et al. The Pathways study: a model for lowering the fat in school means. Am J Clin Nutr. 1999;69 (suppl):810S-5S. [Rec#: 542]. [pmid: 10584048].
Excluded. Topic unrelated.
Sohar E, Sneh E. Follow-up of obese patients: 14 years after a successful reducing diet. Am J Clin Nutr. 1973;26(8):845-8. [Rec#: 622]. [pmid: 4720671].
Excluded. Diet, not reviewed further.
Sonka J, Limanova Z, Zbirkova A, Kratochvil O. Effects of diet, exercise and anorexigenic drugs on serum thyroid hormones. Endokrinologie. 1980;76(3):351-6. [Rec#: 688]. [pmid: 7472292].
Excluded. Mazindol, not reviewed.
Sothern, Udall JN Jr, Suskind R M, Vargas A, Blecker U. Weight loss and growth velocity in obese children after very low calorie diet, exercise, and behavior modification. Acta Paediatr. 2000;89(9):1036-43. [Rec#: 435]. [pmid: 11071081].
Excluded. Diet, not reviewed further.
Sothern M S, von Almen T K, Schumacher H, Zelman M, Farris R P, Carlisle L, et al. An effective multidisciplinary approach to weight reduction in youth. Ann N Y Acad Sci. 1993;699:292-4. [Rec#: 436]. [pmid: 8267331].
Excluded. Subject unrelated.
Sothern M S, von Almen T K, Schumacher H D, Suskind R M, Blecker U. A multidisciplinary approach to the treatment of childhood obesity. Del Med J. 1999;71(6):255-61. [Rec#: 437]. [pmid: 10432772].
Excluded. Diet, not reviewed further.
Spaulding S W, Chopra I J, Sherwin R S, Lyall S S. Effect of caloric restriction and dietary composition of serum T3 and reverse T3 in man. J Clin Endocrinol Metab. 1976;42(1):197-200. [Rec#: 785]. [pmid: 1249190].
Excluded. Topic unrelated.
Spieth L E, Harnish J D, Lenders C M, Raezer L B, Pereira M M, Hangen S J, et al. A low-glycemic index diet in the treatment of pediatric obesity. Archives of pediatrics & adolescent medicine. 2000;154(9):947-51. [Rec#: 228]. [pmid: 10980801].
Excluded. Diet, not reviewed further.
Spranger J. [Phentermine resinate in obesity. Clinical trial of Mirapront in adipose children]. Munch Med Wochenschr. 1965;107(38):1833-4. [Rec#: 438]. [pmid: 5323498].
Excluded. Duration of treatment < 6 months.
Spring B, Wurtman J, Wurtman R, el-Khoury A, Goldberg H, McDermott J, et al. Efficacies of dexfenfluramine and fluoxetine in preventing weight gain after smoking cessation. Am J Clin Nutr. 1995;62(6):1181-7. [Rec#: 934]. [pmid: 7491877].
Excluded. Duration of treatment < 6 months.
Sproule B C. Double-blind trial of anorectic agents. Medical journal of Australia. 1969;1(8):394-5. [Rec#: 266]. [pmid: 4889477].
Excluded. Duration of treatment < 6 months.
Sramek J J, Leibowitz M T, Weinstein S P, Rowe E D, Mendel C M, Levy B, et al. Efficacy and safety of sibutramine for weight loss in obese patients with hypertension well controlled by beta-adrenergic blocking agents: a placebo-controlled, double-blind, randomised trial. J Hum Hypertens. 2002;16(1):13-9. [Rec#: 935]. [pmid: 11840225].
Excluded. Duration of treatment < 6 months.
Stafford R S, Radley D C. National trends in antiobesity medication use. Arch Intern Med. 2003;163:1046-1050. [Rec#: 943]. [pmid: 12742801].
Excluded. Topic unrelated.
Stahl K A, Imperiale T F. An overview of the efficacy and safety of fenfluramine and mazindol in the treatment of obesity. Arch Fam Med. 1993;2(10):1033-8. [Rec#: 936]. [pmid: 8111484].
Excluded. Mazindol, not reviewed.
Stalonas P M, Perri M G, Kerzner A B. Do behavioral treatments of obesity last? A five-year follow-up investigation. Addict Behav. 1984;9(2):175-83. [Rec#: 1039]. [pmid: 6741677].
Excluded. Subject unrelated.
Stamler R, Stamler J, Gosch F C, Civinelli J, Fishman J, McKeever P, et al. Primary prevention of hypertension by nutritional-hygienic means. Final report of a randomized, controlled trial. JAMA. 1989;262(13):1801-7. [Rec#: 861]. [pmid: 2778913].
Excluded. Diet, not reviewed further.
Stamler R, Stamler J, Grimm R, Gosch F C, Elmer P, Dyer A, et al. Nutritional therapy for high blood pressure. Final report of a four- year randomized controlled trial—the Hypertension Control Program. JAMA. 1987;257(11):1484-91. [Rec#: 862]. [pmid: 3546747].
Excluded. Diet, not reviewed further.
Stefanick M L, Mackey S, Sheehan M, Ellsworth N, Haskell W L, Wood P D. Effects of diet and exercise in men and postmenopausal women with low levels of HDL cholesterol and high levels of LDL cholesterol. N Engl J Med. 1998;339(1):12-20. [Rec#: 1012]. [pmid: 9647874].
Excluded. Diet, not reviewed further.
Stellfeldt A, Muller M J, Bode V, Westenhofer J. Behaviour factors and stabilisation of reduced body weight over one year. Aktuelle Ernahrungsmedizin. 2000;25(6):281-288. [Rec#: 356].
Excluded. Diet, not reviewed further.
Stenius-Aarniala B, Poussa T, Kvarnstrom J, Gronlund E L, Ylikahri M, Mustajoki P. Immediate and long term effects of weight reduction in obese people with asthma: randomised controlled study. BMJ. 2000;320(7238):827-32. [Rec#: 146]. [pmcid: 27319]. [pmid: 10731173].
Excluded. Duration of treatment < 6 months.
Stephenson J. Low-carb, low-fat diet gurus face off. JAMA. 2003;289(14):1767-73. [Rec#: 657]. [pmid: 12684342].
Excluded. Topic unrelated.
Stephenson J. Obesity-hypertension link in children?. JAMA. 2003;289(14):1774. [Rec#: 656]. [pmid: 14679252].
Excluded. Topic unrelated.
Steven VJ. Weight loss and blood pressure changes over three years: results of the Trials of Hypertension Prevention (TOHP) Phase II. Cardiovascular Health: Coming Together for the 21st Century. A National Conference. 1998 6F(Abstract)[Rec#: 864]
Excluded. Not found.
Stevens J, Cornell C E, Story M, French S A, Levin S, Becenti A, et al. Development of a questionnaire to assess knowledge, attitudes, and behaviors in American Indian children. Am J Clin Nutr. 1999;69 (suppl):773S-81S. [Rec#: 543]. [pmid: 10584048].
Excluded. Topic unrelated.
Stevens V J, Corrigan S A, Obarzanek E, Bernauer E, Cook N R, Hebert P, et al. Weight loss intervention in phase 1 of the Trials of Hypertension Prevention. The TOHP Collaborative Research Group. Arch Intern Med. 1993;153(7):849-58. [Rec#: 147]. [pmid: 8466377].
Excluded. Diet, not reviewed further.
Stevens V J, Obarzanek E, Cook N R, Lee I M, Appel L J, Smith West D, et al. Long-term weight loss and changes in blood pressure: results of the Trials of Hypertension Prevention, phase II. Ann Intern Med. 2001;134(1):1-11. [Rec#: 148]. [pmid: 11187414].
Excluded. Diet, not reviewed further.
Stewart D A, Bailey J D, Patell H. Tenuate dospan as an appetitie suppressant in the treatment of obese children. Appl Ther. 1970;12(5):34-6. [Rec#: 623]. [pmid: 4912482].
Excluded. Duration of treatment < 6 months.
Stinson J C, Murphy C M, Andrews J F, Tomkin G H. An assessment of the thermogenic effects of fluoxetine in obese subjects. Int J Obes Relat Metab Disord. 1992;16(5):391-5. [Rec#: 937]. [pmid: 1319975].
Excluded. Duration of treatment < 6 months.
Stolley M R, Fitzgibbon M L. Effects of an obesity prevention program on the eating behavior of African American mothers and daughters. Health Educ Behav. 1997;24(2):152-64. [Rec#: 1013]. [pmid: 9079575].
Excluded. Diet, not reviewed further.
Story M, Sherwood N E, Himes J H, Davis M, Jacobs D R Jr, Cartwright Y, et al. An after-school obesity prevention program for African-American girls: the Minnesota GEMS pilot study. Ethn Dis. 2003;13 (1 Suppl 1):S54-64. [Rec#: 879]. [pmid: 14964185].
Excluded. Duration of treatment < 6 months.
Straznicky N E, O'Callaghan C J, Barrington V E, Louis W J. Hypotensive effect of low-fat, high-carbohydrate diet can be independent of changes in plasma insulin concentrations. Hypertension. 1999;34(4 Pt 1):580-5. [Rec#: 786]. [pmid: 10610357].
Excluded. Subject unrelated.
Stunkard A J, Penick S B. Behavior modification in the treatment of obesity. The problem of maintaining weight loss. Arch Gen Psychiatry. 1979;36(7):801-6. [Rec#: 1040]. [pmid: 454096].
Excluded. Subject unrelated.
Summerbell CD, Ashton V, Campbell KJ, Edmunds L, Kelly S, and Waters E. Interventions for treating obesity in children. In: The Cochrane Library, in press.[Rec # 884].
Excluded. Diet only.
Summerbell C D, Watts C, Higgins J P, Garrow J S. Randomised controlled trial of novel, simple, and well supervised weight reducing diets in outpatients. BMJ (Clinical research ed. 1998;317(7171):1487-9. [Rec#: 234]. [pmcid: 117638]. [pmid: 15339831].
Excluded. Duration of treatment < 6 months.
Sung RY T, Yu C W, Chang S K Y, Mo S W, Woo K S, Lam C W K. Effects of dietary intervention and strength training on blood lipid level in obese children. Archives of disease in childhood. 2002;86(6):407-10. [Rec#: 215]. [pmid: 12023168].
Excluded. Subject unrelated.
Svendsen O L, Hassager C, Christiansen C. Effect of an energy-restrictive diet, with or without exercise, on lean tissue mass, resting metabolic rate, cardiovascular risk factors, and bone in overweight postmenopausal women. Am J Med. 1993;95(2):131-40. [Rec#: 865]. [pmid: 8356979].
Excluded. Duration of treatment < 6 months.
Sweeney M E, Hill J O, Heller P A, Baney R, DiGirolamo M. Severe vs moderate energy restriction with and without exercise in the treatment of obesity: efficiency of weight loss. Am J Clin Nutr. 1993;57(2):127-34. [Rec#: 1014]. [pmid: 8424379].
Excluded. Subject unrelated.
Sweet W A. Vertical Banded Gastroplasty: Stable Trends in Weight Control at 10 or More Years. Obes Surg. 1994;4(2):149-152. [pmid: 10742772].
Excluded. Not retrieved by cut-off date.
Swinburn B A, Metcalf P A, Ley S J. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24(4):619-24. [Rec#: 149]. [pmid: 11315819].
Excluded. Diet, not reviewed further.
Swinburn B A, Woollard G A, Chang E C, Wilson M R. Effects of reduced-fat diets consumed ad libitum on intake of nutrients, particularly antioxidant vitamins. J Am Diet Assoc. 1999;99(11):1400-5. [Rec#: 150]. [pmid: 10570677].
Excluded. Diet, not reviewed further.
Szkudlarek J, Elsborg L. Treatment of severe obesity with a highly selective serotonin re-uptake inhibitor as a supplement to a low calorie diet. Int J Obes Relat Metab Disord. 1993;17(12):681-3. [Rec#: 394 ]. [pmid: 8118471].
Excluded. Subject unrelated.
Tan K C, Tso A W, Tam S C, Pang R W, Lam K S. Acute effect of orlistat on post-prandial lipaemia and free fatty acids in overweight patients with Type 2 diabetes mellitus. Diabet Med. 2002;19(11):944-8. [Rec#: 812]. [pmid: 12421432].
Excluded. Topic unrelated.
Tate D F, Jackvony E H, Wing R R. Effects of internet behavioral counseling on weight loss in adults at risk for type 2 diabetes: a randomized trial. JAMA. 2003;289(14):1833-6. [Rec#: 643]. [pmid: 12684363].
Excluded. Subject unrelated.
Taylor C B, Fortmann S P, Flora J, Kayman S, Barrett D C, Jatulis D, et al. Effect of long-term community health education on body mass index. The Stanford Five-City Project. Am J Epidemiol. 1991;134(3):235-49. [Rec#: 690]. [pmid: 1877583].
Excluded. Subject unrelated.
Tershakovec A M, Jawad A F, Stallings V A, Zemel B S, McKenzie J M, Stolley P D, et al. Growth of hypercholesterolemic children completing physician-initiated low-fat dietary intervention. J Pediatr. 1998;133(1):28-34. [Rec#: 1015]. [pmid: 9672506].
Excluded. Diet, not reviewed further.
Teufel N I, Perry C L, Story M, Flint-Wagner H G, Levin S, Clay T E, et al. Pathways family intervention for third-grade American Indian children. Am J Clin Nutr. 1999;69 (suppl):803S-9S. [Rec#: 544]. [pmid: 10584048].
Excluded. Topic unrelated.
Teupe B B, Bergis K. Prospective randomized two-years clinical study comparing additional metformin treatment with reducing diet in type 2 diabetes. Diabete Metab. 1991;17(1 Pt 2):213-7. [Rec#: 151]. [pmid: 1936479].
Excluded. Subject unrelated.
Thaler L, Wassertheil-Smoller S, Blaufox M D, Oberman A, Langford H G. Effect of withdrawal of antihypertensive drug on depressive mood. Am J Hypertens. 1993;6(12):1055-62. [Rec#: 152]. [pmid: 8136096].
Excluded. Topic unrelated.
Thomas-Dobersen D A, Butler-Simon N, Fleshner M. Evaluation of a weight management intervention program in adolescents with insulin-dependent diabetes mellitus. J Am Diet Assoc. 1993;93(5):535-40. [Rec#: 439]. [pmid: 8315162].
Excluded. Subject unrelated.
Thomas RM. Exercise and diet in weight control: effects on mood, metabolic rate, weight loss and maintenance. Dissertation Abstracts International. V 44. Is 1-B. Pg 331.: 1983.[Rec #: 357]
Excluded. Subject unrelated.
Thorpe P C, Isaac P F, Rodgers J A. A controlled trial of mazindol (Sanjorex, Teronac) in the management of the obese rheumatic patients. Curr Ther Res Clin Exp. 1975;17(2):149-55. [Rec#: 624]. [pmid: 803428].
Excluded. Mazindol, not reviewed.
TOHP collaborative research group. Phase I results of the Trials of Hypertension Prevention TOHP Circulation 1990 82(III) 53 [Rec#: 153]
Excluded. Rejected at abstract.
Tomlinson J W, Crabtree N, Clark P M, Holder G, Toogood A A, Shackleton C H, et al. Low-dose growth hormone inhibits 11 beta-hydroxysteroid dehydrogenase type 1 but has no effect upon fat mass in patients with simple obesity. J Clin Endocrinol Metab. 2003;88(5):2113-8. [Rec#: 816]. [pmid: 12727963].
Excluded. Subject unrelated.
Tong P C, Lee Z S, Sea M M, Chow C C, Ko G T, Chan W B, et al. The effect of orlistat-induced weight loss, without concomitant hypocaloric diet, on cardiovascular risk factors and insulin sensitivity in young obese Chinese subjects with or without type 2 diabetes. Arch Intern Med. 2002;162(21):2428-35. [Rec#: 813]. [pmid: 12437401].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Toplak H, Wascher T C. Influence of weight reduction on platelet volume: different effects of a hypocaloric diet and a very low calorie diet. Eur J Clin Invest. 1994;24(11):778-80. [Rec#: 309]. [pmid: 7890017].
Excluded. Subject unrelated.
Torgerson J S, Carlsson B, Stenlof K, Carlsson L M, Bringman E, Sjostrom L A. A low serum leptin level at baseline and a large early decline in leptin predict a large 1-year weight reduction in energy-restricted obese humans. J Clin Endocrinol Metab. 1999;84(11):4197-203. [Rec#: 313]. [pmid: 10566672].
Excluded. Diet, not reviewed further.
Torgerson J S, Lissner L, Lindroos A K, Kruijer H, Sjostrom L. VLCD plus dietary and behavioural support versus support alone in the treatment of severe obesity. A randomised two-year clinical trial. Int J Obes Relat Metab Disord. 1997;21(11):987-94. [Rec#: 155]. [pmid: 9368821].
Excluded. Duration of treatment < 6 months.
Torjesen P A, Birkeland K I, Anderssen S A, Hjermann I, Holme I, Urdal P. Lifestyle changes may reverse development of the insulin resistance syndrome. The Oslo Diet and Exercise Study: a randomized trial. Diabetes Care. 1997;20(1):26-31. [Rec#: 156]. [pmid: 9028689].
Excluded. Diet, not reviewed further.
Toubro S, Astrup A. Randomised comparison of diets for maintaining obese subjects' weight after major weight loss: ad lib, low fat, high carbohydrate diet v fixed energy intake. BMJ. 1997;314(7073):29-34. [Rec#: 691]. [pmid: 9001476]. [pmcid: 2125573].
Excluded. Subject unrelated.
Toubro S, Astrup A V. [A randomized comparison of two weight-reducing diets. Calorie counting versus low-fat carbohydrate-rich ad libitum diet]. Ugeskr Laeger. 1998;160(6):816-20. [Rec#: 319]. [pmid: 9469978].
Excluded. Subject unrelated.
Toubro S, Astrup A V, Breum L, Quaade F. Safety and efficacy of long-term treatment with ephedrine, caffeine and an ephedrine/caffeine mixture. Int J Obes Relat Metab Disord. 1993;17 (Suppl 1):S69-72. [Rec#: 314]. [pmid: 8124414].
Excluded. Subject unrelated.
Toubro S, Hansen D L, Hilsted J C, Porsborg P A, Astrup A V. [The effect of sibutramine for the maintenance of weight loss. A randomized controlled clinical trial]: <Original> Effekt af sibutramin til vaegttabsvedligeholdelse. En randomiseret klinisk kontrolleret undersogelse. Ugeskrift for laeger. 2001;163(21):2935-40. [Rec#: 221]. [pmid: 11402974].
Excluded. Duplicate article.
Toubro S, Hansen D L, Hilsted J C, Porsborg P A, Astrup A V. [The effect of sibutramine for the maintenance of weight loss. A randomized controlled clinical trial]. Ugeskr Laeger. 2001;163(21):2935-40. [Rec#: 157]. [pmid: 11402974].
Excluded. Not found.
Tounian P, Frelut M L, Parlier G, Abounaufal C, Aymard N, Veinberg F, et al. Weight loss and changes in energy metabolism in massively obese adolescents. Int J Obes Relat Metab Disord. 1999;23(8):830-7. [Rec#: 440]. [pmid: 10490784].
Excluded. Diet, not reviewed further.
Tremblay A, Despres J P, Maheux J, Pouliot M C, Nadeau A, Moorjani S, et al. Normalization of the metabolic profile in obese women by exercise and a low fat diet. Med Sci Sports Exerc. 1991;23(12):1326-31. [Rec#: 315]. [pmid: 1798373].
Excluded. Diet, not reviewed further.
Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levelsResults of the Trials of Hypertension Prevention, Phase I. JAMA. 1992;267(9):1213-20. [Rec#: 818]. [pmid: 1586398].
Excluded. Duration of treatment < 6 months.
Trials of Hypertension Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high- normal blood pressure. The Trials of Hypertension Prevention, phase II. Arch Intern Med. 1997;157(6):657-67. 67[Rec#: 8]. [pmid: 9080920].
Excluded. Subject unrelated.
Trouillot T E, Pace D G, McKinley C, Cockey L, Zhi J, Haeussler J, et al. Orlistat maintains biliary lipid composition and hepatobiliary function in obese subjects undergoing moderate weight loss. Am J Gastroenterol. 2001;96(6):1888-94. [Rec#: 938]. [pmid: 11421247].
Excluded. Duration of treatment < 6 months.
Truant A P, Olon L P, Cobb S. Phentermine resin as an adjunct in medical weight reduction: a controlled, randomized, double-blind prospective study. Curr Ther Res Clin Exp. 1972;14(11):726-38. [Rec#: 625]. [pmid: 4629111].
Excluded. Duration of treatment < 6 months.
Tucker JA, Samo JA, Rand CS, Woodward ER. Behavioral interventions to promote adaptive eating behavior and lifestyle changes following surgery for obsity: results of a two-year evalutation. International Journal of Eating Disorders 1991 [Rec#: 158]
Excluded. Diet, not reviewed further.
Tuomilehto J, Karttunen P, Vinni S, Kostiainen E, Uusitupa M. A double-blind evaluation of guar gum in patients with dyslipidaemia. Hum Nutr Clin Nutr. 1983;37(2):109-16. [Rec#: 626]. [pmid: 6345478].
Excluded. Subject unrelated.
Tuomilehto J, Lindstrom J, Eriksson J G, Valle T T, Hamalainen H, Ilanne-Parikka P, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344(18):1343-50. [Rec#: 159]. [pmid: 11333990].
Excluded. Diet, not reviewed further.
Tuomilehto J, Voutilainen E, Huttunen J, Vinni S, Homan K. Effect of guar gum on body weight and serum lipids in hypercholesterolemic females. Acta Med Scand. 1980;208(12):45-8. [Rec#: 627]. [pmid: 7435246].
Excluded. Subject unrelated.
Turner P R, Tuomilehto J, Happonen P, La Ville A E, Shaikh M, Lewis B. Metabolic studies on the hypolipidaemic effect of guar gum. Atherosclerosis. 1990;81(2):145-50. [Rec#: 628]. [pmid: 2157450].
Excluded. Topic unrelated.
Turner R, Murchison L, Wright A D, Oakley N, Kohner E, Hayes R, et al. United Kingdom prospective diabetes study 24: A 6-year, randomized, controlled trial comparing sulfonylurea, insulin, and metformin therapy in patients with newly diagnosed type 2 diabetes that could not be controlled with diet therapy. Annals of Internal Medicine. 1998;128(3):165-75. [Rec#: 160]. [pmid: 9454524].
Excluded. Subject unrelated.
Turner R C, Cull C A, Frighi V, Holman R R. Glycemic control with diet, sulfonylurea, metformin, or insulin in patients with type 2 diabetes mellitus: progressive requirement for multiple therapies (UKPDS 49). UK Prospective Diabetes Study (UKPDS) Group. JAMA. 1999;281(21):2005-12. [Rec#: 161]. [pmid: 10359389].
Excluded. Topic unrelated.
Turner R C, Holman R R, Mathews D R, Oakes S F, Bassett P A, Stratton I M, et al. UK Prospective Diabetes Study (UKPDS). VIII. Study design, progress and performance. Diabetologia. 1991;34(12):877-90. [Rec#: 162]. [pmid: 1778353].
Excluded. Topic unrelated.
Turnin M C, Bourgeois O, Cathelineau G, Leguerrier A M, HalimiS, Sandre-Banon D, et al. Multicenter randomized evaluation of a nutritional education software in obese patients. Diabetes & Metabolism. 2001;27(2 Cahier 1):139-147. [Rec#: 493]. [pmid: 11735084].
Excluded. Subject unrelated.
U.K. Prospective Diabetes Study Group. U.K. prospective diabetes study 16. Overview of 6 years' therapy of type II diabetes: a progressive disease. Diabetes. 1995;44(11):1249-58. [Rec#: 7]. [pmid: 7589820].
Excluded. Subject unrelated.
U.K. Prospective Diabetes Study Group. United Kingdom Prospective Diabetes Study 24: a 6-year, randomized, controlled trial comparing sulfonylurea, insulin, and metformin therapy in patients with newly diagnosed type 2 diabetes that could not be controlled with diet therapy. Ann Intern Med. 1998;128(3):165-75. [Rec#: 9]. [pmid: 9454524].
Excluded. Subject unrelated.
U.K. Prospective Diabetes Study Group. United Kingdom Prospective Diabetes Study (UKPDS). 13: Relative efficacy of randomly allocated diet, sulphonylurea, insulin, or metformin in patients with newly diagnosed non-insulin dependent diabetes followed for three years. BMJ. 1995;310(6972):83-8. [Rec#: 6]. [pmid: 7833731].
Excluded. Diet, not reviewed further.
UK Prospective Diabetes Study (UKPDS) Group. Effect of intensive blood-glucose control with metformin on complications in overweight patients with type 2 diabetes (UKPDS 34). Lancet. 1998;352(9131):854-65. 65[Rec#: 10]. [pmid: 9742977].
Excluded. Subject unrelated.
Uusitupa M, Laitinen J, Siitonen O, Vanninen E, Pyorala K. The maintenance of improved metabolic control after intensified diet therapy in recent type 2 diabetes. Diabetes Res Clin Pract. 1993;19(3):227-38. [Rec#: 164]. [pmid: 8319521].
Excluded. Duration of treatment < 6 months.
Uusitupa M, Louheranta A, Lindstrom J, Valle T, Sundvall J, Eriksson J, et al. The Finnish Diabetes Prevention Study. British Journal of Nutrition. 2000;83 (suppl 1):S137-42. [Rec#: 165]. [pmid: 11177193].
Excluded. Diet, not reviewed further.
Uusitupa M, Siitonen O, Savolainen K, Silvasti M, Penttila I, Parviainen M. Metabolic and nutritional effects of long-term use of guar gum in the treatment of noninsulin-dependent diabetes of poor metabolic control. Am J Clin Nutr. 1989;49(2):345-51. [Rec#: 629]. [pmid: 2537003].
Excluded. Subject unrelated.
Uusitupa M, Sodervik H, Silvasti M, Karttunen P. Effects of a gel forming dietary fiber, guar gum, on the absorption of glibenclamide and metabolic control and serum lipids in patients with non-insulin-dependent (type 2) diabetes. Int J Clin Pharmacol Ther Toxicol. 1990;28(4):153-7. [Rec#: 630]. [pmid: 2110937].
Excluded. Subject unrelated.
Uusitupa M, Tuomilehto J, Karttunen P, Wolf E. Long term effects of guar gum on metabolic control, serum cholesterol and blood pressure levels in type 2 (non-insulin-dependent) diabetic patients with high blood pressure. Ann Clin Res. 1984;16 Suppl 43:126-31. [Rec#: 631]. [pmid: 6398982].
Excluded. Subject unrelated.
Uusitupa M I. Early lifestyle intervention in patients with non-insulin-dependent diabetes mellitus and impaired glucose tolerance. Ann Med. 1996;28(5):445-9. [Rec#: 166] Excluded. Diet, not reviewed further. [pmid: 8949977].
Valle-Jones J C, Brodie N H, O'Hara H, O'Hara J, McGhie R L. A comparative study of phentermine and diethylpropion in the treatment of obese patients in general practice. Pharmatherapeutica. 1983;3(5):300-4. [Rec#: 632]. [pmid: 6844367].
Exclude. Duration of treatment < 6 months.
Van Ameringen M, Mancini C, Pipe B, Campbell M, Oakman J. Topiramate treatment for SSRI-induced weight gain in anxiety disorders. J Clin Psychiatry. 2002;63(11):981-4. [Rec#: 754]. [pmid: 12444810].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
van Baak M, Van Mil E, Astrup A, Finer N, Van GaalL, Hilsted J, et al. Determinants of weight maintenance after weight loss in the storm trial. Int J Obes Relat Metab Disord. 2001;26 (Supplement 1):S183. [Rec#: 494]. [pmid: 11781762].
Excluded. Topic unrelated.
van Gemert W G, Greve J W, Soeters P B. Long-term results of vertical banded gastroplasty: Marlex versus Dacron banding. Obes Surg. 1997;7(2):128-35. [pmid: 9730540].
Excluded. Not retrieved by cut-off date.
van Seters A P, Bouwhuis-Hoogerwerf M L, Goslings B M, van Nieuwkoop L, vanSlooten H, Struijk-Wielinga T. [Long-term treatment of patients with obesity using mazindol and a reducing diet]: <Original> Langdurige behandeling van patienten met vetzucht door middel van mazindol en een vermageringseieet. Nederlands tijdschrift voor geneeskunde. 1982;126(22):990-4. [Rec#: 395 ]. [pmid: 7110390].
Excluded. Mazindol, not reviewed.
van Stratum P, Lussenburg R N, van Wezel L A, Vergroesen A J, Cremer H D. The effect of dietary carbohydrate:fat ratio on energy intake by adult women. Am J Clin Nutr. 1978;31(2):206-12. [Rec#: 787]. [pmid: 623041].
Excluded. Diet, not reviewed further.
Vandongen R, Jenner D A, Thompson C, Taggart A C, Spickett E E, BurkeV, et al. A controlled evaluation of a fitness and nutrition intervention program on cardiovascular health in 10- to 12-year-old children. Preventive medicine. 1995;24(1):9-22. [Rec#: 240]. [pmid: 7740021].
Excluded. Diet, not reviewed further.
Vanina Y, Podolskaya A, Sedky K, Shahab H, Siddiqui A, Munshi F, et al. Body weight changes associated with psychopharmacology. Psychiatr Serv. 2002;53(7):842-7. [Rec#: 755]. [pmid: 12096167].
Excluded. Study design, review or meta-analysis.
Vanninen E, Uusitupa M, Lansimies E, Siitonen O, Laitinen J. Effect of metabolic control on autonomic function in obese patients with newly diagnosed type 2 diabetes. Diabet Med. 1993;10(1):66-73. [Rec#: 167]. [pmid: 8435991].
Excluded. Diet, not reviewed further.
Vanninen E, Uusitupa M, Siitonen O, Laitinen J, Lansimies E. Habitual physical activity, aerobic capacity and metabolic control in patients with newly-diagnosed type 2 (non-insulin-dependent) diabetes mellitus: effect of 1-year diet and exercise intervention. Diabetologia. 1992;35(4):340-6. [Rec#: 168]. [pmid: 1516762].
Excluded. Diet, not reviewed further.
Vastag B. Experimental drugs take aim at obesity. JAMA. 2003;289(14):1763-4. [Rec#: 658]. [pmid: 12684341].
Excluded. Topic unrelated.
Vega G L, Ma P T, Cater N B, Filipchuk N, Meguro S, Garcia-Garcia A B, et al. Effects of adding fenofibrate (200 mg/day) to simvastatin (10 mg/day) in patients with combined hyperlipidemia and metabolic syndrome. Am J Cardiol. 2003;91(8):956-60. [Rec#: 826]. [pmid: 12686335].
Excluded. Topic unrelated.
Vernace B J. Controlled comparative investigation of mazindol, d-amphetamine and placebo. J Obes Bariat Med. 1974;3:124-129. [Rec#: 634].
Excluded. Mazindol, not reviewed.
Vessby B, Unsitupa M, Hermansen K, Riccardi G, Rivellese A A, Tapsell L C, et al. Substituting dietary saturated for monounsaturated fat impairs insulin sensitivity in healthy men and women: The KANWU Study. Diabetologia. 2001;44(3):312-9. [Rec#: 788]. [pmid: 11317662].
Excluded. Subject unrelated.
Vido L, Facchin P, Antonello I, Gobber D, Rigon F. Childhood obesity treatment: double blinded trial on dietary fibres (glucomannan) versus placebo. Padiatrie und Padologie. 1993;28(5):133-6. [Rec#: 241]. [pmid: 8247594].
Excluded. Rejected at abstract.
Visser M, Seidell J C, Koppeschaar H P, Smits P. The effect of fluoxetine on body weight, body composition and visceral fat accumulation. Int J Obes Relat Metab Disord. 1993;17(5):247-53. [Rec#: 635]. [pmid: 8389333].
Excluded. Duration of treatment < 6 months.
Vuorinen-Markkola H, Sinisalo M, Koivisto V A. Guar gum in insulin-dependent diabetes: effects on glycemic control and serum lipoproteins. Am J Clin Nutr. 1992;56(6):1056-60. [Rec#: 636]. [pmid: 1442657].
Excluded. Subject unrelated.
Wadden T A, Anderson D A, Foster G D. Two-year changes in lipids and lipoproteins associated with the maintenance of a 5% to 10% reduction in initial weight: some findings and some questions. Obes Res. 1999;7(2):170-8. [Rec#: 170]. [pmid: 10102254].
Excluded. Diet, not reviewed further.
Wadden T A, Berkowitz R I, Sarwer D B, Prus-Wisniewski R, Steinberg C. Benefits of lifestyle modification in the pharmacologic treatment of obesity: a randomized trial. Arch Intern Med. 2001;161(2):218-27. [Rec#: 172]. [pmid: 11176735].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Wadden T A, Berkowitz R I, Womble L G, Sarwer D B, Arnold M E, Steinberg C M. Effects of sibutramine plus orlistat in obese women following 1 year of treatment by sibutramine alone: a placebo-controlled trial. Obes Res. 2000;8(6):431-7. [Rec#: 173]. [pmid: 11011909].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Wadden T A, Foster G D, Letizia K A. One-year behavioral treatment of obesity: comparison of moderate and severe caloric restriction and the effects of weight maintenance therapy. J Consult Clin Psychol. 1994;62(1):165-71. [Rec#: 174]. [pmid: 8034818].
Excluded. Subject unrelated.
Wadden T A, Foster G D, Letizia K A, Mullen J L. Long-term effects of dieting on resting metabolic rate in obese outpatients. JAMA. 1990;264(6):707-11. [Rec#: 316]. [pmid: 2374273].
Excluded. Subject unrelated.
Wadden T A, Foster G D, Letizia K A, Stunkard A J. A multicenter evaluation of a proprietary weight reduction program for the treatment of marked obesity. Arch Intern Med. 1992;152(5):961-6. [Rec#: 320]. [pmid: 1580722].
Excluded. Diet, not reviewed further.
Wadden T A, Frey D L. A multicenter evaluation of a proprietary weight loss program for the treatment of marked obesity: a five-year follow-up. Int J Eat Disord. 1997;22(2):203-12. [Rec#: 317]. [pmid: 9261660].
Excluded. Diet, not reviewed further.
Wadden T A, Sternberg J A, Letizia K A, Stunkard A J, Foster G D. Treatment of obesity by very low calorie diet, behavior therapy, and their combination: a five-year perspective. Int J Obes. 1989;13 (Suppl 2):39-46. [Rec#: 175]. [pmid: 2793305].
Excluded. Diet, not reviewed further.
Wadden T A, Stunkard A J, Rich L, Rubin C J, Sweidel G, McKinney S. Obesity in black adolescent girls: a controlled clinical trial of treatment by diet, behavior modification, and parental support. Pediatrics. 1990;85(3):345-52. [Rec#: 247]. [pmid: 2304788].
Excluded. Subject unrelated.
Wadden T A, Stunkard A J. Controlled trial of very low calorie diet, behavior therapy, and their combination in the treatment of obesity. J Consult Clin Psychol. 1986;54(4):482-8. [Rec#: 176]. [pmid: 3528252].
Excluded. Diet, not reviewed further.
Wadden T A, Stunkard A J, Brownell K D, Day S C. Treatment of obesity by behavior therapy and very low calorie diet: a pilot investigation. J Consult Clin Psychol. 1984;52(4):692-4. [Rec#: 321]. [pmid: 6470296].
Excluded. Diet, not reviewed further.
Wadden T A, Stunkard A J, Day S C, Gould R A, Rubin C J. Less food, less hunger: reports of appetite and symptoms in a controlled study of a protein-sparing modified fast. Int J Obes. 1987;11(3):239-49. [Rec#: 177]. [pmid: 3667060].
Excluded. Subject unrelated.
Wadden T A, Stunkard A J, Liebschutz J. Three-year follow-up of the treatment of obesity by very low calorie diet, behavior therapy, and their combination. J Consult Clin Psychol. 1988;56(6):925-8. [Rec#: 178]. [pmid: 3204204].
Excluded. Duration of treatment < 6 months.
Wadden T A, Van Itallie T B, Blackburn G L. Responsible and irresponsible use of very-low-calorie diets in the treatment of obesity. JAMA. 1990;263(1):83-5. [Rec#: 323]. [pmid: 2403446].
Excluded. Diet, not reviewed further.
Wadden T A, Vogt R A, Andersen R E, Bartlett S J, Foster G D, Kuehnel R H, et al. Exercise in the treatment of obesity: effects of four interventions on body composition, resting energy expenditure, appetite, and mood. J Consult Clin Psychol. 1997;65(2):269-77. [Rec#: 322]. [pmid: 9086690].
Excluded. Subject unrelated.
Wadden T A, Vogt R A, Foster G D, Anderson D A. Exercise and the maintenance of weight loss: 1-year follow-up of a controlled clinical trial. J Consult Clin Psychol. 1998;66(2):429-33. [Rec#: 179]. [pmid: 9583346].
Excluded. Subject unrelated.
Wagner A, Simon C, Ducimetiere P, Montaye M, Bongard V, Yarnell J, et al. Leisure-time physical activity and regular walking or cycling to work are associated with adiposity and 5 y weight gain in middle-aged men: the PRIME Study. Int J Obes Relat Metab Disord. 2001;25(7):940-8. [Rec#: 324]. [pmid: 11443490].
Excluded. Subject unrelated.
Walberg J L, Ruiz V K, Tarlton S L, Hinkle D E, Thye F W. Exercise capacity and nitrogen loss during a high or low carbohydrate diet. Med Sci Sports Exerc. 1988;20(1):34-43. [Rec#: 789]. [pmid: 3343914].
Excluded. Subject unrelated.
Walker B R, Ballard I M, Gold J A. A multicentre study comparing mazindol and placebo in obese patients. Journal of international medical research. 1977;5(2):85-90. [Rec#: 262]. [pmid: 326596].
Excluded. Mazindol, not reviewed.
Wallace A G. AN 448 Sandoz (Mazindol) in the treatment of obesity. Med J Aust. 1976;1(11):343-5. [Rec#: 638]. [pmid: 775265].
Excluded. Mazindol, not reviewed.
Walsh K M, Leen E, Lean M E. The effect of sibutramine on resting energy expenditure and adrenaline-induced thermogenesis in obese females. Int J Obes Relat Metab Disord. 1999;23(10):1009-15. [Rec#: 939]. [pmid: 10557020].
Excluded. Duration of treatment < 6 months.
Walsh M F, Flynn T J. A 54-month evaluation of a popular very low calorie diet program. J Fam Pract. 1995;41:231-6. [Rec#: 1041]. [pmid: 7650500].
Excluded. Diet, not reviewed further.
Wang G, Dietz W H. Economic burden of obesity in youths aged 6 to 17 years: 1979-1999. Pediatrics. 2002;109(5):E81-1. [pmid: 11986487].
Excluded. Topic: not on weight loss or surgery complication.
Warembourg H, Delomez M. [Clinical trial of an anorectic, x E 106 E]. Lille Med. 1967;12(8) Suppl:852-4. [Rec#: 325]. [pmid: 5630038].
Wassertheil-Smoller S, Blaufox M D, Oberman A, Davis B R, Swencionis C, Knerr M O, et al. Effect of antihypertensives on sexual function and quality of life: the TAIM Study. Ann Intern Med. 1991;114(8):613-20. [Rec#: 180]. [pmid: 2003706].
Excluded. Subject unrelated.
Wassertheil-Smoller S, Blaufox M D, Oberman A S, Langford H G, Davis B R, Wylie-Rosett J. The Trial of Antihypertensive Interventions and Management (TAIM) study. Adequate weight loss, alone and combined with drug therapy in the treatment of mild hypertension. Arch Intern Med. 1992;152(1):131-6. [Rec#: 181]. [pmid: 1728908].
Excluded. Subject unrelated.
Wassertheil-Smoller S, Langford H G, Blaufox M D, Oberman A, Hawkins M, Levine B, et al. Effective dietary intervention in hypertensives: sodium restriction and weight reduction. J Am Diet Assoc. 1985;85(4):423-30. [Rec#: 182]. [pmid: 3884691].
Excluded. Subject unrelated.
Wauters J P, Busset R, Dayer A, Favre H. [Effects of various weight-reducing regimens on body composition in simple obesity. Isotopic analysis]. Schweiz Med Wochenschr. 1970;100(29):1272-8. [Rec#: 330]. [pmid: 5524992].
Excluded. Diet, not reviewed further.
Weber J L, Cunningham-Sabo L, Skipper B, Lytle L, Stevens J, GittelsohnJ, et al. Portion-size estimation training in second- and third-grade American Indian children. American journal of clinical nutrition. 1999;69 (4 Suppl):782S-787S. [Rec#: 396]. [pmid: 10584048].
Excluded. Topic unrelated.
Weinsier R L, Seeman A, Herrera M G, Assal J P, Soeldner J S, Gleason R E. High- and low-carbohydrate diets in diabetes mellitus. Study of effects on diabetic control, insulin secretion, and blood lipids. Ann Intern Med. 1974;80(3):332-41. [Rec#: 790]. [pmid: 4816173].
Excluded. Diet, not reviewed further.
Weinstock R S, Dai H, Wadden T A. Diet and exercise in the treatment of obesity: effects of 3 interventions on insulin resistance. Arch Intern Med. 1998;158(22):2477-83. [Rec#: 183]. [pmid: 9855386].
Excluded. Subject unrelated.
Weintraub M. Long-term weight control: the National Heart, Lung, and Blood Institute funded multimodal intervention study. Clin Pharmacol Ther. 1992;51(5):581-5. [Rec#: 337]. [pmid: 1445528].
Excluded. Topic unrelated.
Weintraub M, Hasday J D, Mushlin A I, Lockwood D H. A double-blind clinical trial in weight control. Use of fenfluramine and phentermine alone and in combination. Arch Intern Med. 1984;144(6):1143-8. [Rec#: 442]. [pmid: 6375610].
Excluded. Duration of treatment < 6 months.
Weintraub M, Rubio A, Golik A, Byrne L, Scheinbaum M L. Sibutramine in weight control: a dose-ranging, efficacy study. Clin Pharmacol Ther. 1991;50(3):330-7. [Rec#: 327]. [pmid: 1914367].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Weintraub M, Sundaresan P R, Schuster B, Averbuch M, Stein E C, Cox C, et al. Long-term weight control study. IV (weeks 156 to 190). The second double-blind phase. Clin Pharmacol Ther. 1992;51(5):608-14. [Rec#: 866]. [pmid: 1587075].
Excluded. Subject unrelated.
Weltman A, Matter S, Stamford B A. Caloric restriction and/or mild exercise: effects on serum lipids and body composition. Am J Clin Nutr. 1980;33(5):1002-9. [Rec#: 1016]. [pmid: 7369151].
Excluded. Diet, not reviewed further.
Werneke U, Taylor D, Sanders T A. Options for pharmacological management of obesity in patients treated with atypical antipsychotics. Int Clin Psychopharmacol. 2002;17(4):145-60. [Rec#: 756]. [pmid: 12131598].
Excluded. Rejected at abstract.
Weststrate J A, van het Hof K H, van den Berg H, Velthuis-te-Wierik E J, de Graaf C, Zimmermanns N J, et al. A comparison of the effect of free access to reduced fat products or their full fat equivalents on food intake, body weight, blood lipids and fat-soluble antioxidants levels and haemostasis variables. Eur J Clin Nutr. 1998;52(6):389-95. [Rec#: 1017]. [pmid: 9683389].
Excluded. Subject unrelated.
Whelton P K, Babnson J, Appel L J, Charleston J, Cosgrove N, Espeland M A, et al. Recruitment in the Trial of Nonpharmacologic Intervention in the Elderly (TONE). J Am Geriatr Soc. 1997;45(2):185-93. [Rec#: 737]. [pmid: 9033517].
Excluded. Topic unrelated.
Whelton P K, Hebert P R, Cutler J, Applegate W B, Eberlein K A, Klag M J, et al. Baseline characteristics of participants in phase I of the Trials of Hypertension Prevention. Ann Epidemiol. 1992;2(3):295-310. [Rec#: 817]. [pmid: 1342280].
Excluded. Topic unrelated.
Whelton P K, Appel L J, Espeland M A, Applegate W B, Ettinger W H, Kostis J B, et al. Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). JAMA. 1998;279(11):839-46. [Rec#: 185]. [pmid: 9515998].
Excluded. Subject unrelated.
Whelton P K, Kumanyika S K, Cook N R, Cutler J A, Borhani N O, Hennekens C H, et al. Efficacy of nonpharmacologic interventions in adults with high-normal blood pressure: results from phase 1 of the Trials of Hypertension Prevention. Trials of Hypertension Prevention Collaborative Research Group. Am J Clin Nutr. 1997;65 (2 Suppl):652S-660S. [Rec#: 184]. [pmid: 9394689].
Excluded. Subject unrelated.
Whitehead J M, McNeill G, Smith J S. The effect of protein intake on 24-h energy expenditure during energy restriction. Int J Obes Relat Metab Disord. 1996;20(8):727-32. [Rec#: 791]. [pmid: 8856395].
Excluded. Diet, not reviewed further.
Wilding J. Early response to orlistat treatment predicts long-term success in overweight and obese patients with co-morbidities. Int J Obes Relat Metab Disord. 2001;25 (Suppl):S108. [Rec#: 186]. [pmid: 11933881].
Excluded. Duration of treatment < 6 months.
Wilke H, Frahm H. [Influence of low-caloric-diet and d-triiodothyronine on serum lipids and body weight (author's transl)]. Med Klin. 1974;69(48):1986-9. [Rec#: 326]. [pmid: 4453291].
Excluded. Rejected at abstract.
Williams P T, Krauss R M, Stefanick M L, Vranizan K M, Wood P D. Effects of low-fat diet, calorie restriction, and running on lipoprotein subfraction concentrations in moderately overweight men. Metabolism. 1994;43(5):655-63. [Rec#: 187]. [pmid: 8177056].
Excluded. Diet, not reviewed further.
Williams P T, Krauss R M, Vranizan K M, Albers J J, Terry R B, Wood P D. Effects of exercise-induced weight loss on low density lipoprotein subfractions in healthy men. Arteriosclerosis. 1989;9(5):623-32. [Rec#: 329]. [pmid: 2783076].
Excluded. Subject unrelated.
Williams P T, Krauss R M, Vranizan K M, Albers J J, Wood P D. Effects of weight-loss by exercise and by diet on apolipoproteins A-I and A-II and the particle-size distribution of high-density lipoproteins in men. Metabolism. 1992;41(4):441-9. [Rec#: 188]. [pmid: 1556953].
Excluded. Diet, not reviewed further.
Williams P T, Krauss R M, Vranizan K M, Wood P D. Changes in lipoprotein subfractions during diet-induced and exercise- induced weight loss in moderately overweight men. Circulation. 1990;81(4):1293-304. [Rec#: 189]. [pmid: 2317911].
Excluded. Diet, not reviewed further.
Williams P T, Wood P D, Krauss R M, Haskell W L, Vranizan K M, Blair S N, et al. Does weight loss cause the exercise-induced increase in plasma high density lipoproteins?. Atherosclerosis. 1983;47(2):173-85. [Rec#: 331]. [pmid: 6870998].
Excluded. Rejected at abstract.
Williamson D, Wadden T, Smith D. LookAHEAD Research GroupUSA. Weight loss intervention of the LookAHEAD trial: Description of procedures for the weight loss induction phase (year 1). Int J Obes Relat Metab Disord. 2002;26 (Supplement 1):S25. [Rec#: 496]. [pmid: 12461680].
Excluded. Topic unrelated.
Williamson D F, Pamuk E, Thun M, Flanders D, Byers T, Heath C. Prospective study of intentional weight loss and mortality in never- smoking overweight US white women aged 40–64 years. Am J Epidemiol. 1995;141(12):1128-41. [Rec#: 739]. [pmid: 7771451].
Excluded. Subject unrelated.
Wilmore J H, Despres J P, Stanforth P R, Mandel S, Rice T, Gagnon J, et al. Alterations in body weight and composition consequent to 20 wk of endurance training: the HERITAGE Family Study. Am J Clin Nutr. 1999;70(3):346-52. [Rec#: 333]. [pmid: 10479196].
Excluded. Subject unrelated.
Wilson A, Kostis J, Philipp C, Appel L, Espeland M, Johnson K, et al. ACE gene (DD) genotype is associated with response to dietary weight loss therapy of hypertension: effect of race and sex. Journal of Hypertension 2000;(18):S124.[Rec#: 190]
Excluded. Not found.
Wilson AC, Kostis JB, hilipp CS, Appel LJ, Espeland M, Folmar S, et al. Blood pressure sensitivity to weight loss in elderly white hypertensives: association with ACE (DD) genotype. American Journal of Hypertension 2000;(13):79A.[Rec#: 191]
Excluded. Subject unrelated.
Wilson P, O'Meara S, Summerbell C, Kelly S. The prevention and treatment of childhood obesity. Qual Saf Health Care. 2003;12:65-74. [Rec#: 885]. [pmid: 12571349].
Excluded. Diet, not reviewed further.
Wing R R. Insulin sensitivity as a predictor of weight regain. Obes Res. 1997;5(1):24-9. [Rec#: 192]. [pmid: 9061712].
Excluded. Subject unrelated.
Wing R R, Anglin K. Effectiveness of a behavioral weight control program for blacks and whites with NIDDM. Diabetes Care. 1996;19(5):409-13. [Rec#: 193]. [pmid: 8732700].
Excluded. Subject unrelated.
Wing R R, Blair E, Marcus M, Epstein L H, Harvey J. Year-long weight loss treatment for obese patients with type II diabetes: does including an intermittent very-low-calorie diet improve outcome?. Am J Med. 1994;97(4):354-62. [Rec#: 194]. [pmid: 7942937].
Excluded. Subject unrelated.
Wing R R, Epstein L H, Marcus M D, Koeske R. Intermittent low-calorie regimen and booster sessions in the treatment of obesity. Behav Res Ther. 1984;22(4):445-9. [Rec#: 195]. [pmid: 6477369].
Excluded. Subject unrelated.
Wing R R, Epstein L H, Nowalk M P, Koeske R, Hagg S. Behavior change, weight loss, and physiological improvements in type II diabetic patients. J Consult Clin Psychol. 1985;53(1):111-22. [Rec#: 196]. [pmid: 3980816].
Excluded. Duration of treatment < 6 months.
Wing R R, Epstein L H, Paternostro-Bayles M, Kriska A, Nowalk M P, Gooding W. Exercise in a behavioural weight control programme for obese patients with Type 2 (non-insulin-dependent) diabetes. Diabetologia. 1988;31(12):902-9. [Rec#: 197]. [pmid: 3071485].
Excluded. Subject unrelated.
Wing R R, Jeffery R W. Benefits of recruiting participants with friends and increasing social support for weight loss and maintenance. J Consult Clin Psychol. 1999;67(1):132-8. [Rec#: 199]. [pmid: 10028217].
Excluded. Subject unrelated.
Wing R R, Jeffery R W. Effect of modest weight loss on changes in cardiovascular risk factors: are there differences between men and women or between weight loss and maintenance?. Int J Obes Relat Metab Disord. 1995;19(1):67-73. [Rec#: 198]. [pmid: 7719395].
Excluded. Diet, not reviewed further.
Wing R R, Jeffery R W. Outpatient treatments of obesity: a comparison of methodology and clinical results. Int J Obes. 1979;3(3):261-79. [Rec#: 328] Excluded. Study design, review or meta-analysis. [pmid: 395116].
Wing RR, Marcus MD, Epstein LA, Jawad A. A “family-based” approach to the treatment of obese type II diabetic patients. Journal of Consulting and Clinical Psychology 1991;(59):156–62.[Rec#: 202]
Excluded. Subject unrelated.
Wing R R, Marcus M D, Salata R, Epstein L H, Miaskiewicz S, Blair E H. Effects of a very-low-calorie diet on long-term glycemic control in obese type 2 diabetic subjects. Arch Intern Med. 1991;151(7):1334-40. [Rec#: 200]. [pmid: 2064484].
Excluded. Duration of treatment < 6 months.
Wing R R, Venditti E, Jakicic J M, Polley B A, Lang W. Lifestyle intervention in overweight individuals with a family history of diabetes. Diabetes Care. 1998;21(3):350-9. [Rec#: 201]. [pmid: 9540015].
Excluded. Diet, not reviewed further.
Wing R R, Jeffery R W. Sample size in clinical outcome research: the case of behavioral weight control. Behavior Therapy. 1984;15(5):550-556. [Rec#: 359].
Excluded. Topic unrelated.
Wing R R, Shiffman S, Drapkin R G, Grilo C M, McDermott M. Moderate versus restrictive diets: Implications for relapse. Behavior Therapy. 1995;26(1):5-24. [Rec#: 203].
Excluded. Subject unrelated.
Wirth A, Platon J. Effect of orlistat on body weight and co-morbidities in clinical practice: The xxl-primary health care observational trial. Int J Obes Relat Metab Disord. 2001;25 (Supplement 2):S23. [Rec#: 497]. [pmid: 11933881].
Excluded. Not RCT/CCT (medication and surgery), not case report or case series (surgery only).
Wirth Alfred, Krause Jutta. Long-term weight loss with sibutramine: A randomized controlled trial. JAMA (Journal of the American Medical Association). 2001;286(11):1331-1339. [Rec#: 498]. [pmcid: 28304]. [pmid: 15339902].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Wise P J. Clinical experience with a new dosage form of phentermine hydrochloride. J Obes Bariatric Med. 1975;4:102-105. [Rec#: 639].
Excluded. Duration of treatment < 6 months.
Wise S D. Clinical studies with fluoxetine in obesity. Am J Clin Nutr. 1992;55 (1 Suppl):181S-184S. [Rec#: 940]. [pmid: 1442668].
Excluded. Study design, review or meta-analysis.
Wolever T M, Mehling C. High-carbohydrate-low-glycaemic index dietary advice improves glucose disposition index in subjects with impaired glucose tolerance. Br J Nutr. 2002;87(5):477-87. [Rec#: 792]. [pmid: 12010586].
Excluded. Subject unrelated.
Wolever T M, Chiasson J L, Josse R G, Hunt J A, Palmason C, Rodger N W, et al. No relationship between carbohydrate intake and effect of acarbose on HbA1c or gastrointestinal symptoms in type 2 diabetic subjects consuming 30–60% of energy from carbohydrate. Diabetes Care. 1998;21(10):1612-8. [Rec#: 205]. [pmid: 9773719].
Excluded. Subject unrelated.
Wolever T M, Chiasson J L, Josse R G, Hunt J A, Palmason C, Rodger N W, et al. Small weight loss on long-term acarbose therapy with no change in dietary pattern or nutrient intake of individuals with non-insulin- dependent diabetes. Int J Obes Relat Metab Disord. 1997;21(9):756-63. [Rec#: 204]. [pmid: 9376887].
Excluded. Subject unrelated.
Wolever T M, Radmard R, Chiasson J L, Hunt J A, Josse R G, Palmason C, et al. One-year acarbose treatment raises fasting serum acetate in diabetic patients. Diabet Med. 1995;12(2):164-72. [Rec#: 206]. [pmid: 7743764].
Excluded. Topic unrelated.
Wolfe B M, Giovannetti P M. Short-term effects of substituting protein for carbohydrate in the diets of moderately hypercholesterolemic human subjects. Metabolism. 1991;40(4):338-43. [Rec#: 793]. [pmid: 2011075].
Excluded. Subject unrelated.
Wolfe B M, Piche L A. Replacement of carbohydrate by protein in a conventional-fat diet reduces cholesterol and triglyceride concentrations in healthy normolipidemic subjects. Clin Invest Med. 1999;22(4):140-8. [Rec#: 794]. [pmid: 10497712].
Excluded. Subject unrelated.
Wood P D, Haskell W L, Blair S N, Williams P T, Krauss R M, Lindgren F T, et al. Increased exercise level and plasma lipoprotein concentrations: a one- year, randomized, controlled study in sedentary, middle-aged men. Metabolism. 1983;32(1):31-9. [Rec#: 332]. [pmid: 6848894].
Excluded. Subject unrelated.
Wood P D, Stefanick M L, Dreon D M, Frey-Hewitt B, Garay S C, Williams P T, et al. Changes in plasma lipids and lipoproteins in overweight men during weight loss through dieting as compared with exercise. N Engl J Med. 1988;319(18):1173-9. [Rec#: 207]. [pmid: 3173455].
Excluded. Diet, not reviewed further.
Wood P D, Stefanick M L, Williams P T, Haskell W L. The effects on plasma lipoproteins of a prudent weight-reducing diet, with or without exercise, in overweight men and women. N Engl J Med. 1991;325(7):461-6. [Rec#: 208]. [pmid: 1852180].
Excluded. Diet, not reviewed further.
Woodgate Derek E, Conquer Julie A. Double-blind study evaluating the effects of a novel herbal supplement on weight loss in overweight adults. FASEB Journal. 2001;15(4):A302. [Rec#: 499].
Excluded. Subject unrelated.
Yale C E. Conversion surgery for morbid obesity: complications and long-term weight control. Surgery. 1989;106(3):474-80. [pmid: 2772823].
Excluded. Not retrieved by cut-off date.
Yang S P, Martin L J, Schneider G. Weight reduction utilizing a protein-sparing modified fast. J Am Diet Assoc. 1980;76(4):343-6. [Rec#: 334]. [pmid: 7391466].
Excluded. Diet, not reviewed further.
Yanovski J A, Yanovski S Z. Treatment of pediatric and adolescent obesity. JAMA. 2003;289(14):1851-3. [Rec#: 641]. [pmid: 12684365].
Excluded. Study design, descriptive.
Yasmin, Mascie-Taylor C G, Brown M J, Hughes M. The effect of dietary intervention on changes in total cholesterol, blood pressure and weight in a Cambridge study. Int J Clin Pract. 1998;52(4):241-5. [Rec#: 336]. [pmid: 9744148].
Excluded. Diet, not reviewed further.
Yeh S L, Lui M Y, Chen W J. Changes of body composition and energy metabolism in obese women before and after weight reduction. Nutritional Sciences Journal. 1998;23(2):133-145. [Rec#: 360].
Excluded. Diet, not reviewed further.
Yetter JG. The role of hypnotherapy and hypnotizability in the treatment of obesity as part of a comprehensive weight reduction program. Dissertation Abstracts International. V 46. Is 7-B. Pg 2471: 1986.[Rec #: 361]
Excluded. Subject unrelated.
Yip I, Go V L, DeShields S, Saltsman P, Bellman M, Thames G, et al. Liquid meal replacements and glycemic control in obese type 2 diabetes patients. Obes Res. 2001;9 Suppl 4:341S-347S. [Rec#: 963]. [pmid: 11707563].
Excluded. Subject unrelated.
Ylitalo V M. Treatment of obese schoolchildren. Klin Padiatr. 1982;194(5):310-4. [Rec#: 444]. [pmid: 7144047].
Excluded. Diet, not reviewed further.
Yoshida T, Sakane N, Umekawa T, Yoshioka K, Kondo M, Wakabayashi Y. Usefulness of mazindol in combined diet therapy consisting of a low-calorie diet and Optifast in severely obese women. Int J Clin Pharmacol Res. 1994;14(4):125-32. [Rec#: 941]. [pmid: 7607785].
Excluded. Mazindol, not reviewed.
Zahorska-Markiewicz B, Kucio C, Piskorska D. Use of yohimbine, an alpha-adrenolytic drug, in obesity. Polskie Archiwum Medycyny Wewnetrznej. 1986;75(5):351-355. [Rec#: 362]. [pmid: 3537986].
Excluded. Unable to find translator.
Zannad Faiez, Gille Bertrand, Grentzinger Alain, BruntzJean-Francois, Hammadi Mokrane, Boivin Jean-Marc, et al. Effects of sibutramine on ventricular dimensions and heart valves in obese patients during weight reduction. American heart journal. 2002;144(3):505-15. [Rec#: 210]. [pmid: 12228789].
Excluded. Sibutramine, not analyzed. Previous meta-analysis reviewed.
Zenk John L, Helmer Tami R, Kassen Laurie J, Kuskowski Michael A. The effect of 7-Keto NaturaleanTM on weight loss: A randomized, double-blind, placebo-controlled trial. Current Therapeutic Research. 2002;63(4):263-272. [Rec#: 500].
Excluded. Subject unrelated.
Zhao Y, Wang X, Yan Z. [A randomized, double-blind, placebo-controlled, multicenter study on sibutramine in over-weighted and obese subjects]. Zhonghua yu fang yi xue za zhi Chinese journal of preventive medicine. 2001;35(5):329-32. [Rec#: 216]. [pmid: 11769634].
Excluded. Duration of treatment < 6 months.
Zhi J, Melia A T, Koss-Twardy S G, Arora S, Patel I H. The effect of orlistat, an inhibitor of dietary fat absorption, on the pharmacokinetics of beta-carotene in healthy volunteers. J Clin Pharmacol. 1996;36(2):152-9. [Rec#: 942]. [pmid: 8852391].
Excluded. Topic unrelated.
Ziemer D C, Berkowitz K J, Panayioto R M, El-Kebbi I M, Musey V C, Anderson L A, et al. A Simple Meal Plan Emphasizing Healthy Food Choices Is as Effective as an Exchange-Based Meal Plan for Urban African Americans With Type 2 Diabetes. Diabetes Care. 2003;26(6):1719-1724. [Rec#: 881]. [pmid: 12766100].
Excluded. Subject unrelated.
Zunft Hans-Joachim Franz, Seppelt Brigitte. Failing long-term weight-loss maintenance after dietary intervention with low-fat products. FASEB Journal. 2002;16(4):A369. [Rec#: 502].
Excluded. Diet, not reviewed further