# Appendix F: Included Studies

Abu-Abeid S, Gavert N, Klausner J M, et al. Bariatric surgery in adolescence. J Pediatr Surg. 2003;38(9):1379-82. [pmid: 14523824].
Notes: Quality Reviewed for Surgery Analyses.
Abu-Abeid S, Szold A. Laparoscopic management of Lap-Band erosion. Obes Surg. 2001;11(1):87-9. [pmid: 11361174].
Notes: Reports complications, considered for surgery analysis.
Abu-Abeid S, Szold A. Results and complications of laparoscopic adjustable gastric banding: an early and intermediate experience. Obes Surg. 1999;9(2):188-90. [pmid: 10340776].
Notes: Quality Reviewed for Surgery Analyses.
Aghahosseini H, Roulet D, Cavin R. [Treatment of morbid obesity with adjustable gastric prosthesis: experience and results at the Riviera Hospital in Montreux]. Rev Med Suisse Romande. 2001;121(10):709-12. [pmid: 11715285].
Notes: Quality Reviewed for Surgery Analyses.
Agren G, Naslund I. A prospective randomized comparison of vertical banded gastroplasty (VBG), loop gastric bypass (GBY), and gastric banding (GB). Int J Obes. 1989;13:595.
Notes: Quality Reviewed for Surgery Analyses.
Al-Jiffry B O, Shaffer E A, Saccone G T, et al. Changes in gallbladder motility and gallstone formation following laparoscopic gastric banding for morbid obesity. Can J Gastroenterol. 2003;17(3):169-74. [pmid: 12677265].
Notes: Quality Reviewed for Surgery Analyses.
Alden J F. Gastric and jejunoileal bypass. A comparison in the treatment of morbid obesity. Arch Surg. 1977;112(7):799-806. [pmid: 880023].
Notes: Quality Reviewed for Surgery Analyses.
Alper D, Ramadan E, Vishne T, et al. Silastic ring vertical gastroplasty- long-term results and complications. Obes Surg. 2000;10(3):250-4. [pmid: 10929157].
Notes: Quality Reviewed for Surgery Analyses.
Andersen T, Backer O G, Astrup A, et al. Horizontal or vertical banded gastroplasty after pretreatment with very- low-calorie formula diet: a randomized trial. Int J Obes. 1987;11(3):295-304. [pmid: 3312050].
Notes: Quality Reviewed for Surgery Analyses.
Andersen T, Backer O G, Stokholm K H, et al. [Gastroplasty versus very low calorie diet in morbid obesity. Short-term results of a randomized clinical trial]: <Original> Gastroplastik versus ekstrem lavkalorie-diaet (very-low-calorie diet) ved svaer adipositas. Korttidsresultater af en randomiseret klinisk undersogelse. Ugeskrift for laeger. 1982;144(6):390-4. [pmid: 7041386].
Notes: Quality Reviewed for Surgery Analyses.
Andersen T, Backer O G, Stokholm K H, et al. Randomized trial of diet and gastroplasty compared with diet alone in morbid obesity. New England journal of medicine. 1984;310(6):352-6. [pmid: 6690963].
Notes: Quality Reviewed for Surgery Analyses. Reports on Diethylproprion; no analysis performed, summary of recent meta-analysis provided.
Andersen T, Stokholm K H, Backer O G, et al. Long-term (5-year) results after either horizontal gastroplasty or very- low-calorie diet for morbid obesity. Int J Obes. 1988;12(4):277-84. [pmid: 3058614].
Notes: Quality Reviewed for Surgery Analyses. Reports on Diethylproprion; no analysis performed, summary of recent meta-analysis provided.
Anderson A E, Soper R T, Scott D H. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. 1980;15(6):876-81. [pmid: 7463289].
Notes: Quality Reviewed for Surgery Analyses.
Anderson J W, Greenway F L, Fujioka K, et al. Bupropion SR enhances weight loss: a 48-week double-blind, placebo- controlled trial. Obes Res. 2002;10(7):633-41. [pmid: 12105285].
Notes: Quality Reviewed for Medication Analyses.
Anderson James W, Greenway Frank, Fujioka Ken, et al. Buproprion SR significantly enhances weight loss when used with a moderate-intensity lifestyle intervention. Diabetes. 2001;50(Supplement 2):A21. [pmid: 11723075].
Notes: Quality Reviewed for Medication Analyses.
Anderson JW on behalf of the orlistat weight maintenance study group. Prevention of weight regain after conventional dieting: a 1-year study with orlistat (xenical), a new gastrointestinal lipase inhibitor. Obesity Research 1997;5(Suppl 1):S2.
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Anthone G J, Lord R V N, DeMeester T R, et al. The duodenal switch operation for the treatment of morbid obesity. Ann Surg. 2003;238(4):618-628. [pmid: 14530733]. [pmcid: 1360120].
Notes: Quality Reviewed for Surgery Analyses.
Bakris G, Calhoun D, Egan B, et al. Orlistat improves blood pressure control in obese subjects with treated but inadequately controlled hypertension. J Hypertens. 2002;20(11):2257-67. [pmid: 12409965].
Notes: Quality Reviewed for Medication Analyses.
Balsiger B M, Poggio J L, Mai J, et al. Ten and more years after vertical banded gastroplasty as primary operation for morbid obesity. J Gastrointest Surg. 2000;4(6):598-605. [pmid: 11307094].
Notes: Quality Reviewed for Surgery Analyses.
Baltasar A, Bou R, Arlandis F, et al. Vertical banded gastroplasty at more than 5 years. Obes Surg. 1998;8(1):29-34. [pmid: 9562483].
Notes: Quality Reviewed for Surgery Analyses.
Belachew M, Belva P H, Desaive C. Long-term results of laparoscopic adjustable gastric banding for the treatment of morbid obesity. Obes Surg. 2002;12(4):564-8. [pmid: 12194552].
Notes: Quality Reviewed for Surgery Analyses.
Belachew M, Legrand M, Vincent V, et al. Laparoscopic adjustable gastric banding. World J Surg. 1998;22(9):955-63. [pmid: 9717421].
Notes: Quality Reviewed for Surgery Analyses.
Berkowitz R I, Wadden T A, Tershakovec A M, et al. Behavior therapy and sibutramine for the treatment of adolescent obesity: a randomized controlled trial. JAMA. 2003;289(14):1805-12. [pmid: 12684359].
Notes: Reports on Sibutramine; no analysis performed, summary of recent meta-analysis provided.
Bloomston M, Zervos E E, Camps M A, et al. Outcome following bariatric surgery in super versus morbidly obese patients: does weight matter?. Obes Surg. 1997;7(5):414-9. [pmid: 9730495].
Notes: Quality Reviewed for Surgery Analyses.
Bray G, Klein S, Levy B, Fitchet M, Perry B. Topiramate produces dose-related weight loss in obese patients. Presented at the 62nd American Diabetes Association Scientific Sessions. 2002 (Abstract)
Notes: Quality Reviewed for Medication Analyses.
Bray G A, Hollander P, Klein S, et al. A 6-Month Randomized, Placebo-Controlled, Dose-Ranging Trial of Topiramate for Weight Loss in Obesity. Obes Res. 2003;11(6):722-733. [pmid: 12805393].
Notes: Quality Reviewed for Medication Analyses.
Breaux C W. Obesity Surgery in Children. Obes Surg. 1995;5(3):279-284. [pmid: 10733812].
Notes: Quality Reviewed for Surgery Analyses.
Breum L, Bjerre U, Bak J F, et al. Long-term effects of fluoxetine on glycemic control in obese patients with non-insulin-dependent diabetes mellitus or glucose intolerance: influence on muscle glycogen synthase and insulin receptor kinase activity. Metabolism. 1995;44(12):1570-6. [pmid: 8786726].
Notes: Quality Reviewed for Medication Analyses.
Brolin R L, Robertson L B, Kenler H A, et al. Weight loss and dietary intake after vertical banded gastroplasty and Roux-en-Y gastric bypass. Ann Surg. 1994;220(6):782-90. [pmid: 7986146]. [pmcid: 1234481].
Notes: Quality Reviewed for Surgery Analyses.
Brolin R E, Bradley L J, Wilson A C, et al. Lipid risk profile and weight stability after gastric restrictive operations for morbid obesity. J Gastrointest Surg. 2000;4(5):464-9. [pmid: 11077320].
Notes: Quality Reviewed for Surgery Analyses.
Brolin R E, Kenler H A, Gorman J H, et al. Long-limb gastric bypass in the superobese. A prospective randomized study. Annals of surgery. 1992;215(4):387-95. [pmid: 1558421]. [pmcid: 1242457].
Notes: Quality Reviewed for Surgery Analyses.
Broom I. Randomised trial of the effect of orlistat on body weight and CVD risk profile in overweight and obese patients with co-morbidities. Int J Obes Relat Metab Disord. 2001;25(Suppl):S106. [pmid: 11933881].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Broom I , Hughes E , Dodgson P , et al. The role of orlistat in the treatment of obese patients with mild to moderate hypercholesterolaemia: consequences for coronary risk. 2001.
Notes: Quality Reviewed for Medication Analyses.
Broom I, Wilding J, Stott P, et al. Randomised trial of the effect of orlistat on body weight and cardiovascular disease risk profile in obese patients: UK Multimorbidity Study. Int J Clin Pract. 2002;56(7):494-9. [pmid: 12296610].
Notes: Quality Reviewed for Medication Analyses.
Buckwalter J A. A prospective comparison of the jejunoileal and gastric bypass operations for morbid obesity. World J Surg. 1977;1(6):757-68. [pmid: 607594].
Notes: Quality Reviewed for Surgery Analyses.
Capella J F, Capella R F. The weight reduction operation of choice: vertical banded gastroplasty or gastric bypass?. Am J Surg. 1996;171(1):74-9. [pmid: 8554155].
Notes: Quality Reviewed for Surgery Analyses.
Caterson I, Astrup A, Zelissen P, Guy-Grand B, Carruba M, Levy B, et al. The long-term effect of Topiramate on body weight maintenance after low-calorie diet-induced wieght loss in obese subjects. Presented at the 18th International Diabetes Federation Congress. 2003 (Abstract)
Notes: Quality Reviewed for Medication Analyses.
Chiasson JL, Lau W, Leiter LA. Fluoxetine has potential in obese NIDDM--multi-center Canadian Trial. Diabetes 1989;38((suppl 2)):603.
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Choban P S, Flancbaum L. The effect of Roux limb lengths on outcome after Roux-en-Y gastric bypass: a prospective, randomized clinical trial. Obes Surg. 2002;12(4):540-5. [pmid: 12194548].
Notes: Quality Reviewed for Surgery Analyses.
Choban P S, Onyejekwe J, Burge J C, et al. A health status assessment of the impact of weight loss following Roux- en-Y gastric bypass for clinically severe obesity. J Am Coll Surg. 1999;188(5):491-7. [pmid: 10235576].
Notes: Quality Reviewed for Surgery Analyses.
Choi Y, Frizzi J, Foley A, et al. Patient satisfaction and results of vertical banded gastroplasty and gastric bypass. Obes Surg. 1999;9(1):33-5. [pmid: 10065578].
Notes: Quality Reviewed for Surgery Analyses.
Connolly V M, Gallagher A, Kesson C M. A study of fluoxetine in obese elderly patients with type 2 diabetes. Diabet Med. 1995;12(5):416-8. [pmid: 7648804].
Notes: Quality Reviewed for Medication Analyses.
Cook C M, Edwards C. Success habits of long-term gastric bypass patients. Obes Surg. 1999;9(1):80-2. [pmid: 10065592].
Notes: Quality Reviewed for Surgery Analyses.
Courcoulas A, Perry Y, Buenaventura P, et al. Comparing the outcomes after laparoscopic versus open gastric bypass: a matched paired analysis. Obes Surg. 2003;13(3):341-6. [pmid: 12841890].
Notes: Quality Reviewed for Surgery Analyses.
Crampton N A, Izvornikov V, Stubbs R S. Silastic ring gastric bypass: results in 64 patients. Obes Surg. 1997;7(6):489-94. [pmid: 9730506].
Notes: Quality Reviewed for Surgery Analyses.
Croft H, Houser T L, Jamerson B D, et al. Effect on body weight of bupropion sustained-release in patients with major depression treated for 52 weeks. Clin Ther. 2002;24(4):662-72. [pmid: 12017410].
Notes: Quality Reviewed for Medication Analyses.
Darga L L, Carroll-Michals L, Botsford S J, et al. Fluoxetine's effect on weight loss in obese subjects. Am J Clin Nutr. 1991;54(2):321-5. [pmid: 1858696].
Notes: Quality Reviewed for Medication Analyses.
Dargent J. Laparoscopic adjustable gastric banding: lessons from the first 500 patients in a single institution. Obes Surg. 1999;9(5):446-52. [pmid: 10605901].
Notes: Quality Reviewed for Surgery Analyses.
Das S K, Roberts S B, Kehayias J J, et al. Body composition assessment in extreme obesity and after massive weight loss induced by gastric bypass surgery. Am J Physiol Endocrinol Metab. 2003;284(6):E1080-8. [pmid: 12604503].
Notes: Quality Reviewed for Surgery Analyses.
Davidson M H, Hauptman J, DiGirolamo M, et al. Weight control and risk factor reduction in obese subjects treated for 2 years with orlistat: a randomized controlled trial. JAMA. 1999;281(3):235-42. [pmid: 9918478].
Notes: Quality Reviewed for Medication Analyses.
Davila-Cervantes A, Ganci-Cerrud G, Gamino R, et al. Open vs. laparoscopic vertical banded gastroplasty: a case control study with a 1-year follow-up. Obes Surg. 2000;10(5):409-12. [pmid: 11054244].
Notes: Quality Reviewed for Surgery Analyses.
de Csepel J, Nahouraii R, Gagner M. Laparoscopic gastric bypass as a reoperative bariatric surgery for failed open restrictive procedures. Surg Endosc. 2001;15(4):393-7. [pmid: 11395822].
Notes: Quality Reviewed for Surgery Analyses.
De Luca M, de Werra C, Formato A, et al. Laparotomic vs laparoscopic lap-band: 4-year results with early and intermediate complications. Obes Surg. 2000;10(3):266-8. [pmid: 10929160].
Notes: Quality Reviewed for Surgery Analyses.
de Wit L T, Mathus-Vliegen L, Hey C, et al. Open versus laparoscopic adjustable silicone gastric banding: a prospective randomized trial for treatment of morbid obesity. Annals of surgery. 1999;230(6):800-5. [pmid: 10615935]. [pmcid: 1420944].
Notes: Quality Reviewed for Surgery Analyses.
de Zwaan M, Lancaster K L, Mitchell J E, et al. Health-related quality of life in morbidly obese patients: effect of gastric bypass surgery. Obes Surg. 2002;12(6):773-80. [pmid: 12568181].
Notes: Quality Reviewed for Surgery Analyses.
Deerochanawong Chaicharn. Effect of treatment with orlistat in overweight or obese Thai patients with type 2 diabetes. Diabetes 2001;50(Supplement 2):A433.
Notes: Quality Reviewed for Medication Analyses.
DeMaria E J, Sugerman H J. A critical look at laparoscopic adjustable silicone gastric banding for surgical treatment of morbid obesity: does it measure up?. Surg Endosc. 2000;14(8):697-9. [pmid: 10954811].
Notes: Quality Reviewed for Surgery Analyses.
DeMaria E J, Sugerman H J, Meador J G, et al. High failure rate after laparoscopic adjustable silicone gastric banding for treatment of morbid obesity. Ann Surg. 2001;233(6):809-18. [pmid: 11371739]. [pmcid: 1421324].
Notes: Quality Reviewed for Surgery Analyses.
Derosa G, Mugellini A, Ciccarelli L, et al. Randomized, double-blind, placebo-controlled comparison of the action of orlistat, fluvastatin, or both an anthropometric measurements, blood pressure, and lipid profile in obese patients with hypercholesterolemia prescribed a standardized diet. Clin Ther. 2003;25(4):1107-22. [pmid: 12809960].
Notes: Quality Reviewed for Medication Analyses.
Derosa Giuseppe, Mugellini Amedeo, Ciccarelli Leonardina, et al. Effects of orlistat, simvastatin, and orlistat+simvastatin in obese patients with hypercholesterolemia: A randomized, open-label trial. Current Therapeutic Research. 2002;63(9):621-633.
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Derzie A J, Silvestri F, Liriano E, et al. Wound closure technique and acute wound complications in gastric surgery for morbid obesity: a prospective randomized trial. J Am Coll Surg. 2000;191(3):238-43. [pmid: 10989897].
Notes: Reports complications, considered for surgery analysis.
Doherty C, Maher JW, Heitshusen DS. Long-term data indicate a progressive loss in efficacy of adjustable silicone gastric banding for the surgical treatment of morbid obesity. Surgery 2002;132(4):724–7; discussion 727–8.
Notes: Quality Reviewed for Surgery Analyses.
Doherty C, Maher J W, Heitshusen D S. Prospective investigation of complications, reoperations, and sustained weight loss with an adjustable gastric banding device for treatment of morbid obesity. J Gastrointest Surg. 1998;2(1):102-8. [pmid: 9841975].
Notes: Quality Reviewed for Surgery Analyses.
Dolan K, Creighton L, Hopkins G, et al. Laparoscopic gastric banding in morbidly obese adolescents. Obes Surg. 2003;13(1):101-4. [pmid: 12630622].
Notes: Quality Reviewed for Surgery Analyses.
Doldi S B, Micheletto G, Lattuada E, et al. Adjustable gastric banding: 5-year experience. Obes Surg. 2000;10(2):171-3. [pmid: 10782180].
Notes: Quality Reviewed for Surgery Analyses.
Dymek M P, Le Grange D, Neven K, et al. Quality of life after gastric bypass surgery: a cross-sectional study. Obes Res. 2002;10(11):1135-42. [pmid: 12429877].
Notes: Quality Reviewed for Surgery Analyses.
Farrell J. Long-term management of obesity in primary care: the role of Orlistat (Xenical). Obesity Research 1997;(5):10S.
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Feng J J, Gagner M. Laparoscopic biliopancreatic diversion with duodenal switch. Semin Laparosc Surg. 2002;9(2):125-9. [pmid: 12152155].
Notes: Quality Reviewed for Surgery Analyses.
Field R J Jr, Field R J 3rd, Park S Y. Vertical banded gastroplasty: is obesity worth it?. J Miss State Med Assoc. 1992;33(12):423-32. [pmid: 1474572].
Notes: Quality Reviewed for Surgery Analyses.
Fielding G A, Rhodes M, Nathanson L K. Laparoscopic gastric banding for morbid obesity. Surgical outcome in 335 cases. Surg Endosc. 1999;13(6):550-4. [pmid: 10347288].
Notes: Quality Reviewed for Surgery Analyses.
Finer N, James W P, Kopelman P G, et al. One-year treatment of obesity: a randomized, double-blind, placebo- controlled, multicentre study of orlistat, a gastrointestinal lipase inhibitor. Int J Obes Relat Metab Disord. 2000;24(3):306-13. [pmid: 10757623].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Fobi M A. Vertical Banded Gastroplasty vs Gastric Bypass: 10 years follow-up. Obes Surg. 1993;3(2):161-164. [pmid: 10757913].
Notes: Quality Reviewed for Surgery Analyses.
Fobi M A, Lee H, Igwe D Jr, et al. Prospective comparative evaluation of stapled versus transected silastic ring gastric bypass: 6-year follow-up. Obes Surg. 2001;11(1):18-24. [pmid: 11361162].
Notes: Quality Reviewed for Surgery Analyses.
Forestieri P, Meucci L, De Luca M, et al. Two years of practice in adjustable silicone gastric banding (LAP- BAND): evaluation of variations of body mass index, percentage ideal body weight and percentage excess body weight. Obes Surg. 1998;8(1):49-52. [pmid: 9562487].
Notes: Quality Reviewed for Surgery Analyses.
Foreyt J. A 2-year multicenter study of the effects of Orlistat (Xenical) on weight loss and disease risk factors. Obesity Research 1997;(5):53.
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Forsell P, Hallerback B, Glise H, et al. Complications following Swedish adjustable gastric banding: a long-term follow-up. Obes Surg. 1999;9(1):11-6. [pmid: 10065574].
Notes: Quality Reviewed for Surgery Analyses.
Forsell P, Hellers G. The Swedish Adjustable Gastric Banding (SAGB) for morbid obesity: 9 year experience and a 4-year follow-up of patients operated with a new adjustable band. Obes Surg. 1997;7(4):345-51. [pmid: 9730522].
Notes: Quality Reviewed for Surgery Analyses.
Franson K, Rossner S. Fat intake and food choices during weight reduction with diet, behavioural modification and a lipase inhibitor. J Intern Med. 2000;247(5):607-14. [pmid: 10810001].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Freeman J B, Kotlarewsky M, Phoenix C. Weight loss after extended gastric bypass. Obes Surg. 1997;7(4):337-44. [pmid: 9730521].
Notes: Quality Reviewed for Surgery Analyses.
Gadde K M, Franciscy D M, Wagner H R 2nd, et al. Zonisamide for weight loss in obese adults: a randomized controlled trial. JAMA. 2003;289(14):1820-5. [pmid: 12684361].
Notes: Quality Reviewed for Medication Analyses.
Gadde K M, Parker C B, Maner L G, et al. Bupropion for weight loss: an investigation of efficacy and tolerability in overweight and obese women. Obes Res. 2001;9(9):544-51. [pmid: 11557835].
Notes: Quality Reviewed for Medication Analyses.
Gatsoulis N, Koulas S, Kiparos G, et al. Laparoscopic cholecystectomy in obese and nonobese patients. Obes Surg. 1999;9(5):459-61. [pmid: 10605904].
Notes: Reports complications, considered for surgery analysis.
Gilliam F G, Veloso F, Bomhof M A, et al. A dose-comparison trial of topiramate as monotherapy in recently diagnosed partial epilepsy. Neurology. 2003;60(2):196-202. [pmid: 12552030].
Notes: Quality Reviewed for Medication Analyses.
Goldstein D J, Rampey A H Jr, Enas G G, et al. Fluoxetine: a randomized clinical trial in the treatment of obesity. Int J Obes Relat Metab Disord. 1994;18(3):129-35. [pmid: 8186809].
Notes: Quality Reviewed for Medication Analyses.
Gotfredsen A, Westergren Hendel H, Andersen T. Influence of orlistat on bone turnover and body composition. Int J Obes Relat Metab Disord. 2001;25(8):1154-60. [pmid: 11486790].
Notes: Quality Reviewed for Medication Analyses.
Goulding S T, Hovell B C. Anaesthetic experience of vertical banded gastroplasty. Br J Anaesth. 1995;75(3):301-6. [pmid: 7547048].
Notes: Quality Reviewed for Surgery Analyses.
Gray D S, Fujioka K, Devine W, et al. Fluoxetine treatment of the obese diabetic. Int J Obes Relat Metab Disord. 1992;16(3):193-8. [pmid: 1317828].
Notes: Quality Reviewed for Medication Analyses.
Gray D S, Fujioka K, Devine W, et al. A randomized double-blind clinical trial of fluoxetine in obese diabetics. Int J Obes Relat Metab Disord. 1992;16 Suppl 4:S67-72. [pmid: 1338389].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Greenstein R J, Rabner J G. Is Adolescent Gastric-Restrictive Antiobesity Surgery Warranted?. Obes Surg. 1995;5(2):138-144. [pmid: 10733801].
Notes: Quality Reviewed for Surgery Analyses.
Griffen W O Jr, Young V L, Stevenson C C. A prospective comparison of gastric and jejunoileal bypass procedures for morbid obesity. Ann Surg. 1977;186(4):500-9. [pmid: 907395]. [pmcid: 1396298].
Notes: Quality Reviewed for Surgery Analyses.
Gustavsson S, Westling A. Laparoscopic adjustable gastric banding: complications and side effects responsible for the poor long-term outcome. Semin Laparosc Surg. 2002;9(2):115-24. [pmid: 12152154].
Notes: Quality Reviewed for Surgery Analyses.
Hall J C, Watts J M, O'Brien P E, et al. Gastric surgery for morbid obesity. The Adelaide Study. Ann Surg. 1990;211(4):419-27. [pmid: 2181950]. [pmcid: 1358027].
Notes: Quality Reviewed for Surgery Analyses.
Halpern A, Mancini M C, Suplicy H, et al. Latin-American trial of orlistat for weight loss and improvement in glycaemic profile in obese diabetic patients. Diabetes Obes Metab. 2003;5(3):180-8. [pmid: 12681025].
Notes: Quality Reviewed for Medication Analyses.
Halpern Alfredo. Latin-American multicentric study with orlistat in overweight or obese patients with type 2 diabetes. Diabetes. 2001;50(Supplement 2):A437. [pmid: 11723075].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Hamilton E C, Sims T L, Hamilton T T, et al. Clinical predictors of leak after laparoscopic Roux-en-Y gastric bypass for morbid obesity. Surg Endosc. 2003;17(5):679-84. [pmid: 12618940].
Notes: Reports complications, considered for surgery analysis.
Hanefeld M, Platon J, Sachse G. Orlistat promotes weight loss and improves glycaemic control in overweight patients with type 2 diabetes. Diabetologia. 2001;44(Supplement 1):A231. [pmid: 11841101].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Hanefeld M, Sachse G. The effects of orlistat on body weight and glycaemic control in overweight patients with type 2 diabetes: a randomized, placebo-controlled trial. Diabetes Obes Metab. 2002;4(6):415-23. [pmid: 12406041].
Notes: Quality Reviewed for Medication Analyses.
Hauptman J, Lucas C, Boldrin M N, et al. Orlistat in the long-term treatment of obesity in primary care settings. Arch Fam Med. 2000;9(2):160-7. [pmid: 10693734].
Notes: Quality Reviewed for Medication Analyses.
Hedenbro J L, Frederiksen S G. Fully stapled gastric bypass with isolated pouch and terminal anastomosis: 1-3 year results. Obes Surg. 2002;12(4):546-50. [pmid: 12194549].
Notes: Quality Reviewed for Surgery Analyses.
Hess D S, Hess D W. Biliopancreatic diversion with a duodenal switch. Obes Surg. 1998;8(3):267-82. [pmid: 9678194].
Notes: Quality Reviewed for Surgery Analyses.
Hesse U J, Berrevoet F, Ceelen W, et al. [Adjustable silicone gastric banding (ASGB, Bioenterics) and the Swedish adjustable gastric banding (SAGB, Obtech) in treatment of morbid obesity]: <Original> Das anpassbare Silicon Gastric Banding (ASGB, Bioenterics) und das Schwedische anpassbare Gastric Banding (SAGB, Obtech) zur Behandlung der morbiden Obesitas. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. 2001;72(1):14-8. [pmid: 11225451].
Notes: Quality Reviewed for Surgery Analyses.
Higa K D, Boone K B, Ho T. Complications of the laparoscopic Roux-en-Y gastric bypass: 1,040 patients--what have we learned?. Obes Surg. 2000;10(6):509-13. [pmid: 11175957].
Notes: Quality Reviewed for Surgery Analyses.
Higa KD, Boone KB, Ho T, et al. Laparoscopic Roux-en-Y gastric bypass for morbid obesity: technique and preliminary results of our first 400 patients. Arch Surg 2000;135(9):1029–33; discussion 1033–4.
Notes: Quality Reviewed for Surgery Analyses.
Higa K D, Ho T, Boone K B. Internal hernias after laparoscopic Roux-en-Y gastric bypass: incidence, treatment and prevention. Obes Surg. 2003;13(3):350-4. [pmid: 12841892].
Notes: Reports complications, considered for surgery analysis.
Hill J O, Hauptman J, Anderson J W, et al. Orlistat, a lipase inhibitor, for weight maintenance after conventional dieting: a 1-y study. Am J Clin Nutr. 1999;69(6):1108-16. [pmid: 10357727].
Notes: Quality Reviewed for Medication Analyses.
Holeczy P, Novak P, Kralova A. Complications in the first year of laparoscopic gastric banding: is it acceptable?. Obes Surg. 1999;9(5):453-5. [pmid: 10605902].
Notes: Reports complications, considered for surgery analysis.
Hollander P A, Elbein S C, Hirsch I B, et al. Role of orlistat in the treatment of obese patients with type 2 diabetes. A 1-year randomized double-blind study. Diabetes Care. 1998;21(8):1288-94. [pmid: 9702435].
Notes: Quality Reviewed for Medication Analyses.
Horchner R, Tuinebreijer W. Improvement of physical functioning of morbidly obese patients who have undergone a Lap-Band operation: one-year study. Obes Surg. 1999;9(4):399-402. [pmid: 10484301].
Notes: Quality Reviewed for Surgery Analyses.
Howard L, Malone M, Michalek A, et al. Gastric Bypass and Vertical Banded Gastroplasty- a Prospective Randomized Comparison and 5-Year Follow-up. Obes Surg. 1995;5(1):55-60. [pmid: 10733794].
Notes: Quality Reviewed for Surgery Analyses.
Jain A K, Kaplan R A, Gadde K M, et al. Bupropion SR vs. placebo for weight loss in obese patients with depressive symptoms. Obes Res. 2002;10(10):1049-56. [pmid: 12376586].
Notes: Quality Reviewed for Medication Analyses.
James W P, Avenell A, Broom J, et al. A one-year trial to assess the value of orlistat in the management of obesity. Int J Obes Relat Metab Disord. 1997;21(Suppl 3):S24-30. [pmid: 9426390].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Kalfarentzos F, Dimakopoulos A, Kehagias I, et al. Vertical banded gastroplasty versus standard or distal Roux-en-Y gastric bypass based on specific selection criteria in the morbidly obese: preliminary results. Obes Surg. 1999;9(5):433-42. [pmid: 10605899].
Notes: Quality Reviewed for Surgery Analyses.
Karason K, Lindroos A K, Stenlof K, et al. Relief of cardiorespiratory symptoms and increased physical activity after surgically induced weight loss: results from the Swedish Obese Subjects study. Arch Intern Med. 2000;160(12):1797-802. [pmid: 10871973].
Notes: Quality Reviewed for Surgery Analyses.
Karason K, Molgaard H, Wikstrand J, et al. Heart rate variability in obesity and the effect of weight loss. Am J Cardiol. 1999;83(8):1242-7. [pmid: 10215292].
Notes: Quality Reviewed for Surgery Analyses.
Karason K, Wallentin I, Larsson B, et al. Effects of obesity and weight loss on left ventricular mass and relative wall thickness: survey and intervention study. BMJ. 1997;315(7113):912-6. [pmid: 9361540]. [pmcid: 2127625].
Notes: Quality Reviewed for Surgery Analyses.
Karason K, Wikstrand J, Sjostrom L, et al. Weight loss and progression of early atherosclerosis in the carotid artery: a four-year controlled study of obese subjects. Int J Obes Relat Metab Disord. 1999;23(9):948-56. [pmid: 10490801].
Notes: Quality Reviewed for Surgery Analyses.
Karhunen L, Franssila-Kallunki A, Rissanen P, et al. Effect of orlistat treatment on body composition and resting energy expenditure during a two-year weight-reduction programme in obese Finns. Int J Obes Relat Metab Disord. 2000;24(12):1567-72. [pmid: 11126207].
Notes: Quality Reviewed for Medication Analyses.
Karlsson J, Sjostrom L, Sullivan M. Swedish obese subjects (SOS)--an intervention study of obesity. Two-year follow-up of health-related quality of life (HRQL) and eating behavior after gastric surgery for severe obesity. Int J Obes Relat Metab Disord. 1998;22(2):113-26. [pmid: 9504319].
Notes: Quality Reviewed for Surgery Analyses.
Kelley D. A one-year study of weight loss and glycaemic control in type II diabetics following orlistat (xenicalTM) treatment. Obesity Research. 1997;5(Suppl 1):21. [pmid: 9467676].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Kelley D E, Bray G A, Pi-Sunyer F X, et al. Clinical efficacy of orlistat therapy in overweight and obese patientswith insulin-treated type 2 diabetes: a 1-year randomized controlledtrial. Diabetes Care. 2002;25(6):1033-1041. [pmid: 12032111].
Notes: Quality Reviewed for Medication Analyses.
Kim C H, Sarr M G. Severe reflux esophagitis after vertical banded gastroplasty for treatment of morbid obesity. Mayo Clin Proc. 1992;67(1):33-5. [pmid: 1732688].
Notes: Quality Reviewed for Surgery Analyses.
Kothari S N, DeMaria E J, Sugerman H J, et al. Lap-band failures: conversion to gastric bypass and their preliminary outcomes. Surgery. 2002;131(6):625-9. [pmid: 12075174].
Notes: Quality Reviewed for Surgery Analyses.
Krempf M, Louvet J P, Allanic H, et al. Weight reduction and long-term maintenance after 18 months treatment with orlistat for obesity. Int J Obes Relat Metab Disord. 2003;27(5):591-7. [pmid: 12704403].
Notes: Quality Reviewed for Medication Analyses.
Krempf Michel, Louvet Jean-Pierre, Allanic Hubert, et al. Orlistat associated with a hypocaloric diet in obese patients promotes and maintains weight loss during an 18-month period. Diabetes. 2001;50(Supplement 2):A21. [pmid: 11723075].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Laws H L, Piantadosi S. Superior gastric reduction procedure for morbid obesity: a prospective, randomized trial. Ann Surg. 1981;193(3):334-40. [pmid: 7212793]. [pmcid: 1345071].
Notes: Quality Reviewed for Surgery Analyses.
Lechner G W, Elliott D W. Comparison of weight loss after gastric exclusion and partitioning. Arch Surg. 1983;118(6):685-92. [pmid: 6847362].
Notes: Quality Reviewed for Surgery Analyses.
Lechner G W, Callender A K. Subtotal gastric exclusion and gastric partitioning: a randomized prospective comparison of one hundred patients. Surgery. 1981;90(4):637-44. [pmid: 7025315].
Notes: Quality Reviewed for Surgery Analyses.
Letiexhe M R, Scheen A J, Gerard P L, et al. Post-gastroplasty recovery of ideal body weight normalizes glucose and insulin metabolism in obese women. J Clin Endocrinol Metab. 1995;80:334-369. [pmid: 7852491].
Notes: Quality Reviewed for Surgery Analyses.
Lindgarde F. The effect of orlistat on body weight and coronary heart disease risk profile in obese patients: the Swedish Multimorbidity Study. J Intern Med. 2000;248(3):245-54. [pmid: 10971792].
Notes: Quality Reviewed for Medication Analyses.
Lindgarde F. Orlistat improves coronary heart disease in high-risk obese population: The Swedish Multimorbidity Study. Obesity Research 1999;(7):70.
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Lucas C P, Boldrin M N, Reaven G M. Effect of orlistat added to diet (30% of calories from fat) on plasma lipids, glucose, and insulin in obese patients with hypercholesterolemia. Am J Cardiol. 2003;91(8):961-4. [pmid: 12686336].
Notes: Quality Reviewed for Medication Analyses.
Lujan J A, Hernandez Q, Frutos M D, et al. Laparoscopic gastric bypass in the treatment of morbid obesity. Preliminary results of a new technique. Surg Endosc. 2002;16(12):1658-62. [pmid: 12140634].
Notes: Quality Reviewed for Surgery Analyses.
Lundell L, Forssell H, Jensen J, et al. Measurement of pouch volume and stoma diameter after gastroplasty. Int J Obes. 1987;11(2):169-74. [pmid: 3610469].
Notes: Quality Reviewed for Surgery Analyses.
Lundell L, Ruth M, Olbe L. Vertical banded gastroplasty or gastric banding for morbid obesity: effects on gastro-oesophageal reflux. Eur J Surg. 1997;163(7):525-31. [pmid: 9248987].
Notes: Quality Reviewed for Surgery Analyses.
MacLean L, Rhode B. Does Genetic Predisposition Influence Surgical Results of Operations for Obesity?. Obes Surg. 1996;6(2):132-137. [pmid: 10729853].
Notes: Quality Reviewed for Surgery Analyses.
MacLean L D, Rhode B M, Forse R A. Late results of vertical banded gastroplasty for morbid and super obesity. Surgery. 1990;107(1):20-7. [pmid: 2296754].
Notes: Quality Reviewed for Surgery Analyses.
MacLean L D, Rhode B M, Nohr C W. Late outcome of isolated gastric bypass. Ann Surg. 2000;231(4):524-8. [pmid: 10749613]. [pmcid: 1421028].
Notes: Quality Reviewed for Surgery Analyses.
MacLean LD, Rhode BM, Sampalis J, et al. Results of the surgical treatment of obesity. Am J Surg 1993;165(1):155–60; discussion 160–2.
Notes: Quality Reviewed for Surgery Analyses.
Marceau P, Biron S, Bourque R A, et al. Biliopancreatic Diversion with a New Type of Gastrectomy. Obes Surg. 1993;3(1):29-35. [pmid: 10757900].
Notes: Quality Reviewed for Surgery Analyses.
Marcus M D, Wing R R, Ewing L, et al. A double-blind, placebo-controlled trial of fluoxetine plus behavior modification in the treatment of obese binge-eaters and non-binge- eaters. Am J Psychiatry. 1990;147(7):876-81. [pmid: 2192563].
Notes: Quality Reviewed for Medication Analyses.
Marshall JS, Srivastava A, Gupta SK, et al. Roux-en-Y gastric bypass leak complications. Arch Surg 2003;138(5):520–3; discussion 523–4.
Notes: Reports complications, considered for surgery analysis.
Mason E E. Vertical banded gastroplasty for obesity. Arch Surg. 1982;117(5):701-6. [pmid: 7073493].
Notes: Quality Reviewed for Surgery Analyses.
Mason E E, Doherty C, Cullen J J, et al. Vertical gastroplasty: evolution of vertical banded gastroplasty. World J Surg. 1998;22(9):919-24. [pmid: 9717417].
Notes: Quality Reviewed for Surgery Analyses.
Matthews B D, Sing R F, DeLegge M H, et al. Initial results with a stapled gastrojejunostomy for the laparoscopic isolated roux-en-Y gastric bypass. Am J Surg. 2000;179(6):476-81. [pmid: 11004334].
Notes: Quality Reviewed for Surgery Analyses.
Melissas J, Christodoulakis M, Spyridakis M, et al. Disorders associated with clinically severe obesity: significant improvement after surgical weight reduction. South Med J. 1998;91(12):1143-8. [pmid: 9853727].
Notes: Quality Reviewed for Surgery Analyses.
Mendoza Espejo R, Diaz Perez de Madrid J, Buitrago F. [Effectiveness of serotonergic agonists in the treatment of obese patients]. Aten Primaria. 1995;16(6):364-6. [pmid: 7488690].
Notes: Quality Reviewed for Medication Analyses.
Michelson D, Amsterdam JD, Kim Y, Sundell K. Changes in weight during a one-year trial with fluoxetine. 152nd Annual Meeting of the American Psychiatric Association. May 15th - 20th, 1999; Washington, DC, USA. 1999.
Micic D, Ivkovic-Lazar T, Dragojevic R, et al. Orlistat, a gastrointestinal lipase inhibitor, in therapy of obesity with concomitant hyperlipidemia. Med Pregl. 1999;52(910):323-33. [pmid: 10624380].
Notes: Quality Reviewed for Medication Analyses.
Miles J M, Leiter L, Hollander P, et al. Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes Care. 2002;25(7):1123-8. [pmid: 12087008].
Notes: Quality Reviewed for Medication Analyses.
Miller K, Hell E. Laparoscopic adjustable gastric banding: a prospective 4-year follow-up study. Obes Surg. 1999;9(2):183-7. [pmid: 10340775].
Notes: Quality Reviewed for Surgery Analyses.
Mitchell J E, Lancaster K L, Burgard M A, et al. Long-term follow-up of patients' status after gastric bypass. Obes Surg. 2001;11(4):464-8. [pmid: 11501356].
Notes: Quality Reviewed for Surgery Analyses.
Mittermair R P, Weiss H, Nehoda H, et al. Laparoscopic Swedish adjustable gastric banding: 6-year follow-up and comparison to other laparoscopic bariatric procedures. Obes Surg. 2003;13(3):412-7. [pmid: 12841903].
Notes: Quality Reviewed for Surgery Analyses.
Morino M, Toppino M, Bonnet G, et al. Laproscopic adjustable silicone gastric banding versus vertical banded gastroplasy in morbidly obese patients. Ann Surg. 2003;238(6):835-842. [pmid: 14631220]. [pmcid: 1356165].
Notes: Quality Reviewed for Surgery Analyses.
Muls E, Kolanowski J, Scheen A, et al. The effects of orlistat on weight and on serum lipids in obese patients with hypercholesterolemia: a randomized, double-blind, placebo-controlled, multicentre study. Int J Obes Relat Metab Disord. 2001;25(11):1713-21. [pmid: 11753595].
Notes: Quality Reviewed for Medication Analyses.
Narbro K, Agren G, Jonsson E, et al. Sick leave and disability pension before and after treatment for obesity: a report from the Swedish Obese Subjects (SOS) study. Int J Obes Relat Metab Disord. 1999;23(6):619-24. [pmid: 10411235].
Notes: Quality Reviewed for Surgery Analyses.
Naslund I. Gastric bypass versus gastroplasty. A prospective study of differences in two surgical procedures for morbid obesity. Acta Chir Scand Suppl. 1987;536:1-60. [pmid: 3475886].
Notes: Quality Reviewed for Surgery Analyses.
Naslund I. The size of the gastric outlet and the outcome of surgery for obesity. Acta Chir Scand. 1986;152:205-10. [pmid: 3716740].
Notes: Quality Reviewed for Surgery Analyses.
Naslund I, Beckman K W. Gastric emptying rate after gastric bypass and gastroplasty. Scand J Gastroenterol. 1987;22( 2):193-201. [pmid: 11659033].
Notes: Quality Reviewed for Surgery Analyses.
Naslund I, Hallgren P, Sjostrom L. Fat cell weight and number before and after gastric surgery for morbid obesity in women. Int J Obes. 1988;12(3):191-7. [pmid: 3391735].
Notes: Quality Reviewed for Surgery Analyses.
Naslund I, Jarnmark I, Andersson H. Dietary intake before and after gastric bypass and gastroplasty for morbid obesity in women. Int J Obes. 1988;12(6):503-13. [pmid: 3069767].
Notes: Quality Reviewed for Surgery Analyses.
Naslund I, Wickbom G, Christoffersson E, et al. A prospective randomized comparison of gastric bypass and gastroplasty. Complications and early results. Acta Chir Scand. 1986;152:681-9. [pmid: 3551425].
Notes: Quality Reviewed for Surgery Analyses.
Naumov V G, Lupanov V P, Dotsenko Iu V, et al. [Six-month xenical (orlistat) therapy of patients with stable angina pectoris concomitant with obesity and hyperlipidemia]. Ter Arkh. 2002;74(1):47-51. [pmid: 11878059].
Notes: Quality Reviewed for Medication Analyses.
Nguyen NT, Goldman C, Rosenquist CJ, et al. Laparoscopic versus open gastric bypass: a randomized study of outcomes, quality of life, and costs. Ann Surg 2001;234(3):279–89; discussion 289–91.
Notes: Quality Reviewed for Surgery Analyses.
Nguyen NT, Ho HS, Palmer LS, et al. A comparison study of laparoscopic versus open gastric bypass for morbid obesity. J Am Coll Surg 2000;191(2):149–55; discussion 155–7.
Notes: Quality Reviewed for Surgery Analyses.
Nguyen NT, Lee SL, Goldman C, et al. Comparison of pulmonary function and postoperative pain after laparoscopic versus open gastric bypass: a randomized trial. J Am Coll Surg 2001;192(4):469–76; discussion 476–7.
Notes: Reports complications, considered for surgery analysis.
Nguyen N T, Rivers R, Wolfe B M. Factors associated with operative outcomes in laparoscopic gastric bypass. J Am Coll Surg. 2003;197:548-557. [pmid: 14522321].
Notes: Reports complications, considered for surgery analysis.
Nilsell K, Thorne A, Sjostedt S, et al. Prospective randomised comparison of adjustable gastric banding and vertical banded gastroplasty for morbid obesity. Eur J Surg. 2001;167(7):504-9. [pmid: 11560385].
Notes: Quality Reviewed for Surgery Analyses.
Nowara H A. Egyptian experience in laparoscopic adjustable gastric banding (technique, complications and intermediate results). Obes Surg. 2001;11(1):70-5. [pmid: 11361172].
Notes: Quality Reviewed for Surgery Analyses.
O'Brien P E, Dixon J B, Brown W, et al. The laparoscopic adjustable gastric band (Lap-Band): a prospective study of medium-term effects on weight, health and quality of life. Obes Surg. 2002;12(5):652-60. [pmid: 12448387].
Notes: Quality Reviewed for Surgery Analyses.
O'Brien P E, Brown W A, Smith A, et al. Prospective study of a laparoscopically placed, adjustable gastric band in the treatment of morbid obesity. Br J Surg. 1999;86(1):113-8. [pmid: 10027373].
Notes: Quality Reviewed for Surgery Analyses.
O'Kane M, Wiles P G, Wales J K. Fluoxetine in the treatment of obese type 2 diabetic patients. Diabet Med. 1994;11(1):105-10. [pmid: 8181239].
Notes: Quality Reviewed for Medication Analyses.
Oh CH, Kim HJ, Oh S. Weight loss following transected gastric bypass with proximal Roux-en-Y. Obes Surg 1997;7(2):142–7; discussion 148.
Notes: Quality Reviewed for Surgery Analyses.
Olbers T, Lonroth H, Fagevik-Olsen M, et al. Laparoscopic gastric bypass: development of technique, respiratory function, and long-term outcome. Obes Surg. 2003;13(3):364-70. [pmid: 12841895].
Notes: Quality Reviewed for Surgery Analyses.
Papakonstantinou A, Alfaras P, Komessidou V, et al. Gastrointestinal complications after vertical banded gastroplasty. Obes Surg. 1998;8(2):215-7. [pmid: 9730397].
Notes: Reports complications, considered for surgery analysis.
Papasavas P K, Hayetian F D, Caushaj P F, et al. Outcome analysis of laparoscopic Roux-en-Y gastric bypass for morbid obesity. The first 116 cases. Surg Endosc. 2002;16(12):1653-7. [pmid: 12239643].
Notes: Quality Reviewed for Surgery Analyses.
Peace K, Dyne J, Russell G, et al. Psychobiological effects of gastric restriction surgery for morbid obesity. N Z Med J. 1989;102(862):76-8. [pmid: 2919020].
Notes: Quality Reviewed for Surgery Analyses.
Pedrinola F, Sztejnsznajd C, Lima N, et al. The addition of dexfenfluramine to fluoxetine in the treatment of obesity: a randomized clinical trial. Obes Res. 1996;4(6):549-54. [pmid: 8946439].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Perugini RA, Mason R, Czerniach DR, et al. Predictors of complication and suboptimal weight loss after laparoscopic Roux-en-Y gastric bypass: a series of 188 patients. Arch Surg 2003;138(5):541–5; discussion 545–6.
Notes: Quality Reviewed for Surgery Analyses.
Pontiroli A E, Pizzocri P, Librenti M C, et al. Laparoscopic adjustable gastric banding for the treatment of morbid (grade 3) obesity and its metabolic complications: a three-year study. J Clin Endocrinol Metab. 2002;87(8):3555-61. [pmid: 12161474].
Notes: Quality Reviewed for Surgery Analyses.
Pories W J, Caro J F, Flickinger E G, et al. The control of diabetes mellitus (NIDDM) in the morbidly obese with the Greenville Gastric Bypass. Ann Surg. 1987;206(3):316-23. [pmid: 3632094]. [pmcid: 1493167].
Notes: Quality Reviewed for Surgery Analyses.
Pories W J, Flickinger E G, Meelheim D, et al. The effectiveness of gastric bypass over gastric partition in morbid obesity: consequence of distal gastric and duodenal exclusion. Ann Surg. 1982;196(4):389-99. [pmid: 7125726]. [pmcid: 1352695].
Notes: Quality Reviewed for Surgery Analyses.
Pud'homme D, Firchet M, Almeras N, Dumont M, Tremblay A, Despres JP. Six-month Topiramate treatment reduces body weight and blood pressure. Presented at the North American Association for the Study of Obesity 2003 Annual Scientific Meeting. 2003 (Abstract)
Notes: Quality Reviewed for Medication Analyses.
Quaade F. Jjunoileal bypass for morbid obesity. A bibliographic study and a randomized clinical trial. Surgical clinics of North America. 1979;59(6):1055-69. [pmid: 394374].
Notes: Quality Reviewed for Surgery Analyses.
Rand C S, Macgregor A M. Adolescents having obesity surgery: a 6-year follow-up. South Med J. 1994;87(12):1208-13. [pmid: 7973919].
Notes: Quality Reviewed for Surgery Analyses.
Randolph J G, Weintraub W H, Rigg A. Jejunoileal bypass for morbid obesity in adolescents. J Pediatr Surg. 1974;9(3):341-5. [pmid: 4843988].
Notes: Quality Reviewed for Surgery Analyses.
Reaven G, Segal K, Hauptman J, et al. Effect of orlistat-assisted weight loss in decreasing coronary heart disease risk in patients with syndrome X. Am J Cardiol. 2001;87(7):827-31. [pmid: 11274935].
Notes: Quality Reviewed for Medication Analyses.
Reddy RM, Riker A, Marra D, et al. Open Roux-en-Y gastric bypass for the morbidly obese in the era of laparoscopy. Am J Surg 2002;184(6):611–5; discussion 615–6.
Notes: Quality Reviewed for Surgery Analyses.
Reinhold R B. Late results of gastric bypass surgery for morbid obesity. J Am Coll Nutr. 1994;13(4):326-31. [pmid: 7963136].
Notes: Quality Reviewed for Surgery Analyses.
Ricca Valdo, Mannucci Edoardo, Mezzani Barbara, et al. Fluoxetine and fluvoxamine combined with individual cognitive-behaviour therapy in binge eating disorder: A one-year follow-up study. Psychotherapy and Psychosomatics. 2001;70(6):298-306. [pmid: 11598429].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Rigg CA. Proceedings: Jejunoileal bypass by morbidly obese adolescent. Acta Paediatr Scand Suppl 1975;(256):62–4.
Notes: Quality Reviewed for Surgery Analyses.
Rissanen A, Wilding J, Van Gaal L, Vercruysse F, Perry B, Fitchet M. The effect of Topiramate on body weight and blood pressure in obese subjects: A long-term, randomized, placebo-controlled trial. Presented at the 18th Internation Diabetes Federation Congress. 2003 (Abstract)
Notes: Quality Reviewed for Medication Analyses.
Rissanen P, Vahtera E, Krusius T, et al. Weight change and blood coagulability and fibrinolysis in healthy obese women. Int J Obes Relat Metab Disord. 2001;25(2):212-8. [pmid: 11410822].
Notes: Quality Reviewed for Medication Analyses.
Rosenfalck A M, Hendel H, Rasmussen M H, et al. Minor long-term changes in weight have beneficial effects on insulin sensitivity and beta-cell function in obese subjects. Diabetes Obes Metab. 2002;4(1):19-28. [pmid: 11890163].
Notes: Quality Reviewed for Medication Analyses.
Rossner S, Sjostrom L, Noack R, et al. Weight loss, weight maintenance, and improved cardiovascular risk factors after 2 years treatment with orlistat for obesity. European Orlistat Obesity Study Group. Obes Res. 2000;8(1):49-61. [pmid: 10678259].
Notes: Quality Reviewed for Medication Analyses.
Samuelsson L, Gottsater A, Lindgarde F. Decreasing levels of tumour necrosis factor alpha and interleukin 6 during lowering of body mass index with orlistat or placebo in obese subjects with cardiovascular risk factors. Diabetes Obes Metab. 2003;5(3):195-201. [pmid: 12681027].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Schauer P R, Ikramuddin S, Gourash W, et al. Outcomes after laparoscopic Roux-en-Y gastric bypass for morbid obesity. Ann Surg. 2000;232(4):515-29. [pmid: 10998650]. [pmcid: 1421184].
Notes: Quality Reviewed for Surgery Analyses.
Scheen A J. [Info-congress. Prevention of type 2 diabetes in obese patients: first results with orlistat in the XENDOS study]. Rev Med Liege. 2002;57(9):617-21. [pmid: 12440353].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Scopinaro N, Gianetta E, Adami G F, et al. Biliopancreatic diversion for obesity at eighteen years. Surgery. 1996;119(3):261-8. [pmid: 8619180].
Notes: Quality Reviewed for Surgery Analyses.
Serrano-Rios Manuel, Armero Franciso, Genis Mar. Orlistat efficacy on weight loss in over-weight or obese patients with type 2 diabetes mellitus. Spanish randomized clinical trial. Diabetes. 2001;50(Supplement 2):A131. [pmid: 11723075].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Shi Yi Fan, Zhu Jun Ren. Effect of orlistat on weight loss and glycemic control in overweight Chinese patients with type 2 diabetes. Diabetes. 2001;50(Supplement 2):A101-A102. [pmid: 11723075].
Notes: Quality Reviewed for Medication Analyses.
Sjostrom C D, Lissner L, Wedel H, et al. Reduction in incidence of diabetes, hypertension and lipid disturbances after intentional weight loss induced by bariatric surgery: the SOS Intervention Study. Obes Res. 1999;7(5):477-84. [pmid: 10509605].
Notes: Quality Reviewed for Surgery Analyses.
Sjostrom C D, Peltonen M, Sjostrom L. Blood pressure and pulse pressure during long-term weight loss in the obese: the Swedish Obese Subjects (SOS) Intervention Study. Obes Res. 2001;9(3):188-95. [pmid: 11323444].
Notes: Quality Reviewed for Surgery Analyses.
Sjostrom C D, Peltonen M, Wedel H, et al. Differentiated long-term effects of intentional weight loss on diabetes and hypertension. Hypertension. 2000;36(1):20-5. [pmid: 10904007].
Notes: Quality Reviewed for Surgery Analyses.
Sjostrom L, Rissanen A, Andersen T, et al. [Randomized placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients]: <Original> Randomizirovannoe platsebo-kontroliruemoe issledovanie po primeneniiu orlistata dlia umen'sheniia massy tela i predotvrashcheniia ee povtornoi pribavki u lits s ozhireniem. Terapevticheskii arkhiv. 2000;72(8):50-4. [pmid: 11019429].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Sjostrom L, Rissanen A, Andersen T, et al. Randomised placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients. European Multicentre Orlistat Study Group. Lancet. 1998;352(9123):167-72. [pmid: 9683204].
Notes: Quality Reviewed for Medication Analyses.
Smith S C, Edwards C B, Goodman G N, et al. Open vs laproscopic Roux-en-Y gastric bypqass: comparison of operative morbidity and mortality. Obes Surg. 2004;14:73-76. [pmid: 14980037].
Notes: Quality Reviewed for Surgery Analyses.
Soper R T, Mason E E, Printen K J, et al. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. 1975;10(1):51-8. [pmid: 1117394].
Notes: Quality Reviewed for Surgery Analyses.
Stanford A, Glascock J M, Eid G M, et al. Laparoscopic Roux-en-Y gastric bypass in morbidly obese adolescents. J Pediatr Surg. 2003;38(3):430-3. [pmid: 12632362].
Notes: Quality Reviewed for Surgery Analyses.
Stenlof K, Rossner S, Vercruysse F, Perry B, Fitchet M, Sjostrom L. Safety and efficacy of Topiramate in the treatment of Type II diabetic obese subjects: A randomized, double-blind, placebo-controlled trial. Presented at the 18th International Diabetes Federation Congress. 2003 (Abstract)
Notes: Quality Reviewed for Medication Analyses.
Stenlof K, Rossner S, Vercruysse F, Perry B, Fitchet M, Sjostrom L. Topiramate decreases weight and blood pressure in obese subjects with Type II diabetes. Presented at the North American Association of the Study of Obesity 2003 Annual Scientific Meeting. 2003 (Abstract)
Notes: Quality Reviewed for Medication Analyses.
Stoner J, Stoner P, Sytsma J. 42-month preliminary follow-up of the silastic ring vertical banded gastroplasty. Obes Surg. 1997;7(6):513-5. [pmid: 9730510].
Notes: Quality Reviewed for Surgery Analyses.
Strauss R S, Bradley L J, Brolin R E. Gastric bypass surgery in adolescents with morbid obesity. J Pediatr. 2001;138(4):499-504. [pmid: 11295712].
Notes: Quality Reviewed for Surgery Analyses.
Sugerman H J, Kellum J M Jr, DeMaria E J, et al. Conversion of failed or complicated vertical banded gastroplasty to gastric bypass in morbid obesity. Am J Surg. 1996;171(2):263-9. [pmid: 8619465].
Notes: Quality Reviewed for Surgery Analyses.
Sugerman H J, Londrey G L, Kellum J M, et al. Weight loss with vertical banded gastroplasty and Roux-Y gastric bypass for morbid obesity with selective versus random assignment. Am J Surg. 1989;157(1):93-102. [pmid: 2910132].
Notes: Quality Reviewed for Surgery Analyses.
Sugerman H J, Starkey J V, Birkenhauer R. A randomized prospective trial of gastric bypass versus vertical banded gastroplasty for morbid obesity and their effects on sweets versus non- sweets eaters. Ann Surg. 1987;205(6):613-24. [pmid: 3296971]. [pmcid: 1493086].
Notes: Quality Reviewed for Surgery Analyses.
Sugerman HJ, Sugerman EL, DeMaria EJ, et al. Bariatric surgery for severely obese adolescents. J Gastrointest Surg 2003;7(1):102–7; discussion 107–8.
Notes: Quality Reviewed for Surgery Analyses.
Suter M, Bettschart V, Giusti V, et al. A 3-year experience with laparoscopic gastric banding for obesity. Surg Endosc. 2000;14(6):532-6. [pmid: 10890959].
Notes: Quality Reviewed for Surgery Analyses.
Suter M, Giusti V, Heraief E, et al. Early results of laparoscopic gastric banding compared with open vertical banded gastroplasty. Obes Surg. 1999;9(4):374-80. [pmid: 10484296].
Notes: Quality Reviewed for Surgery Analyses.
Suter M, Giusti V, Heraief E, et al. Laparoscopic Roux-en-Y gastric bypass: initial 2-year experience. Surg Endosc. 2003;17(4):603-9. [pmid: 12582767].
Notes: Quality Reviewed for Surgery Analyses.
Szold A, Abu-Abeid S. Laparoscopic adjustable silicone gastric banding for morbid obesity: results and complications in 715 patients. Surg Endosc. 2002;16(2):230-3. [pmid: 11967669].
Notes: Quality Reviewed for Surgery Analyses.
Tacchino R M, Mancini A, Perrelli M, et al. Body composition and energy expenditure: relationship and changes in obese subjects before and after biliopancreatic diversion. Metabolism. 2003;52(5):552-8. [pmid: 12759883].
Notes: Quality Reviewed for Surgery Analyses.
The Danish Obesity Project. Randomised trial of jejunoileal bypass versus medical treatment in morbid obesity. Lancet 1979;2(8155):1255–8.
Notes: Quality Reviewed for Surgery Analyses.
Tonstad S, Levy B, Perry B, Fitchet M. Topiramate decreases weight and lowers blood pressure in obese subjects with hypertension. Presented at the North American Association for the Study of Obesity 2003 Annual Scientific Meeting. 2003 (Abstract)
Notes: Quality Reviewed for Medication Analyses.
Toornvliet A C, Pijl H, Frolich M, et al. Insulin and leptin concentrations in obese humans during long-term weight loss. Neth J Med. 1997;51(3):96-102. [pmid: 9360409].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Toppino M, Morino M, Bonnet G, et al. Laparoscopic surgery for morbid obesity: preliminary results from SICE registry (Italian Society of Endoscopic and Minimally Invasive Surgery). Obes Surg. 1999;9(1):62-5. [pmid: 10065587].
Notes: Quality Reviewed for Surgery Analyses.
Toppino M, Morino M, Capuzzi P, et al. Outcome of vertical banded gastroplasty. Obes Surg. 1999;9(1):51-4. [pmid: 10065583].
Notes: Quality Reviewed for Surgery Analyses.
Torgerson J S, Sjostrom L. The Swedish Obese Subjects (SOS) study--rationale and results. Int J Obes Relat Metab Disord. 2001;25 Suppl 1:S2-4. [pmid: 11466577].
Notes: Quality Reviewed for Surgery Analyses.
van de Weijgert E J, Ruseler C H, Elte J W. Long-term follow-up after gastric surgery for morbid obesity: preoperative weight loss improves the long-term control of morbid obesity after vertical banded gastroplasty. Obes Surg. 1999;9(5):426-32. [pmid: 10605898].
Notes: Quality Reviewed for Surgery Analyses.
Van Gaal L, Mertens I, Peiffer F, et al. Effect of weight loss treatment with Orlistat on blood pressure and heart rate among obese patients. Obesity Research. 1999;7(Suppl 1):69. [pmid: 10590785].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
Van Gaal L F, Broom J I, Enzi G, et al. Efficacy and tolerability of orlistat in the treatment of obesity: a 6- month dose-ranging study. Orlistat Dose-Ranging Study Group. Eur J Clin Pharmacol. 1998;54(2):125-32. [pmid: 9626916].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.
van Gemert W G, Adang E M, Greve J W, et al. Quality of life assessment of morbidly obese patients: effect of weight- reducing surgery. Am J Clin Nutr. 1998;67(2):197-201. [pmid: 9459366].
Notes: Quality Reviewed for Surgery Analyses.
Van Rij A M. Gastric bypass and gstric partitioning in morbid obesity: results of a controlled trial. Aus NZ J Med. 1984;14(3 suppl 1):340.
Notes: Quality Reviewed for Surgery Analyses.
VanWoert J, Michalek A, Alger S, et al. A prospective randomized trial (PRT) of gastric bypass (GB) versus vertical banded gatroplasty (VBG) for morbid obesity (MO). Clinical Research. 1992;40(2):A642.
Notes: Quality Reviewed for Surgery Analyses.
Viddal K O. Intestinal bypass. A randomized, prospective clinical study of end-to- side and end-to-end jejunoileal bypass. Scand J Gastroenterol. 1983;18(5):627-34. [pmid: 6675183].
Notes: Quality Reviewed for Surgery Analyses.
Vidgren H M, Agren J J, Valve R S, et al. The effect of orlistat on the fatty acid composition of serum lipid fractions in obese subjects. Clin Pharmacol Ther. 1999;66(3):315-22. [pmid: 10511068].
Notes: Quality Reviewed for Medication Analyses.
Wadden T A, Bartlett S J, Foster G D, et al. Sertraline and relapse prevention training following treatment by very- low-calorie diet: a controlled clinical trial. Obes Res. 1995;3(6):549-57. [pmid: 8653531].
Notes: Quality Reviewed for Medication Analyses.
Weiner R, Blanco-Engert R, Weiner S, et al. Outcome after laparoscopic adjustable gastric banding - 8 years experience. Obes Surg. 2003;13(3):427-34. [pmid: 12841906].
Notes: Quality Reviewed for Surgery Analyses.
Weiner R, Bockhorn H, Rosenthal R, et al. A prospective randomized trial of different laparoscopic gastric banding techniques for morbid obesity. Surgical endoscopy. 2001;15(1):63-8. [pmid: 11178766].
Notes: Quality Reviewed for Surgery Analyses.
Westling A, Gustavsson S. Laparoscopic vs open Roux-en-Y gastric bypass: a prospective, randomized trial. Obes Surg. 2001;11(3):284-92. [pmid: 11433902].
Notes: Quality Reviewed for Surgery Analyses.
White J J, Cheek D, Haller J A Jr. Small bowel bypass is applicable for adolescents with morbid obesity. Am Surg. 1974;40(12):704-8. [pmid: 4429281].
Notes: Quality Reviewed for Surgery Analyses.
Wiesner W, Schob O, Hauser R S, et al. Adjustable laparoscopic gastric banding in patients with morbid obesity: radiographic management, results, and postoperative complications. Radiology. 2000;216(2):389-94. [pmid: 10924559].
Notes: Quality Reviewed for Surgery Analyses.
Wittgrove A C, Clark G W. Laparoscopic gastric bypass, Roux-en-Y- 500 patients: technique and results, with 3–60 month follow-up. Obes Surg. 2000;10(3):233-9. [pmid: 10929154].
Notes: Quality Reviewed for Surgery Analyses.
Yale C E. Gastric surgery for morbid obesity. Complications and long-term weight control. Arch Surg. 1989;124(8):941-6. [pmid: 2757508].
Notes: Quality Reviewed for Surgery Analyses.
Yale C E, Weiler S J. Weight control after vertical banded gastroplasty for morbid obesity. Am J Surg. 1991;162(1):13-8. [pmid: 2063963].
Notes: Quality Reviewed for Surgery Analyses.
Yashkov YI, Timoshin AD, Oppel TA. Vertical banded gastroplasty: first experience in Russia. Obes Surg 1997;7(4):317–20; discussion 321.
Notes: Quality Reviewed for Surgery Analyses.
Zavoral J H. Treatment with orlistat reduces cardiovascular risk in obese patients. J Hypertens. 1998;16(12 Pt 2):2013-7. [pmid: 9886906].
Notes: Quality Reviewed for Medication Analyses. Excluded at meta-analysis.