# Appendix E: TEP and Peer Review Comments

Obesity Peer and TEP Review
Section | Reviewer's Comments | | | | | | | Author's Response to Comments
General comment | I have reviewed this document very carefully. I think you did a really good job with this review. It is very difficult to find anything to add or to critique. The only minor point is that you conclude that the medications produce a clinically significant weight loss yet you don't really talk about what clinically significant means. Those in the area know this means reductions in CVD and diabetes risk factors, but it might be useful to include this information, either in the individual reviews of the medications or at least in the conclusions. | | | | | | | We have noted this in the introduction.
General comment | This is a rigorous and helpful summary of the available evidence. | | | | | | | No response necessary.
General comment | It would be important to re-emphasize later in the report that questions 3 and 4 were not sufficiently addressed in the majority of studies. | | | | | | | Appropriate change made.
General comment | Since I am not an expert in this topic (obesity), I was most concerned with the methods used to identify evidence and the presentation and usefulness of the results. It appears that a rigorous search was used to find relevant articles, and a careful methodology was employed to establish and enforce criteria for inclusion. | | | | | | | No response necessary.
General comment | Conclusions appear to be warranted by the outcomes of the report, and will be especially useful for organizations seeking to clarify the evidence for quality clinical practice, such as the American College of Physicians. I did not perceive any significant bias in your presentation or discussion. | | | | | | | No response necessary.
General comment | In the past year, I have reviewed a number of documents targeting obesity and overweight in adults. Several of the reports included similar methodologies to the ones used here but also included research that did not use medications. | | | | | | | No response necessary.
| When comparing the conclusions of this project (medical studies section) with those of other projects, the results are very similar and they are presented in an unbiased manner. I also think your reference/literature search was exhaustive and very complete.
General comment | p. 15–16 The text and tables should more consistently describe the types of patients enrolled e.g., avg. BMI where available. | | | | | | | Appropriate change made.
General comment | The average weight losses in pharmacological clinical trials are not representative of the weight loss effectiveness observed by clinicians in individual obese patients for several reasons. | | | | | | | We have now included total weight loss for each pooled analysis and have added text to the limitations and future research regarding this point.
General comment | One potential biased statement is the recurrent mention that, “even modest weight loss may be clinically significant.” You reference the introduction later in the document, but there it is referring to weight loss that is substantially greater than recognized by use of pharmacologic treatment. | | | | | | | We disagree, and now note in the report that the total weight loss in the treated groups is above 5 kg, or more than 10 lbs and more than 5% of pretreatment weight loss, which is consistent with a reduction in cardiovascular risk factors. As other reviewers have noted, a very recent study that we could not include in our review, the XENDOS trial, demonstrates a reduction in diabetes in orlistat-treated patients. So we believe the weight loss numbers reported here can have significant health effects.
Introduction | It may be useful to state the inclusion criteria for drugs employed in this report. | | | | | | | This is done in the methods.
Introduction | Paragraph 2, line 2. This 19.8 figure comes from the BRFSS report and is “self-report” I would suggest you replace it with the NCHS data from Flegal, JAMA 2002 which is “measured” rather than “self-reported” data. | | | | | | | These comments all concern the introduction, which was extensively revised taking into account these comments.
Introduction | Paragraph 2, line 4, you say, “comparison is difficult because of changing definitions of obesity.” Since the NHLBI evidence report in 1998, there have been uniform definitions that were used by Flegal and by Mokdad in many reports. Clearly this sentence needs to be modified.
Introduction | Paragraph 4 line 5. Please insert “factors” after risk.
| “Weight loss of only 20 pounds can be associated with marked reductions in the risk of these chronic diseases.” I would suggest to present the weight loss in percentage because that is the universal way of expressing the amount of weight loss necessary to have some health benefits and/or reduce the incidence of chronic disease.
Introduction | You quote data from 1999 regarding the prevalence of pediatric obesity. The latest data from 2000 indicates that 10.4% of 2–5 year olds, 15.3% of 6–11 year olds and 15.5% are overweight. Ogden, CI et al. Prevalence and trends in overweight among US children and adolescents, 1999-2000. JAMA 2002;288;1728–1732.
Introduction | Discussion the health consequences of obesity, there is no mention of liver problems, i.e., non-alcoholic fatty liver disease (AFL). I think that this is a frequent and potentially serious complication and should also be mentioned. If you need references for this, the AGA has a technical and position paper regarding this. Likewise, I am not sure if you want to include psychological issues here, but that is felt to be the most common complication associated with pediatric obesity. (Dietz WH. Health consequences of obesity in youth: childhood predictors of adult disease. Pediatrics 101:S 518–525, 1998.
Introduction | The authors state, “although a precise comparison is difficult because of changing definitions of obesity.” This is incorrect. The studies by Mokdad AH and Flegal KM that were published by the CDC after 1998 using BRFSS and NHANES data have used a uniform definition of obesity that was adopted in 1998 by the NIH and WHO. This classification scheme is still in use today.
Introduction | The study by Flegal KM, Caroll, MD, et al. 2002. Prevalence and trends I obesity among US adults, 1999-2000. JAMA 288(14): 1723–7, used NHANES data (which used measured height and weight). The Mokdad studies used BRFSS data (which used self-reported height and weight), which is an underestimate of obesity prevalence. The Flegal paper reports a prevalence of overweight of 64.5% in 1999-20002.
Introduction | Should have the diagram to help non-surgeons understand the anatomy of these surgeries.
Introduction | In the Introduction, is appropriate for the report and sets the tone of the analyses that follow. The first paragraph suggests obesity is due to the modern high fat diet. The components of the diet that lead to obesity are known. This should be amended. The definitions used for children were not compatible with CDC definitions. This should be amended (i.e., seriously overweight, does this refer to >95^th^ percentile of age and gender). Type II should be written as type 2. Isn't the WHO claim of > 300 million people with obesity inclusive of overweight and obese.
Introduction | Somewhere in the report you should briefly summarize the basic types of surgical interventions.
Methods | It would be a good idea to define what you mean by baseline, do you mean from randomization point, as the orlistat studies often took their baseline as the beginning of the run-in phase, i.e. before randomization. | | | | | | | Often times in the original article this was not clear, although most articles did not have a run-in phase.
Methods | A height of 5 feet and 4 inches needs more justification. | | | | | | | We now state that it makes little difference whether any height between 5 feet and 6 feet is chosen, and as about two-thirds of all participants are women, this range of height encompasses nearly all women, so it doesn't matter what height you pick.
Methods | You need to discuss why adverse events analysis for orlistat and fluoxetine only was carried out. | | | | | | | We now present a pooled adverse event analysis for bupropion and topiramate in addition to orlistat and fluoxetine and the existing adverse event meta-analysis on sibutramine.
Methods | The search picked up only 1,010 hits, of which only 325 were identified from the electronic searching. This seems astonishingly low, and the reason for this is the very limited search strategy that was employed. A “usual” systematic (Cochrane type) review search for this topic would probably identify 15,000 – 25,000 hits. In Appendix A, it would be useful to state the number of hits identified through electronic searching after de-duplication - I assume that this is 325 (as in Fig 1)? | | | | | | | We report the numbers as we encountered them and our yield in this report was typical for EPC reports.
Methods | Why did the authors not use the same search strategies as those employed by the research team who carried out the Aberdeen? The update searches (and the Aberdeen report) specifically exclude children in the search strategies. | | | | | | | Children were a focus in this report and that is why we did not replicate this strategy.
Methods | I would be interested to see the list of 11 articles that were requested but not found. | | | | | | | These are included in the “Excluded Studies” section and characterized as “not found.”
Methods | Second, was there a check against the studies included in the existing “recent” reviews and the articles identified in the update searches - there is no mention of this process in the text, and this would be helpful. | | | | | | | We have added this to the excluded list this was done. We term this “reference mining.”
Methods | For studies included in existing “recent” reviews that were used in this report, did the authors go back to the original papers and abstract data on outcomes and adverse events, or simply use the abstracted data in the existing reports. | | | | | | | We abstracted original data.
Methods | I suggest that it might be simpler to report the meta-analysis done by the authors of this report first, and then (if useful) compare these to those of existing “recent” reports. | | | | | | | Instead of this way to organize the drugs, we chose instead to present the results for FDA-approved drugs first, then non-FDA approved drugs.
Methods | Paragraph 3, Jadad quality score. I am unfamiliar with this, and it would help me to have a bit more description. | | | | | | | We have amplified a little bit on this.
Methods | Paragraph 3, line 3: Insert “said” after specifically. | | | | | | | Appropriate change was made.
Methods | Methods used were sound, and this section was well written. Assumptions made were explicit and the authors carefully considered whether any assumptions made might have altered their conclusions. The lack of pediatric and adolescent evidence could have been addressed in the Methods section, which tends to ignore this subgroup. | | | | | | | No response required.
Methods | I was a little unclear as to whether longer-term outcome evidence (beyond 12 months of treatment) was ineligible or simply very scarce. Outcome data to 12 months is a valuable end-point, but if there is a body of evidence with longer term outcome data (to 24 months for example) this would be informative. | | | | | | | It is scarce.
Methods | Within the 6 and 12-month periods of outcome reported, was treatment continuous for 6 and 12 months in all cases? Was there any attempt to analyze by studies sub-group in order to address the issue of weight loss vs. weight maintenance? I appreciate the complexity of this question, but feel that some statement as to whether the treatment effects summarized in this review are ‘weight loss on treatment’ as opposed to this plus ‘weight maintenance post-treatment’ would be helpful. | | | | | | | They are weight loss on treatment. Unfortunately, weight maintenance post-treatment data are exceedingly scarce.
Methods | The authors correctly point out the lack of evidence on differences in treatment by age/gender/race. There may also be differences by degree of initial obesity - was this variable considered for inclusion in the analysis? | | | | | | | No. In order to do this, we could only do it at the study level and the mean pretreatment BMI varied little in the drug studies. Therefore, there is not enough variance to have useful explanatory power. This would be possible if we had individual patient-level data, but we did not have the resources to request this from original authors.
Methods | I have reservations about how the authors handled heterogeneity among trials of orlistat and fluoxetine and how these results are presented. The authors state “there was significant heterogeneity among studies” of orlistat and fluoxetine at both 6 and 12 months. While the authors use the random effects model appropriately, explore potential reasons for heterogeneity, and present the results of these explorations in the text, the authors ultimately present the heterogeneous pooled effect estimates in the tables and figures. The authors do not go into enough detail about the implications of this heterogeneity for clinical practice - in other words, should we believe this estimate? | | | | | | | We now present sensitivity analyses exploring sources of heterogeneity.
Methods | “Extraction of Adverse Event Data.” As you mention, the fact that each event was counted as if it represented a unique individual, this assumption overestimates the number of people having an adverse event. I would prefer that the adverse event be documented based on the number of events and not be attributed to a unique individual. | | | | | | | It's not possible to do a meaningful analysis without the patient as the unit of analysis.
Methods | The use of a pooled OR for diarrhea may be inappropriate here because the prevalence of diarrhea in exposed individuals is so high. | | | | | | | We agree and have noted this as a limitation.
Methods | Is it too cumbersome to go back and sort out which of these RCT or CT's of pharmacologic agents examined the “goodness of randomization” in terms of the mean BMI's or their equivalents in the different treatment groups? Baseline BMI could be a confounder in subject compliance not only with the underlying dietary recommendation but also with medications. What would have been a desirable design would have been if they had used stratified randomization based on initial BMI and also gender. | | | | | | | Sorry we could not go back and do this.
Methods | It was not clear to me what proportion of the trials of pharmacologic agents also provided dietary counseling for reduced caloric intake for their study subjects and also used caloric intake as a covariate in their analysis. Perhaps, the effect size could be enhanced if the pharmacologic agents are viewed more as adjuvant therapy to caloric restriction. | | | | | | | We now state for each analysis we conducted what proportion of studies had these cointerventions.
Methods | In discussing the decision to drop the review of diet studies, you can cite the fact that the U.S. Preventive Services Task Force is about to publish a review of dietary counseling studies which covers much of this ground. I will forward the correct citation for this report. The reference will be Ann Intern Med. 2003;139(11):933–949. but I will forward the author and title. | | | | | | | We did not drop it for this reason, more because the vast number of studies and heterogeneity would make synthesizing the diet studies a real big job.
Methods | Meta-analysis - I am not sure the “number needed to harm” is necessarily the best way to communicate the absolute rate difference. Most readers don't have an intuitive sense of the meaning (e.g. lower numbers are worse) and it is directly dependent on the event rate in the control group, which might be more variable than we assume. I think it would be more transparent to present the control rate you estimate from the available studies and the calculated rate of side effects in treated patients based on the odds ratio. E.g. for diarrhea, instead of saying the NNH is 1.48 for diarrhea from orlistat, it might be more informative to say Control rate = 30%, treated rate = 97%. (I am guessing at numbers). It gives the reader a clearer sense of what to expect on treatment, even if not all events are directly attributable to treatment. | | | | | | | We are not sure we agree with this comment. The NNH is certainly used by others in the literature.
Methods | As I mentioned, I do not think NNH is particularly useful. If you retain it, I would drop the decimal points - it conveys an exaggerated sense of precision.
Methods | Given the significant heterogeneity, there should be greater discussion of the limitations of presenting a pooled estimate of effects. While recognizing the perils of post hoc analyses looking for sources of heterogeneity, given the consistency of the findings it might be useful to explore other possible sources of heterogeneity across the different medications - are there any common factors in the trials that produced the largest or smallest results with different medications. | | | | | | | We discussed this but did not have the time or resources to do this.
Methods | It would be useful to include start/end date of searches. It would be helpful to note (start of second paragraph on page vi) that the ‘published review on phentermine…’ was systematic. I would have preferred greater emphasis on research needs in the Abstract given the lack of evidence for many of the issues addressed. | | | | | | | These are noted now in the Methods section in the “Literature Search” section.
sibutramine | Perhaps you should state that you used this unpublished sibutramine review in preference to the published review by O'Meara for the HTA programme/NICE as it post-dated O'Meara: O'Meara S, Riemsma R, Shirran L, Mather L, ter Riet G. The clinical effectiveness and cost-effectiveness of sibutramine in the management of obesity: a technology assessment. Health Technol Assess 2002;6(6). | | | | | | | The sibutramine meta-analysis we used was more up to date, being published in 2004.
sibutramine | First, I am puzzled why the O'Meara review (HTA report) was not included. If it had then the authors could have avoided conducting any meta-analysis (except perhaps for fluoxetine).
sibutramine | Why was the HTA review on sibutramine by O'Meara (2002 vol 6 No 6) not included in this report? The authors clearly identified the other two HTA reports in this series; orlistat 2001 vol 5 No 18, surgery 2002 vol 6 No 12.
sibutramine | Last line-I thought that there was “weight” related decrease in lipids in the sibutramine studies | | | | | | | This meta-analysis did report a decrease in lipids with sibutramine treatment, but did not attribute it to weight loss or the drug.
sibutramine | Paragraph 2- There seems to be a discrepancy between numbers of studies. You indicate there are 28, and the in the next two paragraphs you site 11 and 21 studies. Can you please reconcile the differences? | | | | | | | Some studies reported both 6 and 12 month outcomes.
sibutramine | Is the 20–30% increase in achieving 5% weight loss absolute or relative? | | | | | | | We abstracted this from the original article, we think this it is relative.
sibutramine | Why aren't sibutramine and the other agents included in Table 1? | | | | | | | Table 1 only lists the adverse event descriptors we identified for the drugs for which we conducted meta-analysis. For sibutramine we relied on an existing meta-analysis.
sibutramine | More clearly state that the average weight loss with sibutramine was 4.5 kg OVER the weight loss achieved via placebo. | | | | | | | We have now added both the weight loss over placebo and the total weight loss for each of the pooled analysis we did.
sibutramine | In the case of sibutramine, the patients with hypertension appear early and can be ascertained by following blood pressure. There is also data suggesting that 8 weeks of treatment may be adequate to differentiate responders from non-responders. To prevent hypertension, there are clear methods for using a lower initial dose of 10 mg vs. 15 mg. in patients with pre-existing hypertension. For those patients who do not have this idiosyncratic reaction, the effects of sibutramine on blood pressure are mild with only an attenuation of the normally observed decrease in blood pressure that occurs with weight loss. | | | | | | | This comment is noted, but not incorporated into our report because our report summarizes an existing meta-analysis which does not make this point, and we did not systematically search for evidence regarding the temporal relationship of blood pressure response.
orlistat | This report does a good job of summarizing the current state of the evidence for screening and treatment of obesity. Its methodological rigor and detail surpass the earlier, now outdated reviews of this topic. | | | | | | | No response necessary.
orlistat | The literature search did identify, but the text does not discuss the preliminary results of an important RCT of orlistat (Scheen, AJ 2002. [Info-congress. Prevention of type 2 diabetes in obese patients: first results with orlistat in the XENDOS study]. Rev Med Liege 57(9): 617–21.). This study describes the potential long-term (4 years follow-up) outcomes of treatment with orlistat - it is the first study to show that weight loss with a drug reduces incident type 2 diabetes. I realize this study is not yet a published manuscript, but it may deserve mention because of the importance of the findings. | | | | | | | We could not include this because it was published too late to be incorporated into our meta-analysis.
orlistat | The literature review includes most of the important papers except for Orlistat. The “Xendos” trial is a 4 year study which unfortunately is available only in abstract form. This is the longest recent trial of pharmacotherapy - it can be found in: International Journal of Obesity - presented at IASO, San Paolo Brazil, September 2002. Sjostrom, L
orlistat | In the Orlistat trials a higher fat diet was used to enable the effect of the drug to be seen. A specific 30 percent fat target was used and fat was added if the target was not reached. | | | | | | | This comment is noted but we made no change to the manuscript.
orlistat | The pooled random effects estimate of the mean weight loss for orlistat-treated patients, compared to placebo-treated patients, was 2.51 kg…" Was the mean weight loss for placebo-treated groups calculated? In general, it is clearer if you report the mean weight loss for treated and the mean weight loss for placebo groups. | | | | | | | We calculated all of these numbers and how present the total and placebo-corrected weight loss.
phentermine | Phentermine and diethylproprion, although the reviews reported no side effect or adverse event data, were these mentioned in the actual trials? | | | | | | | We did not go back to the original trials for phentermine, diethylpropion, or sibutramine. Adverse event data were not reported in the meta-analysis of phentermine or diethylpropion.
phentermine | The authors say “We note that while phentermine is an FDA-approved weight loss medication it is no longer available in Europe because of concerns about a possible link between phentermine use and heart and lung problems .” What data is this based on?, or is it simply a bureaucratic pronouncement? | | | | | | | We attempted to find the justification for the European decision, could not find any, and have therefore removed this sentence from the report.
phentermine | The section of phentermine is concise, however, it was a little hard to reconcile the banning of the drug in Europe with the report of no side effects. The same holds for diethypropion.
phentermine | It is irrelevant information to include any comment about the fact that a drug is not available in Europe due to possible concerns about heart and lung problems.
fluoxetine | For drugs used for other indications such as fluoxetine, it was not clear that the side effects were different from other approved uses. | | | | | | | We now comment regarding fluoxetine and bupropion that the side effects in the weight loss trials were similar to those reported in other approved uses.
fluoxetine | S Paragraph 2-Same problem of reconciling the number of studies. You indicate there were 9 studies and then you discuss 7 and 6. | | | | | | | Some studies reported both 6 and 12 month outcomes.
bupropion | Bupropion studies in general do not emphasize behavior mod and diet and exercise as much as the sibutramine and orlistat studies do. This should be emphasized and likely do contribute to the lesser weight losses seen in the bupropion studies. | | | | | | | This comment is noted, but we made no change to our report because we did not systematically assess the intensity of the cointerventions, merely their presence or absence.
bupropion | Bupropion - Is there a specific reason why these 4 studies were not pooled? | | | | | | | These are now pooled.
bupropion | Bupropion you switch from using kg for effect size to % weight loss. Wouldn't it be better to use a kg effect size throughout? | | | | | | | We now present a pooled kg meta-analysis.
bupropion | Can you describe the meaning of a Beck Depression score of 15 - were these patients depressed or normal?
bupropion | In the bupropion section, it was confusing in that weight loss was for the first time reported in %. There was a much greater in depth report of these limited studies for bupropion. Was this done because there is less familiarity with this agent? Is this the same for zonisamide and topiramate?
topiramate | Why couldn't studies reporting % weight loss be included (couldn't one convert using average baseline weight?) | | | | | | | Average baseline weight wasn't available for topiramate studies.
Miscellaneous drugs | The coverage of these trials seems disproportionately lengthy in relation to the rest of the review, could some of this information be tabulated? | | | | | | | We have attempted to redress this apparent imbalance.
Miscellaneous drugs | Three drugs, bupropion, zonisamide, topiramate and sertraline were discussed based on the 1–4 available trials that varied in their quality. For the reader there is some disconnect in quality and quantity of discussion.
Miscellaneous drugs | For other drugs reviewed for completeness, the level of detail was excessive.
Miscellaneous drugs | Zonisamide, topiramate and sertraline. Same issue of presenting data as % versus kg as you did for the other studies. | | | | | | | Only % weight loss was reported as an outcome in these studies.
Miscellaneous drugs | It is unclear again why the last 2 agents are reported in percent weight loss.
Miscellaneous drugs | It would be helpful to mention that these investigative drugs are currently licensed only for treatment of seizures. | | | | | | | We mention in the methods that these drugs are not FDA approved for weight loss.
Surgery | RCTs between discredited therapeutic procedures or medications are worthless! All forms of unbanded gastroplasty procedures have been found to be inadequate and should not even be mentioned, except for historical interest, in any comparison. | | | | | | | All of these comments concern the synthesis and reporting of the evidence regarding surgery. In response, we have completely rewritten the surgical section, including new articles, new analyses, and new conclusions.
Surgery | The data are clear that unbanded gastroplasty procedures are inadequate and should only be mentioned for historical interest, but they figure prominently in both reports. I believe the data are also clear that a gastric bypass (GBP) is associated with significantly more weight loss than a vertical banded gastroplasty (VBG). Two additional CSs supporting this statement were not referenced
Surgery | One of our studies that followed our RCT comparing VBG to GBP in which we selectively assigned patients to VBG and GBP, having found from retrospective analysis of the data that “sweets eaters” do poorly after VBG, was not listed. In that study, despite selective assignment, we continued to find a significantly better weight loss at 1,2 and 3 years with GBP.
Surgery | We and others have found that patients with a VBG and an inadequate weight loss or with severe gastroesophageal reflux problems that develop after VBG respond well to conversion to GBP.
Surgery | There was no mention of the partial biliopancreatic diversion procedure or its modification, the duodenal switch.
Surgery | I believe a RCT comparing surgery to non-surgery for any age group would be impractical.
Surgery | You make the point that there is no evidence that surgery gives better weight loss than medical treatment. There may be a paucity of data to support a difference from randomized clinical trials, but the difference is so dramatic from case control studies like the SOS, making this point seems more confusing than helpful.
Surgery | In view of the length and the size of the SOS study, I find it difficult to believe that the superior weight loss efficacy of surgical treatment over medical treatment of obesity is not obvious to any reasonable person, despite the lack of a randomized trial design.
Surgery | In terms of surgery, I think it would be appropriate to include more detail about the SOS study, even though this is not a RCT.
Surgery | From my perspective the report does not adequately address the status of bariatric surgery. The report concludes that heterogeneity in the surgical trials selected for review precluded statistical pooling. This may be a fair assessment of the quality of existing publications regarding bariatric surgery, however, the same approach should have been applied to the summary of adverse events. Most of the report concentrated on summarizing adverse events, a discussion that aggregated studies of widely different procedures with variable short and long-term risks. It was not clear to me why the reviewers took the position that heterogeneity precluded analysis of outcomes but not adverse events.
Surgery | The literature summarizing bariatric surgery experience is lacking in many ways. However, the vast majority of studies describing operations currently accepted by the surgical community demonstrate obesity-related comorbidity control, duration and extent of weight loss that far exceed any trial of medical therapy. Granted that there may not be a statistical methodology for comparing the literature summarizing these therapeutic approaches but for those of us engaged in the practice of treating the obese the results are obvious.
Surgery | The report dismissed bariatric surgery outcomes because the available literature could not be assessed by the methodology selected by the reviewers. Given this, I was surprised that they did not recommend the performance of controlled trials, as did the 1991 NIH panel. Rather, the current report states that these trials cannot be done and recommends conducting observational studies. I cannot agree with that recommendation.
Surgery | In summary, the report as currently written does not adequately summarize the available evidence in support of bariatric surgery. Should the reviewers not be able to revise this the section on adult bariatric surgery it should be eliminated. I would retain the part on the pediatric literature, being that assessment of outcomes for children was the original question posed and the summary provided for pediatrics is adequate.
Surgery | The conclusions concerning surgery were more difficult to determine since there are limited number of RCTs that have compared surgery to diet and the variety of surgical procedures to each other with regards to efficacy and safety.
Surgery | The surgical results again were confusing. In the second report, for example, is the weight gain in the 5 patients related to one procedure versus another?
Surgery | The surgical results again were confusing. In the second report, for example, is the weight gain in the 5 patients related to one procedure versus another?
Surgery | I wonder if you could specify the mean duration (with the range) of the follow up post surgery and the ranges in your report. I am concerned about the current lack of follow up and potential problem of osteopenia in these youngsters from calcium malabsorption, as the mean age of the surgery is at the time of peak bone formation.
Surgery | My first comment is that data for efficacy surgery (magnitude of weight loss) abound in the literature. They tend to be reported as case series.
Surgery | Readers will gain the impression that there is no evidence that surgery provides greater weight loss than diet alone. Yet this conclusion was based on a single RCT performed 20 years ago, and reported an outmoded procedure, which has been abandoned for years.
Surgery | Comparing surgery with conventional treatment in a contemporaneous RCT is idealogically problematic because one of the entry criteria for surgical treatment is the prior attempts, and failure of medical treatments.
Surgery | The implications of a review claiming that there is no evidence that surgery is more efficacious than conservative methods is potentially very profound.
Surgery | The other major omission in the discussion about surgery is any concept of the magnitude of weight loss, which may be expected.
Surgery | Reference #203 is missing and this is a key reference regarding bariatric surgery in adolescents.
Surgery | I would also suggest that you include comments under Surgery in Chapter 4, the importance of long-term follow up of post surgery for adolescents. I also would like to see a plea made for a centralized registry where core clinical information is gathered prospectively in a standardized manner for future pooling of the data as bariatric surgery is on the increase for adolescents.
Surgery | I don't find sufficient justification (other than lack of time) to exclude analysis of the weight loss outcomes from the case-series of surgical treatment.
Surgery | The fact that there is significant heterogeneity in the results of the studies that were reviewed doesn't seem like an argument for not reviewing them - in fact, one could argue that pointing out and exploring reasons for the heterogeneity could be an important contribution of the report.
Surgery | Perhaps, given the number of studies, one could set inclusion criteria based on duration of follow-up that might result in a more manageable number of studies. I think the most important unanswered question is probably the long term effects on weight loss so setting more stringent follow-up requirements (e.g. 2 years or greater) would be reasonable.
Surgery | The description of how individual and aggregate adverse event rates were calculated is not explained in enough detail to understand exactly what was done or the possible effects of your assumptions on your estimates of adverse event rates (especially for surgery). It is unclear what studies contribute to the comparisons of adverse events for different surgical procedures - does a study have to have compared outcomes of both procedures to be included, as opposed to reporting rates for one procedure?
Surgery | There are at least three critical assumptions that could affect the validity of the estimates you present for individual and aggregated outcomes: 1) the assumption that reported events are an approximation of individuals; 2) the assumption that events in related categories (e.g. nausea and vomiting) occur in different individuals; the 3) the assumption you can aggregate reports of events in broad categories (such as “GI symptoms”) even though studies do not uniformly report all the outcomes under each category.
Surgery | • Reorganize the adverse event categories on 49–67 to mimic the “tree” structure used, by indenting subcategories. For example:
| 1) Respiratory major
| a) PE
| DVT/PE
| PE
| Major pulmonary embolus…
| b) Respiratory insufficiency
| ARDS
| Respiratory failure
| c) Chest infections
| Respiratory chest infections
Surgery | More emphasis should be placed on the raw estimates for single endpoints (e.g. vomiting) than on the aggregated endpoints (e.g. GI symptoms).
Surgery | Estimates of combined rates such as “GI, all” should only come from studies that report a minimum number of outcomes, such as at least one outcome in each of the subcategories. Alternatively, estimates calculated by different means could be compared to give a range.
Surgery | Summary tables that highlight the most important and reliable endpoints should be included - the undifferentiated list of comparisons in Table 13 is difficult to wade through.
Surgery | Methods need to clarify which studies contribute to which estimates. I am still unclear why the number of studies contributing to specific outcomes varies depending on what the comparison is (e.g. for “GI, all” 16 studies are cited for the estimate for VBG in the RYBG vs. VBG, but 18 studies for VBG two lines below in the VBG vs. band. I suspect these are errors.
Surgery | It would be preferable if the groupings of symptoms for the surgery studies matched that for the medication studies as closely as possible. Fore example, why is gastritis/reflux not included with other related symptoms like abdominal pain under “GI symptoms” as in the medication studies?
Surgery | As noted above, this section needs to be expanded perhaps with some examples and numbers to illustrate how different numerators and denominators were constructed for individual outcomes and aggregated outcomes. The effect of assuming that each reported adverse event occurred in different patients should be explicitly discussed.
Surgery | What do the non-surgery patients represent here - diet treated? Please define “early” and “late.” Please clarify what the definition of outlier means - the definition does not seem consistent for an individual study.
Surgery | I'm surprised at the finding of no data showing greater weight loss with surgery than diet. That alone will make this newsworthy.
Surgery | When reviewing results of the different bariatric surgeries it is important to recognize what the male:female ratio is as female pattern (gynecoid) obesity patients are easier to operate on and generally suffer from less comorbidities and recover from surgery with less risk for morbidity and mortality.
Surgery | Most of the laparoscopic series are selective of who has a laparoscopic procedure reserving this approach for the less risky less heavy patients, therefore, skewing the data in their favor.
Surgery | Today three procedures are performed with frequency, the RYGBP, the DS and the laparoscopic gastric band (LAP BAND). The LAP BAND best serves the less heavy, most compliant, motivated patient. The long term consequences of this procedure are yet to be determined but most experienced bariatric surgeons worry about the development of esophageal motility disorders and band erosions. The RYGBP has stood the test of time as far as efficacy and safety are concerned. However, side effects such as the inability to tolerate certain solid foods and d the development of dumping symptoms are the major drawbacks of this procedure. The laparoscopic RYGBP can be performed with safety in certain centers with similar results to that of an open approach. However, what is not known are the results of the laparoscopic RYGBP in certain centers and surgeons who are not experienced with bariatric surgery and the leak rate may be significantly higher in these centers/surgeons hands.
Surgery | The DS has certain advantages and disadvantages. The safety and efficacy are comparable if not better than that see n with the RYGBP (Anthone et al, Ann Surg 2003;238:618–628). The advantages include better tolerance of solid food and the absence of dumping symptoms. In addition, the leak rate is low because of the lack of tension at the anastomotic suture line. The disadvantages are the higher risk of malodorous stools and the development of protein calorie malnutrition if the diversion of bile/pancreatic secretions is performed to a degree significant enough to provide an element of fat malabsorption.
Surgery | The malnutrition and other problems with Roux-en-Y need to be documented but so should the benefits of the Roux-en-Y for Type II diabetes (see studies of Porrier).
Surgery | The whole issue of which surgical procedure (page 13) was performed was difficult to understand. It might be better understood if there were diagrams showing the different procedures and locations and how they were lumped together.
Surgery | The surgical discussion seems out of place against the clinical trial data that are presented in the first parts of the paper
Surgery | It might be important to include the number of centers and surgeons in the multicenter reports.
Children | The statement is a bold one specially since I know of one Polish study Ref: Przegl Lek. 1981;38(3):355–8 “Clinical evaluation of Teronac (Mazindol) in the treatment of obesity in children. Part II. Anorectic properties and side effects.” Therefore I suggest modifying the statement to ' Current studies in pharmacological management of obesity in children (<12y/o) is limited to ‘obesity due to secondary causes’ e.g. “Metformin for weight loss in Pediatric patients taking psychotropic drugs.” Ref: American Journal of Psychiatry Morrison et al. 159 (4):655 or in certain syndromes like ‘Prader-Willi syndrome’ and familial hyperlipidemia. | | | | | | | This medication (mazindol) was not a subject of our study. We have noted the presence of this paper in our report.
Children | For pharmacological management of obesity in adolescents, one study should be particularly included, Ref. Int J Obes Relat metab disord. 2000 Dec; 24(12): 1573–8 “Safety and efficacy of treatment with an ephedrine/caffeine mixture. The first double-blind placebo-controlled pilot study in adolescents.” | | | | | | | This medication was not a subject of our study. We have noted the presence of this paper in our report.
Children | For surgical management of obesity in adolescents with LAGB (laparoscopic adjustable gastric banding), there are two excellent recent studies and need inclusion for their direct relevance to the topic in hand and specially since there is a dearth of data in the field, Ref A.: J Pediatr Surg. 2003 Sep; 38(9): 1379–82 “Bariatric surgery in adolescence,” Abu-Abeid S et al and Ref. B: Obes Surg. 2003 Feb; 13(1): 101–4 “Laparoscopic gastric banding in morbidly obese adolescents,” Dolan K et al. | | | | | | | We have added these references to our synthesis.
Children | The authors have made great efforts to obtain evidence, and their methodology for doing so has been appropriate. My particular expertise is in reviews of obesity treatment in children and adolescents and so I cannot comment specifically on the evidence in adults, other than to note the methodological rigour, which has been applied here. I am unaware of any evidence on children and adolescents, which has been missed. | | | | | | | No response necessary.
Children | From a pediatric perspective, the review emphasizes well the need for data. A minor point: adolescents are pediatric patients. I tried to reword things to reflect that. | | | | | | | We did not mean to imply that adolescents are not pediatric patients, we used the terms adolescents and children to denote different ages.
Discussion | This was largely a well-written summary of what had gone before. Much of the ‘Discussion’ material had been addressed in earlier sections of the review. I would have welcomed a brief treatment of similarities/differences in conclusions between the present review and other recent systematic reviews in this area - to what extent does this review add to what was known? To what extent are recent reviews in agreement? | | | | | | | For sibutramine, phentermine, and diethylpropion, we relied on existing systematic reviews. For orlistat, we produced a new review but did not compare our results to previous reviews in a systematic way. For the other drugs ours is the first systematic review and meta-analysis that we are aware of.
Discussion | While it is likely that there are few data on the health economic outcomes of treatment (e.g. financial costs and benefits of pharmacotherapy) was such evidence eligible in the review? Was there simply very little evidence? | | | | | | | This was not one of our key questions. We note, however, that very few of the treatment studies we reviewed have any cost data.
Discussion | The Summary is daunting. Essentially there is little difference between agents from an effectiveness standpoint and only modest weight loss is apparent atone year. However, there is the suggestion that it is better to have lost and gained, then never to have lost at all with regards to risk factors. There is nothing beyond sibutramine for disease state, such as diabetes. | | | | | | | No response necessary.
Discussion | The comparison of Surgery and Pharmacological agents might be facilitated by a table such as the following: | | | | | | | This is a good idea, but the data are way too sparse to be able to meaningfully fill in the cells.
| Treatment | <24.9 | 25–26.9 | 27–29.9 | 30–35 | 35–39.9 | >40
| Lifestyle | 0 | + comorbids | + comorbids | + | + | +
| Meds | 0 | + comorbids | + comorbids | + | + | +
| Surgery | 0 | | | | + comorbids | +
Discussion | On page vi, under Conclusions; I completely disagree with the statement “All of these drugs have significant side effects or safety concerns.” This statement is repeatedly made in the document. | | | | | | | We have eliminated this statement.
Discussion | A review of the literature of this magnitude should specify which are minor side effects, which can be handled with medical supervision, and which are real safety concerns. | | | | | | | We think the classification of “minor” and “real safety concerns” are judgments for the reader to make. We have tried to present the data as accurately as possible for readers to make their own judgments.
Discussion | The only effective therapies for severe obesity are VLCD and surgery. | | | | | | | This is an expert opinion based on this evidence, statements such as this are not allowed in Evidence Reports but are perfectly appropriate for guidelines or other products that use opinion to supplement the evidence in our report.
Discussion | Not enough attention is given to issues of generalizability/external validity. I assume that the studies might have varied considerably in the recruitment/inclusion criteria in ways that might affect their applicability to primary care outpatients. For example, were there run-in periods? | | | | | | | Most studies did not have run-in periods. We have added text to the limitations regarding generalizability.
Future Research | This was a useful summary of the main ‘gaps’ in the evidence. In view of the scale of the obesity epidemic, the lack of evidence for many aspects of treatment is alarming, and this might have merited greater emphasis on research needs in the Abstract and in this section. The paucity of high quality data on bariatric surgery is a particular concern. | | | | | | | No response necessary.
Future Research | The trials summarized were quite heterogeneous with respect to treatment regimen - is it possible to comment on whether pharmacotherapy effects over 12 months are enhanced by lifestyle change? E.g. can the separate effects of dietary and/or assessed physical activity treatments going on simultaneously with the pharmacotherapy be assessed even in general terms? | | | | | | | We included this as a topic for future research, because the existing literature are insufficient to answer this question.
Future Research | Another area of future research would be attempting to determine if the age of onset of obesity has an effect on magnitude of weight loss or if early and rapid responders to medications have a more or less favorable long-term outcome. | | | | | | | This is a good suggestion, but we judge it as a second-level topic for future research, below the topics we list in our report.
Future Research | The Surgical results beg to establish Centers of Excellence for Bariatric Surgery and robust databases to characterize which surgical procedures are being employed. | | | | | | | We agree and note NIH has recently established Bariatric Surgical Centers. We hope our suggestion for future research will be acted on by these Centers.
Future Research | Surgical Therapy - It should be discussed in the discussion section that beyond the RCT that should be done, there should also be a registry developed for adult and adolescent and pediatric surgical therapy. This has already been established for diet and exercise therapy (Wing RR, Hill JO). Furthermore, NIH guidelines for adolescent and pediatric surgery for obesity have not yet been established. | | | | | | | We have suggested observational studies, which would require such registers.
References | Reference 20 should be: Avenell A, Broom J, Brown TJ, Poobalan A, Aucott L, Stearns SC, Smith WCS, Jung RT, Campbell MK, Grant AM. Systematic review of the long-term outcomes of the treatments for obesity and implications for health improvement and the economic consequences for the National Health Service. Health Technol Assess 2003 (in press). | | | | | | | Appropriate changes made.
References | Reference 23 should be: Clegg AJ, Colquitt J, Sidhu MK, Royle P, Loveman E, Walker A. The clinical effectiveness and cost-effectiveness of surgery for people with morbid obesity: a systematic review and economic evaluation. Health Technol Assess 2002;6(12). | | | | | | | Appropriate changes made.
References | Reference 44 should be: Broom I, Hughes E, Dodson P, Reckless J, on behalf of the Orlistat UK Study Group. The role of orlistat in the treatment of obese patients with mild to moderate hypercholesterolaemia: consequences for coronary risk. Br J Cardiol 2002;9(8):460–8. | | | | | | | Appropriate changes made.
References | Reference #203 is not listed in the Reference section | | | | | | | Appropriate changes made.
References | Typographical error--Reference 203 appears omitted but actually has been included under ref. 202. | | | | | | | Appropriate changes made.
Figures and Tables | Is overwhelming and it is hard to determine its importance. | | | | | | | This table has been reviewed.
Figures and Tables | Acceptable and add to the report | | | | | | | No response necessary. This table has been revised.
Figures and Tables | Table 11 is confusing in that it appears to be looking at overall surgical effectiveness and then compares different procedures. It is not as concise as the other tables.
Figures and Tables | Table 12 conveys information in an understandable format. | | | | | | | No response necessary.
Figures and Tables | Tables 13 and 14 are difficult to follow. | | | | | | | These tables have been revised.
Figures and Tables | Figure 1 is excellent | | | | | | | No response necessary.
Figures and Tables | All other figures are good | | | | | | | No response necessary.
Figures and Tables | Evidence tables should include more details on the nature of enrolled patients. | | | | | | | Appropriate change made.
Figures and Tables | The Tables need to be much more clearly titled and labeled, with explanations of the sources of data and meaning of different columns and abbreviations. | | | | | | | Appropriate change made.
Figures and Tables | This figure is unclear - which studies correspond to which subgroups? Are A, B, and C mutually exclusive? | | | | | | | This has been revised in this report.
Figures and Tables | What do these tables represent - needs title to indicate these are weight loss outcomes expressed as difference vs. controls in kgs. | | | | | | | Appropriate change made.
Figures and Tables | I would include some information on the patient populations in these summary tables - e.g., these were patients with fairly severe obesity - BMI 35+. | | | | | | | Appropriate change made.