# Appendix D: Technical Expert Panel (TEP) Members and Peer Reviewers

Technical Expert Panel members

Name | Institution
Gary Anthone, M.D., FACS | University of Southern California, Dept of Surgery
Caroline Apovian, M.D. | Boston Medical Center
Lou Aronne, M.D. | Weill-Cornell College of Medicine
David Arterburn, MD | Department of Veterans Affairs
Patricia Barry, M.D., MPH | Merck Institute of Aging and Health
Sulaiman Bharwani, M.D., FAAP | Louisiana State University Medical Center
George Bray, M.D. | Pennington Biomedical Research Center
William J. Cochran, M.D. | Geisinger Health System
Nick Fitterman, M.D., FACP | North Shore Medical Group
Frank Greenway, M.D. | Pennington Biomedical Research Center
David Heber, M.D. | University of California Los Angeles, School of Medicine & Public Health
Marc Jacobson, M.D. | Schneider Children's Hospital
Sue Y.S. Kimm, M.D., MPH | University of Pittsburg
Evelyn L. Lewis&Clark, M.D., MA | Uniformed Services University
Edward Livingston, M.D. | Southwestern Medical Center
Denis Prud'homme, M.D., M.Sc. | University of Ottawa
Harvey Sugerman, M.D. | Virginia Commonwealth University

Peer Reviewers

Name | Institution
Richard L. Atkinson, M.D. | University of Wisconsin–Madison
Allison Avenell, M.D. | University of Aberdeen Medical School
Peter F. Crookes, M.D. | USC Healthcare Consultation Center
James O. Hill, Ph.D. | UCHSC Center for Human Nutrition
Francine Kaufman, M.D. | Keck School of Medicine
Carolyn Summerbell, Ph.D. | University of Teeside, UK
John Reilly, M.D. | University of Glasgow, Scotland