# Appendix C: Evidence Tables

## Evidence Table 1. Medication

Table 1 Evidence Table. Medication

First author Year | Medication type Study design and Quality Population | | Arm | Intervention | Sample size | | Meta-analysis data
Anderson 2001 | Buproprion | RCT | 1 | Placebo | N entering | 112 | Excluded from meta-analysis because of insufficient statistics.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 3 | 2 | Bupropion | N entering | 110
| | | | Variable dose for 24 dy | N completing | ND
| Population | Adults, Females | 3 | Bupropion | N entering | 105
| | | | Variable dose for 24 dy | N completing | ND
Anderson 2002 | Buproprion | RCT | 1 | Placebo | N entering | 112 | Included in meta-analysis of buproprion.
| | | | Dosage/Duration NR | N completing | 80
| Jadad | 3 | | | | | Average weight loss at 6 months in kg
| | | 2 | Bupropion | N entering | 110 | Arm 1 = -5.2 (6.6)
| Population | Adults, Females | | Variable dose for 48 dy | N completing | 67 | Arm 3 = -10.1 (7.4)
| | | 3 | Bupropion | N entering | 105 | Arm 2 was dropped from analysis because it was a lower dose of the same medication.
| | | | Variable dose for 48 dy | N completing | 57
Croft 2002 | Buproprion | RCT | 1 | Placebo | N entering | 213 | Included in meta-analysis of buproprion.
| | | | Dosage/Duration NR | N completing | 43
| Jadad | 2 | 2 | Bupropion | N entering | 210 | Average weight loss at 13 months in kg
| | | | 300 mg for 44 dy | N completing | 60 | Arm 1 = 0.02 (5.7)
| Population | Adults | | | | | Arm 2 = -1.2 (5.7)
Gadde 2001 | Buproprion | RCT | 1 | Placebo | N entering | 25 | Excluded from meta-analysis because of insufficient statistics.
| | | | Dosage/Duration NR | N completing | 1
| Jadad | 5
| | | 2 | Bupropion | N entering | 25
| Population | Adults, Females | | Variable dose for 2 yr | N completing | 12
Jain 2002 | Buproprion | RCT | 1 | Placebo | N entering | 209 | Included in meta-analysis of buproprion.
| | | | Dosage/Duration NR | N completing | 191
| Jadad | 3 | 2 | Bupropion | N entering | 213 | Average weight loss at 6 months in kg
| | | | Variable dose for 24 dy | N completing | 195 | Arm 1 = -1.7 (4.3)
| Population | Adults, Females | | | | | Arm 2 = -4.4 (4.4)
Andersen 1984 | Diethylpropion | RCT | 1 | Diethylpropion | N entering | 30 | Excluded from meta-analysis because drug has existing meta-analysis.
| | | | 12 mg for 18 dy | N completing | 29
| Jadad | 2
| | | 2 | Open VBG | N entering | 30
| Population | Adults, Female | | Dosage/Duration NR | N completing | 26
Andersen 1988 | Diethylpropion | RCT | 1 | Open VBG | N entering | 30 | Excluded from meta-analysis because drug has existing meta-analysis.
| | | | Dosage/Duration NR | N completing | 26
| Jadad | 2
| | | 2 | Diethylpropion | N entering | 30
| Population | Adults, Females | | 12 mg for 18 dy | N completing | 30
McKay 1973 | Diethylpropion | RCT | 1 | Placebo | N entering | ND | Excluded from meta-analysis because drug has existing meta-analysis.
| | | | Dosage/Duration NR | N completing | 18
| Jadad | 3
| | | 2 | Diethylpropion | N entering | ND
| Population | Adults | | 75 mg for 24 dy | N completing | 20
Breum 1995 | Fluoxetine | RCT | 1 | Placebo | N entering | 20 | Included in meta-analysis of fluoxetine.
| | | | Dosage/Duration NR | N completing | 14
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Fluoxetine | N entering | 20 | Arm 1 = -9.4 (11.5)
| Population | Adults | | 60 mg for 52 dy | N completing | 15 | Arm 2 = -10.1 (10.0)
Chiasson 1989 | Fluoxetine | RCT | 1 | Placebo | N entering | ND | Excluded from meta-analysis because of insufficient statistics.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2
| | | 2 | Fluoxetine | N entering | ND
| Population | Adults | | 60 mg for 36 dy | N completing | ND
Connolly 1995 | Fluoxetine | RCT | 1 | Placebo | N entering | 15 | Included in meta-analysis of fluoxetine.
| | | | Dosage/Duration NR | N completing | 13
| Jadad | 3 | | | | | Average weight loss at 6 months in kg
| | | 2 | Fluoxetine | N entering | 15 | Arm 1 = 0.0 (0.5)
| Population | Adults | | 60 mg for 6 mo | N completing | 11 | Arm 2 = -3.9 (1.5)
Darga 1991 | Fluoxetine | RCT | 1 | Placebo | N entering | 22 | Included in meta-analysis of fluoxetine.
| | | | Dosage/Duration NR | N completing | 16
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Fluoxetine | N entering | 23 | Arm 1 = -4.6 (1.1)
| Population | Adults | | 60 mg for 52 dy | N completing | 14 | Arm 2 = -8.2 (2.2)
Goldstein 1994 | Fluoxetine | RCT | 1 | Placebo | N entering | 184 | Included in meta-analysis of fluoxetine.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 4 | | | | | Average weight loss at 5 months in kg
| | | 2 | Placebo | N entering | 22 | Arm 1 = -2.4 (5.4)
| Population | Adults, Females | | Dosage/Duration NR | N completing | ND | Arm 4 = -5.1 (6.9)
| | | 3 | Placebo | N entering | 22
| | | | Dosage/Duration NR | N completing | ND | Average weight loss at 12 months in kg
| | | 4 | Fluoxetine | N entering | 182 | Arm 1 = -2.1 (6.8)
| | | | 60 mg for 52 dy | N completing | ND | Arm 4 = -1.7 (8.7)
| | | | | | | Arms 1, 2, and 3 were collapsed.
Gray 1992 | Fluoxetine | RCT | 1 | Placebo | N entering | 24 | Excluded from meta-analysis because study reported data on another study already included in analysis (Gray, 1992).
| | | | Dosage/Duration NR | N completing | 24
| Jadad | 3
| | | 2 | Fluoxetine | N entering | 24
| Population | Adults | | 60 mg for 24 dy | N completing | 24
Gray 1992 | Fluoxetine | RCT | 1 | Placebo | N entering | 24 | Included in meta-analysis of fluoxetine.
| | | | Dosage/Duration NR | N completing | 20
| Jadad | 4 | | | | | Average weight loss at 6 months in kg
| | | 2 | Fluoxetine | N entering | 24 | Arm 1 = -1.9 (2.9)
| Population | Adults | | 60 mg for 6 mo | N completing | 16 | Arm 2 = -9.3 (2.4)
Marcus 1990 | Fluoxetine | RCT | 1 | Placebo | N entering | 22 | Included in meta-analysis of fluoxetine.
| | | | Dosage/Duration NR | N completing | 11
| Jadad | 4 | | | | | Average weight loss at 5 months in kg
| | | 2 | Fluoxetine | N entering | 23 | Arm 1 = -2.1 (6.1)
| Population | Adults, Females | | 60 mg for 52 dy | N completing | 13 | Arm 2 = -11.2 (5.8)
| | | | | | | Average weight loss at 9 months in kg
| | | | | | | Arm 1 = -0.7 (6.2)
| | | | | | | Arm 2 = -12.3 (9.8)
| | | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = 0.6 (5.0)
| | | | | | | Arm 2 = -13.9 (12.7)
Mendoza 1995 | Fluoxetine | RCT | 1 | Placebo | N entering | 30 | Included in meta-analysis of fluoxetine.
| | | | Dosage/Duration NR | N completing | 19
| Jadad | 1 | | | | | Average weight loss at 6 months in kg
| | | 2 | Fluoxetine | N entering | ND | Arm 1 = -7.7 (4.0)
| Population | Adults, Females | | 180 mg for 6 mo | N completing | ND | Arm 2 = -12.3 (4.0)
Michelson 1999 | Fluoxetine | RCT | 1 | Placebo | N entering | 96 | Included in meta-analysis of fluoxetine.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 1 | | | | | Average weight loss at 6.5 months in kg
| | | 2 | Fluoxetine | N entering | 97 | Arm 1 = 1.9 (2.3)
| Population | Adults | | 20 mg for 14 dy | N completing | ND | Arm 2 = 1.0 (2.4)
| | | 3 | Fluoxetine | N entering | 100
| | | | 20 mg for 38 dy | N completing | ND | Average weight loss at 11.5 months in kg
| | | 4 | Fluoxetine | N entering | 102
| | | | 20 mg for 50 dy | N completing | ND | Arm 1 = 3.2 (4.3)
| | | | | | | Arm 4 = 3.0 (4.0)
| | | | | | | For 6.5 month analysis, arms 3 and 4 were combined and arm 2 was excluded because it has less than 6 month follow-up. For 11.5 month analysis, arms 2 and 3 were excluded because they had less than 11.5 month follow-up.
O'Kane 1994 | Fluoxetine | RCT | 1 | Placebo | N entering | 10 | Included in meta-analysis of fluoxetine.
| | | | Dosage/Duration NR | N completing | 9
| Jadad | 2 | | | | | Average weight loss at 6 months in kg
| | | 2 | Fluoxetine | N entering | 10 | Arm 1 = 0.2 (1.1)
| Population | Adults | | 60 mg for 12 mo | N completing | 7 | Arm 2 = -6.3 (0.8)
| | | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = 1.5 (1.7)
| | | | | | | Arm 2 = -4.3 (1.9)
Pedrinola 1996 | Fluoxetine | RCT | 1 | Fluoxetine | N entering | 20 | Excluded from meta-analysis because study had no placebo group.
| | | | 40 mg for 8 mo | N completing | 13
| Jadad | 3
| | | 2 | Fluoxetine | N entering | 20
| Population | Adults | | 40 mg for 8 mo | N completing | 20
Ricca 2001 | Fluoxetine | RCT | 1 | Active n/s Cognitive-behavioral | N entering | 20 | Excluded from meta-analysis because study did not report weight loss as an outcome.
| | | | Dosage/Duration NR | N completing | 17
| Jadad | 1
| | | 2 | Fluoxetine | N entering | 22
| Population | Adults | | Variable dose for 24 dy | N completing | 16
| | | 3 | Cognitive-behavioral + fluvoxamine | N entering | 23
| | | | Dosage/Duration NR | N completing | 18
| | | 4 | Fluoxetine | N entering | 21
| | | | Variable dose for 24 dy | N completing | 16
| | | 5 | Fluvoxamine | N entering | 22
| | | | Dosage/Duration NR | N completing | 16
Anderson 1997 | Orlistat | RCT | 1 | Placebo | N entering | ND | Excluded from meta-analysis because of insufficient statistics.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2 | 2 | Orlistat | N entering | ND
| | | | 90 mg for 1 yr | N completing | ND
| Population | Adults | 3 | Orlistat | N entering | ND
| | | | 180 mg for 1 yr | N completing | ND
| | | 4 | Orlistat | N entering | ND
| | | | 360 mg for 1 yr | N completing | ND
Bakris 2002 | Orlistat | RCT | 1 | Placebo | N entering | 276 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 108
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 278 | Arm 1 = -2.7 (6.4)
| Population | Adults | | 360 mg for 52 dy | N completing | 162 | Arm 2 = -5.4 (6.4)
Broom 2001 | Orlistat | RCT | 1 | Placebo | N entering | 266 | Excluded from meta-analysis because study reported data on another study already included in analysis (Broom, 2001).
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2
| | | 2 | Orlistat | N entering | 265
| Population | Adults | | 360 mg for 1 yr | N completing | ND
Broom 2002 | Orlistat | RCT | 1 | Placebo | N entering | 261 | Included in meta-analysis of orlistat
| | | | Dosage/Duration NR | N completing | 161
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 265 | Arm 1 = -2.3 (6.4)
| Population, | Adults Females | | 360 mg for 52 dy | N completing | 186 | Arm 2 = -5.8 (8.5)
Broom 2001 | Orlistat | RCT | 1 | Placebo | N entering | 71 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 60
| Jadad | 2 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | 71 | Arm 1 = -2.6 (3.9)
| Population | Adults | | 360 mg for 52 dy | N completing | 34 | Arm 2 = -4.4 (4.1)
Davidson 1999 | Orlistat | RCT | 1 | Placebo | N entering | 224 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 133
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 668 | Arm 1 = -5.8 (7.7)
| Population | Adul ts, Females | | 360 mg for 52 dy | N completing | 458 | Arm 2 = -8.8 (7.9)
Deerochanawong 2001 | Orlistat | RCT | 1 | Placebo | N entering | 126 | Included in meta-analysis of orlistat
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | 126 | Arm 1 = -1.4 (6.3)
| Population | Adults | | 360 mg for 24 dy | N completing | ND | Arm 2 = -2.6 (6.3)
Derosa 2003 | Orlistat | RCT | 1 | Placebo | N entering | 23 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 23
| Jadad | 3 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | 27 | Arm 1 = -4.2 (0.6)
| Population | Adults | | 360 mg for 1 yr | N completing | 25 | Arm 2 = -5.1 (0.7)
| | | 3 | Fluvastatin | N entering | 24
| | | | Dosage/Duration NR | N completing | 24 | Average weight loss at 12 months in kg
| | | 4 | Orlistat + fluvastatin | N entering | 25 | Arm 1 = -7.6 (0.7)
| | | | 360 mg for 1 yr | N completing | 24 | Arm 2 = -8.6 (1.1)
| | | | | | | Arms 3 and 4 were excluded because they are different medications
Derosa 2002 | Orlistat | RCT | 1 | Orlistat | N entering | 31 | Excluded from meta-analysis because study had no placebo group
| | | | 360 mg for 1 yr | N completing | 28
| Jadad | 3 | 2 | Active n/aSimvastatin | N entering | 29
| | | | (Zocor) | N completing | 29
| Population | Adults | | Dosage/Duration NR
| | | 3 | Orlistat | N entering | 27
| | | | 360 mg for 1 yr | N completing | 26
Farrell 1997 | Orlistat | RCT | 1 | Placebo | N entering | ND | Excluded from meta-analysis because of insufficient statistics.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2 | 2 | Orlistat | N entering | ND
| | | | 180 mg for 2 yr | N completing | ND
| Population | Adults | 3 | Orlistat | N entering | ND
| | | | 360 mg for 2 yr | N completing | ND
Finer 2000 | Orlistat | RCT | 1 | Placebo | N entering | 114 | Excluded from meta-analysis because studydid not report weight loss as an outcome
| | | | Dosage/Duration NR | N completing | 61 | .
| Jadad | 4
| | | 2 | Orlistat | N entering | 114
| Populations, | Adult | | 360 mg for 12 mo | N completing | 59
Foreyt 1997 | Orlistat | RCT | 1 | Placebo | N entering | 224 | Excluded from meta-analysis because study reported data on another study already included in analysis (Davidson, 1999).
| | | | Dosage/Duration NR | N completing | 133
| Jadad | 3
| | | 2 | Orlistat | N entering | 668
| Population | Adults | | 360 mg for 52 dy | N completing | 458
Franson 2000 | Orlistat | RCT | 1 | Placebo | N entering | ND | Excluded from meta-analysis because o f insufficient statistics
| Jadad | 2 | | Dosage/Duration NR | N completing | 14
| Jadad | 3
| | | 2 | Orlistat | N entering | ND
| Population s, | Adults Females | | Dosage data not collected for 52 dy | N completing | 20
Gotfredsen 2001 | Orlistat | RCT | 1 | Placebo | N entering | 14 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 16 | Arm 1 = -8.1 (7.5)
| Population | Adults, Females | | 360 mg for 1 yr | N completing | ND | Arm 2 = -11.2 (7.5)
Halpern 2003 | Orlistat | RCT | 1 | Placebo | N entering | 174 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 141
| Jadad | 4 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | 169 | Arm 1 = -2.58 (17.3)
| Population | Adults | | 360 mg for 6 mo | N completing | 139 | Arm 2 = -4.24 (2.7)
Halpern 2001 | Orlistat | RCT | 1 | Placebo | N entering | 174 | Excluded from meta-analysis because study did not report weight loss as an outcome.
| | | | Dosage/Duration NR | N completing | 141
| Jadad | 4
| | | 2 | Orlistat | N entering | 164
| Population | Adults | | 360 mg for 6 mo | N completing | 139
Hanefeld 2002 | Orlistat | RCT | 1 | Placebo | N entering | 188 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 180
| Jadad | 2 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 195 | Arm 1 = -3.4 (5.3)
| Population | Adults | | 360 mg for 48 dy | N completing | 189 | Arm 2 = -5.3 (5.1)
Hanefeld 2001 | Orlistat | RCT | 1 | Placebo | N entering | ND | Excluded from meta-analysis because study did not report weight loss as an outcome.
| | | | Dosage/Duration NR | N completing | 180
| Jadad | 2
| | | 2 | Orlistat | N entering | ND
| Population | Adults | | 360 mg for 48 dy | N completing | 189
Hauptman 2000 | Orlistat | RCT | 1 | Placebo | N entering | 212 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 91
| Jadad | 3 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | 213 | Arm 1 = -4.7 (8.7)
| Population | Adults, Females | | 180 mg for 2 yr | N completing | 120 | Arm 3 = -8 (8.4)
| | | 3 | Orlistat | N entering | 210 | Average weight loss at 12 months in kg
| | | | 360 mg for 2 yr | N completing | 117 | Arm 1 = -4.1 (8.2)
| | | | | | | Arm 3 = -7.9 (8.3)
| | | | | | | Arm 2 was excluded because it is low dosage.
Hill 1999 | Orlistat | RCT | 1 | Placebo | N entering | 188 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 138
| Jadad | 3 | 2 | Orlistat | N entering | 187 | Average weight loss at 12 months in kg
| | | | 90 mg for 52 dy | N completing | 140 | Arm 1 = -5.9 (7.6)
| Population | Adults, Females | 3 | Orlistat | N entering | 173 | Arm 4 = -7.2 (5.5)
| | | | 180 mg for 52 dy | N completing | 133 | Arms 2 and 3 were excluded because they are low dosage.
| | | 4 | Orlistat | N entering | 181
| | | | 360 mg for 52 dy | N completing | 126
Hollander 1998 | Orlistat | RCT | 1 | Placebo | N entering | 159 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 115
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 163 | Arm 1 = -4.3 (7.2)
| Population | Adults | | 360 mg for 52 dy | N completing | 139 | Arm 2 = -6.2 (6.5)
James 1997 | Orlistat | RCT | 1 | Placebo | N entering | 23 | Excluded from meta-analysis because study did not report weight loss as an outcome.
| | | | Dosage/Duration NR | N completing | 12
| Jadad | 2
| | | 2 | Orlistat | N entering | 23
| Population | Adults, Females | | 360 mg for 52 dy | N completing | 14
Karhunen 2000 | Orlistat | RCT | 1 | Placebo | N entering | 36 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 19
| Jadad | 2 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | 36 | Arm 1 = -8.7 (6.3)
| Population | Adults, Females | | 360 mg for 104 dy | N completing | 19 | Arm 2 = -11.2 (6.3)
| | | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -8.6 (6.3)
| | | | | | | Arm 2 = -13.1 (6.3)
Kelley 1997 | Orlistat | RCT | 1 | Placebo | N entering | 159 | Excluded from meta-analysis because study reported data on another study already included in analysis (Hollander, 1998).
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2
| | | 2 | Orlistat | N entering | 163
| Population | Adults | | 360 mg for 52 dy | N completing | ND
Kelley 2002 | Orlistat | RCT | 1 | Placebo | N entering | 276 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 128
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 274 | Arm 1 = -1.3 (3.2)
| Population | Adults | | 360 mg for 1 yr | N completing | 137 | Arm 2 = -3.9 (3.2)
Krempf 2003 | Orlistat | RCT | 1 | Placebo | N entering | 350 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 350
| Jadad | 2 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 346 | Arm 1 = -4.4 (10.4)
| Population | Adults, Females | | 360 mg for 18 mo | N completing | 346 | Arm 2 = -7.3 (9.6)
Krempf 2001 | Orlistat | RCT | 1 | Placebo | N entering | ND | Excluded from meta-analysis because of insufficient statistics.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2
| | | 2 | Orlistat | N entering | ND
| Population | Adults | | 360 mg for 18 mo | N completing | ND
Lindgarde 1999 | Orlistat | RCT | 1 | Placebo | N entering | 185 | Excluded from meta-analysis because study reported data on another study already included in analysis (Lindgarde, 2000).
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 1
| | | 2 | Orlistat | N entering | 188
| Population | Adult | | 120 mg for 1 yr | N completing | ND
Lindgarde 2000 | Orlistat | RCT | 1 | Placebo | N entering | 186 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 164
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 190 | Arm 1 = -4.3 (5.9)
| Population | Adults | | 360 mg for 1 yr | N completing | 159 | Arm 2 = -5.6 (5.2)
Lucas 2003 | Orlistat | RCT | 1 | Placebo | N entering | 188 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 256 | Arm 1 = -6.1 (6.9)
| Population | Adults, Females | | 360 mg for 1 yr | N completing | ND | Arm 2 = -9.9 (6.4)
Micic 1999 | Orlistat | RCT | 1 | Placebo | N entering | 59 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 49
| Jadad | 3 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | 60 | Arm 1 = -7.3 (6.3)
| Population | Adults, Females | | 360 mg for 24 dy | N completing | 50 | Arm 2 = -10.8 (6.3)
Miles 2002 | Orlistat | RCT | 1 | Placebo | N entering | 261 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 254
| Jadad | 2 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 255 | Arm 1 = -1.8 (3.6)
| Population | Adults | | 360 mg for 1 yr | N completing | 250 | Arm 2 = -4.7 (3.9)
Muls 2001 | Orlistat | RCT | 1 | Placebo | N entering | 147 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 127
| Jadad | 3 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | 147 | Arm 1 = -1.9 (4.5)
| Population | Adults, Females | | 360 mg for 24 dy | N completing | 128 | Arm 2 = -4.7 (3.8)
Naumov 2002 | Orlistat | RCT | 1 | Control | N entering | 15 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 15
| Jadad | 1 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | 15 | Arm 1 = -2.9 (3.0)
| Population | Adults | | 360 mg for 6 mo | N completing | 15 | Arm 2 = -7.5 (2.5)
Reaven 2001 | Orlistat | RCT | 1 | Placebo | N entering | 91 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 156 | Arm 1 = -6.8 (6.4)
| Population | Adults | | 360 mg for 1 yr | N completing | ND | Arm 2 = -9.0 (7.9)
Rissanen 2001 | Orlistat | RCT | 1 | Placebo | N entering | ND | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 26
| Jadad | 2 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | ND | Arm 1 = -7.5 (6.3)
| Population | Adults, Females | | 360 mg for 12 mo | N completing | 25 | Arm 2 = -11.6 (6.3)
| | | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -7.2 (6.3)
| | | | | | | Arm 2 = -13.0 (6.3)
Rosenfalck 2002 | Orlistat | RCT | 1 | Placebo | N entering | ND | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 1
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | ND | Arm 1 = -3.8 (4)
| Population | Adults, Females | | 360 mg for 2 yr | N completing | 3 | Arm 2 = -8.6 (8.3)
Rossner 2000 | Orlistat | RCT | 1 | Placebo | N entering | 243 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 136
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 242 | Arm 1 = -6.4 (6.7)
| Population | Adults, Females | | 180 mg for 2 yr | N completing | 140 | Arm 2 = -8.5 (7.3)
| | | 3 | Orlistat | N entering | 244 | Arm 3 = -9.4 (6.4)
| | | | 360 mg for 2 yr | N completing | 159
Samuelsson 2003 | Orlistat | RCT | 1 | Placebo | N entering | 186 | Excluded from meta-analysis because study reported data on another study already included in analysis (Lindgarde, 2000).
| | | | Dosage/Duration NR | N completing | 186
| Jadad | 2
| | | 2 | Orlistat | N entering | 190
| Population | Adults | | 360 mg for 52 dy | N completing | 190
Scheen 2002 | Orlistat | RCT | 1 | Placebo | N entering | ND | Excluded from meta-analysis because follow-up time was too long to pool.
| | | | Dosage/Duration NR | N completing | 1637
| Jadad | 2
| | | 2 | Orlistat | N entering | ND
| Population | Adults | | 360 mg for 4 yr | N completing | 1640
Serrano-Rios 2001 | Orlistat | RCT | 1 | Placebo | N entering | 118 | Excluded from meta-analysis because study did not report weight loss as an outcome.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2
| | | 2 | Orlistat | N entering | 119
| Population | Adults | | 360 mg for 24 dy | N completing | ND
Shi Yi 2001 | Orlistat | RCT | 1 | Placebo | N entering | ND | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 142
| Jadad | 2 | | | | | Average weight loss at 6 months in kg
| | | 2 | Orlistat | N entering | 986 | Arm 1 = -3.0 (6.3)
| Population | Adults | | 360 mg for 6 mo | N completing | 286 | Arm 2 = -6.1 (6.3)
Sjostrom 1998 | Orlistat | RCT | 1 | Placebo | N entering | 343 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | 123 | Average weight loss at 12 months in kg
| Jadad | 3 | | | | | Arm 1 = -6.1 (6.0)
| | | 2 | Orlistat | N entering | 345 | Arm 2 = -10.3 (6.3)
| Population | Adults, Females | | 360 mg for 2 yr | N completing | 133
Sjostrom 2000 | Orlistat | RCT | 1 | Placebo | N entering | 343 | Excluded from meta-analysis because study reported data on another study already included in analysis(Sjostrom, 1998).
| | | | Dosage/Duration NR | N completing | 123
| Jadad | 3
| | | 2 | Orlistat | N entering | 345
| Population | Adults, Females | | 360 mg for 2 yr | N completing | 133
Toornvliet 1997 | Orlistat | RCT | 1 | Placebo | N entering | ND | Excluded from meta-analysis because of insufficient statistics.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2
| | | 2 | Orlistat | N entering | ND
| Population | Adults, Females | | 180 mg for 2 yr | N completing | ND
| | | 3 | Orlistat | N entering | ND
| | | | 360 mg for 2 yr | N completing | ND
Van Gaal 1998 | Orlistat | RCT | 1 | Placebo | N entering | 125 | Excluded from meta-analysis because of insufficient statistics.
| | | | Dosage/Duration NR | N completing | 123
| Jadad | 3 | 2 | Orlistat | N entering | 122
| | | | 90 mg for 6 mo | N completing | 122
| Population | Adults, Females | 3 | Orlistat | N entering | 124
| | | | 180 mg for 6 mo | N completing | 123
| | | 4 | Orlistat | N entering | 122
| | | | 360 mg for 6 mo | N completing | 120
| | | 5 | Orlistat | N entering | 120
| | | | 720 mg for 6 mo | N completing | 117
Van Gaal 1999 | Orlistat | RCT | 1 | Placebo | N entering | 1119 | Excluded from meta-analysis because study did not report weightloss as anoutcome.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 2
| | | 2 | Orlistat | N entering | 1561
| Population | Adults | | 360 mg for 1 yr | N completing | ND
Vidgren 1999 | Orlistat | RCT | 1 | Placebo | N entering | 38 | Included in meta-analysis of orlistat.
| | | | Dosage/Duration NR | N completing | ND
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Orlistat | N entering | 37 | Arm 1 = -7.8 (6.0)
| Population | Adults, Females | | 360 mg for 12 mo | N completing | ND | Arm 2 = -12 (8.2)
Zavoral 1998 | Orlistat | RCT | 1 | Placebo | N entering | 1119 | Excluded from meta-analysis because study did not report weight loss as an outcome.
| | | | Dosage/Duration NR | N completing | 1119
| Jadad | 2
| | | 2 | Orlistat | N entering | 1561
| Population | Adults, Females | | 360 mg for 52 dy | N completing | 1561
Campbell 1977 | Phentermine | RCT | 1 | Placebo | N entering | 37 | Excluded from meta-analysis because drug has existing meta-analysis.
| | | | Dosage/Duration NR | N completing | 32
| Jadad | 4
| | | 2 | Phentermine | N entering | 34
| Population | Adults | | 30 mg for 6 mo | N completing | 34
Wadden 1995 | Sertraline | RCT | 1 | Placebo | N entering | 27 | Excluded from meta-analysis because interventions of interest were not studied. Data summarized narratively.
| | | | Dosage/Duration NR | N completing | 17
| Jadad | 2
| | | 2 | Sertraline | N entering | 26
| Population | Adults, Females | | Variable dose for 54 dy | N completing | 13
Berkowitz 2003 | Sibutramine | RCT | 1 | Placebo | N entering | 39 | Excluded from meta-analysis because drug has existing meta-analysis.
| | | | Dosage/Duration NR | N completing | 39
| Jadad | 4
| | | 2 | Sibutramine | N entering | 43
| Population | Adolescents | | Variable dose for 12 mo | N completing | 43
Cuellar 2000 | Sibutramine | RCT | 1 | Placebo | N entering | 35 | Excluded from meta-analysis because drug has existing meta-analysis.
| | | | Dosage/Duration NR | N completing | 9
| Jadad | 5
| | | 2 | Sibutramine | N entering | 35
| Population | Adults, Adolescents, Females | | 15 mg for 6 mo | N completing | 22
Fanghanel 2000 | Sibutramine | RCT | 1 | Placebo | N entering | 54 | Excluded from meta-analysis because drug has existing meta-analysis.
| | | | Dosage/Duration NR | N completing | 44
| Jadad | 4
| | | 2 | Sibutramine | N entering | 55
| Population | Adults, Adolescents, Females | | 10 mg for 6 mo | N completing | 40
James 2000 | Sibutramine | RCT | 1 | Placebo | N entering | 145 | Excluded from meta-analysis because drug has existing meta-analysis.
| | | | Dosage/Duration NR | N completing | 57
| Jadad | 5
| | | 2 | Sibutramine | N entering | 352
| Population | Adults, Adolescents, Females | | Variable dose for 18 mo | N completing | 204
Bray 2003 | Topiramate | RCT | 1 | Placebo | N entering | 75 | Included in meta-analysis of topiramate.
| | | | Dosage/Duration NR | N completing | 48
| Jadad | 4 | | | | | Average weight loss at 6 months in % weight loss
| | | 2 | Topiramate | N entering | 76 | Arm 1 = -2.6 (4.8)
| Population | Adults, Females | | Variable dose for 24 dy | N completing | 53 | Arm 3 = -4.8 (4.8)
| | | 3 | Topiramate | N entering | 75 | Arm 4 = -6.3 (4.8)
| | | | Variable dose for 24 dy | N completing | 48 | Arms 2 and 5 were excluded because they were of low/high dosage of the same medication.
| | | 4 | Topiramate | N entering | 76
| | | | Variable dose for 24 dy | N completing | 49
| | | 5 | Topiramate | N entering | 78
| | | | Variable dose for 24 dy | N completing | 44
Bray 2002 | Topiramate | RCT | 1 | Placebo | N entering | 79 | Excluded from meta-analysis because study reported data on another study already included in analysis (Bray, 2003).
| | | | Dosage/Duration NR | N completing | 48
| Jadad | 3
| | | 2 | Topiramate | N entering | 79
| Population | Adults | | Variable dose for 24 dy | N completing | 57
| | | 3 | Topiramate | N entering | 79
| | | | Variable dose for 24 dy | N completing | 49
| | | 4 | Topiramate | N entering | 79
| | | | Variable dose for 24 dy | N completing | 50
| | | 5 | Topiramate | N entering | 79
| | | | Variable dose for 1 dy | N completing | 44
Caterson 2003 | Topiramate | RCT | 1 | Placebo | N entering | ND | Included in meta-analysis of topiramate.
| | | | Dosage/Duration NR | N completing | 97
| Jadad | 2 | | | | | Average weight loss at 11 months in % weight
| | | 2 | Topiramate | N entering | ND
| Population | Adults, Fernales | | Variable dose for 44 by | N completing | 93 | Arm 1=1.8 (4.8)
| | | 3 | Topiramate | N entering | ND | Arm 2 = -5.2 (4.8)
| | | | Variable dose for 44 dy | N completing | 98 | Arm 3 = -6.4 (4.8)
Gilliam 2003 | Topiramate | RCT | 1 | Topiramate | N entering | 125 | Excluded from meta-analysis because study had no placebo group.
| | | | Variable dose for 758 dy | N completing | 99
| Jadad | 2
| | | 2 | Topiramate | N entering | 127
| Population | Adults, Adolescents, Children | | Variable dose for 809 dy | N completing | 93
Pud'homme 2003 | Topiramate | RCT | 1 | Placebo | N entering | 35 | Included in meta-analysis of topiramate.
| | | | Dosage/Duration NR | N completing | 29
| Jadad | 2 | | | | | Average weight loss at 6 months in % weight loss
| | | 2 | Topiramate | N entering | 33 | Arm 1 = 0.2 (3.2)
| Population | Adults, Males | | Variable dose for 24 dy | N completing | 20 | Arm 2 = -5.8 (6.4)
Rissanen 2003 | Topiramate | RCT | 1 | Placebo | N entering | ND | Included in meta-analysis of topiramate.
| | | | Dosage/Duration NR | N completing | 103
| Jadad | 2 | | | | | Average weight loss at 15 months in % weight loss
| | | 2 | Topiramate | N entering | ND | Arm 1 = -2.9 (4.8)
| Population | Adults, Females | | Variable dose for 60 dy | N completing | 133 | Arm 2 = -9.1 (4.8)
| | | 3 | Topiramate | N entering | ND | Arm 3 = -12 (4.8)
| | | | Variable dose for 60 dy | N completing | 123 | Arm 4 was excluded because it was a high dosage study.
| | | 4 | Topiramate | N entering | ND
| | | | Variable dose for 60 dy | N completing | 125
Stenlof 2003 | Topiramate | RCT | 1 | Placebo | N entering | ND | Excluded from meta-analysis because study reported data on another study already included in analysis (Stenlof, 2003).
| | | | Dosage/Duration NR | N completing | 78
| Jadad | 2
| | | 2 | Topiramate | N entering | ND
| Population | Adults | | Variable dose for 40 dy | N completing | 74
| | | 3 | Topiramate | N entering | ND
| | | | Variable dose for 40 dy | N completing | 77
Stenlof 2003 | Topiramate | RCT | 1 | Placebo | N entering | ND | Included in meta-analysis of topiramate.
| | | | Dosage/Duration NR | N completing | 137
| Jadad | 2 | | | | | Average weight loss at 10 months in % weight loss
| | | 2 | Topiramate | N entering | ND | Arm 1 = -3.0 (4.8)
| Population | Adults | | Variable dose for 40 dy | N completing | 127 | Arm 2 = -8.2 (4.8)
| | | 3 | Topiramate | N entering | ND | Arm 3 = -10.0 (4.8)
| | | | Variable dose for 40 dy | N completing | 135
Tonstad 2003 | Topiramate | RCT | 1 | Placebo | N entering | 177 | Included in meta-analysis of topiramate.
| | | | Dosage/Duration NR | N completing | 56
| Jadad | 2 | | | | | Average weight loss at 7 months in % weight loss
| | | 2 | Topiramate | N entering | 176 | Arm 1 = -1.9 (4.8)
| Population | Adults | | Variable dose for 28 dy | N completing | 49 | Arm 2 = -5.9 (4.8)
| | | 3 | Topiramate | N entering | 178 | Arm 3 = -6.5 (4.8)
| | | | Variable dose for 28 dy | N completing | 53
Gadde 2003 | Zonisamide | RCT | 1 | Placebo | N entering | 30 | Excluded from meta-analysis because interventions of interest were not studied. Data summarized narratively.
| | | | Dosage/Duration NR | N completing | 17
| Jadad | 5
| | | 2 | Zonisamide | N entering | 30
| Population | Adults, Females | | Variable dose for 32 dy | N completing | 19

Meta-analysis data reported as an average with its standard deviation in parentheses.

NA = Not available or not applicable

NR, ND = Not reported or not described

### Reference List

1 Andersen T, Backer O G, Stokholm K H, et al. Randomized trial of diet and gastroplasty compared with diet alone in morbid obesity. New England journal of medicine. 1984;310(6):352-6. [pmid: 6690963].
2 Andersen T, Stokholm K H, Backer O G, et al. Long-term (5-year) results after either horizontal gastroplasty or very- low-calorie diet for morbid obesity. Int J Obes. 1988;12(4):277-84. [pmid: 3058614].
3 Anderson J W, Greenway F L, Fujioka K, et al. Bupropion SR enhances weight loss: a 48-week double-blind, placebo- controlled trial. Obes Res. 2002;10(7):633-41. [pmid: 12105285].
4 Anderson James W, Greenway Frank, Fujioka Ken, et al. Buproprion SR significantly enhances weight loss when used with a moderate-intensity lifestyle intervention. Diabetes. 2001;50(Supplement 2):A21. [pmid: 11723075].
5 Anderson JW on behalf of the orlistat weight maintenance study grop. Prevention of weight regain after conventional dieting: a 1-year study with orlistat (xenical), a new gastrointestinal lipase inhibitor. Obesity Research 1997;5(Suppl 1):S2.
6 Bakris G, Calhoun D, Egan B, et al. Orlistat improves blood pressure control in obese subjects with treated but inadequately controlled hypertension. J Hypertens. 2002;20(11):2257-67. [pmid: 12409965].
7 Berkowitz R I, Wadden T A, Tershakovec A M, et al. Behavior therapy and sibutramine for the treatment of adolescent obesity: a randomized controlled trial. JAMA. 2003;289(14):1805-12. [pmid: 12684359].
8 Bray G, Klein S, Levy B, Fitchet M, Perry B. Topiramate produces dose-related weight loss in obese patients. Presented at the 62nd American Diabetes Association Scientific Sessions. 2002 (Abstract)
9 Bray G A, Hollander P, Klein S, et al. A 6-Month Randomized, Placebo-Controlled, Dose-Ranging Trial of Topiramate for Weight Loss in Obesity. Obes Res. 2003;11(6):722-733. [pmid: 12805393].
10 Breum L, Bjerre U, Bak J F, et al. Long-term effects of fluoxetine on glycemic control in obese patients with non-insulin-dependent diabetes mellitus or glucose intolerance: influence on muscle glycogen synthase and insulin receptor kinase activity. Metabolism. 1995;44(12):1570-6. [pmid: 8786726].
11 Broom I. Randomised trial of the effect of orlistat on body weight and CVD risk profile in overweight and obese patients with co-morbidities. Int J Obes Relat Metab Disord. 2001;25(Suppl):S106. [pmid: 11933881].
12 Broom I, Hughes E, Dodgson P, et al. The role of orlistat in the treatment of obese patients with mild to moderate hypercholesterolaemia: consequences for coronary risk. Br J Cariol. 2002;9(8):460-8.
13 Broom I, Wilding J, Stott P, et al. Randomised trial of the effect of orlistat on body weight and cardiovascular disease risk profile in obese patients: UK Multimorbidity Study. Int J Clin Pract. 2002;56(7):494-9. [pmid: 12296610].
14 Campbell C J, Bhalla I P, Steel J M, et al. A controlled trial of phentermine in obese diabetic patients. Practitioner. 1977;218(1308):851-5. [pmid: 329259].
15 Caterson I, Astrup A, Zelissen P, Guy-Grand B, Carruba M, Levy B, et al. The long-term effect of Topiramate on body weight maintenance after low-calorie diet-induced wieght loss in obese subjects. Presented at the 18th International Diabetes Federation Congress. 2003 (Abstract)
16 Chiasson JL, Lau W, Leiter LA. Fluoxetine has potential in obese NIDDM--multi-center Canadian Trial. Diabetes 1989;38 ((suppl 2)):603.
17 Connolly V M, Gallagher A, Kesson C M. A study of fluoxetine in obese elderly patients with type 2 diabetes. Diabet Med. 1995;12(5):416-8. [pmid: 7648804].
18 Croft H, Houser T L, Jamerson B D, et al. Effect on body weight of bupropion sustained-release in patients with major depression treated for 52 weeks. Clin Ther. 2002;24(4):662-72. [pmid: 12017410].
19 Cuellar G E, Ruiz A M, Monsalve M C, et al. Six-month treatment of obesity with sibutramine 15 mg; a double-blind, placebo-controlled monocenter clinical trial in a Hispanic population. Obesity research. 2000;8(1):71-82. [pmid: 10678261].
20 Darga L L, Carroll-Michals L, Botsford S J, et al. Fluoxetine's effect on weight loss in obese subjects. Am J Clin Nutr. 1991;54(2):321-5. [pmid: 1858696].
21 Davidson M H, Hauptman J, DiGirolamo M, et al. Weight control and risk factor reduction in obese subjects treated for 2 years with orlistat: a randomized controlled trial. JAMA. 1999;281(3):235-42. [pmid: 9918478].
22 Deerochanawong Chaicharn. Effect of treatment with orlistat in overweight or obese Thai patients with type 2 diabetes. Diabetes. 2001;50(Supplement 2):A433. [pmid: 11723075].
23 Derosa G, Mugellini A, Ciccarelli L, et al. Randomized, double-blind, placebo-controlled comparison of the action of orlistat, fluvastatin, or both an anthropometric measurements, blood pressure, and lipid profile in obese patients with hypercholesterolemia prescribed a standardized diet. Clin Ther. 2003;25(4):1107-22. [pmid: 12809960].
24 Derosa Giuseppe, Mugellini Amedeo, Ciccarelli Leonardina, et al. Effects of orlistat, simvastatin, and orlistat+simvastatin in obese patients with hypercholesterolemia: A randomized, open-label trial. Current Therapeutic Research. 2002;63(9):621-633.
25 Fanghanel G, Cortinas L, Sanchez-Reyes L, et al. A clinical trial of the use of sibutramine for the treatment of patients suffering essential obesity. Int J Obes Relat Metab Disord. 2000;24(2):144-50. [pmid: 10702763].
26 Farrell J. Long-term management of obesity in primary care: the role of Orlistat (Xenical). Obesity Research 1997;(5):10S.
27 Finer N, James W P, Kopelman P G, et al. One-year treatment of obesity: a randomized, double-blind, placebo- controlled, multicentre study of orlistat, a gastrointestinal lipase inhibitor. Int J Obes Relat Metab Disord. 2000;24(3):306-13. [pmid: 10757623].
28 Foreyt J. A 2-year multicenter study of the effects of Orlistat (Xenical) on weight loss and disease risk factors. Obesity Research 1997;(5):53.
29 Franson K, Rossner S. Fat intake and food choices during weight reduction with diet, behavioral modification and a lipase inhibitor. J Intern Med. 2000;247(5):607-14. [pmid: 10810001].
30 Gadde K M, Franciscy D M, Wagner H R, et al. Zonisamide for weight loss in obese adults: a randomized controlled trial. JAMA. 2003;289(14):1820-5. [pmid: 12684361].
31 Gadde K M, Parker C B, Maner L G, et al. Bupropion for weight loss: an investigation of efficacy and tolerability in overweight and obese women. Obes Res. 2001;9(9):544-51. [pmid: 11557835].
32 Gilliam F G, Veloso F, Bomhof M A, et al. A dose-comparison trial of topiramate as monotherapy in recently diagnosed partial epilepsy. Neurology. 2003;60(2):196-202. [pmid: 12552030].
33 Goldstein D J, Rampey A H Jr, Enas G G, et al. Fluoxetine: a randomized clinical trial in the treatment of obesity. Int J Obes Relat Metab Disord. 1994;18(3):129-35. [pmid: 8186809].
34 Gotfredsen A, Westergren Hendel H, Andersen T. Influence of orlistat on bone turnover and body composition. Int J Obes Relat Metab Disord. 2001;25(8):1154-60. [pmid: 11486790].
35 Gray D S, Fujioka K, Devine W, et al. Fluoxetine treatment of the obese diabetic. Int J Obes Relat Metab Disord. 1992;16(3):193-8. [pmid: 1317828].
36 Gray D S, Fujioka K, Devine W, et al. A randomized double-blind clinical trial of fluoxetine in obese diabetics. Int J Obes Relat Metab Disord. 1992;16 Suppl 4:S67-72. [pmid: 1338389].
37 Halpern A, Mancini M C, Suplicy H, et al. Latin-American trial of orlistat for weight loss and improvement in glycemic profile in obese diabetic patients. Diabetes Obes Metab. 2003;5(3):180-8. [pmid: 12681025].
38 Halpern Alfredo. Latin-American multicentric study with orlistat in overweight or obese patients with type 2 diabetes. Diabetes. 2001;50(Supplement 2):A437. [pmid: 11723075].
39 Hanefeld M, Platon J, Sachse G. Orlistat promotes weight loss and improves glycemic control in overweight patients with type 2 diabetes. Diabetologia. 2001;44(Supplement 1):A231. [pmid: 11841101].
40 Hanefeld M, Sachse G. The effects of orlistat on body weight and glycemic control in overweight patients with type 2 diabetes: a randomized, placebo-controlled trial. Diabetes Obes Metab. 2002;4(6):415-23. [pmid: 12406041].
41 Hauptman J, Lucas C, Boldrin M N, et al. Orlistat in the long-term treatment of obesity in primary care settings. Arch Fam Med. 2000;9(2):160-7. [pmid: 10693734].
42 Hill J O, Hauptman J, Anderson J W, et al. Orlistat, a lipase inhibitor, for weight maintenance after conventional dieting: a 1-y study. Am J Clin Nutr. 1999;69(6):1108-16. [pmid: 10357727].
43 Hollander P A, Elbein S C, Hirsch I B, et al. Role of orlistat in the treatment of obese patients with type 2 diabetes. A 1-year randomized double-blind study. Diabetes Care. 1998;21(8):1288-94. [pmid: 9702435].
44 Jain A K, Kaplan R A, Gadde K M, et al. Bupropion SR vs. placebo for weight loss in obese patients with depressive symptoms. Obes Res. 2002;10(10):1049-56. [pmid: 12376586].
45 James W P, Astrup A, Finer N, et al. Effect of sibutramine on weight maintenance after weight loss: a randomised trial. STORM Study Group. Sibutramine Trial of Obesity Reduction and Maintenance. Lancet. 2000;356(9248):2119-25. [pmid: 11191537].
46 James W P, Avenell A, Broom J, et al. A one-year trial to assess the value of orlistat in the management of obesity. Int J Obes Relat Metab Disord. 1997;21(Suppl 3):S24-30. [pmid: 9426390].
47 Karhunen L, Franssila-Kallunki A, Rissanen P, et al. Effect of orlistat treatment on body composition and resting energy expenditure during a two-year weight-reduction programme in obese Finns. Int J Obes Relat Metab Disord. 2000;24(12):1567-72. [pmid: 11126207].
48 Kelley D. A one-year study of weight loss and glycemic control in type II diabetics following orlistat (xenicalTM) treatment. Obesity Research. 1997;5(Suppl 1):21. [pmid: 9467676].
49 Kelley D E, Bray G A, Pi-Sunyer F X, et al. Clinical efficacy of orlistat therapy in overweight and obese patientswith insulin-treated type 2 diabetes: a 1-year randomized controlled trial. Diabetes Care. 2002;25(6):1033-1041. [pmid: 12032111].
50 Krempf M, Louvet J P, Allanic H, et al. Weight reduction and long-term maintenance after 18 months treatment with orlistat for obesity. Int J Obes Relat Metab Disord. 2003;27(5):591-7. [pmid: 12704403].
51 Krempf Michel, Louvet Jean-Pierre, Allanic Hubert, et al. Orlistat associated with a hypocaloric diet in obese patients promotes and maintains weight loss during an 18-month period. Diabetes. 2001;50(Supplement 2):A21. [pmid: 11723075].
52 Lindgarde F. Orlistat improves coronary heart disease in high-risk obese population: The Swedish Multimorbidity Study. Obesity Research 1999;(7):70.
53 Lindgarde F. The effect of orlistat on body weight and coronary heart disease risk profile in obese patients: the Swedish Multimorbidity Study. J Intern Med. 2000;248(3):245-54. [pmid: 10971792].
54 Lucas C P, Boldrin M N, Reaven G M. Effect of orlistat added to diet (30% of calories from fat) on plasma lipids, glucose, and insulin in obese patients with hypercholesterolemia. Am J Cardiol. 2003;91(8):961-4. [pmid: 12686336].
55 Marcus M D, Wing R R, Ewing L, et al. A double-blind, placebo-controlled trial of fluoxetine plus behavior modification in the treatment of obese binge-eaters and non-binge- eaters. Am J Psychiatry. 1990;147(7):876-81. [pmid: 2192563].
56 McKay R H. Long-term use of diethylpropion in obesity. Curr Med Res Opin. 1973;1(8 ):489-93. [pmid: 4779253].
57 Mendoza Espejo R, Diaz Perez de Madrid J, Buitrago F. [Effectiveness of serotonergic agonists in the treatment of obese patients]. Aten Primaria. 1995;16(6):364-6. [pmid: 7488690].
58 Michelson D, Amsterdam JD, Kim Y, Sundell K. Changes in weight during a one-year trial with fluoxetine. 152nd Annual Meeting of the American Psychiatric Association. May 15th–20th, 1999; Washington, DC, USA. 1999.
59 Micic D, Ivkovic-Lazar T, Dragojevic R, et al. Orlistat, a gastrointestinal lipase inhibitor, in therapy of obesity with concomitant hyperlipidemia. Med Pregl. 1999;52(9-10):323-33. [pmid: 10841675].
60 Miles J M, Leiter L, Hollander P, et al. Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes Care. 2002;25(7):1123-8. [pmid: 12087008].
61 Muls E, Kolanowski J, Scheen A, et al. The effects of orlistat on weight and on serum lipids in obese patients with hypercholesterolemia: a randomized, double-blind, placebo-controlled, multicentre study. Int J Obes Relat Metab Disord. 2001;25(11):1713-21. [pmid: 11753595].
62 Naumov V G, Lupanov V P, Dotsenko IuV, et al. [Six-month xenical (orlistat) therapy of patients with stable angina pectoris concomitant with obesity and hyperlipidemia]. Ter Arkh. 2002;74(1):47-51. [pmid: 11878059].
63 O'Kane M, Wiles P G, Wales J K. Fluoxetine in the treatment of obese type 2 diabetic patients. Diabet Med. 1994;11(1):105-10. [pmid: 8181239].
64 Pedrinola F, Sztejnsznajd C, Lima N, et al. The addition of dexfenfluramine to fluoxetine in the treatment of obesity: a randomized clinical trial. Obes Res. 1996;4(6):549-54. [pmid: 8946439].
65 Pud'homme D, Firchet M, Almeras N, Dumont M, Tremblay A, Despres JP. Six-month Topiramate treatment reduces body weight and blood pressure. Presented at the North American Association for the Study of Obesity 2003 Annual Scientific Meeting. 2003 (Abstract)
66 Reaven G, Segal K, Hauptman J, et al. Effect of orlistat-assisted weight loss in decreasing coronary heart disease risk in patients with syndrome X. Am J Cardiol. 2001;87( 7):827-31. [pmid: 11741556].
67 Ricca Valdo, Mannucci Edoardo, Mezzani Barbara, et al. Fluoxetine and fluvoxamine combined with individual cognitive-behaviour therapy in binge eating disorder: A one-year follow-up study. Psychotherapy and Psychosomatics. 2001;70(6):298-306. [pmid: 11598429].
68 Rissanen A, Wilding J, Van Gaal L, Vercruysse F, Perry B, Fitchet M. The effect of Topiramate on body weight and blood pressure in obese subjects: A long-term, randomized, placebo-controlled trial. Presented at the 18th Internation Diabetes Federation Congress. 2003 (Abstract)
69 Rissanen P, Vahtera E, Krusius T, et al. Weight change and blood coagulability and fibrinolysis in healthy obese women. Int J Obes Relat Metab Disord. 2001;25(2):212-8. [pmid: 11410822].
70 Rosenfalck A M, Hendel H, Rasmussen M H, et al. Minor long-term changes in weight have beneficial effects on insulin sensitivity and beta-cell function in obese subjects. Diabetes Obes Metab. 2002;4(1):19-28. [pmid: 11890163].
71 Rossner S, Sjostrom L, Noack R, et al. Weight loss, weight maintenance, and improved cardiovascular risk factors after 2 years treatment with orlistat for obesity. European Orlistat Obesity Study Group. Obes Res. 2000;8(1):49-61. [pmid: 10678259].
72 Samuelsson L, Gottsater A, Lindgarde F. Decreasing levels of tumor necrosis factor alpha and interleukin 6 during lowering of body mass index with orlistat or placebo in obese subjects with cardiovascular risk factors. Diabetes Obes Metab. 2003;5(3):195-201. [pmid: 12681027].
73 Scheen A J. [Info-congress. Prevention of type 2 diabetes in obese patients: first results with orlistat in the XENDOS study]. Rev Med Liege. 2002;57(9):617-21. [pmid: 12440353].
74 Serrano-Rios Manuel, Armero Franciso, Genis Mar. Orlistat efficacy on weight loss in over-weight or obese patients with type 2 diabetes mellitus. Spanish randomized clinical trial. Diabetes. 2001;50(Supplement 2):A131. [pmid: 11723075].
75 Shi Yi Fan, Zhu Jun Ren. Effect of orlistat on weight loss and glycemic control in overweight Chinese patients with type 2 diabetes. Diabetes. 2001;50(Supplement 2):A101-A102. [pmid: 11723075].
76 Sjostrom L, Rissanen A, Andersen T, et al. [Randomized placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients]: <Original> Randomizirovannoe platsebo-kontroliruemoe issledovanie po primeneniiu orlistata dlia umen'sheniia massy tela i predotvrashcheniia ee povtornoi pribavki u lits s ozhireniem. Terapevticheskii arkhiv. 2000;72(8):50-4. [pmid: 11019429].
77 Sjostrom L, Rissanen A, Andersen T, et al. Randomised placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients. European Multicentre Orlistat Study Group. Lancet. 1998;352(9123):167-72. [pmid: 9683204].
78 Stenlof K, Rossner S, Vercruysse F, Perry B, Fitchet M, Sjostrom L. Safety and efficacy of Topiramate in the treatment of Type II diabetic obese subjects: A randomized, double-blind, placebo-controlled trial. Presented at the 18th International Diabetes Federation Congress. 2003 (Abstract)
79 Stenlof K, Rossner S, Vercruysse F, Perry B, Fitchet M, Sjostrom L. Topiramate decreases weight and blood pressure in obese subjects with Type II diabetes. Presented at the North American Association of rthe Study of Obesity 2003 Annual Scientific Meeting. 2003 (Abstract)
80 Tonstad S, Levy B, Perry B, Fitchet M. Topiramate decreases weight and lowers blood pressure in obese subjects with hypertension. Presented at the North American Association for the Study of Obesity 2003 Annual Scientific Meeting. 2003 (Abstract)
81 Toornvliet A C, Pijl H, Frolich M, et al. Insulin and leptin concentrations in obese humans during long-term weight loss. Neth J Med. 1997;51(3):96-102. [pmid: 9360409].
82 Van Gaal L, Mertens I, Peiffer F, et al. Effect of weight loss treatment with Orlistat on blood pressure and heart rate among obese patients. Obesity Research. 1999;7(Suppl 1):69. [pmid: 10590785].
83 Van Gaal L F, Broom J I, Enzi G, et al. Efficacy and tolerability of orlistat in the treatment of obesity: a 6- month dose-ranging study. Orlistat Dose-Ranging Study Group. Eur J Clin Pharmacol. 1998;54(2):125-32. [pmid: 9626916].
84 Vidgren H M, Agren J J, Valve R S, et al. The effect of orlistat on the fatty acid composition of serum lipid fractions in obese subjects. Clin Pharmacol Ther. 1999;66(3):315-22. [pmid: 10511068].
85 Wadden T A, Bartlett S J, Foster G D, et al. Sertraline and relapse prevention training following treatment by very- low-calorie diet: a controlled clinical trial. Obes Res. 1995;3(6):549-57. [pmid: 8653531].
86 Zavoral J H. Treatment with orlistat reduces cardiovascular risk in obese patients. J Hypertens. 1998;16(12 Pt 2):2013-7. [pmid: 9886906].

## Evidence Table 2. Surgery

Table 2 Evidence Table. Surgery

First author Year | Study design and Quality Population | | Arm | Type of surgery | Sample size | | Meta-analysis data
Abu-Abeid 2003 | Design | Case Series | 1 | LAP adjustable band | N entering | 11 | Included in meta-analysis of weight loss.
| | | | | N completing | 11
| Jadad | NA | | | | | Average weight loss at 23 months in bmi
| | | | | | | Arm 1 = -14.5 (7.6)
| Population | Adolescents, Children, Females
Abu-Abeid 1999 | Design | Case Series | 1 | LAP adjustable band | N entering | 391 | Included in meta-analysis of weight loss.
| | | | | N completing | 356
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | | | | | Arm 1 = -11.2 (5.9)
| Population | Adults, Adolescents, Females
| | | | | | | Average weight loss at 18 months in bmi
| | | | | | | Arm 1 = -13.3 (7.6)
Aghahosseini 2001 | Design | Case Series | 1 | LAP adjustable band | N entering | 84 | Included in meta-analysis of weight loss.
| | | | | N completing | 84
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -29.2 (15.5)
| Population | Adults
| | | | | | | Average weight loss at 24 months in kg
| | | | | | | Arm 1 = -34.6 (20.3)
Agren 1989 | Design | RCT | 1 | Open VBG | N entering | 27 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | 1 | 2 | Open loop gastric bypass | N entering | 25
| | | | | N completing | ND
| Population | Adults | 3 | Open nonadjustable band | N entering | 25
| | | | | N completing | ND
Al-Jiffry. 2003 | Design | Case Series | 1 | Control | N entering | 26 | Excluded from meta-analysis based on expert opinion.
| | | | | N completing | 26
| Jadad | NA | 2 | LAP adjustable band | N entering | 14
| | | | | N completing | 10
| Population | Adults
Alden 1977 | Design | Case Serie | 1 | Jejunal-ileal bypass | N entering | 100 | Included in meta-analysis of weight loss
| | | | | N completing | ND
| Jadad | NA | 2 | Open loop gastric bypass | N entering | 100 | Average weight loss at 12 months in kg
| | | | | N completing | ND | Arm 1 = -40.6 (14.8)
| Population | Adults, Adolescents, Females | | | | | Arm 2 = -40.2 (11.8)
Alper 2000 | Design | Case Series | 1 | Open VBG | N entering | 450 | Included in meta-analysis of weight loss.
| Jadad | NA | | | N completing | 300
| | | | | | | Average weight loss at 62 months in kg
| Population | Adults, Adolescents | | | | | Arm 1 = -37.0 (23.2)
Andersen 1984 | Design | RCT | 1 | Diethylpropion | N entering | 30 | Included in meta-analysis of weight loss.
| | | | | N completing | 29
| Jadad | 2 | 2 | Open VBG | N entering 30 | 30 | Average weight loss at 12 months in kg
| | | | | N completing | 26 | Arm 1 = -18.0 (15.5)
| Population | Adults, Females | | | | | Arm 2 = -22.0 (15.5)
| | | | | | | Average weight loss at 24 months in kg
| | | | | | | Arm 1 = -8.0 (20.3)
| | | | | | | Arm 2 = -30.5 (20.3)
Andersen 1982 | Design | RCT | 1 | Open VBG | N entering | 30 | Included in meta-analysis of weight loss.
| | | | | N completing | 28
| Jadad | 1 | 2 | Very low calorie diet(<1000) | N entering | 30 | Average weight loss at 6 months in kg
| | | | | N completing | 30 | Arm 1 = -26.6 (15.5)
| Population | Adults, Females | | | | | Arm 2 = -25.9 (15.5)
Andersen 1987 | Design | RCT | 1 | Open gastroplasty | N entering | 22 | Included in meta-analysis of weight loss.
| | | | | N completing | 20
| Jadad | 1 | 2 | Open VBG | N entering | 23 | Average weight loss at 12 months in kg
| | | | | N completing | 21 | Arm 1 = 1.0 (12.8)
| Population | Adults, Females | | | | | Arm 2 = -9.7 (14.2)
Andersen 1988 | Design | RCT | 1 | Open VBG | N entering | 30 | Excluded from meta-analysis because study reported data on another study already included in analysis (253).
| | | | | N completing | 26
| Jadad | 2 | 2 | Diethylpropion | N entering | 30
| | | | | N completing | 30
| Population | Adults, Females
Anderson 1980 | Design | Case Series | 1 | Open RYGB, std | N entering | 33 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | NA | 2 | Open VBG | N entering 8 | 8
| | | | | N completing | ND
| Population | Adults, Adolescents, Children
Anthone 2003 | Design | Case Series | 1 | BPD/Duodenal switch | N entering | 701 | Included in meta-analysis of weight loss.
| | | | | N completing | 50
| Jadad | NA | | | | | Average weight loss at 12 months in lbs
| | | | | | | Arm 1 = -127.0 (41.0)
| Population | Adults, Females
| | | | | | | Average weight loss at 60 months in lbs
| | | | | | | Arm 1 = -118.0 (46.0)
Balsige 2000 | Design | Case Series | 1 | Open VBG | N entering | 73 | Included in meta-analysis of weight loss.
| | | | | N completing | 70
| Jadad | NA | | | | | Average weight loss at 120 months in kg
| | | | | | | Arm 1 = -28.0 (33.4)
| Population | Adults, Females
Baltasar 1998 | Design | Case Series | 1 | Open VBG | N entering | 9 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | 2 | Open VBG | N entering | 81 | Average weight loss at 12 months in kg
| | | | | N completing | ND | Arm 4 = -32.0 (15.5)
| Population | Adults, Adolescents | 3 | Open VBG | N entering | 86
| | | | | N completing | ND | Average weight loss at 114 months in kg
| | | | | | | Arm 4 = -32.0 (20.3)
| | | | | | | Arms 1, 2, 3 combined into single arm 4.
Belachew 1998 | Design | Case Series | 1 | LAP adjustable band | N entering | 350 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | | | | | Arm 1 = -11.0 (5.9)
| Population | Adults, Females
| | | | | | | Average weight loss at 41 months in bmi
| | | | | | | Arm 1 = -15.0 (7.6)
Belachew 2002 | Design | Case Series | 1 | LAP adjustable band | N entering | 763 | Included in meta-analysis of weight loss.
| | | | | N completing | 687
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | | | | | Arm 1 = -10.0 (5.9)
| Population | Adults, Females
| | | | | | | Average weight loss at 48 months in bmi
| | | | | | | Arm 1 = -12.0 (7.6)
Bloomston 1997 | Design | Case Series | 1 | Open VBG | N entering | 133 | Excluded from meta-analysis because weight loss not reported by surgery type.
| | | | | N completing | ND
| Jadad | NA | 2 | Open RYGB, std | N entering | ND
| | | | | N completing | 3
| Population | Adults, Females
Breaux 1995 | Design | Case Series | 1 | Open VBG | N entering | 5 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 5
| Jadad | NA | 2 | Open RYGB, std | N entering | 13
| | | | | N completing | 13
| Population | Adults, Adolescents, Children | 3 | BPD/Duodenal switch | N entering | 4
| | | | | N completing | 4
Brolin 1992 | Design | RCT | 1 | Open RYGB, std | N entering | 22 | Included in meta-analysis of weight loss.
| | | | | N completing | 22
| Jadad | 1 | 2 | Open RYGB, long | N entering | 23 | Average weight loss at 12 months in lbs
| | | | | N completing | 23 | Arm 1 = -118.0 (35.0)
| Population | Adults | | | | | Arm 2 = -140.0 (41.0)
| | | | | | | Average weight loss at 48 months in lbs
| | | | | | | Arm 1 = -140.0 (63.0)
| | | | | | | Arm 2 = -159.0 (70.0)
Brolin 2000 | Design | Case Series | 1 | Open gastroplasty | N entering | 56 | Excluded from meta-analysis because weight loss not reported by surgery type.
| | | | | N completing | ND
| Jadad | NA | 2 | Open VBG | N entering | 30
| | | | | N completing | ND
| Population | Adults | 3 | Open RYGB, std | N entering | 565
| | | | | N completing | ND
Brolin 1994 | Design | Case Series | 1 | Open VBG | N entering | 30 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | 2 | Open RYGB, std | N entering | 108 | Average weight loss at 12 months in lbs
| | | | | N completing | ND | Arm 1 = -74.0 (23.0)
| | | | | | | Arm 2 = -91.0 (34.1)
| Population | Adults, Females
| | | | | | | Average weight loss at 48 months in lbs
| | | | | | | Arm 1 = -57.0 (44.7)
| | | | | | | Arm 2 = -90.0 (44.7)
Buckwalter 1977 | Design | RCT | 1 | Jejunal-ileal bypass | N entering | 19 | Included in meta-analysis of weight loss.
| | | | | N completing | 6
| Jadad | 2 | 2 | Open RYGB, std | N entering | 19 | Average weight loss at 12 months in kg
| | | | | N completing | 6 | Arm 1 = -31.5 (15.5)
| Population | Adults, Females | | | | | Arm 2 = -43.0 (15.5)
Capella 1996 | Design | Case Series | 1 | Open VBG | N entering | 329 | Included in meta-analysis of weight loss.
| | | | | N completing | 121
| Jadad | NA | 2 | Open RYGB, std | N entering | 623 | Average weight loss at 60 months in lbs
| | | | | N completing | 65 | Arm 1 = -66.0 (44.7)
| Population | Adults, Females | | | | | Arm 2 = -100.0 (44.7)
Choban 2002 | Design | RCT | 1 | Open RYGB, std | N entering | 35 | Included in meta-analysis of weight loss.
| | | | | N completing | 33
| Jadad | 2 | 2 | Open RYGB, std | N entering | 34 | Average weight loss at 12 months in kg
| | | | | N completing | 34 | Arm 1 = -44.0 (15.5)
| Population | Adults, Females | 3 | Open RYGB, std | N entering | 33 | Arm 2 = -39.0 (15.5)
| | | | | N completing | 33 | Arm 3 = -60.0 (15.5)
| | | 4 | Open RYGB, long | N entering | 31 | Arm 4 = -64.0 (15.5)
| | | | | N completing | 28
| | | | | | | Average weight loss at 36 months in kg
| | | | | | | Arm 1 = -41.0 (20.3)
| | | | | | | Arm 2 = -31.0 (20.3)
| | | | | | | Arm 3 = -59.0 (20.3)
Choban 1999 | Design | Case Series | 1 | Open RYGB, std | N entering | 107 | Included in meta-analysis of weight loss
| | | | | N completing | 54
| Jadad | NA | | | | | Average weight loss at 23 months in kg
| | | | | | | Arm 1 = -42.0 (20.3)
| Population | Adults, Females
Choi 1999 | Design | Case Series | 1 | Open VBG | N entering | ND | Included in meta-analysis of weight loss
| | | | | N completing | 17
| Jadad | NA | 2 | Open RYGB, std | N entering | ND | Average weight loss at 12 months in kg
| | | | | N completing | 12 | Arm 1 = -39.3 (15.5)
| Population | Adults, Females | | | | | Arm 2 = -46.7 (15.5)
| | | | | | | Average weight loss at 19 months in kg
| | | | | | | Arm 1 = -38.4 (15.5)
| | | | | | | Arm 2 = -54.6 (15.5)
Cook 1999 | Design | Case Series | 1 | Open RYGB, std | N entering | 100 | Excluded from meta-analysis because weight loss not reported by surgery type
| | | | | N completing | 100
| Jadad | NA
| Population | Adults, Females
Courcoulas 2003 | Design | Case Series | 1 | LAP RYGB, std | N entering | 80 | Included in meta-analysis of weight loss
| | | | | N completing | 12
| Jadad | NA | 2 | Open RYGB, std | N entering | 80 | Average weight loss at 12 months in bmi
| | | | | N completing | 12 | Arm 1 = -15.2 (5.9)
| Population | Adults, Females | | | | | Arm 2 = -15.1 (5.9)
Crampton 1997 | Design | Case Series | 1 | Open RYGB, std | N entering | 64 | Included in meta-analysis of weight loss
| | | | | N completing | 6
| Jadad | NA | | | | | Average weight loss at 24 months in kg
| | | | | | | Arm 1 = -48.0 (20.5)
| Population | Adults, Females
Dargent 1999 | Design | Case Series | 1 | LAP adjustable band | N entering | 500 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | NA
| Population | Adults, Adolescents, Females
Das 2003 | Design | Case Series | 1 | Open RYGB, std | N entering | 20 | Included in meta-analysis of weight loss.
| | | | | N completing | 20
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -44.7 (14.6)
| Population | Adults, Females
Davila-Cervantes 2000 | Design | Case Series | 1 | Open VBG | N entering | 20 | Included in meta-analysis of weight loss.
| | | | | N completing | 19
| Jadad | NA | 2 | LAP VBG | N entering | 20 | Average weight loss at 12 months in kg
| | | | | N completing | 20 | Arm 1 = -31.0 (15.5)
| Population | Adults, Females | | | | | Arm 2 = -28.0 (15.5)
de Csepel 2001 | Design | Case Series | 1 | LAP RYGB, std | N entering | 7 | Excluded from meta-analysis because study sample size < 10.
| | | | | N completing | 7
| Jadad | NA
| Population | Adults, Females
De Luca 2000 | Design | Case Series | 1 | LAP adjustable band | N entering | 22 | Included in meta-analysis of weight loss.
| | | | | N completing | 22
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | 2 | Open adjustable band | N entering | 47 | Arm 1 = -35.1 (15.5)
| Population | Adults, Females | | | N completing | 47 | Arm 2 = -25.1 (15.5)
| | | | | | | Average weight loss at 36 months in kg
| | | | | | | Arm 1 = -54.9 (20.3)
| | | | | | | Arm 2 = -43.0 (20.3)
de Wit 1999 | Design | RCT | 1 | LAP adjustable band | N entering | 25 | Included in meta-analysis of weight loss.
| | | | | N completing | 25
| Jadad | 2 | 2 | Open adjustable band | N entering | 25 | Average weight loss at 12 months in kg
| | | | | N completing | 24 | Arm 1 = -35.0 (15.5)
| Population | Adults | | | | | Arm 2 = -34.4 (15.5)
de Zwaan 2002 | Design | Case Series | 1 | Control | N entering | 164 | Included in meta-analysis of weight loss.
| | | | | N completing | 110
| Jadad | NA | 2 | Open RYGB, std | N entering | 100 | Average weight loss at 168 months in bmi
| | | | | N completing | 78 | Arm 2 = -11.0 (6.7)
| Population | Adults, Adolescents, Females | | | | | Arm 1 excluded because mean weight loss not reported.
DeMaria 2000 | Design | Case Series | 1 | LAP adjustable band | N entering | 300 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 115
| Jadad | NA
| Population | Adults
DeMaria 2001 | Design | Case Series | 1 | LAP adjustable band | N entering | 37 | Included in meta-analysis of weight loss.
| | | | | N completing | 4
| Jadad | NA | | | | | Average weight loss at 12 months in lbs
| | | | | | | Arm 1 = -44.0 (34.1)
| Population | Adults, Females
| | | | | | | Average weight loss at 36 months in lbs
| | | | | | | Arm 1 = -61.0 (44.7)
Doherty 2002 | Design | Case Series | 1 | Open adjustable band | N entering | 40 | Included in meta-analysis of weight loss.
| | | | | N completing | 13
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| Population | Adults | 2 | LAP adjustable band | N entering | 22 | Arm 1 = -34.0 (15.5)
| | | | | N completing | 13 | Arm 2 = -19.0 (15.5)
| | | | | | | Average weight loss at 72 months in kg
| | | | | | | Arm 1 = -21.0 (20.3)
| | | | | | | Arm 2 = -10.0 (20.3)
Doherty 1998 | Design | Case Series | 1 | Open adjustable band | N entering | 40 | Included in meta-analysis of weight loss.
| | | | | N completing | 24
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -35.0 (15.5)
| Population | Adults
| | | | | | | Average weight loss at 48 months in kg
| | | | | | | Arm 1 = -29.0 (20.3)
Dolan 2003 | Design | Case Series | 1 | LAP adjustable band | N entering | 17 | Included in meta-analysis of weight loss.
| | | | | N completing | 17
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -30.9 (11.6)
| Population | Adults, Adolescents, Children
| | | | | | | Average weight loss at 24 months in kg
| | | | | | | Arm 1 = -35.6 (11.8)
Doldi 2000 | Design | Case Series | 1 | Open adjustable band | N entering | 64 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 64
| Jadad | NA
| | | 2 | LAP adjustable band | N entering | 109
| Population | Adults, Females | | | N completing | 109
Dymek 2002 | Design | Case Series | 1 | Control | N entering | 80 | Included in meta-analysis of weight loss.
| | | | | N completing | 80
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | Open RYGB, std | N entering | 236 | Arm 2 = -18.3 (5.9)
| Population | Adults, Females | | | N completing | ND | Arm 1 excluded because weight loss was not reported
Feng 2002 | Design | Case Series | 1 | BPD/Duodenal switch | N entering | 40 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 40
| Jadad | NA
| Population | Adults
Field 1992 | Design | Case Series | 1 | Open VBG | N entering | 36 | Included in meta-analysis of weight loss.
| | | | | N completing | 11
| Jadad | NA | | | | | Average weight loss at 120 months in bmi
| | | | | | | Arm 1 = -7.5 (7.6)
| Population | Adults, Adolescents, Females
Fielding 1999 | Design | Case Series | 1 | LAP adjustable band | N entering | 335 | Included in meta-analysis of weight loss.
| | | | | N completing | 308
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -37.0 (10.0)
| Population | Adults
| | | | | | | Average weight loss at 18 months in kg
| | | | | | | Arm 1 = -41.0 (18.0)
Fobi 1993 | Design | Case Series | 1 | Open VBG | N entering | 100 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 43
| Jadad | NA | 2 | Open RYGB, std | N entering | 100
| | | | | N completing | 46
| Population | Adults, Females
Fobi 2001 | Design | CCT | 1 | Open RYGB, std | N entering | 25 | Included in meta-analysis of weight loss.
| | | | | N completing | 22
| Jadad | 0 | 2 | Open RYGB, std | N entering | 25 | Average weight loss at 12 months in lbs
| | | | | N completing | 20 | Arm 1 = -20.6 (34.1)
| Population | Adults, Females | | | | | Arm 2 = -18.7 (34.1)
| | | | | | | Average weight loss at 72 months in lbs
| | | | | | | Arm 1 = -21.6 (44.7)
| | | | | | | Arm 2 = -21.7 (44.7)
Forestieri 1998 | Design | Case Series | 1 | Open adjustable band | N entering | 52 | Included in meta-analysis of weight loss.
| | | | | N completing | 52
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | 2 | LAP adjustable band | N entering | 10 | Arm 3 = -35.6 (17.0)
| Population | Adults, Adolescents, Females | | | N completing | 10
| | | | | | | Average weight loss at 24 months in kg
| | | | | | | Arm 3 = -61.6 (13.7)
| | | | | | | Arms 1, 2 combined into single arm 3.
Forsell 1999 | Design | Case Series | 1 | Open adjustable band | N entering | 326 | Included in meta-analysis of weight loss.
| | | | | N completing | 311
| Jadad | NA | | | | | Average weight loss at 28 months in kg
| | | | | | | Arm 1 = -37.0 (20.3)
| Population | Adults, Females
Forsell 1997 | Design | Case Series | 1 | Open adjustable band | N entering | 50 | Included in meta-analysis of weight loss.
| | | | | N completing | 46
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -42.0 (9.0)
| Population | Adults
| | | | | | | Average weight loss at 48 months in kg
| | | | | | | Arm 1 = -54.5 (8.0)
Freeman 1997 | Design | Case Series | 1 | Open RYGB, std | N entering | 40 | Included in meta-analysis of weight loss
| | | | | N completing | 37
| Jadad | NA | 2 | Open RYGB, long | N entering | 81 | Average weight loss at 12 months in bmi
| | | | | N completing | 69 | Arm 1 = -13.0 (5.9)
| Population | Adults, Adolescents, Females | | | | | Arm 2 = -14.0 (5.9)
| | | | | | | Average weight loss at 36 months in bmi
| | | | | | | Arm 1 = -18.0 (7.7)
| | | | | | | Arm 2 = -16.0 (7.7)
Goulding 1995 | Design | Case Series | 1 | Open VBG | N entering | 200 | Included in meta-analysis of weight loss.
| | | | | N completing | 114
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | | | | | Arm 1 = -13.2 (5.9)
| Population | Adults, Adolescents, Females
Greenstein 1995 | Design | Case Series | 1 | Open VBG | N entering | 14 | Included in meta-analysis of weight loss.
| | | | | N completing | 14
| Jadad | NA | | | | | Average weight loss at 12 months in lbs
| | | | | | | Arm 1 = -15.8 (12.4)
| Population | Adults, Adolescents, Females
| | | | | | | Average weight loss at 36 months in lbs
| | | | | | | Arm 1 = -54.9 (42.1)
Griffen 1977 | Design | CCT | 1 | Open RYGB, std | N entering | 32 | Included in meta-analysis of weight loss.
| | | | | N completing | 18
| Jadad | 0 | 2 | Jejunal-ileal bypass | N entering | 27 | Average weight loss at 12 months in kg
| | | | | N completing | 22 | Arm 1 = -51.0 (21.8)
| Population | Adults | | | | | Arm 2 = -57.9 (25.3)
Gustavsson 2002 | Design | Case Series | 1 | LAP adjustable band | N entering | 90 | Included in meta-analysis of weight loss.
| | | | | N completing | 90
| Jadad | NA | | | | | Average weight loss at 60 months in bmi
| | | | | | | Arm 1 = -9.3 (7.6)
| Population | Adults
Hall 1990 | Design | RCT | 1 | Open VBG | N entering | 106 | Included in meta-analysis of weight loss.
| | | | | N completing | 80
| Jadad | 3 | | | | | Average weight loss at 12 months in kg
| | | 2 | Open gastroplasty | N entering | 105 | Arm 1 = -36.0 (16.3)
| Population | Adults, Females | | | N completing | 67 | Arm 2 = -29.0 (29.0)
| | | | | | | Arm 3 = -42.0 (18.8)
| | | 3 | Open RYGB, std | N entering | 99
| | | | | N completing | 85 | Average weight loss at 36 months in kg
| | | | | | | Arm 1 = -33.0 (20.3)
| | | | | | | Arm 2 = -17.0 (24.0)
| | | | | | | Arm 3 = -39.0 (21.3)
Hedenbro 2002 | Design | Case Series | 1 | Open RYGB, std | N entering | 146 | Included in meta-analysis of weight loss.
| | | | | N completing | 15
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -47.0 (15.5)
| Population | Adults, Females
| | | | | | | Average weight loss at 36 months in kg
| | | | | | | Arm 1 = -53.0 (20.3)
Hess 1998 | Design | Case Series | 1 | BPD/Duodenal switch | N entering | 440 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -55.0 (15.5)
| Population | Adults, Females
Hesse 2001 | Design | Case Series | 1 | Open adjustable band | N entering | 29 | Included in meta-analysis of weight loss.
| | | | | N completing | 29
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | 2 | Open adjustable band | N entering | 41 | Arm 1 = -24.8 (15.5)
| Population | Adults, Females | | | N completing | 41 | Arm 2 excluded because it only reported 6 month follow-up.
Higa 2000 | Design | Case Series | 1 | LAP RYGB, std | N entering | 1040 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | NA
| Population | Adults, Females
Higa 2000 | Design | Case Series | 1 | LAP RYGB, std | N entering | 400 | Excluded from meta-analysis because study reported data on another study already included in analysis (949).
| | | | | N completing | ND
| Jadad | NA
| Population | Adults, Adolescents, Females
Horchner 1999 | Design | Case Series | 1 | LAP adjustable band | N entering | 42 | Included in meta-analysis of weight loss.
| | | | | N completing | 39
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -22.4 (15.5)
| Population | Adults, Females.
Howard 1995 | Design | RCT | 1 | Open RYGB, std | N entering | ND | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 6
| Jadad | 1 | 2 | Open VBG | N entering | ND
| | | | | N completing | 6
| Population | Adults, Females
Kalfarentzos 1999 | Design | Case Series | 1 | Open VBG | N entering | 35 | Included in meta-analysis of weight loss.
| | | | | N completing | 9
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | Open RYGB, std | N entering | 38 | Arm 1 = -13.3 (5.9)
| Population | Adults, Adolescents, Females | | | N completing | 7 | Arm 2 = -16.5 (5.9)
| | | 3 | Open RYGB, long | N entering | 17 | Average weight loss at 36 months in bmi
| | | | | N completing | 2 | Arm 1 = -10.2 (7.6)
| | | | | | | Arm 2 = -14.0 (7.6)
| | | | | | | Arm 3 excluded from 36 month analysis because maximum follow-up time reported was 24 months.
Karason 1997 | Design | Case Series | 1 | Control | N entering | 43 | Excluded from meta-analysis based on expert opinion.
| | | | | N completing | 43
| Jadad | NA | 2 | Control | N entering | 35
| | | | | N completing | 31
| Population | Adults | 3 | Gastric surgery NOS | N entering | 41
| | | | | N completing | 41
Karason 2000 | Design | Case Series | 1 | Control | N entering | 1310 | Excluded from meta-analysis because study reported data on another study already included in analysis (733).
| | | | | N completing | 1099
| Jadad | NA | 2 | Gastric surgery NOS | N entering | 1310
| | | | | N completing | 1210
| Population | Adults
Karason 1999 | Design | Case Series | 1 | Control | N entering | 28 | Excluded from meta-analysis because study reported data on another study already included in analysis (733).
| | | | | N completing | 24
| Jadad | NA | 2 | Gastric surgery NOS | N entering | 28
| | | | | N completing | 28
| Population | Adults
Karason 1999 | Design | Case Series | 1 | Control | N entering | 19 | Excluded from meta-analysis because study reported data on another study already included in analysis (733).
| | | | | N completing | 17
| Jadad | NA | 2 | Gastric surgery NOS | N entering | 20
| | | | | N completing | 19
| Population | Adults
Karlsson 1998 | Design | Case Series | 1 | Control | N entering | 487 | Excluded from meta-analysis because study reported data on another study already included in analysis (733).
| | | | | N completing | 487
| Jadad | NA | 2 | Open VBG | N entering | 315
| | | | | N completing | 315
| Population | Adults | 3 | Open adjustable band | N entering | 136
| | | | | N completing | 136
| | | 4 | Open RYGB, std | N entering | 36
| | | | | N completing | 36
Kim 1992 | Design | Case Series | 1 | Open RYGB, std | N entering | 2 | Excluded from meta-analysis because study sample size < 10.
| | | | | N completing | 2
| Jadad | NA
| Population | Adults, Females
Kothari 2002 | Design | Case Series | 1 | LAP adjustable band | N entering | 36 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 36
| Jadad | NA
| Population | Adults
Laws 1981 | Design | RCT | 1 | Open RYGB, std | N entering | 27 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | 2 | 2 | Open gastroplasty | N entering | 26
| | | | | N completing | ND
| Population | Adults
Lechner 1983 | Design | CCT | 1 | Open gastroplasty | N entering | 147 | Included in meta-analysis of weight loss.
| | | | | N completing | 16
| Jadad | 0 | | | | | Average weight loss at 12 months in kg
| | | 2 | Open RYGB, std | N entering | 95 | Arm 1 = -28.6 (17.1)
| Population | Adults, Females | | | N completing | 8 | Arm 2 = -43.6 (12.1)
| | | | | | | Average weight loss at 24 months in kg
| | | | | | | Arm 1 = -28.8 (18.0)
| | | | | | | Arm 2 = -45.5 (13.3)
Lechner 1981 | Design | RCT | 1 | Open VBG | N entering | 50 | Excluded from meta-analysis because study reported data on another study already included in analysis (1140).
| | | | | N completing | 50
| Jadad | 1 | 2 | Open RYGB, std | N entering | 50
| | | | | N completing | 50
| Population | Adults, Females
Letiexhe 1995 | Design | Case Series | 1 | Open VBG | N entering | 8 | Excluded from meta-analysis because study sample size < 10.
| | | | | N completing | 8
| Jadad | NA
| Population | Adults, Females
Lujan 2002 | Design | Case Series | 1 | LAP RYGB, std | N entering | 50 | Included in meta-analysis of weight loss.
| | | | | N completing | 50
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | | | | | Arm 1 = -14.0 (5.9)
| Population | Adults, Females
| | | | | | | Average weight loss at 18 months in bmi
| | | | | | | Arm 1 = -17.0 (7.6)
Lundell 1987 | Design | RCT | 1 | Open nonadjustable band | N entering | 12 | Excluded from meta-analysis because weight loss not reported by surgery type.
| | | | | N completing | 12 | .
| Jadad | 2 | 2 | Open gastroplasty | N entering | 15
| | | | | N completing | 15
| Population | Adults, Females
Lundell 1997 | Design | RCT | 1 | Open VBG | N entering | 24 | Excluded from meta-analysis because weight loss not reported by surgery type.
| | | | | N completing | ND
| Jadad | 1 | 2 | Open adjustable band | N entering | 26
| | | | | N completing | ND
| Population | Adults
MacLean 2000 | Design | Case Series | 1 | Open RYGB, std | N entering | 277 | Included in meta-analysis of weight loss.
| | | | | N completing | 243
| Jadad | NA | | | | | Average weight loss at 60 months in bmi
| | | | | | | Arm 1 = -17.3 (7.6)
| Population | Adults
MacLean 1990 | Design | Case Series | 1 | Open VBG | N entering | 201 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 57
| Jadad | NA
| Population | Adults
MacLean 1996 | Design | Case Series | 1 | Open VBG | N entering | 21 | Excluded from meta-analysis because weight loss not reported by surgery type.
| | | | | N completing | 21
| Jadad | NA | 2 | Open RYGB, std | N entering | 57
| | | | | N completing | 57
| Population | Adults
MacLean 1993 | Design | RCT | 1 | Open VBG | N entering | 54 | Excluded from meta-analysis because weight loss not reported by surgery type.
| | | | | N completing | 54
| Jadad | 1 | 2 | Open RYGB, std | N entering | 52
| | | | | N completing | 52
| Population | Adults
Marceau 1993 | Design | Case Series | 1 | BPD/Duodenal switch | N entering | 149 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 27
| Jadad | NA | 2 | BPD/Duodenal switch | N entering | 156
| | | | | N completing | 10
| Population | Adults, Females
Mason 1998 | Design | Case Series | 1 | Open VBG | N entering | 70 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 40
| Jadad | NA | 2 | Open VBG | N entering | 43
| | | | | N completing | 23
| Population | Adults
Mason 1982 | Design | Case Series | 1 | Open VBG | N entering | 42 | Excluded from meta-analysis because follow-up time was less than 12 months.
| | | | | N completing | ND
| Jadad | NA
| Population | Adults
Matthews 2000 | Design | Case Series | 1 | LAP RYGB, std | N entering | 48 | Included in meta-analysis of weight loss.
| | | | | N completing | 27
| Jadad | NA | | | | | Average weight loss at 12 months in lbs
| | | | | | | Arm 1 = -115.0 (34.1)
| Population | Adults, Females
Melissas 1998 | Design | Case Series | 1 | Open VBG | N entering | 62 | Included in meta-analysis of weight loss.
| | | | | N completing | 12
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -44.0 (13.0)
| Population | Adults, Females
| | | | | | | Average weight loss at 48 months in kg
| | | | | | | Arm 1 = -47.0 (18.0)
Miller 1999 | Design | Case Series | 1 | LAP adjustable band | N entering | ND | Included in meta-analysis of weight loss.
| | | | | N completing | 102
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | 2 | LAP adjustable band | N entering | ND | Arm 1 = -12.0 (15.5)
| Population | Adults, Adolescents, Females | | | N completing | 54 | Arm 2 = -17.0 (15.5)
| | | | | | | Average weight loss at 36 months in kg
| | | | | | | Arm 1 = -44.0 (20.3)
| | | | | | | Arm 2 = -48.0 (20.3)
Mitchell 2001 | Design | Case Series | 1 | Open RYGB, std | N entering | 100 | Included in meta-analysis of weight loss.
| | | | | N completing | 78
| Jadad | NA | | | | | Average weight loss at 180 months in kg
| | | | | | | Arm 1 = -30.1 (20.3)
| Population | Adults, Females
Mittermair 2003 | Design | Case Series | 1 | LAP adjustable band | N entering | 454 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -35.5 (15.5)
| Population | Adults, Females
| | | | | | | Average weight loss at 36 months in kg
| | | | | | | Arm 1 = -54.0 (20.3)
Morino 2003 | Design | RCT | 1 | LAP adjustable band | N entering | 49 | Included in meta-analysis of weight loss.
| | | | | N completing | 44
| Jadad | 1 | | | | | Average weight loss at 12 months in bmi
| | | | | | | Arm 1 = -9.2 (5.9)
| Population | Females | | | | | Arm 2 = -9.0 (5.9)
| | | 2 | LAP VBG | N entering | 51
| | | | | N completing | 49 | Average weight loss at 36 months in bmi
| | | | | | | Arm 1 = -14.1 (7.7)
| | | | | | | Arm 2 = -13.5 (7.7)
Narbro 1999 | Design | Case Series | 1 | Control | N entering | 369 | Excluded from meta-analysis because study reported data on another study already included in analysis (733).
| | | | | N completing | 339
| Jadad | NA | 2 | Gastric surgery NOS | N entering | 369
| | | | | N completing | 339
| Population | Adults
Naslund 1987 | Design | RCT | 1 | Open loop gastric bypass | N entering | 29 | Included in meta-analysis of weight loss.
| | | | | N completing | 29
| Jadad | 1 | | | | | Average weight loss at 12 months in kg
| | | 2 | Open gastroplasty | N entering | 28 | Arm 1 = -42.3 (10.9)
| Population | Adults, Females | | | N completing | 28 | Arm 2 = -29.9 (10.0)
| | | | | | | Average weight loss at 36 months in kg
| | | | | | | Arm 1 = -38.4 (13.2)
| | | | | | | Arm 2 = -24.7 (13.1)
Naslund 1986 | Design | RCT | 1 | Open loop gastric bypass | N entering | 29 | Excluded from meta-analysis because study reported data on another study already included in analysis (1078).
| | | | | N completing | 29
| Jadad | 1 | 2 | Open gastroplasty | N entering | 28
| | | | | N completing | 28
| Population | Adults, Females
Naslund 1987 | Design | RCT | 1 | Open gastroplasty | N entering | 28 | Excluded from meta-analysis because study reported data on another study already included in analysis (1078).
| | | | | N completing | 28
| Jadad | 1 | 2 | Open loop gastric bypass | N entering | 29
| | | | | N completing | 29
| Population | Adults, Females
Naslund 1988 | Design | RCT | 1 | Open loop gastric bypass | N entering | 26 | Excluded from meta-analysis because study reported data on another study already included in analysis (1078).
| | | | | N completing | 26
| Jadad | 1 | 2 | Open gastroplasty | N entering | 25
| | | | | N completing | 25
| Population | Adults, Females
Naslun 1988 | Design | RCT | 1 | Open loop gastric bypass | N entering | 26 | Excluded from meta-analysis because study reported data on another study already included in analysis (1078).
| | | | | N completing | 26
| Jadad | 2 | 2 | Open gastroplasty | N entering | 25
| | | | | N completing | 23
| Population | Adults, Females
Naslund 1986 | Design | RCT | 1 | Open loop gastric bypass | N entering | 29 | Excluded from meta-analysis because study reported data on another study already included in analysis (1078).
| | | | | N completing | 29
| Jadad | 1 | 2 | Open VBG | N entering | 28
| | | | | N completing | 28
| Population | Adults, Females
Nguyen 2001 | Design | CCT | 1 | LAP RYGB, std | N entering | 79 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | 1 | 2 | Open RYGB, std | N entering | 76
| | | | | N completing | ND
| Population | Adults, Females
Nguyen 2000 | Design | Case Series | 1 | LAP RYGB, std | N entering | 35 | Excluded from meta-analysis because weight loss not reported by surgery type.
| | | | | N completing | 35
| Jadad | NA | 2 | Open RYGB, std | N entering | 69
| | | | | N completing | 35
| Population | Adults, Females
Nilsell 2001 | Design | RCT | 1 | Open VBG | N entering | 30 | Included in meta-analysis of weight loss.
| | | | | N completing | 16
| Jadad | 2 | | | | | Average weight loss at 12 months in kg
| | | 2 | Open adjustable band | N entering | 16 | Arm 1 = -41.0 (15.5)
| Population | Adults, Females | | | N completing | 3 | Arm 2 = -24.0 (15.5)
| | | | | | | Average weight loss at 60 months in kg
| | | | | | | Arm 1 = -35.0 (19.2)
| | | | | | | Arm 2 = -43.0 (12.0)
Nowara 2001 | Design | Case Series | 1 | LAP adjustable band | N entering | 34 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | LAP adjustable band | N entering | 74 | Arm 3 = -11.7 (5.9)
| Population | Adults, Females | | | N completing | ND
| | | | | | | Average weight loss at 24 months in bmi
| | | | | | | Arm 3 = -14.6 (7.6)
| | | | | | | Arms 1, 2 combined into single arm 3.
O'Brien 1999 | Design | Case Series | 1 | LAP adjustable band | N entering | 302 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 289
| Jadad | NA
| Population | Adults, Adolescents, Females
O'Brien 2002 | Design | Case Series | 1 | LAP adjustable band | N entering | 659 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | LAP adjustable band | N entering | 50 | Arm 3 = -10.0 (5.9)
| Population | Adults, Adolescents, Females | | | N completing | ND
| | | | | | | Average weight loss at 72 months in bmi
| | | | | | | Arm 3 = -13.0 (7.6)
| | | | | | | Arms 1 & 2 combined into single arm 3.
Oh 1997 | Design | Case Series | 1 | Open RYGB, std | N entering | 194 | Included in meta-analysis of weight loss.
| | | | | N completing | 14
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -47.5 (15.5)
| Population | Adults, Adolescents, Females
| | | | | | | Average weight loss at 48 months in kg
| | | | | | | Arm 1 = -48.5 (20.3)
Olbers 2003 | Design | Case Series | 1 | LAP RYGB, std | N entering | 140 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | LAP RYGB, std | N entering | 10 | Arm 3 = -15.0 (5.9)
| Population | Adults, Females | | | N completing | ND
| | | | | | | Average weight loss at 60 months in bmi
| | | | | | | Arm 3 = -14.5 (7.6)
| | | | | | | Arms 1 & 2 combined into single arm 3.
Papasavas 2002 | Design | Case Series | 1 | LAP RYGB, std | N entering | 113 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | LAP RYGB, std | N entering | 3 | Arm 3 = -16.3 (5.9)
| Population | Adults, Females | | | N completing | ND
| | | | | | | Average weight loss at 18 months in bmi
| | | | | | | Arm 3 = -17.3 (7.6)
| | | | | | | Arms 1 & 2 combined into single arm 3.
Peace 1989 | Design | Case Series | 1 | Open gastroplasty | N entering | 48 | Included in meta-analysis of weight loss.
| | | | | N completing | 39
| Jadad | NA | | | | | Average weight loss at 17 months in kg
| | | | | | | Arm 1 = -42.3 (15.8)
| Population | Adults, Females
Perugin 2003 | Design | Case Series | 1 | LAP RYGB, std | N entering | 188 | Included in meta-analysis of weight loss.
| | | | | N completing | 93
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | | | | | Arm 1 = -48.0 (15.5)
| Population | Adults, Females
Pontiroli 2002 | Design | Case Series | 1 | Control | N entering | 120 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | LAP adjustable band | N entering | 143 | Arm 2 = -16.3 (5.9)
| Population | Adults, Females | | | N completing | 56
| | | | | | | Average weight loss at 18 months in bmi
| | | | | | | Arm 2 = -7.9 (7.6)
| | | | | | | Arm 1 excluded because no sample size was reported
Pories 1982 | Design | RCT | 1 | Open RYGB, std | N entering | 42 | Included in meta-analysis of weight loss.
| | | | | N completing | 42
| Jadad | 1 | | | | | Average weight loss at 12 months in lbs
| | | 2 | Open gastroplasty | N entering | 45 | Arm 1 = -108.5 (34.1)
| Population | Adults, Females | | | N completing | 45 | Arm 2 = -68.3 (34.1)
| | | | | | | Average weight loss at 18 months in lbs
| | | | | | | Arm 1 = -113.3 (44.7)
| | | | | | | Arm 2 = -66.2 (44.7)
Pories 1987 | Design | Case Series | 1 | Open RYGB, std | N entering | 397 | Included in meta-analysis of weight loss.
| | | | | N completing | 26
| Jadad | NA | | | | | Average weight loss at 12 months in lbs
| | | | | | | Arm 1 = -106.0 (34.1)
| Population | Adults, Females
| | | | | | | Average weight loss at 72 months in lbs
| | | | | | | Arm 1 = -85.0 (44.7)
Quaade 1979 | Design | RCT | 1 | Control | N entering | 66 | Excluded from meta-analysis because study reported data on another study already included in analysis (1140)
| | | | | N completing | ND
| Jadad | 1 | 2 | Jejunal-ileal bypass | N entering | 130
| | | | | N completing | ND
| Population | Adults, Females
Rand 1994 | Design | Case Series | 1 | Open RYGB, std | N entering | 30 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 30
| Jadad | NA
| | | 2 | Open VBG | N entering | 4
| Population | Adults, Adolescents, Children, Females | | | N completing | 4
Randolph 1974 | Design | Case Series | 1 | Jejunal-ileal bypass | N entering | 4 | Excluded from meta-analysis because study sample size < 10.
| | | | | N completing | 4
| Jadad | NA
| Population | Adolescents, Females
Reddy 2002 | Design | Case Series | 1 | Open RYGB, std | N entering | 103 | Excluded from meta-analysis because follow-up time was less than 12 months.
| | | | | N completing | 98
| Jadad | NA
| Population | Adults, Females
Reinhold 1994 | Design | Case Series | 1 | Open loop gastric bypass | N entering | 66 | Excluded from meta-analysis because weight loss not reported by surgery type.
| | | | | N completing | ND
| Jadad | NA | 2 | Open RYGB, std | N entering | ND
| | | | | N completing | 3
| Population | Adults, Females
Rigg 1975 | Design | Case Series | 1 | Jejunal-ileal bypass | N entering | 8 | Excluded from meta-analysis because study sample size < 10.
| | | | | N completing | 8
| Jadad | NA
| Population | Adolescents .
Schauer 2000 | Design | Case Series | 1 | LAP RYGB, std | N entering | 275 | Included in meta-analysis of weight loss.
| | | | | N completing | 5
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | | | | | Arm 1 = -16.8 (5.9)
| Population | Adults, Adolescents, Females
| | | | | | | Average weight loss at 24 months in bmi
| | | | | | | Arm 1 = -20.9 (7.6)
Scopinaro 1996 | Design | Case Series | 1 | BPD/Duodenal switch | N entering | 1217 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | NA
| Population | Adults, Adolescents, Children
Sjostrom 2000 | Design | Case Series | 1 | Control | N entering | 346 | Excluded from meta-analysis because study reported data on another study already included in analysis (733).
| | | | | N completing | 232
| Jadad | NA
| | | 2 | Open VBG | N entering | 227
| Population | Adults | | | N completing | 164
| | | 3 | Open adjustable band | N entering | 86
| | | | | N completing | 63
| | | 4 | Open RYGB, std | N entering | 33
| | | | | N completing | 24
Sjostrom 1999 | Design | Case Series | 1 | Control | N entering | 845 | Excluded from meta-analysis because study reported data on another study already included in analysis (733)
| | | | | N completing | 712
| Jadad | NA | 2 | Open adjustable band | N entering | ND
| | | | | N completing | 191
| Population | Adults | 3 | Open VBG | N entering | ND
| | | | | N completing | 534
| | | 4 | Open RYGB, std | N entering | ND
| | | | | N completing | 42
Sjostrom 2001 | Design | Case Series | 1 | Control | N entering | 1031 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | 2 | Open VBG | N entering | 834 | Arm 1 = -1.6 (6.6)
| Population | Adults | | | N completing | ND | Arm 2 = -30.7 (11.8)
| | | | | | | Arm 3 = -25.8 (12.9)
| | | 3 | Open adjustable band | N entering | 255 | Arm 4 = -44.0 (15.0)
| | | | | N completing | 988
| | | | | | | Average weight loss at 66 months in kg
| | | 4 | Open RYGB, std | N entering | 68 | Arm 1 = 1.5 (10.2)
| | | | | N completing | ND | Arm 2 = -20.8 (13.1)
| | | | | | | Arm 3 = -20.7 (16.6)
Smith 2004 | Design | Case Series | 1 | LAP RYGB, std | N entering | 328 | Included in meta-analysis of weight loss.
| | | | | N completing | 328
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | Open RYGB, std | N entering | 451 | Arm 1 = -17.2 (5.9)
| Population | | | | N completing | 451 | Arm 2 = -19.2 (5.9)
Soper 1975 | Design | Case Series | 1 | Open RYGB, std | N entering | 834 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | NA
| | | 2 | Open gastroplasty | N entering | 3
| Population | Adults, Adolescents | | | N completing | ND
Stanford 2003 | Design | Case Series | 1 | LAP RYGB, std | N entering | 4 | Excluded from meta-analysis because study sample size < 10.
| | | | | N completing | 4
| Jadad | NA
| Population | Adults, Adolescents, Females
Stoner 1997 | Design | Case Series | 1 | Open VBG | N entering | 202 | Included in meta-analysis of weight loss.
| | | | | N completing | 165
| Jadad | NA | | | | | Average weight loss at 12 months in lbs
| | | | | | | Arm 1 = -78.0 (34.1)
| Population | Adults
| | | | | | | Average weight loss at 42 months in lbs
| | | | | | | Arm 1 = -85.0 (44.7)
Strauss 2001 | Design | Case Series | 1 | Open RYGB, std | N entering | 10 | Excluded from meta-analysis because study sample size < 10.
| | | | | N completing | 9
| Jadad | NA
| Population | Adolescents
Sugerman 2003 | Design | Case Series | 1 | Open gastroplasty | N entering | 1 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | NA | 2 | Open VBG | N entering | 2
| | | | | N completing | ND
| Population | Adolescents, Children | 3 | Open RYGB, std | N entering | 15
| | | | | N completing | ND
| | | 4 | LAP gastroplasty | N entering | 2
| | | | | N completing | ND
| | | 5 | Open RYGB, long | N entering | 13
| | | | | N completing | ND
Sugerman 1989 | Design | Case Series | 1 | Open VBG | N entering | 40 | Included in meta-analysis of weight loss.
| | | | | N completing | 28
| Jadad | NA | | | | | Average weight loss at 12 months in lbs
| | | 2 | Open RYGB, std | N entering | 182 | ^Arm 1 = -61.0 (34.1)
| Population | Adults | | | N completing | 141 | ^Arm 2 = -96.0 (34.1)
| | | | | | | Average weight loss at 36 months in lbs
| | | | | | | Arm 1 = -54.0 (44.7)
| | | | | | | Arm 2 = -88.0 (44.7)
Sugerman 1996 | Design | Case Series | 1 | Open RYGB, std | N entering | 54 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in lbs
| | | 2 | Open RYGB, std | N entering | 4 | Arm 3 = -99.0 (34.1)
| Population | Adults | | | N completing | ND
| | | | | | | Average weight loss at 72 months in lbs
| | | | | | | Arm 3 = -92.0 (44.7)
| | | | | | | Arms 1 & 2 combined into single arm 3.
Sugerman 1987 | Design | RCT | 1 | Open RYGB, std | N entering | 20 | Included in meta-analysis of weight loss.
| | | | | N completing | 18
| Jadad | 2 | | | | | Average weight loss at 12 months in lbs
| | | 2 | Open VBG | N entering | 20 | Arm 1 = -96.0 (25.0)
| Population | Adults, Females | | | N completing | 16 | Arm 2 = -71.0 (24.0)
| | | | | | | Average weight loss at 36 months in lbs
| | | | | | | Arm 1 = -91.0 (28.0)
| | | | | | | Arm 2 = -60.0 (32.0)
Suter 2000 | Design | Case Series | 1 | LAP adjustable band | N entering | ND | Included in meta-analysis of weight loss.
| | | | | N completing | 101
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | LAP adjustable band | N entering | ND | Arm 3 = -13.0 (5.9)
| Population | Adults, Females | | | N completing | 47
| | | | | | | Average weight loss at 24 months in bmi
| | | | | | | Arm 3 = -13.0 (7.6)
| | | | | | | Arms 1, 2 combined into single arm 3.
Suter 2003 | Design | Case Series | 1 | LAP RYGB, std | N entering | 80 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | LAP RYGB, std | N entering | 27 | Arm 3 = -13.2 (5.9)
| Population | Adults, Females | | | N completing | ND
| | | | | | | Average weight loss at 24 months in bmi
| | | | | | | Arm 3 = -12.2 (7.6)
| | | | | | | Arms 1 & 2 combined into single arm 3.
Suter 1999 | Design | Case Series | 1 | Open VBG | N entering | 73 | Included in meta-analysis of weight loss.
| | | | | N completing | 73
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | 2 | Open VBG | N entering | 40 | Arm 4 = -12.5 (5.9)
| Population | Adults, Females | | | N completing | 76 | Arm 5 = -14.7 (5.9)
| | | 3 | Open VBG | N entering | 84
| | | | | N completing | 76 | Average weight loss at 24 months in bmi
| | | 4 | LAP nonadjustable band | N entering | 76 | Arm 4 = -14.5 (7.6)
| | | | | N completing | 76 | Arm 5 = -14.7 (7.6)
| | | | | | | Arms 1, 2, 3 combined into single arm 5.
Szold 2002 | Design | Case Series | 1 | LAP adjustable band | N entering | 715 | Included in meta-analysis of weight loss.
| | | | | N completing | 121
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | | | | | Arm 1 = -10.1 (5.9)
| Population | Adults, Adolescents, Females
| | | | | | | Average weight loss at 36 months in bmi
| | | | | | | Arm 1 = -11.1 (7.6)
Tacchino 2003 | Design | Case Series | 1 | Control | N entering | 53 | Included in meta-analysis of weight loss.
| | | | | N completing | 53
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | 2 | BPD/Duodenal switch | N entering | 101 | Arm 2 = -43.3 (15.5)
| Population | Adults, Females | | | N completing | 101
| | | | | | | Average weight loss at 24 months in kg
| | | | | | | Arm 2 = -46.0 (20.3)
| | | | | | | Arm 1 excluded because mean weight loss not reported.
The Danish Obesity Project 1979 | Design | RCT | 1 | Control | N entering | 69 | Included in meta-analysis of weight loss.
| | | | | N completing | 52
| Jadad | 1 | | | | | Average weight loss at 24 months in kg
| | | 2 | Jejunal-ileal bypass | N entering | 133 | Arm 1 = -5.9 (13.1)
| Population | Adults | | | N completing | 130 | Arm 2 = -42.9 (22.0)
Toppino 1999 | Design | Case Series | 1 | LAP nonadjustable band | N entering | 10 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 1
| Jadad | NA | 2 | LAP adjustable band | N entering | 361
| | | | | N completing | 56
| Population | Adults | 3 | LAP VBG | N entering | 120
| | | | | N completing | 20
Toppino 1999 | Design | Case Series | 1 | Open VBG | N entering | 218 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | NA | 2 | LAP VBG | N entering | 107
| | | | | N completing | ND
| Population | Adults, Females
Torgerson 2001 | Design | Case Series | 1 | Control | N entering | 712 | Excluded from meta-analysis because study reported data on another study already included in analysis (733).
| | | | | N completing | 232
| Jadad | NA | 2 | Open adjustable band | N entering | ND
| | | | | N completing | ND
| Population | Adults | 3 | Open RYGB, std | N entering | ND
| | | | | N completing | ND
| | | 4 | Open VBG | N entering | ND
| | | | | N completing | ND
van de Weijgert 1999 | Design | Case Series | 1 | Open RYGB, std | N entering | 100 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 75
| Jadad | NA | 2 | Open VBG | N entering | 100
| | | | | N completing | 78
| Population | Adults, Females
van Gemert 1998 | Design | Case Series | 1 | Control | N entering | 20 | Included in meta-analysis of weight loss.
| | | | | N completing | 20
| Jadad | NA | 2 | Open RYGB, std | N entering | ND | Average weight loss at 86 months in kg
| | | | | N completing | 18 | Arm 2 = -41.4 (20.3)
| Population | Adults, Females | 3 | Open VBG | N entering | ND | Arm 3 = -38.0 (20.3)
| | | | | N completing | 14 | Arm 4 = -48.3 (20.3)
| | | 4 | Open VBG | N entering | ND
| | | | | N completing | 30
Van Rij 1984 | Design | RCT | 1 | Open RYGB, std | N entering | 42 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 42
| Jadad | 1 | 2 | Open gastroplasty | N entering | 45
| | | | | N completing | 45
| Population | Adults .
VanWoert 1992 | Design | RCT | 1 | Open RYGB, std | N entering | 15 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | 1 | 2 | Open VBG | N entering | 17
| | | | | N completing | ND
| Population | Adults
Viddal 1983 | Design | RCT | 1 | Jejunal-ileal bypass | N entering | 10 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | 1 | 2 | Jejunal-ileal bypass | N entering | 11 | Average weight loss at 18 months in kg
| | | | | N completing | ND | Arm 1 = -37.0 (20.3)
| Population | Adults, Females | | | | | Arm 2 = -40.0 (20.3)
Weiner 2001 | Design | RCT | 1 | LAP adjustable band | N entering | 51 | Included in meta-analysis of weight loss.
| | | | | N completing | ND
| Jadad | 1 | | | | | Average weight loss at 12 months in kg
| | | 2 | LAP adjustable band | N entering | 50 | Arm 1 = -50.9 (15.5)
| Population | Adults, Females | | | N completing | ND | Arm 2 = -55.8 (15.5)
| | | | | | | Average weight loss at 18 months in kg
| | | | | | | Arm 1 = -50.9 (20.3)
| | | | | | | Arm 2 = -56.8 (20.3)
Weiner 2003 | Design | Case Series | 1 | LAP adjustable band | N entering | 984 | Included in meta-analysis of weight loss.
| | | | | N completing | 955
| Jadad | NA | | | | | Average weight loss at 12 months in bmi
| | | | | | | Arm 1 = -12.8 (5.9)
| Population | Adults, Females
| | | | | | | Average weight loss at 36 months in bmi
| | | | | | | Arm 1 = -14.8 (7.6)
Westling 2001 | Design | RCT | 1 | LAP RYGB, std | N entering | 30 | Included in meta-analysis of weight loss.
| | | | | N completing | 30
| Jadad | 2 | 2 | Open RYGB, std | N entering | 21 | Average weight loss at 12 months in bmi
| | | | | N completing | 21 | Arm 1 = -14.0 (3.0)
| Population | Adults, Females | | | | | Arm 2 = -13.0 (3.0)
White 1974 | Design | Case Series | 1 | Jejunal-ileal bypass | N entering | 1 | Excluded from meta-analysis because study sample size < 10.
| | | | | N completing | 1
| Jadad | NA | 2 | Jejunal-ileal bypass | N entering | 2
| | | | | N completing | 3
| Population | Adults, Adolescents, Children, Males
Wiesner 2000 | Design | Case Series | 1 | LAP adjustable band | N entering | 98 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | ND
| Jadad | NA
| Population | Adults, Females
Wittgrove 2000 | Design | Case Series | 1 | LAP RYGB, std | N entering | 500 | Excluded from meta-analysis because study did not report mean weight loss.
| | | | | N completing | 4
| Jadad | NA
| Population | Adults
Yale 1989 | Design | Case Series | 1 | Open RYGB, std | N entering | 251 | Included in meta-analysis of weight loss.
| | | | | N completing | 225
| Jadad | NA | | | | | Average weight loss at 12 months in kg
| | | 2 | Open gastroplasty | N entering | 186 | Arm 1 = -46.0 (13.0)
| Population | Adults, Adolescents, Females | | | N completing | 106 | Arm 2 = -30.0 (18.0)
| | | | | | | Arm 3 = -35.0 (11.0)
| | | 3 | Open VBG | N entering | 100
| | | | | N completing | 89 | Average weight loss at 36 months in kg
| | | | | | | Arm 3 = -33.0 (15.0)
| | | | | | | Average weight loss at 60 months in kg
| | | | | | | Arm 1 = -41.0 (19.0)
Yale 1991 | Design | Case Series | 1 | Open VBG | N entering | 100 | Included in meta-analysis of weight loss.
| | | | | N completing | 98
| Jadad | NA | 2 | Open VBG | N entering | 100 | Average weight loss at 12 months in lbs
| | | | | N completing | 97 | Arm 1 = -75.0 (30.0)
| Population | Adults, Females | | | | | Arm 2 = -77.0 (24.0)
Yashko 1997 | Design | Case Series | 1 | Open VBG | N entering | 24 | Excluded from meta-analysis because study did not report follow-up time.
| | | | | N completing | ND
| Jadad | NA
| Population | Adults

Meta-analysis data reported as an average with its standard deviation in parentheses.

NA = Not available or not applicable

NR, ND = Not reported or not described

### Reference List

1 Abu-Abeid S, Gavert N, Klausner J M, et al. Bariatric surgery in adolescence. J Pediatr Surg. 2003;38(9):1379-82. [pmid: 14523824].
2 Abu-Abeid S, Szold A. Results and complications of laparoscopic adjustable gastric banding: an early and intermediate experience. Obes Surg. 1999;9(2):188-90. [pmid: 10340776].
3 Aghahosseini H, Roulet D, Cavin R. [Treatment of morbid obesity with adjustable gastric prosthesis: experience and results at the Riviera Hospital in Montreux]. Rev Med Suisse Romande. 2001;121(10):709-12. [pmid: 11715285].
4 Agren G, Naslund I. A prospective randomized comparison of vertical banded gastroplasty (VBG), loop gastric bypass (GBY), and gastric banding (GB). Int J Obes. 1989;13:595.
5 Al-Jiffry B O, Shaffer E A, Saccone G T, et al. Changes in gallbladder motility and gallstone formation following laparoscopic gastric banding for morbid obesity. Can J Gastroenterol. 2003;17(3):169-74. [pmid: 12677265].
6 Alden J F. Gastric and jejunoileal bypass. A comparison in the treatment of morbid obesity. Arch Surg. 1977;112(7):799-806. [pmid: 880023].
7 Alper D, Ramadan E, Vishne T, et al. Silastic ring vertical gastroplasty- long-term results and complications. Obes Surg. 2000;10(3):250-4. [pmid: 10929157].
8 Andersen T, Backer O G, Astrup A, et al. Horizontal or vertical banded gastroplasty after pretreatment with very- low-calorie formula diet: a randomized trial. Int J Obes. 1987;11(3):295-304. [pmid: 3312050].
9 Andersen T, Backer O G, Stokholm K H, et al. [Gastroplasty versus very low calorie diet in morbid obesity. Short-term results of a randomized clinical trial]: <Original> Gastroplastik versus ekstrem lavkalorie-diaet (very-low-calorie diet) ved svaer adipositas. Korttidsresultater af en randomiseret klinisk undersogelse. Ugeskrift for laeger. 1982;144(6):390-4. [pmid: 7041386].
10 Andersen T, Backer O G, Stokholm K H, et al. Randomized trial of diet and gastroplasty compared with diet alone in morbid obesity. New England journal of medicine. 1984;310(6):352-6. [pmid: 6690963].
11 Andersen T, Stokholm K H, Backer O G, et al. Long-term (5-year) results after either horizontal gastroplasty or very- low-calorie diet for morbid obesity. Int J Obes. 1988;12(4):277-84. [pmid: 3058614].
12 Anderson A E, Soper R T, Scott D H. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. 1980;15(6):876-81. [pmid: 7463289].
13 Anthone G J, Lord R V N, DeMeester T R, et al. The duodenal switch operation for the treatment of morbid obesity. Ann Surg. 2003;238(4):618-628. [pmid: 14530733]. [pmcid: 1360120].
14 Balsiger B M, Poggio J L, Mai J, et al. Ten and more years after vertical banded gastroplasty as primary operation for morbid obesity. J Gastrointest Surg. 2000;4(6):598-605. [pmid: 11307094].
15 Baltasar A, Bou R, Arlandis F, et al. Vertical banded gastroplasty at more than 5 years. Obes Surg. 1998;8(1):29-34. [pmid: 9562483].
16 Belachew M, Belva P H, Desaive C. Long-term results of laparoscopic adjustable gastric banding for the treatment of morbid obesity. Obes Surg. 2002;12(4):564-8. [pmid: 12194552].
17 Belachew M, Legrand M, Vincent V, et al. Laparoscopic adjustable gastric banding. World J Surg. 1998;22(9):955-63. [pmid: 9717421].
18 Bloomston M, Zervos E E, Camps M A, et al. Outcome following bariatric surgery in super versus morbidly obese patients: does weight matter?. Obes Surg. 1997;7(5):414-9. [pmid: 9730495].
19 Breaux C W. Obesity Surgery in Children. Obes Surg. 1995;5(3):279-284. [pmid: 10733812].
20 Brolin R L, Robertson L B, Kenler H A, et al. Weight loss and dietary intake after vertical banded gastroplasty and Roux-en-Y gastric bypass. Ann Surg. 1994;220(6):782-90. [pmid: 7986146]. [pmcid: 1234481].
21 Brolin R E, Bradley L J, Wilson A C, et al. Lipid risk profile and weight stability after gastric restrictive operations for morbid obesity. J Gastrointest Surg. 2000;4(5):464-9. [pmid: 11077320].
22 Brolin R E, Kenler H A, Gorman J H, et al. Long-limb gastric bypass in the superobese. A prospective randomized study. Annals of surgery. 1992;215(4):387-95. [pmid: 1558421]. [pmcid: 1242457].
23 Buckwalter J A. A prospective comparison of the jejunoileal and gastric bypass operations for morbid obesity. World J Surg. 1977;1(6):757-68. [pmid: 607594].
24 Capella J F, Capella R F. The weight reduction operation of choice: vertical banded gastroplasty or gastric bypass?. Am J Surg. 1996;171(1):74-9. [pmid: 8554155].
25 Choban P S, Flancbaum L. The effect of Roux limb lengths on outcome after Roux-en-Y gastric bypass: a prospective, randomized clinical trial. Obes Surg. 2002;12(4):540-5. [pmid: 12194548].
26 Choban P S, Onyejekwe J, Burge J C, et al. A health status assessment of the impact of weight loss following Roux- en-Y gastric bypass for clinically severe obesity. J Am Coll Surg. 1999;188(5):491-7. [pmid: 10235576].
27 Choi Y, Frizzi J, Foley A, et al. Patient satisfaction and results of vertical banded gastroplasty and gastric bypass. Obes Surg. 1999;9(1):33-5. [pmid: 10065578].
28 Cook C M, Edwards C. Success habits of long-term gastric bypass patients. Obes Surg. 1999;9(1):80-2. [pmid: 10065592].
29 Courcoulas A, Perry Y, Buenaventura P, et al. Comparing the outcomes after laparoscopic versus open gastric bypass: a matched paired analysis. Obes Surg. 2003;13(3):341-6. [pmid: 12841890].
30 Crampton N A, Izvornikov V, Stubbs R S. Silastic ring gastric bypass: results in 64 patients. Obes Surg. 1997;7(6):489-94. [pmid: 9730506].
31 Dargent J. Laparoscopic adjustable gastric banding: lessons from the first 500 patients in a single institution. Obes Surg. 1999;9(5):446-52. [pmid: 10605901].
32 Das S K, Roberts S B, Kehayias J J, et al. Body composition assessment in extreme obesity and after massive weight loss induced by gastric bypass surgery. Am J Physiol Endocrinol Metab. 2003;284(6):E1080-8. [pmid: 12604503].
33 Davila-Cervantes A, Ganci-Cerrud G, Gamino R, et al. Open vs. laparoscopic vertical banded gastroplasty: a case control study with a 1-year follow-up. Obes Surg. 2000;10(5):409-12. [pmid: 11054244].
34 de Csepel J, Nahouraii R, Gagner M. Laparoscopic gastric bypass as a reoperative bariatric surgery for failed open restrictive procedures. Surg Endosc. 2001;15(4):393-7. [pmid: 11395822].
35 De Luca M, de Werra C, Formato A, et al. Laparotomic vs laparoscopic lap-band: 4-year results with early and intermediate complications. Obes Surg. 2000;10(3):266-8. [pmid: 10929160].
36 de Wit L T, Mathus-Vliegen L, Hey C, et al. Open versus laparoscopic adjustable silicone gastric banding: a prospective randomized trial for treatment of morbid obesity. Annals of surgery. 1999;230(6):800-5. [pmid: 10615935]. [pmcid: 1420944].
37 de Zwaan M, Lancaster K L, Mitchell J E, et al. Health-related quality of life in morbidly obese patients: effect of gastric bypass surgery. Obes Surg. 2002;12(6):773-80. [pmid: 12568181].
38 DeMaria E J, Sugerman H J. A critical look at laparoscopic adjustable silicone gastric banding for surgical treatment of morbid obesity: does it measure up?. Surg Endosc. 2000;14(8):697-9. [pmid: 10954811].
39 DeMaria E J, Sugerman H J, Meador J G, et al. High failure rate after laparoscopic adjustable silicone gastric banding for treatment of morbid obesity. Ann Surg. 2001;233(6):809-18. [pmid: 11371739]. [pmcid: 1421324].
40 Doherty C, Maher J W, Heitshusen D S. Prospective investigation of complications, reoperations, and sustained weight loss with an adjustable gastric banding device for treatment of morbid obesity. J Gastrointest Surg. 1998;2(1):102-8. [pmid: 9841975].
41 Doherty C, Maher JW, Heitshusen DS. Long-term data indicate a progressive loss in efficacy of adjustable silicone gastric banding for the surgical treatment of morbid obesity. Surgery 2002;132(4):724–7; discussion 727–8.
42 Dolan K, Creighton L, Hopkins G, et al. Laparoscopic gastric banding in morbidly obese adolescents. Obes Surg. 2003;13(1):101-4. [pmid: 12630622].
43 Doldi S B, Micheletto G, Lattuada E, et al. Adjustable gastric banding: 5-year experience. Obes Surg. 2000;10(2):171-3. [pmid: 10782180].
44 Dymek M P, Le Grange D, Neven K, et al. Quality of life after gastric bypass surgery: a cross-sectional study. Obes Res. 2002;10(11):1135-42. [pmid: 12429877].
45 Feng J J, Gagner M. Laparoscopic biliopancreatic diversion with duodenal switch. Semin Laparosc Surg. 2002;9(2):125-9. [pmid: 12152155].
46 Field R J Jr, Field R J 3rd, Park S Y. Vertical banded gastroplasty: is obesity worth it?. J Miss State Med Assoc. 1992;33(12):423-32. [pmid: 1474572].
47 Fielding G A, Rhodes M, Nathanson L K. Laparoscopic gastric banding for morbid obesity. Surgical outcome in 335 cases. Surg Endosc. 1999;13(6):550-4. [pmid: 10347288].
48 Fobi M A. Vertical Banded Gastroplasty vs Gastric Bypass: 10 years follow-up. Obes Surg. 1993;3(2):161-164. [pmid: 10757913].
49 Fobi M A, Lee H, Igwe D Jr, et al. Prospective comparative evaluation of stapled versus transected silastic ring gastric bypass: 6-year follow-up. Obes Surg. 2001;11(1):18-24. [pmid: 11361162].
50 Forestieri P, Meucci L, De Luca M, et al. Two years of practice in adjustable silicone gastric banding (LAP- BAND): evaluation of variations of body mass index, percentage ideal body weight and percentage excess body weight. Obes Surg. 1998;8(1):49-52. [pmid: 9562487].
51 Forsell P, Hallerback B, Glise H, et al. Complications following Swedish adjustable gastric banding: a long-term follow-up. Obes Surg. 1999;9(1):11-6. [pmid: 10065574].
52 Forsell P, Hellers G. The Swedish Adjustable Gastric Banding (SAGB) for morbid obesity: 9 year experience and a 4-year follow-up of patients operated with a new adjustable band. Obes Surg. 1997;7(4):345-51. [pmid: 9730522].
53 Freeman J B, Kotlarewsky M, Phoenix C. Weight loss after extended gastric bypass. Obes Surg. 1997;7(4):337-44. [pmid: 9730521].
54 Goulding S T, Hovell B C. Anaesthetic experience of vertical banded gastroplasty. Br J Anaesth. 1995;75(3):301-6. [pmid: 7547048].
55 Greenstein R J, Rabner J G. Is Adolescent Gastric-Restrictive Antiobesity Surgery Warranted?. Obes Surg. 1995;5(2):138-144. [pmid: 10733801].
56 Griffen W O Jr, Young V L, Stevenson C C. A prospective comparison of gastric and jejunoileal bypass procedures for morbid obesity. Ann Surg. 1977;186(4):500-9. [pmid: 907395]. [pmcid: 1396298].
57 Gustavsson S, Westling A. Laparoscopic adjustable gastric banding: complications and side effects responsible for the poor long-term outcome. Semin Laparosc Surg. 2002;9(2):115-24. [pmid: 12152154].
58 Hall J C, Watts J M, O'Brien P E, et al. Gastric surgery for morbid obesity. The Adelaide Study. Ann Surg. 1990;211(4):419-27. [pmid: 2181950]. [pmcid: 1358027].
59 Hedenbro J L, Frederiksen S G. Fully stapled gastric bypass with isolated pouch and terminal anastomosis: 1–3 year results. Obes Surg. 2002;12(4):546-50. [pmid: 12194549].
60 Hess D S, Hess D W. Biliopancreatic diversion with a duodenal switch. Obes Surg. 1998;8(3):267-82. [pmid: 9678194].
61 Hesse U J, Berrevoet F, Ceelen W, et al. [Adjustable silicone gastric banding (ASGB, Bioenterics) and the Swedish adjustable gastric banding (SAGB, Obtech) in treatment of morbid obesity]: <Original> Das anpassbare Silicon Gastric Banding (ASGB, Bioenterics) und das Schwedische anpassbare Gastric Banding (SAGB, Obtech) zur Behandlung der morbiden Obesitas. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. 2001;72(1):14-8. [pmid: 11225451].
62 Higa K D, Boone K B, Ho T. Complications of the laparoscopic Roux-en-Y gastric bypass: 1,040 patients--what have we learned?. Obes Surg. 2000;10(6):509-13. [pmid: 11175957].
63 Higa KD, Boone KB, Ho T, et al . Laparoscopic Roux-en-Y gastric bypass for morbid obesity: technique and preliminary results of our first 400 patients. Arch Surg 2000;135(9):1029–33; discussion 1033–4.
64 Horchner R, Tuinebreijer W. Improvement of physical functioning of morbidly obese patients who have undergone a Lap-Band operation: one-year study. Obes Surg. 1999;9(4):399-402. [pmid: 10484301].
65 Howard L, Malone M, Michalek A, et al. Gastric Bypass and Vertical Banded Gastroplasty- a Prospective Randomized Comparison and 5-Year Follow-up. Obes Surg. 1995;5(1):55-60. [pmid: 10733794].
66 Kalfarentzos F, Dimakopoulos A, Kehagias I, et al. Vertical banded gastroplasty versus standard or distal Roux-en-Y gastric bypass based on specific selection criteria in the morbidly obese: preliminary results. Obes Surg. 1999;9(5):433-42. [pmid: 10605899].
67 Karason K, Lindroos A K, Stenlof K, et al. Relief of cardiorespiratory symptoms and increased physical activity after surgically induced weight loss: results from the Swedish Obese Subjects study. Arch Intern Med. 2000;160(12):1797-802. [pmid: 10871973].
68 Karason K, Molgaard H, Wikstrand J, et al. Heart rate variability in obesity and the effect of weight loss. Am J Cardiol. 1999;83(8):1242-7. [pmid: 10215292].
69 Karason K, Wallentin I, Larsson B, et al. Effects of obesity and weight loss on left ventricular mass and relative wall thickness: survey and intervention study. BMJ. 1997;315( 7113):912-6. [pmcid: 506849]. [pmid: 11645013].
70 Karason K, Wikstrand J, Sjostrom L, et al. Weight loss and progression of early atherosclerosis in the carotid artery: a four-year controlled study of obese subjects. Int J Obes Relat Metab Disord. 1999;23(9):948-56. [pmid: 10490801].
71 Karlsson J, Sjostrom L, Sullivan M. Swedish obese subjects (SOS)--an intervention study of obesity. Two-year follow-up of health-related quality of life (HRQL) and eating behavior after gastric surgery for severe obesity. Int J Obes Relat Metab Disord. 1998;22(2):113-26. [pmid: 9504319].
72 Kim C H, Sarr M G. Severe reflux esophagitis after vertical banded gastroplasty for treatment of morbid obesity. Mayo Clin Proc. 1992;67(1):33-5. [pmid: 1732688].
73 Kothari S N, DeMaria E J, Sugerman H J, et al. Lap-band failures: conversion to gastric bypass and their preliminary outcomes. Surgery. 2002;131(6):625-9. [pmid: 12075174].
74 Laws H L, Piantadosi S. Superior gastric reduction procedure for morbid obesity: a prospective, randomized trial. Ann Surg. 1981;193(3):334-40. [pmid: 7212793]. [pmcid: 1345071].
75 Lechner G W, Elliott D W. Comparison of weight loss after gastric exclusion and partitioning. Arch Surg. 1983;118(6):685-92. [pmid: 6847362].
76 Lechner G W, Callender A K. Subtotal gastric exclusion and gastric partitioning: a randomized prospective comparison of one hundred patients. Surgery. 1981;90(4):637-44. [pmid: 7025315].
77 Letiexhe M R, Scheen A J, Gerard P L, et al. Post-gastroplasty recovery of ideal body weight normalizes glucose and insulin metabolism in obese women. J Clin Endocrinol Metab. 1995;80:334-369. [pmid: 7852491].
78 Lujan J A, Hernandez Q, Frutos M D, et al. Laparoscopic gastric bypass in the treatment of morbid obesity. Preliminary results of a new technique. Surg Endosc. 2002;16(12):1658-62. [pmid: 12140634].
79 Lundell L, Forssell H, Jensen J, et al. Measurement of pouch volume and stoma diameter after gastroplasty. Int J Obes. 1987;11(2):169-74. [pmid: 3610469].
80 Lundell L, Ruth M, Olbe L. Vertical banded gastroplasty or gastric banding for morbid obesity: effects on gastro-oesophageal reflux. Eur J Surg. 1997;163(7):525-31. [pmid: 9248987].
81 MacLean L, Rhode B. Does Genetic Predisposition Influence Surgical Results of Operations for Obesity?. Obes Surg. 1996;6(2):132-137. [pmid: 10729853].
82 MacLean L D, Rhode B M, Forse R A. Late results of vertical banded gastroplasty for morbid and super obesity. Surgery. 1990;107(1):20-7. [pmid: 2296754].
83 MacLean L D, Rhode B M, Nohr C W. Late outcome of isolated gastric bypass. Ann Surg. 2000;231(4):524-8. [pmid: 10749613]. [pmcid: 1421028].
84 MacLean LD, Rhode BM, Sampalis J, et al. Results of the surgical treatment of obesity. Am J Surg 1993;165(1):155–60; discussion 160–2.
85 Marceau P, Biron S, Bourque R A, et al. Biliopancreatic Diversion with a New Type of Gastrectomy. Obes Surg. 1993;3(1):29-35. [pmid: 10757900].
86 Mason E E. Vertical banded gastroplasty for obesity. Arch Surg. 1982;117(5):701-6. [pmid: 7073493].
87 Mason E E, Doherty C, Cullen J J, et al. Vertical gastroplasty: evolution of vertical banded gastroplasty. World J Surg. 1998;22(9):919-24. [pmid: 9717417].
88 Matthews B D, Sing R F, DeLegge M H, et al. Initial results with a stapled gastrojejunostomy for the laparoscopic isolated roux-en-Y gastric bypass. Am J Surg. 2000;179(6):476-81. [pmid: 11004334].
89 Melissas J, Christodoulakis M, Spyridakis M, et al. Disorders associated with clinically severe obesity: significant improvement after surgical weight reduction. South Med J. 1998;91(12):1143-8. [pmid: 9853727].
90 Miller K, Hell E. Laparoscopic adjustable gastric banding: a prospective 4-year follow-up study. Obes Surg. 1999;9 (2):183-7. [pmid: 11109072].
91 Mitchell J E, Lancaster K L, Burgard M A, et al. Long-term follow-up of patients' status after gastric bypass. Obes Surg. 2001;11(4):464-8. [pmid: 11501356].
92 Mittermair R P, Weiss H, Nehoda H, et al. Laparoscopic Swedish adjustable gastric banding: 6-year follow-up and comparison to other laparoscopic bariatric procedures. Obes Surg. 2003;13(3):412-7. [pmid: 12841903].
93 Morino M, Toppino M, Bonnet G, et al. Laproscopic adjustable silicone gastric banding versus vertical banded gastroplasy in morbidly obese patients. Ann Surg. 2003;238(6):835-842. [pmid: 14631220]. [pmcid: 1356165].
94 Narbro K, Agren G, Jonsson E, et al. Sick leave and disability pension before and after treatment for obesity: a report from the Swedish Obese Subjects (SOS) study. Int J Obes Relat Metab Disord. 1999;23(6):619-24. [pmid: 10411235].
95 Naslund I. The size of the gastric outlet and the outcome of surgery for obesity. Acta Chir Scand. 1986;152:205-10. [pmid: 3716740].
96 Naslund I. Gastric bypass versus gastroplasty. A prospective study of differences in two surgical procedures for morbid obesity. Acta Chir Scand Suppl. 1987;536:1-60. [pmid: 3475886].
97 Naslund I, Beckman K W. Gastric emptying rate after gastric bypass and gastroplasty. Scand J Gastroenterol. 1987;22 (2):193-201. [pmid: 11659033].
98 Naslund I, Hallgren P, Sjostrom L. Fat cell weight and number before and after gastric surgery for morbid obesity in women. Int J Obes. 1988;12(3):191-7. [pmid: 3391735].
99 Naslund I, Jarnmark I, Andersson H. Dietary intake before and after gastric bypass and gastroplasty for morbid obesity in women. Int J Obes. 1988;12(6):503-13. [pmid: 3069767].
100 Naslund I, Wickbom G, Christoffersson E, et al. A prospective randomized comparison of gastric bypass and gastroplasty. Complications and early results. Acta Chir Scand. 1986;152:681-9. [pmid: 3551425].
101 Nguyen NT, Goldman C, Rosenquist CJ, et al. Laparoscopic versus open gastric bypass: a randomized study of outcomes, quality of life, and costs. Ann Surg 2001;234(3):279–89; discussion 289–91.
102 Nguyen NT, Ho HS, Palmer LS, et al. A comparison study of laparoscopic versus open gastric bypass for morbid obesity. J Am Coll Surg 2000;191(2):149–55; discussion 155–7.
103 Nilsell K, Thorne A, Sjostedt S, et al. Prospective randomised comparison of adjustable gastric banding and vertical banded gastroplasty for morbid obesity. Eur J Surg. 2001;167(7):504-9. [pmid: 11560385].
104 Nowara H A. Egyptian experience in laparoscopic adjustable gastric banding (technique, complications and intermediate results). Obes Surg. 2001;11(1):70-5. [pmid: 11361172].
105 O'Brien P E, Dixon J B, Brown W, et al. The laparoscopic adjustable gastric band (Lap-Band): a prospective study of medium-term effects on weight, health and quality of life. Obes Surg. 2002;12 (5):652-60. [pmid: 12568201].
106 O'Brien P E, Brown W A, Smith A, et al. Prospective study of a laparoscopically placed, adjustable gastric band in the treatment of morbid obesity. Br J Surg. 1999;86(1):113-8. [pmid: 10027373].
107 Oh CH, Kim HJ, Oh S. Weight loss following transected gastric bypass with proximal Roux-en-Y. Obes Surg 1997;7(2):142–7; discussion 148.
108 Olbers T, Lonroth H, Fagevik-Olsen M, et al. Laparoscopic gastric bypass: development of technique, respiratory function, and long-term outcome. Obes Surg. 2003;13(3):364-70. [pmid: 12841895].
109 Papasavas P K, Hayetian F D, Caushaj P F, et al. Outcome analysis of laparoscopic Roux-en-Y gastric bypass for morbid obesity. The first 116 cases. Surg Endosc. 2002;16(12):1653-7. [pmid: 12239643].
110 Peace K, Dyne J, Russell G, et al. Psychobiological effects of gastric restriction surgery for morbid obesity. N Z Med J. 1989;102(862):76-8. [pmid: 2919020].
111 Perugini RA, Mason R, Czerniach DR, et al. Predictors of complication and suboptimal weight loss after laparoscopic Roux-en-Y gastric bypass: a series of 188 patients. Arch Surg 2003;138(5):541–5; discussion 545–6.
112 Pontiroli A E, Pizzocri P, Librenti M C, et al. Laparoscopic adjustable gastric banding for the treatment of morbid (grade 3) obesity and its metabolic complications: a three-year study. J Clin Endocrinol Metab. 2002;87(8):3555-61. [pmid: 12161474].
113 Pories W J, Caro J F, Flickinger E G, et al. The control of diabetes mellitus (NIDDM) in the morbidly obese with the Greenville Gastric Bypass. Ann Surg. 1987;206(3):316-23. [pmid: 3632094]. [pmcid: 1493167].
114 Pories W J, Flickinger E G, Meelheim D, et al. The effectiveness of gastric bypass over gastric partition in morbid obesity: consequence of distal gastric and duodenal exclusion. Ann Surg. 1982;196(4):389-99. [pmid: 7125726]. [pmcid: 1352695].
115 Quaade F. Jjunoileal bypass for morbid obesity. A bibliographic study and a randomized clinical trial. Surgical clinics of North America. 1979;59(6):1055-69. [pmid: 394374].
116 Rand C S, Macgregor A M. Adolescents having obesity surgery: a 6-year follow-up. South Med J. 1994;87(12):1208-13. [pmid: 7973919].
117 Randolph J G, Weintraub W H, Rigg A. Jejunoileal bypass for morbid obesity in adolescents. J Pediatr Surg. 1974;9(3):341-5. [pmid: 4843988].
118 Reddy RM, Riker A, Marra D, et al. Open Roux-en-Y gastric bypass for the morbidly obese in the era of laparoscopy. Am J Surg 2002;184(6):611–5; discussion 615–6.
119 Reinhold R B. Late results of gastric bypass surgery for morbid obesity. J Am Coll Nutr. 1994;13(4):326-31. [pmid: 7963136].
120 Rigg CA. Proceedings: Jejunoileal bypass by morbidly obese adolescent. Acta Paediatr Scand Suppl 1975;(256):62–4.
121 Schauer P R, Ikramuddin S, Gourash W, et al. Outcomes after laparoscopic Roux-en-Y gastric bypass for morbid obesity. Ann Surg. 2000;232(4):515-29. [pmid: 10998650]. [pmcid: 1421184].
122 Scopinaro N, Gianetta E, Adami G F, et al. Biliopancreatic diversion for obesity at eighteen years. Surgery. 1996;119(3):261-8. [pmid: 8619180].
123 Sjostrom C D, Lissner L, Wedel H, et al. Reduction in incidence of diabetes, hypertension and lipid disturbances after intentional weight loss induced by bariatric surgery: the SOS Intervention Study. Obes Res. 1999;7(5):477-84. [pmid: 10509605].
124 Sjostrom C D, Peltonen M, Sjostrom L. Blood pressure and pulse pressure during long-term weight loss in the obese: the Swedish Obese Subjects (SOS) Intervention Study. Obes Res. 2001;9(3):188-95. [pmid: 11323444].
125 Sjostrom C D, Peltonen M, Wedel H, et al. Differentiated long-term effects of intentional weight loss on diabetes and hypertension. Hypertension. 2000;36(1):20-5. [pmid: 10904007].
126 Smith S C, Edwards C B, Goodman G N, et al. Open vs laproscopic Roux-en-Y gastric bypqass: comparison of operative morbidity and mortality. Obes Surg. 2004;14:73-76. [pmid: 14980037].
127 Soper R T, Mason E E, Printen K J, et al. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. 1975;10(1):51-8. [pmid: 1117394].
128 Stanford A, Glascock J M, Eid G M, et al. Laparoscopic Roux-en-Y gastric bypass in morbidly obese adolescents. J Pediatr Surg. 2003;38(3):430-3. [pmid: 12632362].
129 Stoner J, Stoner P, Sytsma J. 42-month preliminary follow-up of the silastic ring vertical banded gastroplasty. Obes Surg. 1997;7(6):513-5. [pmid: 9730510].
130 Strauss R S, Bradley L J, Brolin R E. Gastric bypass surgery in adolescents with morbid obesity. J Pediatr. 2001;138(4):499-504. [pmid: 11295712].
131 Sugerman H J, Kellum J M Jr, DeMaria E J, et al. Conversion of failed or complicated vertical banded gastroplasty to gastric bypass in morbid obesity. Am J Surg. 1996;171(2):263-9. [pmid: 8619465].
132 Sugerman H J, Londrey G L, Kellum J M, et al. Weight loss with vertical banded gastroplasty and Roux-Y gastric bypass for morbid obesity with selective versus random assignment. Am J Surg. 1989;157(1):93-102. [pmid: 2910132].
133 Sugerman H J, Starkey J V, Birkenhauer R. A randomized prospective trial of gastric bypass versus vertical banded gastroplasty for morbid obesity and their effects on sweets versus non- sweets eaters. Ann Surg. 1987;205(6):613-24. [pmid: 3296971]. [pmcid: 1493086].
134 Sugerman HJ, Sugerman EL, DeMaria EJ, et al. Bariatric surgery for severely obese adolescents. J Gastrointest Surg 2003;7(1):102–7; discussion 107–8.
135 Suter M, Bettschart V, Giusti V, et al. A 3-year experience with laparoscopic gastric banding for obesity. Surg Endosc. 2000;14(6):532-6. [pmid: 10890959].
136 Suter M, Giusti V, Heraief E, et al. Early results of laparoscopic gastric banding compared with open vertical banded gastroplasty. Obes Surg. 1999;9(4):374-80. [pmid: 10484296].
137 Suter M, Giusti V, Heraief E, et al. Laparoscopic Roux-en-Y gastric bypass: initial 2-year experience. Surg Endosc. 2003;17(4):603-9. [pmid: 12582767].
138 Szold A, Abu-Abeid S. Laparoscopic adjustable silicone gastric banding for morbid obesity: results and complications in 715 patients. Surg Endosc. 2002;16(2 ):230-3. [pmid: 12489003].
139 Tacchino R M, Mancini A, Perrelli M, et al. Body composition and energy expenditure: relationship and changes in obese subjects before and after biliopancreatic diversion. Metabolism. 2003;52(5):552-8. [pmid: 12759883].
140 The Danish Obesity Project. Randomised trial of jejunoileal bypass versus medical treatment in morbid obesity. Lancet. 1979;2(8155):1255-8. [pmid: 93179].
141 Toppino M, Morino M, Bonnet G, et al. Laparoscopic surgery for morbid obesity: preliminary results from SICE registry (Italian Society of Endoscopic and Minimally Invasive Surgery). Obes Surg. 1999;9(1):62-5. [pmid: 10065587].
142 Toppino M, Morino M, Capuzzi P, et al. Outcome of vertical banded gastroplasty. Obes Surg. 1999;9(1):51-4. [pmid: 10065583].
143 Torgerson J S, Sjostrom L. The Swedish Obese Subjects (SOS) study--rationale and results. Int J Obes Relat Metab Disord. 2001;25 Suppl 1:S2-4. [pmid: 11466577].
144 van de Weijgert E J, Ruseler C H, Elte J W. Long-term follow-up after gastric surgery for morbid obesity: preoperative weight loss improves the long-term control of morbid obesity after vertical banded gastroplasty. Obes Surg. 1999;9(5):426-32. [pmid: 10605898].
145 van Gemert W G, Adang E M, Greve J W, et al. Quality of life assessment of morbidly obese patients: effect of weight- reducing surgery. Am J Clin Nutr. 1998;67(2):197-201. [pmid: 9459366].
146 Van Rij A M. Gastric bypass and gstric partitioning in morbid obesity: results of a controlled trial. Aus NZ J Med. 1984;14(3 suppl 1):340.
147 VanWoert J, Michalek A, Alger S, et al. A prospective randomized trial (PRT) of gastric bypass (GB) versus vertical banded gatroplasty (VBG) for morbid obesity (MO). Clinical Research. 1992;40(2):A642.
148 Viddal K O. Intestinal bypass. A randomized, prospective clinical study of end-to- side and end-to-end jejunoileal bypass. Scand J Gastroenterol. 1983;18(5):627-34. [pmid: 6675183].
149 Weiner R, Blanco-Engert R, Weiner S, et al. Outcome after laparoscopic adjustable gastric banding - 8 years experience. Obes Surg. 2003;13(3):427-34. [pmid: 12841906].
150 Weiner R, Bockhorn H, Rosenthal R, et al. A prospective randomized trial of different laparoscopic gastric banding techniques for morbid obesity. Surgical endoscopy. 2001;15(1):63-8. [pmid: 11178766].
151 Westling A, Gustavsson S. Laparoscopic vs open Roux-en-Y gastric bypass: a prospective, randomized trial. Obes Surg. 2001;11(3):284-92. [pmid: 11433902].
152 White J J, Cheek D, Haller J A Jr. Small bowel bypass is applicable for adolescents with morbid obesity. Am Surg. 1974;40(12):704-8. [pmid: 4429281].
153 Wiesner W, Schob O, Hauser R S, et al. Adjustable laparoscopic gastric banding in patients with morbid obesity: radiographic management, results, and postoperative complications. Radiology. 2000;216(2):389-94. [pmid: 10924559].
154 Wittgrove A C, Clark G W. Laparoscopic gastric bypass, Roux-en-Y- 500 patients: technique and results, with 3–60 month follow-up. Obes Surg. 2000;10(3):233-9. [pmid: 10929154].
155 Yale C E. Gastric surgery for morbid obesity. Complications and long-term weight control. Arch Surg. 1989;124(8):941-6. [pmid: 2757508].
156 Yale C E, Weiler S J. Weight control after vertical banded gastroplasty for morbid obesity. Am J Surg. 1991;162(1):13-8. [pmid: 2063963].
157 Yashkov YI, Timoshin AD, Oppel TA. Vertical banded gastroplasty: first experience in Russia. Obes Surg 1997;7(4):317–20; discussion 321.