# Appendix A: Preliminary Search Methodologies - Obesity

An asterisk after a term indicates truncation

SEARCH #1 (Performed 10/16/02)

DATABASE SEARCHED AND TIME PERIOD COVERED:

PUBMED - 1966-2002/Oct.

SEARCH STRATEGY:

diethylpropion* OR mazindol* OR phentermine* OR fluoxetine* OR sibutramine* OR orlistat* OR sertaline*

AND

obesity OR obes* [ti] OR obes* [ab]

AND

random allocation OR randomi* OR randomized controlled trials OR randomized controlled trial[pt]

NUMBER OF ITEMS RETRIEVED: 192

SEARCH #2 (Performed 10/16/02)

DATABASE SEARCHED AND TIME PERIOD COVERED:

PUBMED - 1966-2002/Oct.

SEARCH STRATEGY:

diethylpropion* OR mazindol* OR phentermine* OR fluoxetine* OR sibutramine* OR orlistat* OR sertaline*

AND

obesity OR obes* [ti] OR obes* [ab]

AND

controlled clinical trials OR controlled clinical trial[pt]

NUMBER OF ITEMS RETRIEVED: 168

SEARCH #3 (Performed 10/16/02)

DATABASE SEARCHED AND TIME PERIOD COVERED:

PUBMED - 1966-2002/Oct.

SEARCH STRATEGY:

anti-obesity agents AND (therapeutic use OR adverse effects)

AND

random allocation OR randomi* OR randomized controlled trials OR randomized controlled trial[pt]

NUMBER OF ITEMS RETRIEVED: 150

SEARCH #4 (Performed 10/16/02)

DATABASE SEARCHED AND TIME PERIOD COVERED:

PUBMED - 1966-2002/Oct.

SEARCH STRATEGY:

anti-obesity agents AND (therapeutic use OR adverse effects)

AND

controlled clinical trials OR controlled clinical trial[pt]

NUMBER OF ITEMS RETRIEVED: 172

## Obesity Updates to Aberdeen Searches Methodologies

An asterisk after a term indicates truncation

An exclamation point after a term indicates that the term is exploded - ie. the term and all terms under it in the hierarchy are being searched.

SEARCH #1 (Performed 11/21/2002)

DATABASE SEARCHED:

Medline

TIME PERIOD COVERED:

2000-2001

SEARCH STRATEGY:

OBESITY! OR OBESITY IN DIABETES! OR OBESITY, MORBID OR HYPERPHAGIA! OR BULIMIA! OR OBES? OR WEIGHT LOSS OR OVERWEIGHT OR WEIGHT MAINT? OR WEIGHT REDUC? OR (LOSS OR LOST OR LOSE OR LOSING)WITHIN 2 WORDS OF WEIGHT OR DIET WITHIN 5 WORDS OF WEIGHT OR WEIGHT CONTROL

AND

RANDOMIZED CONTROLLED TRIALS OR RANDOM ALLOCATION OR CLINICAL TRIALS! OR DOCUMENT TYPE=RANDOMIZED CONTROLLED TRIAL OR DOCUMENT TYPE=CLINICAL TRIAL OR CLIN TRIAL?/TI,AB OR PLACEBOS OR PLACEBO?/TI,AB OR RANDOM?/TI,AB OR RESEARCH DESIGN)OR(SINGL? OR DOUBL? OR TREBL? OR TRIPL?)(BLIND? OR MASK?)/TI,AB)

NOT

CHILD! OR CHILD? OR INFANT? OR ADOLESCEN?

AND

HUMAN

NUMBER OF ITEMS RETRIEVED: 996

SEARCH #2 (Performed 11/21/02)

DATABASE SEARCHED:

EMBASE

TIME PERIOD COVERED: 2000-2001

SEARCH STRATEGY:

OBESITY OR DIABETIC OBESITY OR MORBID OBESITY OR HYPERPHAGIA OR BULIMIA OR OVERWEIGHT OR WEIGHT REDUC? OR WEIGHT MAINT? OR WEIGHT CONTROL?) OR OBES?) OR DIET WITHIN 5 WORKDS OF WEIGHT

AND

MULTICENTER STUDY OR RANDOMIZED CONTROLLED TRIAL OR META ANALYSIS OR CROSSOVER PROCEDURE OR DOUBLE BLIND PROCEDURE OR SINGLE BLIND PROCEDURE OR RANDOMIZATION OR PLACEBO OR DRUG COMPARISON OR CLINICAL STUDY RANDOM? OR (SINGL? OR DOUBL? OR TRIPL? OR TREBL?)WITHIN 25 WORDS OF (BLIND? OR MASK?)) OR CLIN? WITH 25 WORDS OF TRIAL OR DOCUMENT TYPE= RANDOMIZED CONTROLLED TRIAL

NOT

CHILD! OR CHILD? OR INFANT? OR ADOLESCEN?

AND

HUMAN

NUMBER OF ITEMS RETRIEVED: 1319

SEARCH #3:

DATABASE SEARCHED:

Medline

TIME PERIOD COVERED:

2000-2001

SEARCH STRATEGY:

OBESITY! OR OBESITY IN DIABETES! OR OBESITY, MORBID OR HYPERPHAGIA! OR BULIMIA! OR OBES? OR WEIGHT LOSS OR OVERWEIGHT OR WEIGHT MAINT? OR WEIGHT REDUC? OR (LOSS OR LOST OR LOSE OR LOSING)WITHIN 2 WORDS OF WEIGHT OR DIET WITHIN 5 WORDS OF WEIGHT OR WEIGHT CONTROL

AND

RANDOMIZED CONTROLLED TRIALS OR RANDOM ALLOCATION OR CLINICAL TRIALS! OR DOCUMENT TYPE=RANDOMIZED CONTROLLED TRIAL OR DOCUMENT TYPE=CLINICAL TRIAL OR CLIN TRIAL?/TI,AB OR PLACEBOS OR PLACEBO?/TI,AB OR RANDOM?/TI,AB OR RESEARCH DESIGN)OR(SINGL? OR DOUBL? OR TREBL? OR TRIPL?)(BLIND? OR MASK?)/TI,AB)

AND

CHILD! OR CHILD? OR ADOLESCEN?

AND

HUMAN

NUMBER OF ITEMS RETRIEVED: 297

SEARCH #4:

DATABASE SEARCHED:

EMBASE

TIME PERIOD COVERED: 2000-2001

SEARCH STRATEGY:

OBESITY OR DIABETIC OBESITY OR MORBID OBESITY OR HYPERPHAGIA OR BULIMIA OR OVERWEIGHT OR WEIGHT REDUC? OR WEIGHT MAINT? OR WEIGHT CONTROL?) OR OBES?) OR DIET WITHIN 5 WORKDS OF WEIGHT

AND

MULTICENTER STUDY OR RANDOMIZED CONTROLLED TRIAL OR META ANALYSIS OR CROSSOVER PROCEDURE OR DOUBLE BLIND PROCEDURE OR SINGLE BLIND PROCEDURE OR RANDOMIZATION OR PLACEBO OR DRUG COMPARISON OR CLINICAL STUDY RANDOM? OR (SINGL? OR DOUBL? OR TRIPL? OR TREBL?)WITHIN 25 WORDS OF (BLIND? OR MASK?)) OR CLIN? WITH 25 WORDS OF TRIAL OR DOCUMENT TYPE=RANDOMIZED CONTROLLED TRIAL

AND

CHILD! OR CHILD? OR ADOLESCEN?

AND

HUMAN

NUMBER OF ITEMS RETRIEVED: 265

SEARCH #5 (Performed 11/22/02)

DATABASES SEARCHED:

CAB Abstracts

TIME PERIOD COVERED:

2000-2001

SEARCH STRATEGY:

OBES? OR OVEREATING OR OVERWEIGHT OR OVERFEEDING OR WEIGHT REDUCTION OR WEIGHT HYPERGLYCAEMIA SYNDROME OR WEIGHT HYPERGLYC? OR WEIGHT LOSSES OR WEIGHT GAIN OR HYPERPHAGI? OR BULIMI? OR WEIGHT LOS? OR WEIGHT AND (MAINT? OR REDUC? OR LOS? OR DIET? OR CONTROL?)OR OBESITY HYPERGLYC? SYNDROME?

AND

RANDOM? OR TRIAL? OR PLACEBO? OR VOLUNTEER? OR (SINGL? OR DOUBL? OR TREBL? OR TRIPL?) WITHIN 25 WORDS OF (BLIND? OR MASK?)

AND

MAN

NUMBER OF ITEMS RETRIEVED: 588

SEARCH #6 (Performed 11/22/02)

DATABASES SEARCHED:

BIOSIS Previews

TIME PERIOD COVERED:

2000-2001

SEARCH STRATEGY:

OBES? OR HYPERPHAGI? OR BULIMI? OR WEIGHT()LOS? OR OVERWEIGHT OR WEIGHT AND (MAINT? OR REDUC? OR LOS? OR DIET? OR CONTROL

AND

RANDOM? OR TRIAL? OR PLACEBO?

AND

HUMAN

NUMBER OF ITEMS RETRIEVED: 1322

SEARCH #7:

DATABASE SEARCHED:

Allied & Complementary Medicine

TIME PERIOD COVERED: 2001-2003

SEARCH STRATEGY:

(OBES? OR BULIMI? OR WEIGHT()LOSS? OR OVERWEIGHT)OR (WEIGHT AND (MAINT? OR REDUC? OR LOS? OR DIET? OR CONTROL?)

AND

RANDOMIZED CONTROLLED TRIALS OR RANDOM ALLOCATION OR DOUBLE BLIND METHOD OR RESEARCH DESIGN OR CLIN?(25W)TRIAL?/TI,AB OR PLACEBO OR RANDOM?/TI,AB OR TRIAL? OR SINGL? OR DOUBL? OR TREBL? OR TRIPL?)(25W)(BLIND? OR MASK?)/TI,AB) OR CLINICAL TRIALS!

NUMBER OF ITEMS RETRIEVED: 63

SEARCH #8

DATABASES SEARCHED:

SPORTDiscus

TIME PERIOD COVERED:

2000-2001

SEARCH STRATEGY:

OBES? OR HYPERPHAGI? OR BULIMI? OR WEIGHT()LOS? OR OVERWEIGHT OR WEIGHT (MAINT? OR REDUC? OR CONTROL) OR LOS?(2W)WEIGHT OR DIET?(5W)WEIGHT

AND

DOUBLE BLIND METHOD OR PROSPECTIVE STUDY OR COMPARATIVE STUDY OR RESEARCH DESIGN OR PLACEBO OR CLIN?(25W)TRIAL?/TI,AB OR PLACEBO?/TI,AB OR RANDOM?/TI,AB OR (SINGL? OR DOUBL? OR TREBL? OR TRIPL?)(25W)(BLIND? OR MASK?)/TI,AB

NUMBER OF ITEMS RETRIEVED: 110

SEARCH #9 (Performed 12/9/02)

DATABASE SEARCHED:

PsycINFO

TIME PERIOD COVERED:

2000-2001

SEARCH STRATEGY:

OBES? OR HYPERPHAGIA? OR BINGE-EATING OR BULIMI? NON-PURG? OR OVERWEIGHT OR WEIGHT (LOS? OR MAINT? OR REDUC? OR CONTROL) OR DIET?(5W)WEIGHT

AND

CLIN?(25N)TRIAL? OR PLACEBO? OR RANDOM? OR CONTROL? OR (SING? OR DOUBL? OR TREBL? OR TRIPL?)(25N)(BLIND? OR MASK?)

AND

HUMAN

NUMBER OF ITEMS RETRIEVED: 407

SEARCH #10 (Performed 12/9/02)

DATABASE SEARCHED:

SciSearch (Science Citation Index)

TIME PERIOD COVERED:

2000-2001

SEARCH STRATEGY:

OBES? OR OVERWEIGHT

AND

(TRIAL? OR STUD?) AND RANDOM?

NOT

RAT? ? OR MICE OR MOUSE OR HAMSTER? OR PORCINE OR MURINE

NUMBER OF ITEMS RETRIEVED: 520

SEARCH #11 (Performed 12/5/02)

DATABASE SEARCHED:

CINAHL

TIME PERIOD COVERED:

2000-2001

SEARCH STRATEGY:

hyperphagia or bulimia or obese or (weight and loss) or overweight

and

clinical and trial? or random or randomized or placeb? or volunteer?

NUMBER OF ITEMS RETRIEVED: 80

SEARCH #12

DATABASE SEARCHED:

Cochrane Library

TIME PERIOD COVERED:

2000-2001

SEARCH STRATEGY:

OBESITY-IN-DIABETES OR OBESITY OR OBESITY-MORBID OR ((HYPERPHAGIA OR BULIMIA OR WEIGHT-LOSS OR OBES* OR OVERWEIGHT)) OR (WEIGHT AND (LOSS or MAINT* or DIET* OR CONTROL OR REDUC* OR LOS*)

NOT

NEOPLASMS*

NUMBER OF ITEMS RETRIEVED: 1443