# Appendixes

Appendix A: Preliminary Search Methodologies - Obesity

Appendix B: Sample Data Abstraction Forms

Appendix C: Evidence Tables

Appendix D: Technical Expert Panel (TEP) Members and Peer Reviewers

Appendix E: TEP and Peer Review Comments

Appendix F: Included Studies

Appendix G: Excluded Studies