# List of Acronyms/Abbreviations

ACSM | American College of Sports Medicine
AHRQ | Agency for Healthcare Research and Quality
ANCOVA | Analysis of Covariance
ANOVA | Analysis of Variance
BIVAS | Body Image Visual Analog Scale
BDI | Beck Depression Index
BMI | Body Mass Index
CATCH | Child and Adolescent Trial for Cardiovascular Health
CDC | Centers for Disease Control and Prevention
CHD | Congenital Heart Disease
Comp | Comparison group
ECG | Electrocardiogram
EPC | Evidence-based Practice Center
ES | Effect size
FACT | Functional Assessment of Cancer Therapy
HAD scale | Hospital Anxiety and Depression
HDC | High dose chemotherapy
HF | High frequency
HHI | Herth Hope Index
HMO | Health Maintenance Organization
HS | High structure
IEE | Intervention Effect Estimate
IGF | Insulin-like Growth Factor
kcal | Kilocalories
KPS | Karnofsky Performance Status Scale
LASA | Linear Analog Self-Assessment Measure
LF | Low frequency
LS | Low structure
MAC | Mental Adjustment to Cancer Scale
mCAFT | Modified Canadian Aerobic Fitness Test
MOS-SF | Medical Outcomes Study - Social Functioning
NCI | National Cancer Institute
NKCA | Natural Killer Cell Cytotoxic Activity
NS | Not significant
PA | Physical activity
PACE | Patient-centered Assessment and Counseling for Exercise
PARQ | Physical Activity Readiness Questionnaire
PE | Physical Education
PFS | Piper Fatigue Scale
PKPCT | Power as Knowing Participation in Change Test
POMS | Profile of Mood Status
PSA | Prostate-Specific Antigen
PSBT | Protein of photosystem II reaction center
RCT | Randomized Controlled Trial
QOL | Quality of life
RSE | Rosenberg Self-Esteem
SAS | Symptom Assessment Scales
SWLS | Satisfaction With Life Scale
SCL | Symptom Checklist
SF-36 | Social Functioning - 36
STAI | Strait Anxiety Inventory
TEP | Technical Expert Panel
TOI | Trial Outcome Index
TSCS | Tennessee Self-Concept Scale