# Listing of Excluded Studies—Cancer Population

(reason for exclusion is provided in italics following each reference)

1 Astrup A. Physical activity and weight gain and fat distribution changes with menopause: current evidence and research issues. Medicine & Science in Sports & Exercise. 1999;31(11 Suppl):564-7.
not an exercise intervention
2 Baldwin M K, Courenya K. Exercise and Self-Esteem in Breast Cancer Survivors: An Application of the Exercise and Self-Esteem Model. Journal of Sport & Exercise Psychology. 1997;19:347-58.
not an exercise intervention
3 Beger H G, Schwarz A, Bergmann U. Progress in gastrointestinal tract surgery: the impact of gastrointestinal endoscopy. Surgical Endoscopy. 2003;17(2):342-50. [pmid: 12457213].
not an exercise intervention
4 Bensenor I M, Cook N R, Lee I M, et al. Active and passive smoking and risk of colds in women. Annals of Epidemiology. 2001;11(4):225-31. [pmid: 11306340].
not an exercise intervention
5 Berger K, Ajani U A, Kase C S, et al. Light-to-moderate alcohol consumption and risk of stroke among U.S. male physicians. New England Journal of Medicine. 1999;18(341):1557-64.
not an exercise intervention
6 Blanchard C M, Courneya K S, Laing D. Effects of acute exercise on state anxiety in breast cancer survivors. Oncology Nursing Forum. 2001;28(10):1617-21. [pmid: 11759309].
not an exercise intervention / examined effect of an acute bout of exercise
7 Bremer B A, Moore C T, Bourbon B M, et al. Perceptions of control, physical exercise, and psychological adjustment to breast cancer in South African women. Annals of Behavioral Medicine. 1997;19(1):51-60. [pmid: 9603678].
not an exercise intervention
8 Brown J K. Nutrition and Physical Activity During and After Cancer Treatment: An American Cancer Society Guide for Informed Choices. CA Cancer J Clin. 2003;53:268-91. [pmid: 14570227].
review
9 Caan B J, Flatt S W, Rock C L, et al. Low-energy reporting in women at risk for breast cancer recurrence. Women's Healthy Eating and Living Group. Cancer Epidemiology, Biomarkers & Prevention. 2000;9(10):1091-7.
not an exercise intervention
10 Cerulli J, Malone M. Outcomes of pharmacological and surgical treatment for obesity. Pharmacoeconomics. 1998;14(3):269-83. [pmid: 10186466].
review
11 Chlebowski R T. Breast cancer risk reduction: strategies for women at increased risk. Annual Review of Medicine. 2002;53:519-40. [pmid: 11818488].
review
12 Chlebowski R T. The American Cancer Society Guide for Nutrition and Physical Activity for Cancer Survivors: A Call to Action for Clinical Investigators. CA Cancer J Clin. 2003;53(5):266-7. [pmid: 14570226].
review
13 Chlebowski R T, Aiello E, McTiernan A. Weight loss in breast cancer patient management. Journal of Clinical Oncology. 2002;20(4):1128-43. [pmid: 11844838].
review
14 Chung K C, Walters M R, Greenfield M L, et al. Endoscopic versus open carpal tunnel release: a cost-effectiveness analysis. Plastic & Reconstructive Surgery. 1998;102(4):1089-99. [pmid: 9734428].
not an exercise intervention
15 Courneya K S. Exercise in Cancer Survivors: An Overview of Research. Medicine & Science in Sports & Exercise. 2003;35(11):1846-52. [pmid: 14600549].
review
16 Courneya K S, Freidenreich C M. Framework PEACE: An Organizational Model for Examining Physical Exercise Across the Cancer Experience. Annals of Behavioral Medicine. 2001;23(4):263-72. [pmid: 11761343].
review
17 Courneya K S, Friedenreich C M. Relationship between exercise pattern across the cancer experience and current quality of life in colorectal cancer survivors.[comment]. Journal of Alternative & Complementary Medicine. 1997;3(3):215-26.
not an exercise intervention
18 Courneya K S, Friedenreich C M. Relationship Between Exercise During Treatment and Current Quality of Life Among Survivors of Breast Cancer. Journal of Psychosocial Oncology. 1997;15(3/4):35-57.
not an exercise intervention
19 Courneya K S, Friedenreich C M. Physical exercise and quality of life following cancer diagnosis: a literature review. Annals of Behavioral Medicine. 1999;21(2):171-9. [pmid: 10499138].
review
20 Courneya K S, Friedenreich C M, Arthur K, et al. Physical exercise and quality of life in postsurgical colorectal cancer patients. Psychology, Health & Medicine. 1999;4(2):181-7.
review
21 Courneya K S, Keats M R, Turner A R. Physical exercise and quality of life in cancer patients following high dose chemotherapy and autologous bone marrow transplantation. Psycho-Oncology. 2000;9(2):127-36. [pmid: 10767750].
not an exercise intervention
22 Cunningham A J, Edmonds C V, Jenkins G P, et al. A randomized controlled trial of the effects of group psychological therapy on survival in women with metastatic breast cancer. Psycho-Oncology. 1998;7(6):508-17. [pmid: 9885092].
not an exercise intervention
23 Dally D L, Dahar W, Scott A, et al. The impact of a health education program targeting patients with high visit rates in a managed care organization. American Journal of Health Promotion. 2002;17(2):101-11. [pmid: 12471862].
not an exercise intervention
24 Daneryd P. Epoetin alfa for protection of metabolic and exercise capacity in cancer patients. Seminars in Oncology. 2002;29(3 Suppl 8):69-74. [pmid: 12082657].
not an exercise intervention
25 de Waard F, Ramlau R, Mulders Y, et al. A feasibility study on weight reduction in obese postmenopausal breast cancer patients. European Journal of Cancer Prevention. 1993;2(3):233-8. [pmid: 8490542].
not an exercise intervention
26 Decker W A, Turner-McGlade J, Fehir K M. Psychosocial aspects and the physiological effects of a cardiopulmonary exercise program in patients undergoing bone marrow transplantation (BMT) for acute leukemia (AL). Transplantation Proceedings. 1989;21(1 Pt 3):3068-9. [pmid: 2650427].
no concurrent comparison group
27 DeMarini D M. Dietary interventions of human carcinogenesis. Mutation Research. 1998;400(12):457-65. [pmid: 9685704].
not an exercise intervention
28 Demark-Wahnefried W, Clipp E C, McBride C, et al. Design of FRESH START: a randomized trial of exercise and diet among cancer survivors. Medicine & Science in Sports & Exercise. 2003;35(3):415-24. [pmid: 12618570].
no data
29 Demark-Wahnefried W, Morey M C, Clipp E C, et al. Leading the Way in Exercise and Diet (Project LEAD): intervening to improve function among older breast and prostate cancer survivors. Controlled Clinical Trials. 2003;24(2):206-23. [pmid: 12689742].
no data
30 Dimeo F, Bertz H, Finke J, et al. An aerobic exercise program for patients with haematological malignancies after bone marrow transplantation. Bone Marrow Transplantation. 1996;18(6):1157-60. [pmid: 8971388].
no concurrent comparison group
31 Dimeo F, Rumberger B G, Keul J. Aerobic exercise as therapy for cancer fatigue. Medicine & Science in Sports & Exercise. 1998;30(4):475-8. [pmid: 9565925].
no concurrent comparison group
32 Durak E P, Lilly P C. The Application of an Exercise and Wellness Program for Cancer Patients: A Preliminary Outcomes Report. Journal of Strength and Conditioning Research. 1998;12(1):3-6.
no concurrent comparison group
33 Friedenreich C M. Physical activity and cancer prevention: from observational to intervention research. Cancer Epidemiology, Biomarkers & Prevention. 2001;10(4):287-301.
review
34 Friendenreich C M, Courneya K S. Exercise as rehabilitation for cancer patients. Clinical Journal of Sport Medicine. 1996;6(4):237-44. [pmid: 8894336].
review
35 Gann P H, Ma J, Giovannucci E, et al. Lower prostate cancer risk in men with elevated plasma lycopene levels: results of a prospective analysis. Cancer Research. 1999;59(6):1225-30. [pmid: 10096552].
not an exercise intervention
36 Goel V, Sawka C A, Thiel E C, et al. Randomized trial of a patient decision aid for choice of surgical treatment for breast cancer. Medical Decision Making. 2001;21(1):1-6. [pmid: 11206942].
not an exercise intervention
37 Goodwin P, Esplen M J, Butler K, et al. Multidisciplinary weight management in locoregional breast cancer: results of a phase II study. Breast Cancer Research & Treatment. 1998;48(1):53-64. [pmid: 9541189].
not an exercise intervention
38 Greenwald P, Clifford C K, Milner J A. Diet and cancer prevention. European Journal of Cancer Prevention. 2001;37(8):948-65.
review
39 Gustavsson A, Bendahl P O, Cwikiel M, et al. No serious late cardiac effects after adjuvant radiotherapy following mastectomy in premenopausal women with early breast cancer. International Journal of Radiation Oncology, Biology, Physics. 1999;42(4):745-54. [pmid: 10098429].
not an exercise intervention
40 Hicks JE. Exercise for Cancer Patients. 5 ed. Baltimore: Williams & Wilkins; 1990.
review
41 Hoffman-Goetz L. Physical activity and cancer prevention: Animal-tumor reviews. Medicine & Science in Sports & Exercise. 2003;35(11):1828-33. [pmid: 14600546].
review
42 Irwin M L, Crumley D, McTiernan A, et al. Physical activity levels before and after a diagnosis of breast carcinoma: the Health, Eating, Activity, and Lifestyle (HEAL) study. Cancer. 2003;97(7):1746-57. [pmid: 12655532].
cross sectional study
43 Jacobs E T, Giuliano A R, Roe D J, et al. Baseline dietary fiber intake and colorectal adenoma recurrence in the wheat bran fiber randomized trial. Journal of the National Cancer Institute. 2002;94(21):1620-5. [pmid: 12419788].
not an exercise intervention
44 Janer G, Sala M, Kogevinas M. Health promotion trials at worksites and risk factors for cancer. Scandinavian Journal of Work, Environment & Health. 2002;28(3):141-57. [pmid: 12109553].
review
45 Jones L W, Courneya K S. Exercise discussions during cancer treatment consultations. Cancer Practice. 2002;10(2):66-74. [pmid: 12100105].
not an exercise intervention
46 Kerr C. Translating “mind-in-body”: two models of patient experience underlying a randomized controlled trial of qigong. Culture, Medicine & Psychiatry. 2002;26(4):419-47.
description of intervention yet to be done
47 Khushalani N I, McKinley B P, Gibbs J F, et al. Regional chemotherapy is indicated after surgical resection of colorectal metastases to the liver: a debate. Journal of Surgical Oncology. 2003;82(1):65-72. [pmid: 12501170].
review
48 Kolden G G, Strauman T J, Ward A, et al. A pilot study of group exercise training (GET) for women with primary breast cancer: feasibility and health benefits. Psycho-Oncology. 2002;11(5):447-56. [pmid: 12228878].
no concurrent comparison group
49 Lambert C P, Sullivan D H, Freeling S A, et al. Effects of testosterone replacement and/or resistance exercise on the composition of megestrol acetate stimulated weight gain in elderly men: a randomized controlled trial. Journal of Clinical Endocrinology & Metabolism. May. 2002;87(5):2100-6. [pmid: 11994348].
does not include cancer patients/survivors
50 Lamberts S W. The endocrinology of gonadal involution: menopause and andropause. Annales d Endocrinologie. 2003;64(2):77-81. [pmid: 12773935].
review
51 Lee I M. Physical activity and cancer prevention - Data from epidemiologic studies. Medicine & Science in Sports & Exercise. 2003;35(11):1823-7. [pmid: 14600545].
review
52 Liu S, Lee I M, Ajani U, et al. Intake of vegetables rich in carotenoids and risk of coronary heart disease in men: The Physicians' Health Study. International Journal of Epidemiology. 2001;30(1):130-5. [pmid: 11171873].
not an exercise intervention
53 Liu S, Manson J E, Lee I M, et al. Fruit and vegetable intake and risk of cardiovascular disease: The Women's Health Study. American Journal of Clinical Nutrition. 2000;72(4):922-8. [pmid: 11010932].
does not include cancer patients
54 Loft S, Poulsen H E. Cancer risk and oxidative DNA damage in man. Journal of Molecular Medicine. 1996;74(6):297-312. [pmid: 8862511].
review
55 Love R R, Wiebe D A, Newcomb P A, et al. Effects of tamoxifen on cardiovascular risk factors in postmenopausal women. Annals of Internal Medicine. 1991;115(11):860-4. [pmid: 1952472].
not an exercise intervention
56 Martinez M E, Heddens D, Earnest D L, et al. Physical activity, body mass index, and prostaglandin E2 levels in rectal mucosa. Journal of the National Cancer Institute. 1999;91(11):950-3. [pmid: 10359547].
does not include cancer patients/survivors
57 Mathewson-Chapman M. Pelvic muscle exercise/biofeedback for urinary incontinence after prostatectomy: an education program. Journal of Cancer Education. 1997;12(4):218-23. [pmid: 9440013].
review
58 Maxwell A E, Bastani R, Vida P, et al. Physical activity among older Filipino-American women. Women & Health. 2002;36(1):67-79. [pmid: 12215004].
not an exercise intervention
59 McTiernan A. Intervention studies in exercise and cancer prevention. Medicine & Science in Sports & Exercise. 2003;35(11):1841-5. [pmid: 14600548].
review
60 McTiernan A. Physical Activity, Exercise, and Cancer: Prevention to Treatment - Symposium Overview. Medicine & Science in Sports & Exercise. 2003;35(11):1821-2. [pmid: 14600544].
review
61 McTiernan A, Schwartz R S, Potter J, et al. Exercise clinical trials in cancer prevention research: a call to action. Cancer Epidemiology, Biomarkers & Prevention. 1999;8(3):201-7.
review
62 McTiernan A, Ulrich C, Kumai C, et al. Anthropometric and hormone effects of an eight-week exercise-diet intervention in breast cancer patients: results of a pilot study. Cancer Epidemiology, Biomarkers & Prevention. 1998;7(6):477-81.
no concurrent comparison group
63 Meyskens F L J. Chemoprevention of human cancer: A reasonable strategy?. Recent Results in Cancer Research. 1999;151:113-21. [pmid: 10337722].
review
64 Mock V. Fatigue Management: Evidence and Guidelines for Practice. Cancer. 2001;Supp 92(6):1699–707.
review
65 Morey M C, Pieper C F, Crowley G M, et al. Exercise adherence and 10-year mortality in chronically ill older adults. Journal of the American Geriatrics Society. 2002;50(12):1929-33. [pmid: 12473002].
comment
66 Moseley A, Piller N, Carati C. Combined opto-electronic perometry and bioimpedance to measure objectively the effectiveness of a new treatment intervention for chronic secondary leg lymphedema. Lymphology. 2002;35(4):136-43. [pmid: 12570322].
not an exercise intervention
67 Navarro A M, Rock C L, McNicholas L J, et al. Community-based education in nutrition and cancer: the Por La Vida Cuidandome curriculum. Journal of Cancer Education. 2000;15(3):168-72. [pmid: 11019766].
does not include cancer patients/survivors
68 Nelson J P. Perceived health, self-esteem, health habits, and perceived benefits and barriers to exercise in women who have and who have not experienced stage I breast cancer. Oncology Nursing Forum. 1991;18(7):1191-7. [pmid: 1945965].
not an exercise intervention
69 Oliveria S A, Christos P J. The epidemiology of physical activity and cancer. Annals of the New York Academy of Sciences. 1997;833:79-90. [pmid: 9616742].
not an exercise intervention
70 Ornish D M, Lee K L, Fair W R, et al. Dietary trial in prostate cancer: Early experience and implications for clinical trial design. Urology. 2001;57(4 Suppl 1):200-1. [pmid: 11295627].
no data
71 Pasagian-Macaulay A, Meilahn E N, Bradlow H L, et al. Urinary markers of estrogen metabolism 2- and 16 alpha-hydroxylation in premenopausal women. Steroids. 1996;61(8):461-7. [pmid: 8870165].
not an exercise intervention
72 Peters C, Lotzerich H, Niemeier B, et al. Influence of a Moderate Exercise Training on Natural Killer Cytotoxicity and Personality Traits in Cancer Patients. Anticancer Research. 1994;14:1033-6. [pmid: 8074446].
no concurrent comparison group
73 Petrek J A, Peters M M, Nori S, et al. Axillary lymphadenectomy. A prospective, randomized trial of 13 factors influencing drainage, including early or delayed arm mobilization. Archives of Surgery. 1990;125(3):378-82. [pmid: 2407228].
not an exercise intervention
74 Pinto B, Eakin E, Maruyama N. Health Behavior Changes After a Cancer Diagnosis: What do we know and where do we go from here?. Annals of Behavioral Medicine. 2000;22(1):38-52. [pmid: 10892527].
review
75 Porock D, Kristjanson L J, Tinnelly K, et al. An exercise intervention for advanced cancer patients experiencing fatigue: a pilot study. Journal of Palliative Care. 2000;16(3):30-6. [pmid: 11019505].
no concurrent comp group
76 Pradhan A D, Manson J E, Rifai N, et al. C-reactive protein, interleukin 6, and risk of developing type 2 diabetes mellitus. JAMA. 2001;286(3):327-34. [pmid: 11466099].
not an exercise intervention
77 Primic-Zakelj M. Screening mammography for early detection of breast cancer. Annals of Oncology. 1999;10(Supp 6):121-7. [pmid: 10676563].
review
78 Robinson R G. Strontium-89--precursor targeted therapy for pain relief of blastic metastatic disease. Cancer. 1993;72(11 Suppl):3433-5. [pmid: 8252505].
not an exercise intervention
79 Rock C L, Demark-Wahnefried W. Can lifestyle modification increase survival in women diagnosed with breast cancer?. Journal of Nutrition. 2002;132(11 Suppl):3504S-7S. [pmid: 12421877].
review
80 Rock C L, Flatt S W, Newman V, et al. Factors associated with weight gain in women after diagnosis of breast cancer. Women's Healthy Eating and Living Study Group. Journal of the American Dietetic Association. 1999;99(10):1212-21. [pmid: 10524383].
not an exercise intervention
81 Rock C L, Thomson C, Caan B J, et al. Reduction in fat intake is not associated with weight loss in most women after breast cancer diagnosis: evidence from a randomized controlled trial. Cancer. 2001;91(1):25-34. [pmid: 11148556].
not an exercise intervention
82 Salih A K, Fentiman I S. Breast cancer prevention. International Journal of Clinical Practice. 2002;56(4):267-71. [pmid: 12074209].
comment
83 Sandler RS. Aspirin and other nonsteroidal anti-inflammatory agents in the prevention of colorectal cancer. Important Advances in Oncology. 1996:123–37.
review
84 Sarna L, Conde F. Physical activity and fatigue during radiation therapy: a pilot study using actigraph monitors. Oncology Nursing Forum. 2001;28(6):1043-6. [pmid: 11475878].
observation of pa during radiation therapy
85 Schmitz K H, Ahmed R L, Yee D. Effects of a 9-month strength training intervention on insulin, insulin-like growth factor (IGF)-I, IGF-binding protein (IGFBP)-1, and IGFBP-3 in 30–50-year-old women. Cancer Epidemiology, Biomarkers & Prevention. 2002;11(12):1597-604.
does not include cancer patients/survivors
86 Schwartz A L. Patterns of exercise and fatigue in physically active cancer survivors. Oncology Nursing Forum. 1998;25(3):485-91. [pmid: 9766293].
not an exercise intervention
87 Schwartz A L. Fatigue mediates the effects of exercise on quality of life. Quality of Life Research. 1999;8(6):529-38. [pmid: 10548868].
no concurrent comparison group
88 Schwartz A L. Exercise and weight gain in breast cancer patients receiving chemotherapy. Cancer Practice. 2000;8(5):231-7. [pmid: 11898235].
no concurrent comparison group
89 Schwartz A L. Daily fatigue patterns and effect of exercise in women with breast cancer. Cancer Practice. 2000;8(1):16-24. [pmid: 11898235].
no concurrent comparison group
90 Schwartz A L, Mori M, Gao R, et al. Exercise reduces daily fatigue in women with breast cancer receiving chemotherapy. Medicine & Science in Sports & Exercise. 2001;33(5):718-23. [pmid: 11323538].
no concurrent comparison group
91 Seddon B, Bidmead M, Wilson J, et al. Target volume definition in conformal radiotherapy for prostate cancer: quality assurance in the MRC RT-01 trial. Radiotherapy & Oncology. 2000;56(1):73-83. [pmid: 10869758].
not an exercise intervention
92 Sharkey A M, Carey A B, Heise C T, et al. Cardiac rehabilitation after cancer therapy in children and young adults. American Journal of Cardiology. 1993;71(16):1488-90. [pmid: 8517409].
no concurrent comparison group
93 Shephard R J. Exercise in the prevention and treatment of cancer. An update. Sports Medicine. 1993;15(4):258-80. [pmid: 8460289].
review
94 Shore S, Shepard R J. Immune responses to exercise in children treated for cancer. Journal of Sports Medicine & Physical Fitness. 1999;39(3):240-3. [pmid: 10573667].
no concurrent comparison group
95 Silber J H, Cnaan A, Clark B J, et al. Design and baseline characteristics for the ACE Inhibitor After Anthracycline (AAA) study of cardiac dysfunction in long-term pediatric cancer survivors. American Heart Journal. 2001;142(4):577-85. [pmid: 11579345].
not an exercise intervention
96 Stephens R J, Hopwood P, Girling D J. Defining and analysing symptom palliation in cancer clinical trials: a deceptively difficult exercise. British Journal of Cancer. 1999;79(34):538-44. [pmid: 10027327].
not an exercise intervention
97 Stoll B A. Timing of weight gain in relation to breast cancer risk. Annals of Oncology. 1995;6(3):245-8. [pmid: 7612489].
review
98 Stoll B A. Western nutrition and the insulin resistance syndrome: a link to breast cancer. European Journal of Clinical Nutrition. 1999;53(2):83-7. [pmid: 10556982].
review
99 Stone N J. Primary prevention of coronary disease. Clinical Cornerstone. 1998;1(1):31-49. [pmid: 10682162].
review
100 Stone P. The measurement, causes and effective management of cancer-related fatigue. International Journal of Palliative Nursing. 2002;8(3):120-8. [pmid: 11923740].
review
101 Tworoger S S, Yasui Y, Ulrich C M, et al. Mailing strategies and recruitment into an intervention trial of the exercise effect on breast cancer biomarkers. Cancer Epidemiology, Biomarkers & Prevention. 2002;11(1):73-7.
not an exercise intervention
102 Veyrat-Follet C, Bruno R, Olivares R, et al. Clinical trial simulation of docetaxel in patients with cancer as a tool for dosage optimization. Clinical Pharmacology & Therapeutics. 2000;68(6):677-87. [pmid: 11180028].
not an exercise intervention
103 Waddell T K. Treatment of patients with lung cancer and severe emphysema: lessons from lung volume reduction surgery. Surgical Oncology. 2002;11(4):201-6. [pmid: 12450556].
review
104 Walsh G L, Morice R C, Putnam J B Jr, et al. Resection of lung cancer is justified in high-risk patients selected by exercise oxygen consumption. Annals of Thoracic Surgery. 1994;58(3):704-10. [pmid: 7944692].
not an exercise intervention
105 Washburn R A, McAuley E, Katula J, et al. The physical activity scale for the elderly (PASE): evidence for validity. Journal of Clinical Epidemiology. 1999;52(7):643-51. [pmid: 10391658].
not an exercise intervention
106 Weisberg J, Wanger J, Olson J, et al. Megestrol acetate stimulates weight gain and ventilation in underweight COPD patients. Chest. 2002;121(4):1070-8. [pmid: 11948034].
does not focus on cancer patients
107 Wenger N K. The current state of hormonal prevention of coronary heart disease in menopausal women. Revista Espanola de Cardiologia. 2003;56(1):1-8. [pmid: 12549992].
not in English / review
108 Westerlind K C. Physical Activity and Cancer Prevention - Mechanisms. Medicine & Science in Sports & Exercise. 2003;35(11):1834-40. [pmid: 14600547].
review
109 Willhite L. Osteoporosis in women: prevention and treatment. Journal of the American Pharmaceutical Association. 1998;38(5):614-23. [pmid: 9782696].
not an exercise intervention
110 Williamson D F, Pamuk E, Thun M, et al. Prospective study of intentional weight loss and mortality in overweight white men aged 40–64 years. American Journal of Epidemiology. 1999;149(6):491-503. [pmid: 10084238].
not an exercise intervention
111 Winningham M L. Walking program for people with cancer. Getting started. Cancer Nursing. 1991;14(5):270-6. [pmid: 1933847].
not an exercise intervention
112 World Health Organization, ed. Weight control and physical activity. Lyon: IARC Press; 2002. Vainio H, Bianchini F, eds. IARC Handbooks of Cancer Prevention; No. 6.
review
113 Young-McCaughan S, Mays MZ, Arzola SM, et-al. Research and commentary: Change in exercise tolerance, activity and sleep patterns, and quality of life in patients with cancer participating in a structured exercise program. Oncology Nursing Forum. Online. 2003; 30(3):441–54.
no concurrent comparison group
114 Young-McCaughan S, Sexton D L. A retrospective investigation of the relationship between aerobic exercise and quality of life in women with breast cancer. Oncology Nursing Forum. 1991;18(4):751-7. [pmid: 2067964].
not an exercise intervention