# Listing of Excluded Studies—General Population

(reason for exclusion is provided in italics following each reference)

1 Effectiveness of health checks conducted by nurses in primary care: final results of the OXCHECK study. Imperial Cancer Research Fund OXCHECK Study Group. BMJ. 1995;310(6987):1099–104.
No physical activity intervention
2 Cardiovascular disease prevention for women attending breast and cervical cancer screening programs: the WISEWOMAN projects. The WISEWOMAN Workgroup. Prev Med. 1999;28(5):496–502.
No physical activity or fitness outcome
3 The Diabetes Prevention Program. Design and methods for a clinical trial in the prevention of type 2 diabetes. Diabetes Care. 1999;22(4):623–34.
No physical activity or fitness outcome
4 Effects of physical activity counseling in primary care: the Activity Counseling Trial: a randomized controlled trial. Jama. 2001;286(6):677–87.
Less than 3 months followup
5 Acquista V W, Wachtel T J, Gomes C I, et al. Home-based Health Risk Appraisal and screening program. J Community Health. 1988;13(1):43-52. [pmid: 3360980].
No concurrent control group
6 Albright C L, Cohen S, Gibbons L, et al. Incorporating physical activity advice into primary care: physician-delivered advice within the activity counseling trial. Am J Prev Med. 2000;18(3):225-34. [pmid: 10722989].
Less than 3 months followup
7 Allen J K. Coronary risk factor modification in women after coronary artery bypass surgery. Nurs Res. 1996;45(5):260-5. [pmid: 8831651].
Targeted vascular disease patients
8 Allen L, Iwata B. Reinforcing exercise maintenance using high-rate activities. Behav Mod. 1980;4:337-54.
Fewer than 75 subjects total
9 Andersen L B, Klausen K, Nisbeth O. [One-year effect of health counseling on life style and risk factors of heart disease]. Ugeskr Laeger. 2002;164(13):1814-8. [pmid: 11957440].
Non-english language
10 Andersen R E, Franckowiak S C, Snyder J, et al. Can inexpensive signs encourage the use of stairs? Results from a community intervention. Ann Intern Med. 1998;129(5):363-9. [pmid: 9735063].
No concurrent control group
11 Andersen R E, Wadden T A, Bartlett S J, et al. Effects of lifestyle activity vs structured aerobic exercise in obese women: a randomized trial. JAMA. 1999;281(4):335-40. [pmid: 9929086].
Fewer than 75 subjects total
12 Anderssen S A, Haaland A, Hjermen I, et al. Oslo diet and exercise study: a one year randomized intervention trial. Effect on haemostatic variables and other coronary risk factors. Nutrition Metabolism in Cardiovascular Disease. 1995;5:189-200.
Less than 3 months followup
13 Annesi J J. Effects of computer feedback on adherence to exercise. Percept Mot Skills. 1998;87(2):723-30. [pmid: 9842630].
No physical activity or fitness outcome
14 Annesi J J. Goal-setting protocol in adherence to exercise by Italian adults. Percept Mot Skills. 2002;94(2):453-8. [pmid: 12509165].
Fewer than 75 subjects total
15 Armstrong C, Sallis J, Hovell M, et al. Stages of change self-efficacy and the adoption of vigorous exercise: A prospective analysis. Journal of Sport and Exercise Psychology. 1993;15:390-402.
No physical activity intervention
16 Avila P, Hovell M F. Physical activity training for weight loss in Latinas: a controlled trial. Int J Obes Relat Metab Disord. 1994;18(7):476-82. [pmid: 7920873].
Fewer than 75 subjects total
17 Babyak M, Blumenthal J A, Herman S, et al. Exercise treatment for major depression: maintenance of therapeutic benefit at 10 months. Psychosom Med. 2000;62(5):633-8. [pmid: 11020092].
No concurrent control group
18 Bacon L, Keim N L, Van Loan M D, et al. Evaluating a ‘non-diet’ wellness intervention for improvement of metabolic fitness, psychological well-being and eating and activity behaviors. Int J Obes Relat Metab Disord. 2002;26(6):854-65. [pmid: 12037657].
Less than 3 months followup
19 Baigis J, Korniewicz D M, Chase G, et al. Effectiveness of a home-based exercise intervention for HIV-infected adults: a randomized trial. J Assoc Nurses AIDS Care. 2002;13(2):33-45. [pmid: 11936063].
Less than 3 months followup
20 Baranowski T, Simons-Morton B, Hooks P, et al. A center-based program for exercise change among black-American families. Health Educ Q. 1990;17(2):179-96. [pmid: 2347694].
Less than 3 months followup
21 Barker F. Worksite health promotion - today and tomorrow. Decreasing barriers: a blueprint for workplace health in the nineties. Dallas: American Heart Association; 1988:5–16.
Less than 3 months followup
22 Barnard R J, Anthony D F. Effect of health maintenance programs on Los Angeles City firefighters. J Occup Med. 1980;22(10):667-9. [pmid: 7431135].
No concurrent control group
23 Baum J G, Clark H B, Sandler J. Preventing relapse in obesity through posttreatment maintenance systems: comparing the relative efficacy of two levels of therapist support. J Behav Med. 1991;14(3):287-302. [pmid: 1875405].
Fewer than 75 subjects total
24 Bauman A E, Bellew B, Owen N, et al. Impact of an Australian mass media campaign targeting physical activity in 1998. Am J Prev Med. 2001;21(1):41-7. [pmid: 11418256].
Less than 3 months followup
25 Belcher J D, Ellison R C, Shepard W E, et al. Lipid and lipoprotein distributions in children by ethnic group, gender, and geographic location--preliminary findings of the Child and Adolescent Trial for Cardiovascular Health (CATCH). Prev Med. 1993;22(2):143-53. [pmid: 8512601].
No physical activity or fitness outcome
26 Bell A C, Swinburn B A, Amosa H, et al. A nutrition and exercise intervention program for controlling weight in Samoan communities in New Zealand. Int J Obes Relat Metab Disord. 2001;25(6):920-7. [pmid: 11439309].
Less than 3 months followup
27 Bell B, Blanke D. The effects of a worksite fitness program on employee absenteeism. Health Values1989. 1989;13:3-11.
Less than 3 months followup
28 Bell B, Blanke D. The effects of an employee fitness program on health care costs and utilization. Health Values. 1992 1992;16:3–13.
Less than 3 months followup
29 Bernacki E J, Baun W B. The relationship of job performance to exercise adherence in a corporate fitness program. J Occup Med. 1984;26(7):529-31. [pmid: 6747739].
No concurrent control group
30 Bertera R L. Behavioral risk factor and illness day changes with workplace health promotion: two-year results. Am J Health Promot. 1993;7(5):365-73. [pmid: 10148712].
Less than 3 months followup
31 Binder E F, Schechtman K B, Ehsani A A, et al. Effects of exercise training on frailty in community-dwelling older adults: results of a randomized, controlled trial. J Am Geriatr Soc. 2002;50(12):1921-8. [pmid: 12473001].
Less than 3 months followup
32 Bishop P, Donnelly J. Home based activity program for obese children. Am Corr Ther. 1987;41:12-9.
Fewer than 75 subjects total
33 Bjorkelund C, Bengtsson C. Feasibility of a primary health care programme aiming at reducing cardiovascular and cerebrovascular risk factors among women in a Swedish community, Stromstad. Scand J Prim Health Care. 1991;9(2):89-95. [pmid: 1891663].
No physical activity or fitness outcome
34 Bjorkelund C, Bengtsson C. Risk factor pattern for cardiovascular and cerebrovascular disease as observed in the female population of a Swedish community, Stromstad. Scand J Prim Health Care. 1991;9(1):11-5. [pmid: 1891663].
No physical activity or fitness outcome
35 Blair S, Kohl H, Gordon N. Physical activity and health: A lifestyle approach. Med Ex Nutr Health. 1992;1:54-7.
No physical activity intervention
36 Blair S N, Applegate W B, Dunn A L, et al. Activity Counseling Trial (ACT): rationale, design, and methods. Activity Counseling Trial Research Group. Med Sci Sports Exerc. 1998;30(7):1097-106. [pmid: 9662679].
Less than 3 months followup
37 Blair S N, Blair A, Howe H G, et al. Leisure time physical activity and job performance. Res Q Exerc Sport. 1980;51(4):718-23. [pmid: 7209129].
No physical activity intervention
38 Blair S N, Collingwood T R, Reynolds R, et al. Health promotion for educators: impact on health behaviors, satisfaction, and general well-being. Am J Public Health. 1984;74(2):147-9. [pmid: 6691526]. [pmcid: 1651402].
Less than 3 months followup
39 Blair S N, Piserchia P V, Wilbur C S, et al. A public health intervention model for work-site health promotion. Impact on exercise and physical fitness in a health promotion plan after 24 months. JAMA. 1986;255(7):921-6. [pmid: 3944998].
Less than 3 months followup
40 Blake S, Jeffrey R, Finnegan J, et al. Process evaluation of a community-based physical activity campaign: the Minnesota Heart Health Program experience. Health Ed Res. 1987;2:115-21.
No concurrent control group
41 Blamey A, Mutrie N, Aitchison T. Health promotion by encouraged use of stairs. BMJ. 1995;311(7000):289-90. [pmid: 7633234].
No concurrent control group
42 Blumenthal J A, Emery C F, Madden D J, et al. Cardiovascular and behavioral effects of aerobic exercise training in healthy older men and women. J Gerontol. 1989;44(5):M147-57. [pmid: 2768768].
Less than 3 months followup
43 Bobalik J, Jensen R, Pavelka R. Alterations in pre-exercise versus post-exercise data after four months of supervised exercise. Fitness in Business. 1986;1:62-7.
Less than 3 months followup
44 Booth M, Bauman A, Oldenburg B, et al. Effects of a national mass-media campaign on physical activity participation. Health Promot Int. 1992;7:241-7.
No concurrent control group
45 Borg P, Kukkonen-Harjula K, Fogelholm M, et al. Effects of walking or resistance training on weight loss maintenance in obese, middle-aged men: a randomized trial. Int J Obes Relat Metab Disord. 2002;26(5):676-83. [pmid: 12032753].
No physical activity intervention
46 Boudreau F, Godin G, Pineau R, et al. Health risk appraisal in an occupational setting and its impact on exercise behavior. J Occup Environ Med. 1995;37(9):1145-50. [pmid: 8528724].
Less than 3 months followup
47 Brassington G S, Atienza A A, Perczek R E, et al. Intervention-related cognitive versus social mediators of exercise adherence in the elderly. Am J Prev Med. 2002;23(2 Suppl):80-6. [pmid: 12133741].
Less than 3 months followup
48 Brown W, Lee C. Exercise and dietary modification with women on non-English speaking background: A pilot study with Polish-Australian women. Int J Behav Med. 1994;1(3):185-203. [pmid: 16250796].
Fewer than 75 subjects total
49 Brownell K D, Stunkard A J, Albaum J M. Evaluation and modification of exercise patterns in the natural environment. Am J Psychiatry. 1980;137(12):1540-5. [pmid: 7435710].
No concurrent control group
50 Brownson R C, Smith C A, Pratt M, et al. Preventing cardiovascular disease through community-based risk reduction: the Bootheel Heart Health Project. Am J Public Health. 1996;86(2):206-13. [pmid: 8633737]. [pmcid: 1380329].
No concurrent control group
51 Brynteson P, Adams T Mn. The effects of conceptually based physical education programs on attitudes and exercise habits of college alumni after 2 to 11 years of follow-up. Res Q Exerc Sport. 1993;64(2):208-12. [pmid: 8341844].
No physical activity or fitness outcome
52 Buchner D M, Cress M E, de Lateur B J, et al. The effect of strength and endurance training on gait, balance, fall risk, and health services use in community-living older adults. J Gerontol A Biol Sci Med Sci. 1997;52(4):M218-24. [pmid: 9224433].
Less than 3 months followup
53 Buchner D M, Cress M E, Wagner E H, et al. The Seattle FICSIT/MoveIt study: the effect of exercise on gait and balance in older adults. J Am Geriatr Soc. 1993;41(3):321-5. [pmid: 8440857].
No physical activity or fitness outcome
54 Burckhardt C S, Mannerkorpi K, Hedenberg L, et al. A randomized, controlled clinical trial of education and physical training for women with fibromyalgia. J Rheumatol. 1994;21(4):714-20. [pmid: 8035399].
Less than 3 months followup
55 Burke V, Giangiulio N, Gillam H F, et al. Health promotion in couples adapting to a shared lifestyle. Health Educ Res. 1999;14(2):269-88. [pmid: 10387506].
Less than 3 months followup
56 Burn G E, Naylor P J, Page A. Assessment of stages of change for exercise within a worksite lifestyle screening program. Am J Health Promot. 1999;13(3):143-5. [pmid: 10351538].
No physical activity intervention
57 Burton L C, Paglia M J, German P S, et al. The effect among older persons of a general preventive visit on three health behaviors: smoking, excessive alcohol drinking, and sedentary lifestyle. The Medicare Preventive Services Research Team. 1995;24(5):492-7.
Less than 3 months followup
58 Burton L C, Steinwachs D M, German P S, et al. Preventive services for the elderly: would coverage affect utilization and costs under Medicare?. Am J Public Health. 1995;85(3):387-91. [pmid: 7892924]. [pmcid: 1614868].
Less than 3 months followup
59 Bush P J, Zuckerman A E, Taggart V S, et al. Cardiovascular risk factor prevention in black school children: the “Know Your Body” evaluation project. Health Educ Q. 1989;16(2):215-27. [pmid: 2732064].
Less than 3 months followup
60 Bush P J, Zuckerman A E, Theiss P K, et al. Cardiovascular risk factor prevention in black schoolchildren: two-year results of the “Know Your Body” program. Am J Epidemiol. 1989;129(3):466-82. [pmid: 2916540].
Less than 3 months followup
61 Buxton K, Mercer T, Wyse J. Assessment of the stage of exercise behavior change in young adult females. In: Bell F, van Gyn G, eds, eds. Access to Active Living: Proceedings for the 10th Commonwealth & International Scientific Congress. Victoria, BC, Canada: University of Victoria; 1994:256–61.
No physical activity intervention
62 Buxton K, Wyse J, Mercer T, et al. Assessing the stages of exercise behavior change and the stages of physical activity behavior change in a British worksite sample [abstract]. Journal of Sport Sciences. 1995;13:S50-S1.
No physical activity intervention
63 Calfas K, Sallis J, Lovato C, et al. Physical activity and its determinants before and after college graduation. Medicine, Exercise, Nurtition and Health. 1994;3:323-34.
Less than 3 months followup
64 Calfas K J, Long B J, Sallis J F, et al. A controlled trial of physician counseling to promote the adoption of physical activity. Prev Med. 1996;25(3):225-33. [pmid: 8780999].
Less than 3 months followup
65 Calfas K J, Sallis J F, Nichols J F, et al. Project GRAD: two-year outcomes of a randomized controlled physical activity intervention among young adults. Graduate Ready for Activity Daily. Am J Prev Med. 2000;18(1):28-37. [pmid: 10808980].
Less than 3 months followup
66 Calfas K J, Sallis J F, Oldenburg B, et al. Mediators of change in physical activity following an intervention in primary care: PACE. Prev Med. 1997;26(3):297-304. [pmid: 9144753].
Less than 3 months followup
67 Cambien F, Richard J L, Ducimetiere P, et al. The Paris Cardiovascular Risk Factor Prevention Trial. Effects of two years of intervention in a population of young men. J Epidemiol Community Health. 1981;35(2):91-7. [pmid: 7299342].
No physical activity or fitness outcome
68 Campbell M K, Tessaro I, DeVellis B, et al. Effects of a tailored health promotion program for female blue-collar workers: health works for women. Prev Med. 2002;34(3):313-23. [pmid: 11902848].
Less than 3 months followup
69 Campbell N C, Ritchie L D, Thain J, et al. Secondary prevention in coronary heart disease: a randomised trial of nurse led clinics in primary care. Heart. 1998;80(5):447-52. [pmid: 9930042]. [pmcid: 1728827].
Less than 3 months followup
70 Cardinal B. Predicting exercise behavior using components of the transtheoretical model of behavior change. Journal of Sport Behavior. 1997;20:272-83.
Fewer than 75 subjects total
71 Cardinal B. Interaction between stage of exercise and history of relapse. Journal of Human Movement Studies. 1998;34:175-85.
No physical activity intervention
72 Cardinal B. Extended stage model of physical activity behavior. Journal of Human Movement Studies. 1999;37:37-54.
No concurrent control group
73 Cardinal B, Engels H, Zhu W. Application of the transtheoretical model of behavior change to preadolescents' physical activity and exercise behavior. Pediatric Exercise Science. 1998;10:69-80.
No physical activity intervention
74 Cardinal B J, Sachs M L. Prospective analysis of stage-of-exercise movement following mail-delivered, self-instructional exercise packets. Am J Health Promot. 1995;9(6):430-2. [pmid: 10150534].
No concurrent control group
75 Cardinal B J, Sachs M L. Effects of mail-mediated, stage-matched exercise behavior change strategies on female adults' leisure-time exercise behavior. J Sports Med Phys Fitness. 1996;36(2):100-7. [pmid: 8898515].
Less than 3 months followup
76 Castro C M, King A C, Brassington G S. Telephone versus mail interventions for maintenance of physical activity in older adults. Health Psychol. 2001;20(6):438-44. [pmid: 11714186].
Less than 3 months followup
77 Castro C M, Wilcox S, O'Sullivan P, et al. An exercise program for women who are caring for relatives with dementia. Psychosom Med. 2002;64(3):458-68. [pmid: 12021419].
Less than 3 months followup
78 Cauley J A, Kriska A M, LaPorte R E, et al. A two year randomized exercise trial in older women: effects on HDL-cholesterol. Atherosclerosis. 1987;66(3):247-58. [pmid: 3307795].
Less than 3 months followup
79 Clark M, Hampson S E. Implementing a psychological intervention to improve lifestyle self-management in patients with type 2 diabetes. Patient Educ Couns. Mar. 2001;42(3):247-56. [pmid: 11164324].
Less than 3 months followup
80 Clark N M, Janz N K, Dodge J A, et al. Changes in functional health status of older women with heart disease: evaluation of a program based on self-regulation. J Gerontol B Psychol Sci Soc Sci. 2000;55(2):S117-26. [pmid: 10794196].
Targeted vascular disease patients
81 Coates T J, Jeffery R W, Slinkard L A. Heart healthy eating and exercise: introducing and maintaining changes in health behaviors. Am J Public Health. 1981;71(1):15-23. [pmid: 7258426].
No concurrent control group
82 Coleman K J, Raynor H R, Mueller D M, et al. Providing sedentary adults with choices for meeting their walking goals. Prev Med. 1999;28(5):510-9. [pmid: 10329342].
Fewer than 75 subjects total
83 Cooper K H, Purdy J G, Friedman A, et al. An aerobics conditioning program for the Fort Worth, Texas School District. Res Q. 1975;46(3):345-50. [pmid: 1059208].
Less than 3 months followup
84 Corbin C, Laurie D. Exercise for a Lifetime: An Educational Effort. The Physician and the Sportsman. 1978(Jan 6):51–5.
Less than 3 months followup
85 Corry JM. MetLife's experience with fitness and wellness programming. Stat Bull Metrop Insur Co. 1990;71(4):19–20, 2–5.
No concurrent control group
86 Cox K L, Burke V, Gorely T J, et al. Controlled comparison of retention and adherence in home- vs center-initiated exercise interventions in women ages 40–65 years: The S.W.E.A.T. Study (Sedentary Women Exercise Adherence Trial). Prev Med. 2003;36(1):17-29. [pmid: 12473421].
Less than 3 months followup
87 Cox K L, Burke V, Morton A R, et al. Long-term effects of exercise on blood pressure and lipids in healthy women aged 40–65 years: The Sedentary Women Exercise Adherence Trial (SWEAT). J Hypertens. 2001;19(10):1733-43. [pmid: 11593092].
No physical activity intervention
88 Cox K L, Puddey I B, Burke V, et al. Determinants of change in blood pressure during S.W.E.A.T.: the sedentary women exercise adherence trial. Clin Exp Pharmacol Physiol. 1996;23(67):567-9. [pmid: 8800586].
Less than 3 months followup
89 Cox M, Shephard R J, Corey P. Influence of an employee fitness programme upon fitness, productivity and absenteeism. Ergonomics. 1981;24(10):795-806. [pmid: 7318813].
No concurrent control group
90 Craighead L, Blum M. Supervised exercise in behavioral treatment for moderate obesity. Behav Ther. 1989;20:49-59.
Fewer than 75 subjects total
91 Critchley J, Isaacs AJ, Rosenthall R, et al. The Newcastle exercise project. Organisational aspects may influence adherence rates. BMJ. 2000;320(7247):1472; author repply 3–4.
No physical activity intervention
92 Crow R, Blackburn H, Jacobs D, et al. Population strategies to enhance physical activity: the Minnesota Heart Health Program. Acta Med Scand Suppl. 1986;711:93-112. [pmid: 3465209].
No concurrent control group
93 Cupples M E, McKnight A. Randomised controlled trial of health promotion in general practice for patients at high cardiovascular risk. BMJ. 1994;309(6960):993-6. [pmid: 7950723].
Less than 3 months followup
94 Daltroy L H, Robb-Nicholson C, Iversen M D, et al. Effectiveness of minimally supervised home aerobic training in patients with systemic rheumatic disease. Br J Rheumatol. 1995;34(11):1064-9. [pmid: 8542209].
Fewer than 75 subjects total
95 Davis S, Lambert L, Gomez Y, et al. Southwest cardiovascular curriculum project: study findings for American Indian elementary students. J Health Educ. 1995;26:S72-81.
Less than 3 months followup
96 De Bourdeaudhuij I, Sallis J. Relative contribution of psychosocial variables to the explanation of physical activity in three population-based adult samples. Prev Med. 2002;34(2):279-88. [pmid: 11817925].
No physical activity intervention
97 DeBusk RF, Stenestrand U, Sheehan M, et al. Training effects of long versus short bouts of exercise in healthy subjects. Am J Cardiol. 1990 1990;65(15):1010–3.
Fewer than 75 subjects total
98 DeLuca R, Holborn S. Effects of a variable-ratio reinforcement schedule with changing criteria on exercise in obese and non-obese boys. J Appl Behav Anal. 1992;25:671-9. [pmid: 1429319]. [pmcid: 1279749].
Fewer than 75 subjects total
99 Dempsey J, Kimiecik J, Horn T. Parental influence on children's moderate to vigorous physical activity participation: an expectancy value approach. Pediatric Exercise Sci. 1993;5:151-67.
No concurrent control group
100 Dobs A S, Masters R B, Rajaram L, et al. A comparison of education methods and their impact on behavioral change in patients with hyperlipidemia. Patient Educ Couns. 1994;24(2):157-64. [pmid: 7746765].
No physical activity intervention
101 Donnelly J E, Jacobsen D J, Whatley J E, et al. Nutrition and physical activity program to attenuate obesity and promote physical and metabolic fitness in elementary school children. Obes Res. 1996;4(3):229-43. [pmid: 8732957].
Less than 3 months followup
102 Donovan R J, Jones S, Holman C D, et al. Assessing the reliability of a stage of change scale. Health Educ Res. 1998;13(2):285-91. [pmid: 10181026].
No physical activity intervention
103 Dornelas E A, Wylie-Rosett J, Swencionis C. The DIET study: long-term outcomes of a cognitive-behavioral weight-control intervention in independent-living elders. Dietary Intervention: Evaluation of Technology. J Am Diet Assoc. 1998;98(11):1276-81. [pmid: 9813583].
No concurrent control group
104 Dowell A C, Ochera J J, Hilton S R, et al. Prevention in practice: results of a 2-year follow-up of routine health promotion interventions in general practice. Fam Pract. 1996;13(4):357-62. [pmid: 8872092].
No physical activity intervention
105 Driggers D A, Swedberg J, Johnson R, et al. The maximum exercise stress test: is it a behavior-modification tool?. J Fam Pract. 1984;18(5):715-8. [pmid: 6716067].
Fewer than 75 subjects total
106 Dubbert P M, Cooper K M, Kirchner K A, et al. Effects of nurse counseling on walking for exercise in elderly primary care patients. J Gerontol A Biol Sci Med Sci. 2002;57(11):M733-40. [pmid: 12403802].
Less than 3 months followup
107 Duncan B, Boyce W T, Itami R, et al. A controlled trial of a physical fitness program for fifth grade students. J Sch Health. 1983;53(8):467-71. [pmid: 6358700].
Fewer than 75 subjects total
108 Dunn A L, Marcus B H, Kampert J B, et al. Comparison of lifestyle and structured interventions to increase physical activity and cardiorespiratory fitness: a randomized trial. JAMA. 1999;281(4):327-34. [pmid: 9929085].
Less than 3 months followup
109 Dunn AL, Marcus BH, Kampert JB, et al. Reduction in cardiovascular disease risk factors: 6-month results from Project Active. Prev Med. 1997 Nov-Dec 1997;26(6):883–92.
Less than 3 months followup
110 Durbeck D C, Heinzelmann F, Schacter J, et al. The National Aeronautics and Space Administration-U.S. Public Health Service Health Evaluation and Enhancement Program. Summary of results. American Journal of Cardiology. 1972;30(7):784-90. [pmid: 4678168].
Less than 3 months followup
111 Dwyer T, Coonan W E, Leitch D R, et al. An investigation of the effects of daily physical activity on the health of primary school students in South Australia. Int J Epidemiol. 1983;12(3):308-13. [pmid: 6629620].
Less than 3 months followup
112 Dzewaltowski D A, Estabrooks P A, Johnston J A. Healthy youth places promoting nutrition and physical activity. Health Educ Res. 2002;17(5):541-51. [pmid: 12408199].
No physical activity or fitness outcome
113 Eddy J M, Eynon D, Nagy S, et al. Impact of a physical fitness program in a blue-collar workforce. Health Values. 1990;14(6):14-23. [pmid: 10107726].
Less than 3 months followup
114 Edmundson E, Parcel G S, Perry C L, et al. The effects of the child and adolescent trial for cardiovascular health intervention on psychosocial determinants of cardiovascular disease risk behavior among third-grade students. Am J Health Promot. 1996;10(3):217-25. [pmid: 10163302].
Less than 3 months followup
115 Elder JP, McGraw SA, Stone EJ, et al. CATCH: process evaluation of environmental factors and programs. Health Educ Q. 1994;Suppl 2:S107–27.
No physical activity or fitness outcome
116 Elmer P J, Grimm R Jr, Laing B, et al. Lifestyle intervention: results of the Treatment of Mild Hypertension Study (TOMHS). Prev Med. 1995;24(4):378-88. [pmid: 7479629].
Less than 3 months followup
117 Emmons K M, Linnan L A, Shadel W G, et al. The Working Healthy Project: a worksite health-promotion trial targeting physical activity, diet, and smoking. J Occup Environ Med. 1999;41(7):545-55. [pmid: 10412096].
Less than 3 months followup
118 Emmons K M, Marcus B H, Linnan L, et al. Mechanisms in multiple risk factor interventions: smoking, physical activity, and dietary fat intake among manufacturing workers. Working Well Research Group. Prev Med. 1994;23(4):481-9. [pmid: 7971876].
Less than 3 months followup
119 Epstein L, Koeske R, Wing R. Adherence to exercise in obese children. J Cardiac Rehabil. 1984;4:185-95.
Fewer than 75 subjects total
120 Epstein L, Wing R, Koeske R, et al. A comparison of lifestyle change and programmed aerobic exercise on weight and fitness changes in obese children. Behav Ther. 1982;13:651-65.
Fewer than 75 subjects total
121 Epstein L, Wing R, Koeske R, et al. A comparison of lifestyle exercise, aerobic exercise, and calisthenics on weight loss in obese children. Behav Ther. 1985;16:345-56.
Fewer than 75 subjects total
122 Epstein L, Wing R, Thompson J, et al. Attendance and fitness in aerobics exercise: the effects of contract and lottery procedures. Behav Modif. 1980;4:465-79.
Fewer than 75 subjects total
123 Epstein L, Woodall K, Goreczny A, et al. The modification of activity patterns and energy expenditure in obese young girls. Behav Ther. 1984;15:101-8.
Fewer than 75 subjects total
124 Epstein L H, Valoski A M, Vara L S, et al. Effects of decreasing sedentary behavior and increasing activity on weight change in obese children. Health Psychol. 1995;14(2):109-15. [pmid: 7789345].
Fewer than 75 subjects total
125 Eriksson J, Lindstrom J, Valle T, et al. Prevention of Type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42(7):793-801. [pmid: 10440120].
No physical activity or fitness outcome
126 Eriksson K F, Lindgarde F. Prevention of type 2 (non-insulin-dependent) diabetes mellitus by diet and physical exercise. The 6-year Malmo feasibility study. Diabetologia. 1991;34(12):891-8. [pmid: 1778354].
No physical activity intervention
127 Estabrooks P A, Courneya K S, Nigg C R. Effect of a stimulus control intervention on attendance at a university fitness center. Behav Modif. 1996;20(2):202-15. [pmid: 8934867].
Less than 3 months followup
128 Ettinger W H Jr, Burns R, Messier S P, et al. A randomized trial comparing aerobic exercise and resistance exercise with a health education program in older adults with knee osteoarthritis. The Fitness Arthritis and Seniors Trial (FAST). JAMA. 1997;277(1):25-31. [pmid: 8980206].
Less than 3 months followup
129 Ewart C K, Young D R, Hagberg J M. Effects of school-based aerobic exercise on blood pressure in adolescent girls at risk for hypertension. Am J Public Health. 1998;88(6):949-51. [pmid: 9618627]. [pmcid: 1508242].
Less than 3 months followup
130 Fardy P S, White R E, Haltiwanger-Schmitz K, et al. Coronary disease risk factor reduction and behavior modification in minority adolescents: the PATH program. J Adolesc Health. 1996;18(4):247-53. [pmid: 8860788].
Less than 3 months followup
131 Farquhar J W, Fortmann S P, Flora J A, et al. Effects of communitywide education on cardiovascular disease risk factors. The Stanford Five-City Project. JAMA. 1990;264(3):359-65. [pmid: 2362332].
Less than 3 months followup
132 Farquhar J W, Fortmann S P, Maccoby N, et al. The Stanford Five-City Project: design and methods. Am J Epidemiol. 1985;122(2):323-34. [pmid: 4014215].
Less than 3 months followup
133 Farquhar J W, Maccoby N, Wood P D, et al. Community education for cardiovascular health. Lancet. 1977;1(8023):1192-5. [pmid: 68285].
Less than 3 months followup
134 Fisher S P, Fisher M M. Development, implementation, and evaluation of a health promotion program in a college setting. J Am Coll Health. 1995;44(2):81-3. [pmid: 7593999].
Fewer than 75 subjects total
135 Fitzgibbon M L, Stolley M R, Dyer A R, et al. A community-based obesity prevention program for minority children: rationale and study design for Hip-Hop to Health Jr. Prev Med. 2002;34(2):289-97. [pmid: 11817926].
No physical activity or fitness outcome
136 Flores R. Dance for health: improving fitness in African American and Hispanic adolescents. Public Health Rep. 1995;110(2):189-93. [pmid: 7630998]. [pmcid: 1382101].
Less than 3 months followup
137 Foreyt J, Goodrick G, Reeves R, et al. Response to free-living adults to behavioral treatment of obesity: attrition and compliance to exercise. Behav Ther. 1993;24:659-69.
Less than 3 months followup
138 Friedlander A L, Genant H K, Sadowsky S, et al. A two-year program of aerobics and weight training enhances bone mineral density of young women. J Bone Miner Res. 1995;10(4):574-85. [pmid: 7610928].
Less than 3 months followup
139 Fries J F, Bloch D A, Harrington H, et al. Two-year results of a randomized controlled trial of a health promotion program in a retiree population: the Bank of America Study. Am J Med. 1993;94(5):455-62. [pmid: 8498389].
Less than 3 months followup
140 Frost H, Klaber Moffett J A, Moser J S, et al. Randomised controlled trial for evaluation of fitness programme for patients with chronic low back pain. BMJ. 1995;310(6973):151-4. [pmid: 7833752].
Less than 3 months followup
141 Fuchs R. Causal models of physical exercise participation: testing the predictive power of the construct “pressure to change”. J App Soc Psychol. 1996;26(21):1931-60.
No physical activity intervention
142 Fuchs R K, Bauer J J, Snow C M. Jumping improves hip and lumbar spine bone mass in prepubescent children: a randomized controlled trial. J Bone Miner Res. 2001;16(1):148-56. [pmid: 11149479].
No physical activity intervention
143 Fuchs R K, Snow C M. Gains in hip bone mass from high-impact training are maintained: a randomized controlled trial in children. J Pediatr. 2002;141(3):357-62. [pmid: 12219055].
No physical activity intervention
144 Fuchs Z, Viskoper J R, Drexler I, et al. Comprehensive individualised nonpharmacological treatment programme for hypertension in physician-nurse clinics: two year follow-up. J Hum Hypertens. 1993;7(6):585-91. [pmid: 8114055].
Fewer than 75 subjects total
145 Gaede P, Beck M, Vedel P, et al. Limited impact of lifestyle education in patients with Type 2 diabetes mellitus and microalbuminuria: results from a randomized intervention study. Diabet Med. 2001;18(2):104-8. [pmid: 11251672].
Less than 3 months followup
146 Gamble R P, Boreham C A, Stevens A B. Effects of a 10-week exercise intervention programme on exercise and work capacities in Belfast's ambulance-men. Occup Med (Lond). 1993;43(2):85-9. [pmid: 8495008].
Less than 3 months followup
147 Garcia A, King A. Predicting long-term adherence to aerobic exercise: a comparison of two models. J Sport Exerc Psychol. 1991;13:394-410.
Fewer than 75 subjects total
148 Garcia A, Sahay A, Grimes C, et al. Physical fitness status of over 2800 pre-adolescents from a diverse high-risk population. J Appl Sport Psychol. 1997;9:S94.
Reference unobtainable
149 Gately P J, Cooke C B, Butterly R J, et al. The effects of a children's summer camp programme on weight loss, with a 10 month follow-up. Int J Obes Relat Metab Disord. 2000;24(11):1445-52. [pmid: 11126341].
No concurrent control group
150 German P S, Burton L C, Shapiro S, et al. Extended coverage for preventive services for the elderly: response and results in a demonstration population. Am J Public Health. 1995;85(3):379-86. [pmid: 7892924]. [pmcid: 1614862].
Less than 3 months followup
151 Glanz K, Shigaki D, Farzanfar R, et al. Participant reactions to a computerized telephone system for nutrition and exercise counseling. Patient Educ Couns. 2003;49(2):157-63. [pmid: 12566210].
No physical activity or fitness outcome
152 Goldfield G S, Kalakanis L E, Ernst M M, et al. Open-loop feedback to increase physical activity in obese children. Int J Obes Relat Metab Disord. 2000;24(7):888-92. [pmid: 10918536].
Fewer than 75 subjects total
153 Goldstein M, Pinto B, Lynn H, et al. Physician-based physical activity counseling for middle-aged and older adults: a randomized trial. Ann Behav Med. 1999;21:40-7. [pmid: 18425653].
Less than 3 months followup
154 Goodman R M, Wheeler F C, Lee P R. Evaluation of the Heart To Heart Project: lessons from a community-based chronic disease prevention project. Am J Health Promot. 1995;9(6):443-55. [pmid: 10150535].
Less than 3 months followup
155 Gorley P, Gordon S. An examination of the transtheoretical model and exercise behavior in older adults. Journal of Sport and Exercise Psychology. 1995;17:312-24.
Less than 3 months followup
156 Gortmaker S L, Cheung L W, Peterson K E, et al. Impact of a school-based interdisciplinary intervention on diet and physical activity among urban primary school children: eat well and keep moving. Arch Pediatr Adolesc Med. 1999;153(9):975-83. [pmid: 10482216].
Less than 3 months followup
157 Gortmaker S L, Peterson K, Wiecha J, et al. Reducing obesity via a school-based interdisciplinary intervention among youth: Planet Health. Arch Pediatr Adolesc Med. 1999;153(4):409-18. [pmid: 10201726].
Less than 3 months followup
158 Gossard D, Haskell W L, Taylor C B, et al. Effects of low- and high-intensity home-based exercise training on functional capacity in healthy middle-aged men. Am J Cardiol. 1986;57(6):446-9. [pmid: 3946263].
Fewer than 75 subjects total
159 Gran B. Non-pharmacological methods reduce drug use in the treatment of hypertension. A two-year trial in general practice. Scand J Prim Health Care. 1991;9(2):121-8. [pmid: 1891656].
No physical activity intervention
160 Grembowski D, Patrick D, Diehr P, et al. Self-efficacy and health behavior among older adults. J Health Soc Behav. 1993;34(2):89-104. [pmid: 8277130].
Less than 3 months followup
161 Halbert J, Crotty M, Weller D, et al. Primary care-based physical activity programs: effectiveness in sedentary older patients with osteoarthritis symptoms. Arthritis Rheum. 2001;45(3):228-34. [pmid: 11409662].
Fewer than 75 subjects total
162 Hallam J, Petosa R. A worksite intervention to enhance social cognitive theory constructs to promote exercise adherence. Am J Health Promot. 1998;13(1):4-7. [pmid: 10186934].
No physical activity or fitness outcome
163 Hanefeld M, Fischer S, Schmechel H, et al. Diabetes Intervention Study. Multi-intervention trial in newly diagnosed NIDDM. Diabetes Care. 1991;14(4):308-17. [pmid: 2060433].
Less than 3 months followup
164 Hardman A E, Hudson A, Jones P R, et al. Brisk walking and plasma high density lipoprotein cholesterol concentration in previously sedentary women. BMJ. 1989;299(6709):1204-5. [pmid: 2513052].
Fewer than 75 subjects total
165 Harrell J S, Johnston L F, Griggs T R, et al. An occupation based physical activity intervention program: improving fitness and decreasing obesity. Aaohn J. 1996;44(8):377-84. [pmid: 8852235].
Less than 3 months followup
166 Harrell J S, McMurray R G, Bangdiwala S I, et al. Effects of a school-based intervention to reduce cardiovascular disease risk factors in elementary-school children: the Cardiovascular Health in Children (CHIC) study. J Pediatr. 1996;128(6):797-805. [pmid: 8648539].
Less than 3 months followup
167 Harrell J S, McMurray R G, Gansky S A, et al. A public health vs a risk-based intervention to improve cardiovascular health in elementary school children: the Cardiovascular Health in Children Study. Am J Public Health. 1999;89(10):1529-35. [pmid: 10511835]. [pmcid: 1508806].
Less than 3 months followup
168 Harris J. Northern Telecom: a million dollar medically based program in a rapidly changing high tech environment. Am J Health Promot. 1986;1:50-9.
No concurrent control group
169 Heath G W, Leonard B E, Wilson R H, et al. Community-based exercise intervention: Zuni Diabetes Project. Diabetes Care. 1987;10(5):579-83. [pmid: 3677975].
No physical activity or fitness outcome
170 Heimendinger J, Feng Z, Emmons K, et al. The Working Well Trial: baseline dietary and smoking behaviors of employees and related worksite characteristics. The Working Well Research Group. Prev Med. 1995;24(2):180-93. [pmid: 7597021].
Less than 3 months followup
171 Heinonen A, Kannus P, Sievanen H, et al. Good maintenance of high-impact activity-induced bone gain by voluntary, unsupervised exercises: An 8-month follow-up of a randomized controlled trial. J Bone Miner Res. 1999;14(1):125-8. [pmid: 10404026].
Fewer than 75 subjects total
172 Heirich M A, Foote A, Erfurt J C, et al. Work-site physical fitness programs. Comparing the impact of different program designs on cardiovascular risks. J Occup Med. May. 1993;35(5):510-7. [pmid: 8515323].
Less than 3 months followup
173 Hellenius M L, Dahlof C, Aberg H, et al. Quality of life is not negatively affected by diet and exercise intervention in healthy men with cardiovascular risk factors. Qual Life Res. 1995;4(1):13-20. [pmid: 7711685].
Less than 3 months followup
174 Hellenius M L, de Faire U, Berglund B, et al. Diet and exercise are equally effective in reducing risk for cardiovascular disease. Results of a randomized controlled study in men with slightly to moderately raised cardiovascular risk factors. Atherosclerosis. 1993;103(1):81-91. [pmid: 8280188].
Less than 3 months followup
175 Henritze J, Brammell H L, McGloin J. LIFECHECK: a successful, low touch, low tech, in-plant, cardiovascular disease risk identification and modification program. Am J Health Promot. 1992;7(2):129-36. [pmid: 10148717].
Less than 3 months followup
176 Hinkleman L L, Nieman D C. The effects of a walking program on body composition and serum lipids and lipoproteins in overweight women. J Sports Med Phys Fitness. 1993;33(1):49-58. [pmid: 8350608].
Fewer than 75 subjects total
177 Hoffmeister H, Mensink G B, Stolzenberg H, et al. Reduction of coronary heart disease risk factors in the German cardiovascular prevention study. Prev Med. 1996;25(2):135-45. [pmid: 8860278].
No physical activity or fitness outcome
178 Holcomb J D, Lira J, Kingery P M, et al. Evaluation of Jump Into Action: a program to reduce the risk of non-insulin dependent diabetes mellitus in school children on the Texas-Mexico border. J Sch Health. 1998;68(7):282-8. [pmid: 9779403].
Less than 3 months followup
179 Homel P J, Daniels P, Reid T R, et al. Results of an experimental school-based health development programme in Australia. Int J Health Educ. 1981;24(4):263-70. [pmid: 7344373].
Less than 3 months followup
180 Hopper C, Munoz K, Gruber M, et al. A school-based cardiovascular exercise and nutrition program with parent participation: an evaluation study. Children's Health Care. 1996;25(3):221-35.
Less than 3 months followup
181 Hopper C A, Gruber M B, Munoz K D, et al. Effect of including parents in a school-based exercise and nutrition program for children. Res Q Exerc Sport. 1992;63(3):315-21. [pmid: 1513963].
Less than 3 months followup
182 Hornbrook M C, Stevens V J, Wingfield D J. Seniors' Program for Injury Control and Education. J Am Geriatr Soc. 1993;41(3):309-14. [pmid: 8440855].
No physical activity or fitness outcome
183 Huber M, Pitz P, Nowak B, et al. Barriers and opportunities in providing wellness programs for hourly and salaried employees. Decreasing barriers: a blueprint for workplace health in the nineties. Dallas: American Heart Association; 1988:23–42.
No physical activity or fitness outcome
184 Huddy D C, Hebert J L, Hyner G C, et al. Facilitating changes in exercise behavior: effect of structured statements of intention on perceived barriers to action. Psychol Rep. 1995;76(3 Pt 1):867-75. [pmid: 7568603].
Less than 3 months followup
185 Huuskonen J, Vaisanen S B, Kroger H, et al. Regular physical exercise and bone mineral density: a four-year controlled randomized trial in middle-aged men. The DNASCO study. Osteoporos Int. 2001;12(5):349-55. [pmid: 11444081].
Less than 3 months followup
186 investigators O. The Oslo Diet and Exercise Study (ODES): design and objectives. Control Clin Trials. 1993;14(3):229–43.
187 Irwin M L, Yasui Y, Ulrich C M, et al. Effect of exercise on total and intra-abdominal body fat in postmenopausal women: a randomized controlled trial. JAMA. 2003;289(3):323-30. [pmid: 12525233].
No physical activity or fitness outcome
188 Jacobson B, Humphrey S. Buns on the run. Decreasing barriers: a blueprint for workplace health in the nineties. Dallas: American Heart Association; 1988:59–64.
No physical activity or fitness outcome
189 Jakicic J M, Wing R R, Butler B A, et al. Prescribing exercise in multiple short bouts versus one continuous bout: effects on adherence, cardiorespiratory fitness, and weight loss in overweight women. Int J Obes Relat Metab Disord. 1995;19(12):893-901. [pmid: 8963358].
Fewer than 75 subjects total
190 Jakicic J M, Winters C, Lang W, et al. Effects of intermittent exercise and use of home exercise equipment on adherence, weight loss, and fitness in overweight women: a randomized trial. JAMA. 1999;282(16):1554-60. [pmid: 10546695].
Less than 3 months followup
191 Jarvis K L, Friedman R H, Heeren T, et al. Older women and physical activity: using the telephone to walk. Womens Health Issues. 1997;7(1):24-9. [pmid: 9009864].
Less than 3 months followup
192 Jason L A, Greiner B J, Naylor K, et al. A large-scale, short-term, media-based weight loss program. Am J Health Promot. 1991;5(6):432-7. [pmid: 10146842].
Fewer than 75 subjects total
193 Jeffery R W, French S A. Preventing weight gain in adults: design, methods and one year results from the Pound of Prevention study. Int J Obes Relat Metab Disord. 1997;21(6):457-64. [pmid: 9192229].
Less than 3 months followup
194 Jeffery R W, Wing R R, Thorson C, et al. Use of personal trainers and financial incentives to increase exercise in a behavioral weight-loss program. J Consult Clin Psychol. 1998;66(5):777-83. [pmid: 9803696].
Less than 3 months followup
195 Jette A M, Harris B A, Sleeper L, et al. A home-based exercise program for nondisabled older adults. J Am Geriatr Soc. 1996;44(6):644-9. [pmid: 8642153].
Less than 3 months followup
196 Jette A M, Lachman M, Giorgetti M M, et al. Exercise--it's never too late: the strong-for-life program. Am J Public Health. 1999;89(1):66-72. [pmid: 9987467]. [pmcid: 1508501].
Less than 3 months followup
197 Johannesson M, Aberg H, Agreus L, et al. Cost-benefit analysis of non-pharmacological treatment of hypertension. J Intern Med. 1991;230(4):307-12. [pmid: 1919423].
No physical activity intervention
198 Johnson C C, Nicklas T A, Arbeit M L, et al. Cardiovascular intervention for high-risk families: the Heart Smart Program. South Med J. 1991;84(11):1305-12. [pmid: 1948212].
Fewer than 75 subjects total
199 Jula A, Ronnemaa T, Rastas M, et al. Long-term nopharmacological treatment for mild to moderate hypertension. J Intern Med. 1990;227(6):413-21. [pmid: 2191071].
Fewer than 75 subjects total
200 Juneau M, Rogers F, De Santos V, et al. Effectiveness of self-monitored, home-based, moderate-intensity exercise training in middle-aged men and women. Am J Cardiol. 1987;60(1):66-70. [pmid: 3604945].
Less than 3 months followup
201 Kanders B S, Ullmann-Joy P, Foreyt J P, et al. The black American lifestyle intervention (BALI): the design of a weight loss program for working-class African-American women. J Am Diet Assoc. 1994;94(3):310-2. [pmid: 8120297].
Fewer than 75 subjects total
202 Katzel L I, Bleecker E R, Colman E G, et al. Effects of weight loss vs aerobic exercise training on risk factors for coronary disease in healthy, obese, middle-aged and older men. A randomized controlled trial. JAMA. 1995;274(24):1915-21. [pmid: 8568984].
Fewer than 75 subjects total
203 Kearney J M, de Graaf C, Damkjaer S, et al. Stages of change towards physical activity in a nationally representative sample in the European Union. Public Health Nutr. 1999;2(1A):115-24. [pmid: 10933631].
No physical activity intervention
204 Keefe F, Blumenthal J. The life fitness program: a behavioral approach to making exercise a habit. J Behav Ther Exp Psychiatry. 1980;11:31-4.
Fewer than 75 subjects total
205 Kelder S H, Perry C L, Klepp K I. Community-wide youth exercise promotion: long-term outcomes of the Minnesota Heart Health Program and the Class of 1989 Study. J Sch Health. 1993;63(5):218-23. [pmid: 8336479].
Less than 3 months followup
206 Kelly R B. Controlled trial of a time-efficient method of health promotion. Am J Prev Med. 1988;4(4):200-7. [pmid: 3166825].
Less than 3 months followup
207 Kerr J, Eves F, Carroll D. Posters can prompt less active people to use the stairs. J Epidemiol Community Health. 2000;54(12):942. [pmid: 11076994].
Less than 3 months followup
208 Kerr J, McKenna J. A randomized control trial of new tailored walking campaigns in an employee sample. J Health Commun. 2000;5(3):265-79. [pmid: 11185026].
Less than 3 months followup
209 Killen J D, Robinson T N, Telch M J, et al. The Stanford Adolescent Heart Health Program. Health Educ Q. 1989;16(2):263-83. [pmid: 2732068].
Less than 3 months followup
210 Killen J D, Telch M J, Robinson T N, et al. Cardiovascular disease risk reduction for tenth graders. A multiple- factor school-based approach. JAMA. 1988;260(12):1728-33. [pmid: 3411756].
Less than 3 months followup
211 King A, Frederiksen L. Low cost strategies for increasing exercise behavior: relapse preparation training and social support. Behav Modif. 1984;8(3–20).
Fewer than 75 subjects total
212 King A, Oka R, Pruitt L, et al. Developing optimal exercise regimens for seniors: A clinical trial. Ann Behav Med. 1997;19(suppl):S56.
Less than 3 months followup
213 King A C, Baumann K, O'Sullivan P, et al. Effects of moderate-intensity exercise on physiological, behavioral, and emotional responses to family caregiving: a randomized controlled trial. J Gerontol A Biol Sci Med Sci. 2002;57(1):M26-36. [pmid: 11773209].
Less than 3 months followup
214 King A C, Brassington G. Enhancing physical and psychological functioning in older family caregivers: the role of regular physical activity. Ann Behav Med. 1997;19(2):91-100. [pmid: 9603683].
Fewer than 75 subjects total
215 King A C, Carl F, Birkel L, et al. Increasing exercise among blue-collar employees: the tailoring of worksite programs to meet specific needs. Prev Med. 1988;17(3):357-65. [pmid: 3405990].
Fewer than 75 subjects total
216 King A C, Frey-Hewitt B, Dreon D M, et al. Diet vs exercise in weight maintenance. The effects of minimal intervention strategies on long-term outcomes in men. Arch Intern Med. 1989;149(12):2741-6. [pmid: 2596943].
Fewer than 75 subjects total
217 King A C, Friedman R, Marcus B, et al. Harnessing motivational forces in the promotion of physical activity: the Community Health Advice by Telephone (CHAT) project. Health Educ Res. 2002;17(5):627-36. [pmid: 12408207].
No physical activity or fitness outcome
218 King A C, Haskell W L, Taylor C B, et al. Group- vs home-based exercise training in healthy older men and women. A community-based clinical trial. JAMA. 1991;266(11):1535-42. [pmid: 1880885].
Less than 3 months followup
219 King A C, Haskell W L, Young D R, et al. Long-term effects of varying intensities and formats of physical activity on participation rates, fitness, and lipoproteins in men and women aged 50 to 65 years. Circulation. 1995;91(10):2596-604. [pmid: 7743622].
Less than 3 months followup
220 King A C, Sallis J F, Dunn A L, et al. Overview of the Activity Counseling Trial (ACT) intervention for promoting physical activity in primary health care settings. Activity Counseling Trial Research Group. Med Sci Sports Exerc. 1998;30(7):1086-96. [pmid: 9662678].
Less than 3 months followup
221 King A C, Taylor C B, Haskell W L. Effects of differing intensities and formats of 12 months of exercise training on psychological outcomes in older adults. Health Psychol. 1993;12(4):292-300. [pmid: 8404803].
Less than 3 months followup
222 King A C, Taylor C B, Haskell W L, et al. Strategies for increasing early adherence to and long-term maintenance of home-based exercise training in healthy middle-aged men and women. Am J Cardiol. 1988;61(8):628-32. [pmid: 3344690].
Fewer than 75 subjects total
223 King A C, Taylor C B, Haskell W L, et al. Influence of regular aerobic exercise on psychological health: a randomized, controlled trial of healthy middle-aged adults. Health Psychol. 1989;8(3):305-24. [pmid: 2767021].
Less than 3 months followup
224 King M B, Whipple R H, Gruman C A, et al. The Performance Enhancement Project: improving physical performance in older persons. Arch Phys Med Rehabil. 2002;83(8):1060-9. [pmid: 12161826].
Less than 3 months followup
225 King T K, Marcus B H, Pinto B M, et al. Cognitive-behavioral mediators of changing multiple behaviors: smoking and a sedentary lifestyle. Prev Med. 1996;25(6):684-91. [pmid: 8936570].
No physical activity intervention
226 Knadler G, Rogers T. “Mountain Climb Month”, a low-cost exercise intervention program at a high-risk worksite. Fit Business. 1987;10:64-7.
Reference unobtainable
227 Kochevar A J, Smith K L, Bernard M A. Effects of a community-based intervention to increase activity in American Indian elders. J Okla State Med Assoc. 2001;94(10):455-60. [pmid: 11642001].
Fewer than 75 subjects total
228 Kohl H W 3rd, Dunn A L, Marcus B H, et al. A randomized trial of physical activity interventions: design and baseline data from project active. Med Sci Sports Exerc. 1998;30(2):275-83. [pmid: 9662676].
Less than 3 months followup
229 Kovar P A, Allegrante J P, MacKenzie C R, et al. Supervised fitness walking in patients with osteoarthritis of the knee. A randomized, controlled trial. Ann Intern Med. 1992;116(7):529-34. [pmid: 1543305].
Less than 3 months followup
230 Kraus W E, Torgan C E, Duscha B D, et al. Studies of a targeted risk reduction intervention through defined exercise (STRRIDE). Med Sci Sports Exerc. 2001;33(10):1774-84. [pmid: 11581566].
No physical activity or fitness outcome
231 Kronenfeld J J, Jackson K, Blair S N, et al. Evaluating health promotion: a longitudinal quasi-experimental design. Health Educ Q. 1987;14(2):123-39. [pmid: 3597109].
Less than 3 months followup
232 Kukkonen-Harjula K, Laukkanen R, Vuori I, et al. Effects of walking training on health-related fitness in healthy middle-aged adults--a randomized controlled study. Scand J Med Sci Sports. 1998;8(4):236-42. [pmid: 9764446].
Reference unobtainable
233 Kuller L H, Simkin-Silverman L R, Wing R R, et al. Women's Healthy Lifestyle Project: A randomized clinical trial: results at 54 months. Circulation. 2001;103(1):32-7. [pmid: 11136682].
Less than 3 months followup
234 Kumanyika S K, Charleston J B. Lose weight and win: a church-based weight loss program for blood pressure control among black women. Patient Educ Couns. 1992;19(1):19-32. [pmid: 1298945].
Fewer than 75 subjects total
235 Laforge R G, Velicer W F, Richmond R L, et al. Stage distributions for five health behaviors in the United States and Australia. Prev Med. 1999;28(1):61-74. [pmid: 9973589].
No physical activity intervention
236 Lamb S E, Bartlett H P, Ashley A, et al. Can lay-led walking programmes increase physical activity in middle aged adults? A randomised controlled trial. J Epidemiol Community Health. 2002;56(4):246-52. [pmid: 11896130].
Less than 3 months followup
237 Larsen P, Simons N. Evaluating a federal health and fitness program: indicators of improving health. Aaohn J. 1993;41(3):143-8. [pmid: 8476445].
No concurrent control group
238 Lasco R A, Curry R H, Dickson V J, et al. Participation rates, weight loss, and blood pressure changes among obese women in a nutrition-exercise program. Public Health Rep. 1989;104(6):640-6. [pmid: 2511599]. [pmcid: 1580152].
No concurrent control group
239 Laurie D. Knowledge, attitudes and reported behavior before and after a lecture-laboratory physical fitness class. The Physical Educator. 1981;38:50-4.
Less than 3 months followup
240 Leatt P, Hattin H, West C, et al. Seven year follow-up of employee fitness program. Can J Public Health. 1988;79(1):20-5. [pmid: 3355962].
No concurrent control group
241 Lee C. Getting fit: A minimal intervention for aerobic exercise. Behav Change. 1992;9(4):223-8.
Fewer than 75 subjects total
242 Leermakers E A, Perri M G, Shigaki C L, et al. Effects of exercise-focused versus weight-focused maintenance programs on the management of obesity. Addict Behav. 1999;24(2):219-27. [pmid: 10336103].
Fewer than 75 subjects total
243 Leermarkers E A, Jakicic J M, Viteri J, et al. Clinic-based vs. home-based interventions for preventing weight gain in men. Obes Res. Sep. 1998;6(5):346-52. [pmid: 9738550].
Fewer than 75 subjects total
244 Leighton R F, Repka F J, Birk T J, et al. The Toledo Exercise and Diet Study. Results at 26 weeks. Arch Intern Med. 1990;150(5):1016-20. [pmid: 2184789].
Fewer than 75 subjects total
245 Leppink H, DeGrassi A. Changes in risk behavior: a two-year follow-up study. Proceedings 13th Annual Meeting, Soc. Prospect. Man. 1977(104–7).
No concurrent control group
246 Leslie E, Owen N, Fotheryham M. Campus-based physical activity interventions: process and outcomes. Deakin University: Sydney. 1998.
Reference unobtainable
247 Leveille S G, Wagner E H, Davis C, et al. Preventing disability and managing chronic illness in frail older adults: a randomized trial of a community-based partnership with primary care. J Am Geriatr Soc. 1998;46(10):1191-8. [pmid: 9777899].
Less than 3 months followup
248 Lewis BS, Lynch WD. The effect of physician advice on exercise behavior. Prev Med. 1993 1993;22(1):110–21.
Less than 3 months followup
249 Lewis C E, Raczynski J M, Heath G W, et al. Physical activity of public housing residents in Birmingham, Alabama. Am J Public Health. 1993;83(7):1016-20. [pmid: 8328596]. [pmcid: 1694781].
No physical activity intervention
250 Lewis C E, Raczynski J M, Heath G W, et al. Promoting physical activity in low-income African-American communities: the PARR project. Ethn Dis. 1993;3(2):106-18. [pmid: 8324487].
Less than 3 months followup
251 Li F, Harmer P, McAuley E, et al. An evaluation of the effects of Tai Chi exercise on physical function among older persons: a randomized contolled trial. Ann Behav Med. 2001;23(2):139-46. [pmid: 11394556].
Less than 3 months followup
252 Logsdon D N, Lazaro C M, Meier R V. The feasibility of behavioral risk reduction in primary medical care. Am J Prev Med. 1989;5(5):249-56. [pmid: 2789846].
Less than 3 months followup
253 Long B, Haney C. Enhancing physical activity in sedentary women: information, locus of control, and attitudes. J Sport Psychol. 1986;8:8-24.
Fewer than 75 subjects total
254 Long B J, Calfas K J, Wooten W, et al. A multisite field test of the acceptability of physical activity counseling in primary care: project PACE. Am J Prev Med. 1996;12(2):73-81. [pmid: 8777071].
Less than 3 months followup
255 Lowther M, Mutrie N, Scott E M. Promoting physical activity in a socially and economically deprived community: a 12 month randomized control trial of fitness assessment and exercise consultation. J Sports Sci. 2002;20(7):577-88. [pmid: 12166883].
Less than 3 months followup
256 Lytle L A. Lessons from the Child and Adolescent Trial for Cardiovascular Health (CATCH): interventions with children. Curr Opin Lipidol. 1998;9(1):29-33. [pmid: 9502332].
No physical activity or fitness outcome
257 Maccoby N, Farquhar J W, Wood P D, et al. Reducing the risk of cardiovascular disease: effects of a community-based campaign on knowledge and behavior. J Community Health. 1977;3(2):100-14. [pmid: 617630].
Less than 3 months followup
258 Madsen J, Sallis J F, Rupp J W, et al. Relationship between self-monitoring of diet and exercise change and subsequent risk factor changes in children and adults. Patient Educ Couns. 1993;21(12):61-9. [pmid: 8337206].
Less than 3 months followup
259 Maibach E, Fora J, Nass C. Changes in self-efficacy and health behavior in response to a minimal contact community health campaign. Health Communication. 1991;3(1):1-15.
Less than 3 months followup
260 Malmgren S, Andersson G. Who were reached by and participated in a one year newspaper health information campaign?. Scand J Soc Med. 1986;14(3):133-40. [pmid: 3764373].
No concurrent control group
261 Manios Y, Kafatos A. Health and nutrition education in elementary schools: changes in health knowledge, nutrient intakes and physical activity over a six year period. Public Health Nutr. 1999;2(3A):445-8. [pmid: 10933628].
Less than 3 months followup
262 Manios Y, Kafatos A, Mamalakis G. The effects of a health education intervention initiated at first grade over a 3 year period: physical activity and fitness indices. Health Educ Res. 1998;13(4):593-606. [pmid: 10345909].
Less than 3 months followup
263 Manios Y, Moschandreas J, Hatzis C, et al. Evaluation of a health and nutrition education program in primary school children of Crete over a three-year period. Prev Med. 1999;28(2):149-59. [pmid: 10048106].
Less than 3 months followup
264 Marcus A C, Wheeler R C, Cullen J W, et al. Quasi-experimental evaluation of the Los Angeles Know Your Body program: knowledge, beliefs, and self-reported behaviors. Prev Med. 1987;16(6):803-15. [pmid: 3432230].
Less than 3 months followup
265 Marcus B H, Albrecht A E, King T K, et al. The efficacy of exercise as an aid for smoking cessation in women: a randomized controlled trial. Arch Intern Med. 1999;159(11):1229-34. [pmid: 10371231].
Less than 3 months followup
266 Marcus B H, Emmons K M, Simkin-Silverman L R, et al. Evaluation of motivationally tailored vs. standard self-help physical activity interventions at the workplace. Am J Health Promot. 1998;12(4):246-53. [pmid: 10178617].
Less than 3 months followup
267 Marcus B H, Goldstein M G, Jette A, et al. Training physicians to conduct physical activity counseling. Prev Med. 1997;26(3):382-8. [pmid: 9144763].
Fewer than 75 subjects total
268 Marcus B H, King T K, Albrecht A E, et al. Rationale, design, and baseline data for Commit to Quit: an exercise efficacy trial for smoking cessation among women. Prev Med. 1997;26(4):586-97. [pmid: 9245683].
Less than 3 months followup
269 Marcus B H, Stanton A L. Evaluation of relapse prevention and reinforcement interventions to promote exercise adherence in sedentary females. Res Q Exerc Sport. 1993;64(4):447-52. [pmid: 8278671].
Less than 3 months followup
270 Margitic S, Sevick M A, Miller M, et al. Challenges faced in recruiting patients from primary care practices into a physical activity intervention trial. Activity Counseling Trial Research Group. Prev Med. 1999;29(4):277-86. [pmid: 10547053].
Less than 3 months followup
271 Martin J E, Dubbert P M, Katell A D, et al. Behavioral control of exercise in sedentary adults: studies 1 through 6. J Consult Clin Psychol. 1984;52(5):795-811. [pmid: 6501665].
Fewer than 75 subjects total
272 McAuley E, Blissmer B, Katula J, et al. Physical activity, self-esteem, and self-efficacy relationships in older adults: a randomized controlled trial. Ann Behav Med. 2000;22(2):131-9. [pmid: 10962706].
Less than 3 months followup
273 McAuley E, Blissmer B, Marquez D X, et al. Social relations, physical activity, and well-being in older adults. Prev Med. 2000;31(5):608-17. [pmid: 11071843].
No physical activity or fitness outcome
274 McAuley E, Courneya K S, Rudolph D L, et al. Enhancing exercise adherence in middle-aged males and females. Prev Med. 1994;23(4):498-506. [pmid: 7971878].
Less than 3 months followup
275 McAuley E, Katula J, Mihalko S L, et al. Mode of physical activity and self-efficacy in older adults: a latent growth curve analysis. J Gerontol B Psychol Sci Soc Sci. 1999;54(5):P283-92. [pmid: 10542821].
Less than 3 months followup
276 McAuley E, Marquez D X, Jerome G J, et al. Physical activity and physique anxiety in older adults: fitness, and efficacy influences. Aging Ment Health. 2002;6(3):222-30. [pmid: 12217090].
No physical activity or fitness outcome
277 McAuley E, Mihalko S L, Bane S M. Exercise and self-esteem in middle-aged adults: multidimensional relationships and physical fitness and self-efficacy influences. J Behav Med. 1997;20(1):67-83. [pmid: 9058180].
Less than 3 months followup
278 McKenzie T. A behaviorally-oriented residential camping program for obese children and adolescents. Ed Treat Child. 1986;9:67-78.
Less than 3 months followup
279 McKenzie T L, Sallis J F, Kolody B, et al. Long-term effects of a physical education curriculum and staff development program: SPARK. Res Q Exerc Sport. 1997;68(4):280-91. [pmid: 9421840].
No physical activity intervention
280 McMurdo M E, Burnett L. Randomised controlled trial of exercise in the elderly. Gerontology. 1992;38(5):292-8. [pmid: 1427129].
Less than 3 months followup
281 McMurdo M E, Johnstone R. A randomized controlled trial of a home exercise programme for elderly people with poor mobility. Age Ageing. 1995;24(5):425-8. [pmid: 8669348].
Less than 3 months followup
282 Meyer A J, Nash J D, McAlister A L, et al. Skills training in a cardiovascular health education campaign. Journal of Consulting & Clinical Psychology. 1980;48(2):129-42. [pmid: 7365050].
Less than 3 months followup
283 Mills K M, Stewart A L, King A C, et al. Factors associated with enrollment of older adults into a physical activity promotion program. J Aging Health. 1996;8(1):96-113. [pmid: 10160566].
No concurrent control group
284 Minor M A, Hewett J E, Webel R R, et al. Efficacy of physical conditioning exercise in patients with rheumatoid arthritis and osteoarthritis. Arthritis Rheum. 1989;32(11):1396-405. [pmid: 2818656].
Targeted osteoarthritis patients
285 Montgomery S, Byrne J. Involvement in a corporate sponsored physical fitness program; its effects on job satisfaction, absenteeism, medical usage, health behaviors and health care program participation. Abstracts from the International Conference on Exercise, Fitness and Health. Toronto: Ontario Ministry of Culture and Recreation; 1988.
Reference unobtainable
286 Nader P R, Baranowski T, Vanderpool N A, et al. The family health project: cardiovascular risk reduction education for children and parents. J Dev Behav Pediatr. 1983;4(1):3-10. [pmid: 6833501].
Fewer than 75 subjects total
287 Narayan K M, Hoskin M, Kozak D, et al. Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. 1998;15(1):66-72. [pmid: 9472866].
Less than 3 months followup
288 Naylor P, McKenna J. Stages of change self-efficacy and behavioral preferences for exercise among British university students [abstract]. Journal of Sport Sciences. 1995;13(1):S68.
No physical activity intervention
289 Neale A, Singleton S, Dupuis M, et al. The use of behavioral contracting to increase exercise activity. Am J Health Prom. 1990;4:441-7.
No concurrent control group
290 Neff K, King A. Exercise programme adherence in older adults: the importance of acheiving one's expected benefits. Med Exerc Nutr Health. 1995;4:355-62.
Less than 3 months followup
291 Nichols JF, Wellman E, Caparosa S, et al. Impact of a worksite behavioral skills intervention. Am J Health Promot. 2000;14(4):218–21, ii.
Fewer than 75 subjects total
292 Nigg C R, Courneya K S. Transtheoretical Model: examining adolescent exercise behavior. J Adolesc Health. 1998;22(3):214-24. [pmid: 9502009].
No concurrent control group
293 Nigg C R, Courneya K S, Estabrooks P A. Maintaining attendance at a fitness center: an application of the decision balance sheet. Behav Med. 1997;23(3):130-7. [pmid: 9397285].
Less than 3 months followup
294 Noland M P. The effects of self-monitoring and reinforcement on exercise adherence. Res Q Exerc Sport. 1989;60(3):216-24. [pmid: 2489846].
Less than 3 months followup
295 Norris S L, Grothaus L C, Buchner D M, et al. Effectiveness of physician-based assessment and counseling for exercise in a staff model HMO. Prev Med. 2000;30(6):513-23. [pmid: 10901494].
Less than 3 months followup
296 Nurminen E, Malmivaara A, Ilmarinen J, et al. Effectiveness of a worksite exercise program with respect to perceived work ability and sick leaves among women with physical work. Scand J Work Environ Health. 2002;28(2):85-93. [pmid: 12019592].
Less than 3 months followup
297 Ochera J, Hilton S, Bland J M, et al. A study of the provision of health checks and health-promotion clinics in 18 general practices. Journal of Clinical Nursing. 1993;2(5):273-7.
No physical activity intervention
298 Oka R K, King A C, Young D R. Sources of social support as predictors of exercise adherence in women and men ages 50 to 65 years. Womens Health. 1995;1(2):161-75. [pmid: 9373378].
No physical activity or fitness outcome
299 Oman R F, King A C. The effect of life events and exercise program format on the adoption and maintenance of exercise behavior. Health Psychol. 2000;19(6):605-12. [pmid: 11129364].
Less than 3 months followup
300 Osler M, Jespersen N B. The effect of a community-based cardiovascular disease prevention project in a Danish municipality. Dan Med Bull. 1993;40(4):485-9. [pmid: 8222768].
Less than 3 months followup
301 Owen N, Bauman A, Booth M, et al. Serial mass-media campaigns to promote physical activity: reinforcing or redundant?. Am J Public Health. 1995;85(2):244-8. [pmid: 7856786]. [pmcid: 1615311].
No concurrent control group
302 Paradis G, O'Loughlin J, Elliott M, et al. Coeur en sante St-Henri--a heart health promotion programme in a low income, low education neighbourhood in Montreal, Canada: theoretical model and early field experience. J Epidemiol Community Health. 1995;49(5):503-12. [pmid: 7499994].
No concurrent control group
303 Parcel G S, Simons-Morton B, O'Hara N M, et al. School promotion of healthful diet and physical activity: impact on learning outcomes and self-reported behavior. Health Educ Q. 1989;16(2):181-99. [pmid: 2732062].
Less than 3 months followup
304 Pate R, Ward D, Felton G, et al. Effects of a community-based intervention on physical activity and fitness in rural youth. Med Sci Sports Exerc. 1997;29:S157.
Abstract only
305 Patrick K, Sallis J F, Prochaska J J, et al. A multicomponent program for nutrition and physical activity change in primary care: PACE+ for adolescents. Arch Pediatr Adolesc Med. 2001;155(8):940-6. [pmid: 11483123].
Less than 3 months followup
306 Pauly J T, Palmer J A, Wright C C, et al. The effect of a 14-week employee fitness program on selected physiological and psychological parameters. J Occup Med. 1982;24(6):457-63. [pmid: 7097377].
No concurrent control group
307 Peel G R, Booth M L. Impact evaluation of the Royal Australian Air Force health promotion program. Aviat Space Environ Med. 2001;72(1):44-51. [pmid: 11194993].
No concurrent control group
308 Perri M G, Anton S D, Durning P E, et al. Adherence to exercise prescriptions: effects of prescribing moderate versus higher levels of intensity and frequency. Health Psychol. 2002;21(5):452-8. [pmid: 12211512].
Less than 3 months followup
309 Perri M G, Martin A D, Leermakers E A, et al. Effects of group- versus home-based exercise in the treatment of obesity. J Consult Clin Psychol. 1997;65(2):278-85. [pmid: 9086691].
Fewer than 75 subjects total
310 Perri M G, McAdoo W G, McAllister D A, et al. Enhancing the efficacy of behavior therapy for obesity: effects of aerobic exercise and a multicomponent maintenance program. J Consult Clin Psychol. 1986;54(5):670-5. [pmid: 3771884].
Less than 3 months followup
311 Perry C, Klepp K, Halper A. Promoting healthy eating and physical activity patterns among adolescents: a pilot study of “Slice Of Life”. Health Educ Res. 1987;1:93-103.
Less than 3 months followup
312 Perry C L, Stone E J, Parcel G S, et al. School-based cardiovascular health promotion: the child and adolescent trial for cardiovascular health (CATCH). J Sch Health. 1990;60(8):406-13. [pmid: 2255198].
No physical activity or fitness outcome
313 Persson L G, Lindstrom K, Lingfors H, et al. Results from an intervention programme dealing with cardiovascular risk factors. Experiences from a study of men aged 33–42 in Habo, Sweden. Scand J Prim Health Care. 1996;14(3):184-92. [pmid: 8885032].
No concurrent control group
314 Petchers M K, Hirsch E Z, Bloch B A. A longitudinal study of the impact of a school heart health curriculum. J Community Health. 1988;13(2):85-94. [pmid: 3417889].
No physical activity or fitness outcome
315 Peterson K E, Sorensen G, Pearson M, et al. Design of an intervention addressing multiple levels of influence on dietary and activity patterns of low-income, postpartum women. Health Educ Res. 2002;17(5):531-40. [pmid: 12408198].
No physical activity or fitness outcome
316 Peterson TR, Aldana SG. Improving exercise behavior: an application of the stages of change model in a worksite setting. Am J Health Promot. 1999; 13(4):229–32, iii.
Less than 3 months followup
317 Petrella R J. Moderate aerobic exercise to increase fitness in older adults. Clin J Sport Med. 2000;10(4):307. [pmid: 11086764].
No physical activity intervention
318 Petrella R J, Bartha C. Home based exercise therapy for older patients with knee osteoarthritis: a randomized clinical trial. J Rheumatol. 2000;27(9):2215-21. [pmid: 10990236].
Less than 3 months followup
319 Petrella R J, Wight D. An office-based instrument for exercise counseling and prescription in primary care. The Step Test Exercise Prescription (STEP). Arch Fam Med. 2000;9(4):339-44. [pmid: 10776362].
No physical activity or fitness outcome
320 Petrini MF. Postmenopausal women and walking. Arch Intern Med. 12 1999;159(7):756–7.
No physical activity intervention
321 Pinto B M, Friedman R, Marcus B H, et al. Effects of a computer-based, telephone-counseling system on physical activity. Am J Prev Med. 2002;23(2):113-20. [pmid: 12121799].
Less than 3 months followup
322 Pinto B M, Goldstein M G, DePue J D, et al. Acceptability and feasibility of physician-based activity counseling. The PAL project. Am J Prev Med. 1998;15(2):95-102. [pmid: 9713664].
Less than 3 months followup
323 Pinto B M, Lynn H, Marcus B H, et al. Physician-based activity counseling: intervention effects on mediators of motivational readiness for physical activity. Ann Behav Med. 2001;23(1):2-10. [pmid: 11302351].
Less than 3 months followup
324 Pohjonen T, Ranta R. Effects of worksite physical exercise intervention on physical fitness, perceived health status, and work ability among home care workers: five-year follow-up. Prev Med. 2001;32(6):465-75. [pmid: 11394950].
No physical activity intervention
325 Pollock M L, Carroll J F, Graves J E, et al. Injuries and adherence to walk/jog and resistance training programs in the elderly. Med Sci Sports Exerc. 1991;23(10):1194-200. [pmid: 1758297].
Fewer than 75 subjects total
326 Poston W S 2nd, Haddock C K, Olvera N E, et al. Evaluation of a culturally appropriate intervention to increase physical activity. Am J Health Behav. 2001;25(4):396-406. [pmid: 11488550].
Less than 3 months followup
327 Pritchard J E, Nowson C A, Wark J D. A worksite program for overweight middle-aged men achieves lesser weight loss with exercise than with dietary change. J Am Diet Assoc. 1997;97(1):37-42. [pmid: 8990415].
Less than 3 months followup
328 Boileau R, E M, D D, et al. Aerobic exercise training and cardiorespiratory fitness in older adults: a randomized controlled trial. J Aging and Physical activity. 1999;7:374–85.
Less than 3 months followup
329 Ravussin E, Valencia M E, Esparza J, et al. Effects of a traditional lifestyle on obesity in Pima Indians. Diabetes Care. 1994;17(9):1067-74. [pmid: 7988310].
No physical activity intervention
330 Ready A E. Walking program maintenance in women with elevated serum cholesterol. Behav Med. 1996;22(1):23-31. [pmid: 8805958].
Fewer than 75 subjects total
331 Reger B, Cooper L, Booth-Butterfield S, et al. Wheeling Walks: a community campaign using paid media to encourage walking among sedentary older adults. Prev Med. 2002;35(3):285-92. [pmid: 12202072].
Less than 3 months followup
332 Reid EL, Morgan RW. Exercise prescription: a clinical trial. Am J Public Health. 1979 1979;69(6):591–5.
No concurrent control group
333 Rejeski W, Brawley L. Shaping active lifestyles in older adults: a group-facilitated behavior change intervention. Ann Behav Med. 1997;19(suppl):S106.
Fewer than 75 subjects total
334 Rejeski W J, Focht B C, Messier S P, et al. Obese, older adults with knee osteoarthritis: weight loss, exercise, and quality of life. Health Psychol. 2002;21(5):419-26. [pmid: 12211508].
Less than 3 months followup
335 Resnick B. Testing the effect of the WALC intervention on exercise adherence in older adults. J Gerontol Nurs. 2002;28(6):40-9. [pmid: 12071273].
Fewer than 75 subjects total
336 Resnicow K, Davis M, Smith M, et al. Results of the TeachWell worksite wellness program. Am J Public Health. Feb. 1998;88(2):250-7. [pmid: 9491016]. [pmcid: 1508191].
Less than 3 months followup
337 Resnicow K, Jackson A, Braithwaite R, et al. Healthy Body/Healthy Spirit: a church-based nutrition and physical activity intervention. Health Educ Res. 2002;17(5):562-73. [pmid: 12408201].
No concurrent control group
338 Resnicow K, Yaroch A L, Davis A, et al. GO GIRLS!: results from a nutrition and physical activity program for low-income, overweight African American adolescent females. Health Educ Behav. 2000;27(5):616-31. [pmid: 11009130].
Less than 3 months followup
339 Rikli R E, Edwards D J. Effects of a three-year exercise program on motor function and cognitive processing speed in older women. Res Q Exerc Sport. 1991;62(1):61-7. [pmid: 2028094].
No physical activity or fitness outcome
340 Rippe J M, Price J M, Hess S A, et al. Improved psychological well-being, quality of life, and health practices in moderately overweight women participating in a 12-week structured weight loss program. Obes Res. 1998;6(3):208-18. [pmid: 9618125].
Fewer than 75 subjects total
341 Robbins S, Coogle C, Link-Mullison M. The utility of brief health promotion workshops. Health Ed. 1987; Aug./Sep.:36–8.
Less than 3 months followup
342 Roberts K, Dench S, Minten J, et al. Community response to leisure centre provision in Belfast. London UK: Sports Council. 1989.
No concurrent control group
343 Robison J I, Rogers M A, Carlson J J, et al. Effects of a 6-month incentive-based exercise program on adherence and work capacity. Med Sci Sports Exerc. 1992;24(1):85-93. [pmid: 1549001].
Less than 3 months followup
344 Rosenfeld O, Tenenbaum G, Ruskin H, et al. Behavioural modifications following a physical activity programme in the Israeli pharmaceutical industry. AUstralian Journal of Sports Science. 1990;22:93-6.
No physical activity or fitness outcome
345 Rowland D, DiGuiseppi C, Gross M, et al. Randomised controlled trial of site specific advice on school travel patterns. Arch Dis Child. Jan. 2003;88(1):8-11. [pmid: 12495948].
No physical activity intervention
346 Rowley K G, Daniel M, Skinner K, et al. Effectiveness of a community-directed ‘healthy lifestyle’ program in a remote Australian aboriginal community. Aust N Z J Public Health. 2000;24(2):136-44. [pmid: 10790932].
No concurrent control group
347 Rudman W. Do on-site health and fitness programs affect worker productivity?. Fitness in Business. 1987;2:2-8.
No physical activity intervention
348 Rudman W, Steinhardt M. Fitness in the workplace: the effects of a corporate health and fitness program on work culture. Health Values. 1988;12:4-17.
No concurrent control group
349 Russell WD, Dzewaltowski DA, Ryan GJ. The effectiveness of a point-of-decision prompt in deterring sedentary behavior. Am J Health Promot. 1999;13(5):257–9, ii.
No concurrent control group
350 Sahota P, Rudolf M C, Dixey R, et al. Evaluation of implementation and effect of primary school based intervention to reduce risk factors for obesity. BMJ. 2001;323(7320):1027-9. [pmid: 11691759]. [pmcid: 59380].
Less than 3 months followup
351 Sahota P, Rudolf M C, Dixey R, et al. Randomised controlled trial of primary school based intervention to reduce risk factors for obesity. BMJ. 2001;323(7320):1029-32. [pmid: 11691759]. [pmcid: 59381].
Less than 3 months followup
352 Sallis J F, Calfas K J, Nichols J F, et al. Evaluation of a university course to promote physical activity: project GRAD. Res Q Exerc Sport. 1999;70(1):1-10. [pmid: 10100330].
Less than 3 months followup
353 Sallis J F, Haskell W L, Wood P D, et al. Physical activity assessment methodology in the Five-City Project. Am J Epidemiol. 1985;121(1):91-106. [pmid: 3964995].
Less than 3 months followup
354 Sallis J F, McKenzie T L, Alcaraz J E, et al. The effects of a 2-year physical education program (SPARK) on physical activity and fitness in elementary school students. Sports, Play and Active Recreation for Kids. Am J Public Health. 1997;87(8):1328-34. [pmid: 9279269]. [pmcid: 1381094].
No physical activity intervention
355 Segal R, Evans W, Johnson D, et al. Structured exercise improves physical functioning in women with stages I and II breast cancer: results of a randomized controlled trial. J Clin Oncol. 2001;19(3):657-65. [pmid: 11157015].
Targeted patients with acute disease
356 Sevick M A, Dunn A L, Morrow M S, et al. Cost-effectiveness of lifestyle and structured exercise interventions in sedentary adults: results of project ACTIVE. Am J Prev Med. 2000;19(1):1-8. [pmid: 10865157].
Less than 3 months followup
357 Sharpe P A, Connell C M. Exercise beliefs and behaviors among older employees: a health promotion trial. Gerontologist. 1992;32(4):444-9. [pmid: 1427245].
Less than 3 months followup
358 Sharpe P A, Jackson K L, White C, et al. Effects of a one-year physical activity intervention for older adults at congregate nutrition sites. Gerontologist. 1997;37(2):208-15. [pmid: 9127977].
Less than 3 months followup
359 Shaw L W. Effects of a prescribed supervised exercise program on mortality and cardiovascular morbidity in patients after myocardial infarction. The National Exercise and Heart Disease Project. Am J Cardiol. 1981;48(1):39-46. [pmid: 7304429].
Targeted patients with acute disease
360 Shephard R, Lavallee H. Impact of enhanced physical education in the prepubescent child: Trois Rivieres revisited. Pediatr Exerc Sci. 1993;5:177-89.
Less than 3 months followup
361 Shephard R J. Twelve years experience of a fitness program for the salaried employees of a Toronto life assurance company. Am J Health Promot. 1992;6(4):292-301. [pmid: 10148753].
Less than 3 months followup
362 Shephard R J, Jequier J C, Lavallee H, et al. Habitual physical activity: effects of sex, milieu, season and required activity. J Sports Med Phys Fitness. 1980;20(1):55-66. [pmid: 7442229].
Less than 3 months followup
363 Shore G, Prasad P, Zroback M. Metrofit: A cost-effective fitness program. Fitness in Business. 1989;4:146-53.
No concurrent control group
364 Siegel J, Manfredi T. Effects of a ten-month fitness program on children. Physician Sportsmed. 1984;12:91-7.
Less than 3 months followup
365 Simkin-Silverman L, Wing R R, Hansen D H, et al. Prevention of cardiovascular risk factor elevations in healthy premenopausal women. Prev Med. 1995;24(5):509-17. [pmid: 8524727].
No physical activity or fitness outcome
366 Simkin-Silverman L R, Wing R R, Boraz M A, et al. Maintenance of cardiovascular risk factor changes among middle-aged women in a lifestyle intervention trial. Womens Health. 1998;4(3):255-71. [pmid: 9787651].
Less than 3 months followup
367 Simmonds G, Naylor P, Riddoch C, et al. Stage-based counseling for exercise in primary care: A controlled trial. Journal of Sport Sciences. 1996;14:45-6.
No physical activity or fitness outcome
368 Simmons D, Fleming C, Voyle J, et al. A pilot urban church-based programme to reduce risk factors for diabetes among Western Samoans in New Zealand. Diabet Med. 1998;15(2):136-42. [pmid: 9507914].
Less than 3 months followup
369 Simons-Morton B G, Parcel G S, Baranowski T, et al. Promoting physical activity and a healthful diet among children: results of a school-based intervention study. Am J Public Health. 1991;81(8):986-91. [pmid: 1854016]. [pmcid: 1405714].
Less than 3 months followup
370 Simons-Morton D G. The context of the Activity Counseling Trial. Med Sci Sports Exerc. 1998;30(7):1084-5. [pmid: 9662679].
Less than 3 months followup
371 Simons-Morton D G, Hogan P, Dunn A L, et al. Characteristics of inactive primary care patients: baseline data from the activity counseling trial. For the Activity Counseling Trial Research Group. Prev Med. 2000;31(5):513-21. [pmid: 11071831].
Less than 3 months followup
372 Simpson J M, Oldenburg B, Owen N, et al. The Australian National Workplace Health Project: design and baseline findings. Prev Med. 2000;31(3):249-60. [pmid: 10964639].
Less than 3 months followup
373 Singh R B, Rastogi S S, Ghosh S, et al. The diet and moderate exercise trial (DAMET): results after 24 weeks. Acta Cardiol. 1992;47(6):543-57. [pmid: 1290315].
Less than 3 months followup
374 Singh R B, Singh N K, Rastogi S S, et al. Effects of diet and lifestyle changes on atherosclerotic risk factors after 24 weeks on the Indian Diet Heart Study. Am J Cardiol. 1993;71(15):1283-8. [pmid: 8498367].
Less than 3 months followup
375 Sinha D P. Project lifestyle: developing positive health lifestyles for schoolchildren in Antigua. J Sch Health. 1992;62(10):449-53. [pmid: 1289654].
No physical activity or fitness outcome
376 Slava S, Laurie D, Corbin C. Long-term effects of a conceptual physical education program. Res Q Exerc Sport. 1984;55:161-8.
Less than 3 months followup
377 Smolander J, Blair S N, Kohl H W 3rd. Work ability, physical activity, and cardiorespiratory fitness: 2-year results from Project Active. J Occup Environ Med. 2000;42(9):906-10. [pmid: 10998766].
Less than 3 months followup
378 Snyder K A, Donnelly J E, Jabobsen D J, et al. The effects of long-term, moderate intensity, intermittent exercise on aerobic capacity, body composition, blood lipids, insulin and glucose in overweight females. Int J Obes Relat Metab Disord. 1997;21(12):1180-9. [pmid: 9426387].
Fewer than 75 subjects total
379 Song T, SHephard R, Cox M. Absenteeism, employee turnover and sustained exercise participation. J Sports Med Phys Fit. 1981;22:392-9.
Less than 3 months followup
380 Sorensen G, Thompson B, Glanz K, et al. Work site-based cancer prevention: primary results from the Working Well Trial. Am J Public Health. 1996;86(7):939-47. [pmid: 8669517]. [pmcid: 1380434].
Less than 3 months followup
381 Sorensen M. Maintenance of exercise behavior for individuals at risk for cardiovascular disease. Percept Mot Skills. 1997;85(3 Pt 1):867-80. [pmid: 9399292].
Less than 3 months followup
382 Speck B J, Looney S W. Effects of a minimal intervention to increase physical activity in women: daily activity records. Nurs Res. 2001;50(6):374-8. [pmid: 11725940].
Fewer than 75 subjects total
383 Spilman M A, Goetz A, Schultz J, et al. Effects of a corporate health promotion program. J Occup Med. 1986;28(4):285-9. [pmid: 3084731].
No physical activity or fitness outcome
384 Spink K, Carron A. The effects of team building on the adherence patterns of female exercise participants. J Sport Exerc Psychol. 1993;15:39-49.
Less than 3 months followup
385 Stamler R, Stamler J, Gosch F C, et al. Primary prevention of hypertension by nutritional-hygienic means. Final report of a randomized, controlled trial. JAMA. 1989;262(13):1801-7. [pmid: 2778913].
No physical activity or fitness outcome
386 Stamler R, Stamler J, Gosch F C, et al. Primary prevention of hypertension--a randomized controlled trial. Ann Clin Res. 1984;16(Suppl 43):136-42. [pmid: 6398983].
Less than 3 months followup
387 Stevens V J, Corrigan S A, Obarzanek E, et al. Weight loss intervention in phase 1 of the Trials of Hypertension Prevention. The TOHP Collaborative Research Group. Arch Intern Med. 1993;153(7):849-58. [pmid: 8466377].
Less than 3 months followup
388 Stewart A, Verboncoeur C, McLellan B, et al. Preliminary outcomes of CHAMPS II: a physical activity promotion program for seniors in a Medicare HMO setting. In: Research CIfA, ed. Specialty Conference on Physical Activity Interventions; 1997:31.
Reference unobtainable
389 Stewart A L, Mills K M, Sepsis P G, et al. Evaluation of CHAMPS, a physical activity promotion program for older adults. Ann Behav Med. 1998;19(4):353-61.
No concurrent control group
390 Stewart A L, Verboncoeur C J, McLellan B Y, et al. Physical activity outcomes of CHAMPS II: a physical activity promotion program for older adults. J Gerontol A Biol Sci Med Sci. 2001;56(8):M465-70. [pmid: 11487597].
Less than 3 months followup
391 Stone W J, Rothstein D E, Shoenhair C L. Coronary health disease risk factors and health related fitness in long- term exercising versus sedentary corporate executives. Am J Health Promot. 1991;5(3):169-72. [pmid: 10146832].
Fewer than 75 subjects total
392 Stucky-Ropp R C, DiLorenzo T M. Determinants of exercise in children. Prev Med. 1993;22(6):880-9. [pmid: 8115345].
No physical activity intervention
393 Suter E, Marti B. Predictors of exercise adoption and adherence of middle-aged sedentary men in a randomized controlled trial. Clin J Sports Med. 1992;2:261-7.
Fewer than 75 subjects total
394 Swinburn B A, Walter L G, Arroll B, et al. Green prescriptions: attitudes and perceptions of general practitioners towards prescribing exercise. Br J Gen Pract. 1997;47(422):567-9. [pmid: 9406491]. [pmcid: 1313106].
No physical activity or fitness outcome
395 Swinburn B A, Walter L G, Arroll B, et al. The green prescription study: a randomized controlled trial of written exercise advice provided by general practitioners. Am J Public Health. 1998;88(2):288-91. [pmid: 9491025]. [pmcid: 1508188].
Less than 3 months followup
396 Taggart A C, Taggart J, Siedentop D. Effects of a home-based activity program. A study with low fitness elementary school children. Behav Modif. 1986;10(4):487-507. [pmid: 3800856].
Fewer than 75 subjects total
397 Tell G, Vellar O. Noncommunicable disease risk factor intervention in Norwegian adolescents: The Oslo Youth Study. In: Hetzel B, Berenson G, eds, eds. Cardiovascular risk factors in childhood: Epidemiology and prevention.: Elsevier Science Publishers: Amsterdam.; 1987.
Less than 3 months followup
398 Tessaro I A, Taylor S, Belton L, et al. Adapting a natural (lay) helpers model of change for worksite health promotion for women. Health Educ Res. 2000;15(5):603-14. [pmid: 11184219].
No physical activity or fitness outcome
399 Thomas-Dobersen D A, Butler-Simon N, Fleshner M. Evaluation of a weight management intervention program in adolescents with insulin-dependent diabetes mellitus. J Am Diet Assoc. 1993;93(5):535-40. [pmid: 8315162].
Fewer than 75 subjects total
400 Thompson C, Wankel L. The effects of perceived activity choice upon frequency of exercise behavior. J Appl Soc Psychol. 1980;10:436-43.
Fewer than 75 subjects total
401 Toobert D J, Glasgow R E, Radcliffe J L. Physiologic and related behavioral outcomes from the Women's Lifestyle Heart Trial. Ann Behav Med. 2000;22(1):1-9. [pmid: 10892523].
Fewer than 75 subjects total
402 Toobert D J, Strycker L A, Glasgow R E, et al. Enhancing support for health behavior change among women at risk for heart disease: the Mediterranean Lifestyle Trial. Health Educ Res. 2002;17(5):574-85. [pmid: 12408202].
No physical activity or fitness outcome
403 Trost S G, Pate R R, Saunders R, et al. A prospective study of the determinants of physical activity in rural fifth-grade children. Prev Med. 1997;26(2):257-63. [pmid: 9085396].
No physical activity intervention
404 Tudor-Smith C, Nutbeam D, Moore L, et al. Effects of the Heartbeat Wales programme over five years on behavioural risks for cardiovascular disease: quasi-experimental comparison of results from Wales and a matched reference area. BMJ. 1998;316(7134):818-22. [pmid: 9549451]. [pmcid: 28483].
Less than 3 months followup
405 Tworoger S S, Yasui Y, Ulrich C M, et al. Mailing strategies and recruitment into an intervention trial of the exercise effect on breast cancer biomarkers. Cancer Epidemiol Biomarkers Prev. 2002;11(1):73-7. [pmid: 11815403].
No physical activity intervention
406 Uusitupa M, Louheranta A, Lindstrom J, et al. The Finnish Diabetes Prevention Study. Br J Nutr. 2000;83(Suppl 1):S137-42. [pmid: 10889804].
Less than 3 months followup
407 Uusitupa M I. Early lifestyle intervention in patients with non-insulin-dependent diabetes mellitus and impaired glucose tolerance. Ann Med. 1996;28(5):445-9. [pmid: 8949977].
No physical activity or fitness outcome
408 Vandongen R, Jenner D A, Thompson C, et al. A controlled evaluation of a fitness and nutrition intervention program on cardiovascular health in 10- to 12-year-old children. Prev Med. 1995;24(1):9-22. [pmid: 7740021].
Less than 3 months followup
409 Wadden T A, Vogt R A, Andersen R E, et al. Exercise in the treatment of obesity: effects of four interventions on body composition, resting energy expenditure, appetite, and mood. J Consult Clin Psychol. 1997;65(2):269-77. [pmid: 9086690].
Fewer than 75 subjects total
410 Wadden T A, Vogt R A, Foster G D, et al. Exercise and the maintenance of weight loss: 1-year follow-up of a controlled clinical trial. J Consult Clin Psychol. 1998;66(2):429-33. [pmid: 9583346].
Fewer than 75 subjects total
411 Wallace J, Buchner D, Grothaus L, et al. Implementation and effectiveness of a community based health promotion program for older adults. under review. [1998 - under review].
Less than 3 months followup
412 Walter H J. Primary prevention of chronic disease among children: the school-based “Know Your Body” intervention trials. Health Educ Q. 1989;16(2):201-14. [pmid: 2732063].
No physical activity or fitness outcome
413 Walter H J, Hofman A, Connelly P A, et al. Coronary heart disease prevention in childhood: one-year results of a randomized intervention study. Am J Prev Med. 1986;2(4):239-45. [pmid: 3453186].
No physical activity or fitness outcome
414 Walter H J, Hofman A, Vaughan R D, et al. Modification of risk factors for coronary heart disease. Five-year results of a school-based intervention trial. N Engl J Med. 1988;318(17):1093-100. [pmid: 3281016].
Less than 3 months followup
415 Wankel L, Thompson C. Motivating people to be physically active: self-persuasion vs. balanced decision making. J Appl Soc Psychol. 1977;7:332-40.
Less than 3 months followup
416 Wankel L M, Yardley J K, Graham J. The effects of motivational interventions upon the exercise adherence of high and low self-motivated adults. Can J Appl Sport Sci. 1985;10(3):147-56. [pmid: 4053262].
Fewer than 75 subjects total
417 Webber L S, Osganian S K, Feldman H A, et al. Cardiovascular risk factors among children after a 2 1/2-year intervention-The CATCH Study. Prev Med. 1996;25(4):432-41. [pmid: 8818067].
No physical activity or fitness outcome
418 Weber J, Wertheim H. Relationships of self-monitoring, special attention, body fat percent, and self-motivation to attendance at a community gymnasium. J Sport Exerc Psychol. 1989;11:105-14.
Fewer than 75 subjects total
419 Wier L T, Jackson A S, Pinkerton M B. Evaluation of the NASA/JSC Health Related Fitness Program. Aviat Space Environ Med. 1989;60(5):438-44. [pmid: 2730488].
Less than 3 months followup
420 Wiesemann A, Metz J, Nuessel E, et al. Four years of practice-based and exercise-supported behavioural medicine in one community of the German CINDI area. Countrywide Integrated Non-Communicable Diseases Intervention. Int J Sports Med. 1997;18(4):308-15. [pmid: 9231850].
Targeted osteoarthritis patients
421 Wiggam J, French R, Henderson H. The effects of a token economy on distance walked by senior citizens in a retirement center. Am Corr Ther J. 1986;40:6-12.
No concurrent control group
422 Wild B, Smith C, Martin J, et al. Worksite and community health promotion/risk reduction project: Virginia, 1987-1991. MMWR. 1992;41:55-7. [pmid: 1731183].
No concurrent control group
423 Wimbush E, MacGregor A, Fraser E. The effects of a national mass media campaign on walking in Scotland. Health Promot Int. [in press - 1998].
No concurrent control group
424 Wing R R, Jeffery R W, Pronk N, et al. Effects of a personal trainer and financial incentives on exercise adherence in overweight women in a behavioral weight loss program. Obes Res. 1996;4(5):457-62. [pmid: 8885210].
Fewer than 75 subjects total
425 Wing R R, Venditti E, Jakicic J M, et al. Lifestyle intervention in overweight individuals with a family history of diabetes. Diabetes Care. 1998;21(3):350-9. [pmid: 9540015].
Less than 3 months followup
426 Winkleby M A, Taylor C B, Jatulis D, et al. The long-term effects of a cardiovascular disease prevention trial: the Stanford Five-City Project. Am J Public Health. 1996;86(12):1773-9. [pmid: 9003136]. [pmcid: 1380732].
Less than 3 months followup
427 Wold B, Anderssen N. Health promotion aspects of family and peer influences on sport participation. Int J Sport Psychol. 1992;23:343-59.
Fewer than 75 subjects total
428 Wood E, Olmstead C, Craig J. An evaluation of lifestyle risk factors and absenteeism after two years in a worksite health promotion program. Am J Health Promot. 1989;4:128-33.
Less than 3 months followup
429 Woods C, Mutrie N, Scott M. Physical activity intervention: a transtheoretical model-based intervention designed to help sedentary young adults become active. Health Educ Res. 2002;17(4):451-60. [pmid: 12197590].
Less than 3 months followup
430 Woollard J, Beilin L, Lord T, et al. A controlled trial of nurse counselling on lifestyle change for hypertensives treated in general practice: preliminary results. Clin Exp Pharmacol Physiol. 1995;22(67):466-8. [pmid: 8582105].
No physical activity or fitness outcome
431 Writing Group of the PCRG. Effects of Comprehensive Lifestyle Modification on Blood Pressure Control: Main Results of the PREMIER Clinical Trial. JAMA. 2003;289(16):2083-93. [pmid: 12709466].
432 Yanek L R, Becker D M, Moy T F, et al. Project Joy: faith based cardiovascular health promotion for African American women. Public Health Rep. 2001;116(Suppl 1):68-81. [pmid: 11889276]. [pmcid: 1913665].
Less than 3 months followup
433 Yarvote P M, McDonagh T J, Goldman M E, et al. Organization and evaluation of a physical fitness program in industry. J Occup Med. 1974;16(9):589-98. [pmid: 4853489].
Less than 3 months followup
434 Young D R, Appel L J, Jee S, et al. The effects of aerobic exercise and T'ai Chi on blood pressure in older people: results of a randomized trial. J Am Geriatr Soc. 1999;47(3):277-84. [pmid: 10078888].
Fewer than 75 subjects total
435 Young D R, Haskell W L, Taylor C B, et al. Effect of community health education on physical activity knowledge, attitudes, and behavior. The Stanford Five-City Project. Am J Epidemiol. 1996;144(3):264-74. [pmid: 8686695].
Less than 3 months followup
436 Young D R, King A C, Sheehan M, et al. Stage of motivational readiness: predictive ability for exercise behavior. Am J Health Behav. 2002;26(5):331-41. [pmid: 12206443].
Less than 3 months followup
437 Zakarian J M, Hovell M F, Hofstetter C R, et al. Correlates of vigorous exercise in a predominantly low SES and minority high school population. Prev Med. 1994;23(3):314-21. [pmid: 8078852].
No physical activity intervention
438 Zoltick J, Karch R, Newton D, et al. Health promotion in a military/corporate setting. Med Sci Sports Exerc. 1990;22:S44 (abstract).
Abstract only