# References and Included Studies

(appearing in text and evidence tables)

1 Macera C A, Jones D A, Yore M M, et al. Prevalence of physical activity, including lifestyle activities among adults--United States, 2000-2001. MMWR. 2003;52(32):764-8. [pmid: 12917582].
2 Centers for Disease Control and Prevention (CDC). Prevalence of Physical activity, including lifestyle activities among adults - United States, 2000-2001. Morbidity and Mortality Weekly Report. 2003;52(32):764-9. [pmid: 12917582].
3 Grunbaum J A, Kann L, Kinchen S A, et al. Youth Risk Behavior Surveillance - United States, 2001. Morbidity and Mortality Weekly Review. 2002;51(SS-4):1-66.
4 Ries LAG, Eisner MP, Kosary CL, et al. SEER Cancer Statistics Review. National Cancer Institute, Bethesda, MD. Available at: http://seer.cancer.gov/ csr/1975_2000. Accessed December 22, 2003.
5 McTiernan A, Ulrich C, Kumai C, et al. Anthropometric and hormone effects of an eight-week exercise-diet intervention in breast cancer patients: Results of a pilot study. Cancer Epidemiology, Biomarkers & Prevention. 1998;7(6):477-81.
6 Friedenreich C M. Physical activity and cancer prevention: from observational to intervention research. Cancer Epidemiol Biomarkers Prev. 2001;10(4):287-301. [pmid: 11319168].
7 Courneya K S, Friedenreich C M. Physical exercise and quality of life following cancer diagnosis: a literature review. Annals of Behavioral Medicine. 1999;21(2):171-9. [pmid: 10499138].
8 Brown J. Nutrition and Physical Activity During and After Cancer Treatment: An American Cancer Society Guide for Informed Choices. CA Cancer J Clin. 2003;53:268-91. [pmid: 14570227].
9 Casperson C J, Powell K E, Christenson G M. Physical activity, exercise, and physical fitness: Definitions and distinctions for health-related research. Public Health Reports. 1985;100(2):126-31. [pmid: 3920711]. [pmcid: 1424733].
10 National Coalition for Cancer Survivorship. Glossary. Available at: http://www.canceradvocacy.org/ resources/glossary.aspx#C. Accessed December 22, 2003.
11 ES [computer program]. Version 1.01. St. Paul: Assessment Systems Corporation; 1996.
12 US Department of Health and Human Services. Physical activity and health: A report of the Surgeon General: National Center for Chronic Disease Prevention and Health Promotion; 1996.
13 Courneya K S, Freidenreich C M. Framework PEACE: An organizational model for examining physical exercise across the cancer experience. Annals of Behavioral Medicine. 2001;23(4):263-72. [pmid: 11761343].
14 Friedenreich C M. Physical activity and cancer prevention: from observational to intervention research. Cancer Epidemiology, Biomarkers & Prevention. 2001;10(4):287-301.
15 World Health Organization, ed. Weight control and physical activity. Lyon: IARCPress; 2002. Vainio H, Bianchini F, eds. IARC Handbooks of Cancer Prevention; No. 6.
16 Eden K B, Orleans C T, Mulrow C D, et al. Does counseling by clinicians improve physical activity? A summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137(3):208-15. [pmid: 12160371].
17 Kahn E B, Ramsey L T, Brownson R C, et al. The effectiveness of interventions to increase physical activity. A systematic review. Am J Prev Med. 2002;22(4 Suppl):73-107. [pmid: 11985936].
18 US Preventive Services Task Force. Behavioral counseling in primary care to promote physical activity: recommendation and rationale. Ann Intern Med. 2002;137(3):205-7. [pmid: 12160370].
19 Task Force on Community Preventive Services. Recommendations to increase physical activity in communities. Am J Prev Med. 2002;22(4 Suppl):67-72. [pmid: 11985935].
20 Stone E J, McKenzie T L, Welk G J, et al. Effects of physical activity interventions in youth. Review and synthesis. Am J Prev Med. 1998;15(4):298-315. [pmid: 9838974].
21 King A C, Rejeski W J, Buchner D M. Physical activity interventions targeting older adults. A critical review and recommendations. Am J Prev Med. 1998;15(4):316-33. [pmid: 9838975].
22 Taylor W C, Baranowski T, Young D R. Physical activity interventions in low-income, ethnic minority, and populations with disability. Am J Prev Med. 1998;15(4):334-43. [pmid: 9838976].
23 Dishman R K, Oldenburg B, O'Neal H, et al. Worksite physical activity interventions. Am J Prev Med. 1998;15(4):344-61. [pmid: 9838977].
24 Marcus B H, Owen N, Forsyth L H, et al. Physical activity interventions using mass media, print media, and information technology. Am J Prev Med. 1998;15(4):362-78. [pmid: 9838978].
25 Sallis J F, Bauman A, Pratt M. Environmental and policy interventions to promote physical activity. Am J Prev Med. 1998;15(4):379-97. [pmid: 9838979].
26 Dunn A L, Andersen R E, Jakicic J M. Lifestyle physical activity interventions. History, short- and long-term effects, and recommendations. Am J Prev Med. 1998;15(4):398-412. [pmid: 9838980].
27 Simons-Morton D G, Calfas K J, Oldenburg B, et al. Effects of interventions in health care settings on physical activity or cardiorespiratory fitness. Am J Prev Med. 1998;15(4):413-30. [pmid: 9838981].
28 Ashenden R, Silagy C, Weller D. A systematic review of the effectiveness of promoting lifestyle change in general practice. Fam Pract. 1997;14(2):160-76. [pmid: 9137956].
29 Baranowski T, Anderson C, Carmack C. Mediating variable framework in physical activity interventions. How are we doing? How might we do better?. Am J Prev Med. 1998;15(4):266-97. [pmid: 9838973].
30 Dishman R K, Buckworth J. Increasing physical activity: a quantitative synthesis. Med Sci Sports Exerc. 1996;28(6):706-19. [pmid: 8784759].
31 Eaton C B, Menard L M. A systematic review of physical activity promotion in primary care office settings. Br J Sports Med. 1998;32(1):11-6. [pmid: 9562157].
32 Hillsdon M, Thorogood M. A systematic review of physical activity promotion strategies. Br J Sports Med. 1996;30(2):84-9. [pmid: 8799589].
33 Ketola E, Sipila R, Makela M. Effectiveness of individual lifestyle interventions in reducing cardiovascular disease and risk factors. Ann Med. 2000;32(4):239-51. [pmid: 10852140].
34 Lawlor D A, Hanratty B. The effect of physical activity advice given in routine primary care consultations: a systematic review. J Public Health Med. 2001;23(3):219-26. [pmid: 11585195].
35 Lewis B A, Marcus B H, Pate R R, et al. Psychosocial mediators of physical activity behavior among adults and children. Am J Prev Med. 2002;23(2 Suppl):26-35. [pmid: 12133735].
36 Marshall S J, Biddle S J. The transtheoretical model of behavior change: a meta-analysis of applications to physical activity and exercise. Ann Behav Med. 2001;23(4):229-46. [pmid: 11761340].
37 Petrella R J, Lattanzio C. Does counseling help patients get active? Systematic review of the literature. Canadian Family Physician. 2002;48:72-80. [pmid: 11852615]. [pmcid: 2213933].
38 Shepard R. Fitness and exercise programs: A review of methodology and health impact. American Journal of Health Promotion. 1996;10(6):436-52. [pmid: 10163310].
39 Conn V S, Minor M A, Burks K J, et al. Integrative review of physical activity intervention research with aging adults. Journal of the American Geriatrics Society. 2003;51:1159-68. [pmid: 12890083].
40 Friedenreich C M, Courneya K S. Exercise as rehabilitation for cancer patients. Clinical Journal of Sport Medicine. 1996;6(4):237-44. [pmid: 8894336].
41 Rock C L, Demark-Wahnefried W. Can lifestyle modification increase survival in women diagnosed with breast cancer?. Journal of Nutrition. 2002;132(11 Suppl):3504S-7S. [pmid: 12421877].
42 Stone P. The measurement, causes and effective management of cancer-related fatigue. International Journal of Palliative Nursing. 2002;8(3):120-8. [pmid: 11923740].
43 Chlebowski R T, Aiello E, McTiernan A. Weight loss in breast cancer patient management. Journal of Clinical Oncology. 2002;20(4):1128-43. [pmid: 11844838].
44 Briss P A, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Prevention Services--methods. The Task Force on Community Preventive Services. American Journal of Preventive Medicine. 2000;18(1 Suppl):35-43. [pmid: 10806980].
45 Shephard R J. Worksite fitness and exercise programs: A review of methodology and health impact. American Journal of Health Promotion. 1996;10(6):436-52. [pmid: 10163310].
46 Zaza S, Wright-De Aguero L, Briss P A, et al. Task Force on Community Preventive Services. Data collection instrument and procledure for systematic reviews in the Guide to Community Preventive Services. Am J Prev Med. 2000;18(1S):44-74. [pmid: 10806979].
47 Chen S C, Chen M F. Timing of shoulder exercise after modified radical mastectomy: a prospective study. Changgeng Yi Xue Za Zhi. 1999;22(1):37-43. [pmid: 10695222].
48 Follmann D, Elliott P, Cutler J. Variance imputation for overviews of clinical trials with continuous response. J Clinical Epidemiology. 1992;45(7):769-773.
49 Luepker R V, Murray D M, Jacobs D R J, et al. Community education for cardiovascular disease prevention: risk factor changes in the Minnesota Heart Health Program. Am J Public Health. 1994;84(9):1383-93. [pmid: 8092360]. [pmcid: 1615184].
50 Eaton C B, Lapane K L, Garber C E, et al. Effects of a community-based intervention on physical activity: the Pawtucket Heart Health Program. Am J Public Health. 1999;89(11):1741-4. [pmid: 10553400]. [pmcid: 1508977].
51 Bauer R L, Heller R F, Challah S. United Kingdom Heart Disease Prevention Project: 12-year follow-up of risk factors. Am J Epidemiol. 1985;121(4):563-9. [pmid: 4014145].
52 Nader P R, Stone E J, Lytle L A, et al. Three-year maintenance of improved diet and physical activity: the CATCH cohort. Child and Adolescent Trial for Cardiovascular Health. Arch Pediatr Adolesc Med. 1999;153(7):695-704. [pmid: 10401802].
53 Luepker R V, Perry C L, McKinlay S M, et al. Outcomes of a field trial to improve children's dietary patterns and physical activity. The Child and Adolescent Trial for Cardiovascular Health. CATCH collaborative group. JAMA. 1996;275(10):768-76. [pmid: 8598593].
54 Goran M I, Poehlman E T. Endurance training does not enhance total energy expenditure in healthy elderly persons. Am J Physiol. 1992;263(5 Pt 1):E950-7. [pmid: 1476185].
55 Cohen J. Statistical Power Analysis in the Behavioral Sciences. 2nd ed. Hillsdale, NY: Lawrence Erlbaum; 1992.
56 Howard J K, Bindler R M, Synoground G, et al. A cardiovascular risk reduction program for the classroom. J Sch Nurs. 1996;12(4):4-11. [pmid: 9043262].
57 Bull F C, Jamrozik K, Blanksby B A. Tailored advice on exercise--does it make a difference?. Am J Prev Med. 1999;16(3):230-9. [pmid: 10198663].
58 Steptoe A, Doherty S, Rink E, et al. Behavioural counselling in general practice for the promotion of healthy behaviour among adults at increased risk of coronary heart disease: randomised trial. BMJ. 1999;319(7215):943–7; discussion 7–8.
59 Halbert J A, Silagy C A, Finucane P M, et al. Physical activity and cardiovascular risk factors: effect of advice from an exercise specialist in Australian general practice. Med J Aust. 2000;173(2):84-7. [pmid: 10937036].
60 Kerse N M, Flicker L, Jolley D, et al. Improving the health behaviours of elderly people: randomised controlled trial of a general practice education programme. Bmj. 1999;319(7211):683-7. [pmid: 10480825]. [pmcid: 28221].
61 Green B B, McAfee T, Hindmarsh M, et al. Effectiveness of telephone support in increasing physical activity levels in primary care patients. Am J Prev Med. 2002;22(3):177-83. [pmid: 11897462].
62 Stevens W, Hillsdon M, Thorogood M, et al. Cost-effectiveness of a primary care based physical activity intervention in 45–74 year old men and women: a randomised controlled trial. Br J Sports Med. 1998;32(3):236-41. [pmid: 9773174].
63 Gillett P, White A, Caserta M. Effect of exercise and/or fitness education on fitness in older, sedentary, obese women. J Aging Phys Activity. 1996;4:42-55.
64 Pereira M A, Kriska A M, Day R D, et al. A randomized walking trial in postmenopausal women: effects on physical activity and health 10 years later. Arch Intern Med. 1998;158(15):1695-701. [pmid: 9701104].
65 Burke V, Milligan R A, Thompson C, et al. A controlled trial of health promotion programs in 11-year-olds using physical activity “enrichment” for higher risk children. J Pediatr. 1998;132(5):840-8. [pmid: 9709707].
66 Dale D, Corbin C B. Physical activity participation of high school graduates following exposure to conceptual or traditional physical education. Res Q Exerc Sport. 2000;71(1):61-8. [pmid: 10999261].
67 O'Loughlin J, Renaud L, Paradis G, et al. Screening school personnel for cardiovascular disease risk factors: short-term impact on behavior and perceived role as promoters of heart health. Prev Med. 1996;25(6):660-7. [pmid: 8936567].
68 Gemson D H, Sloan R P. Efficacy of computerized health risk appraisal as part of a periodic health examination at the worksite. Am J Health Promot. 1995;9(6):462-6. [pmid: 10150537].
69 Lombard D N, Lombard T N, Winett R A. Walking to meet health guidelines: the effect of prompting frequency and prompt structure. Health Psychol. 1995;14(2):164-70. [pmid: 7789352].
70 Mutrie N, Carney C, Blamey A, et al. “Walk in to Work Out”: a randomised controlled trial of a self help intervention to promote active commuting. J Epidemiol Community Health. 2002;56(6):407-12. [pmid: 12011193].
71 Linenger J M, Chesson C Vn, Nice D S. Physical fitness gains following simple environmental change. Am J Prev Med. 1991;7(5):298-310. [pmid: 1790036].
72 Perkio-Makela M. Influence of exercise-focused group activities on the physical activity, functional capacity, and work ability of female farmers--a three-year follow-Up. Int J Occup Saf Ergon. 1999;5(3):381-94. [pmid: 10602655].
73 Marcus B H, Bock B C, Pinto B M, et al. Efficacy of an individualized, motivationally-tailored physical activity intervention. Ann Behav Med. 1998;20(3):174-80. [pmid: 9989324].
74 Belisle M, Roskies E, Levesque J M. Improving adherence to physical activity. Health Psychol. 1987;6(2):159-72. [pmid: 3104026].
75 Steptoe A, Rink E, Kerry S. Psychosocial predictors of changes in physical activity in overweight sedentary adults following counseling in primary care. Prev Med. 2000;31(2 Pt 1):183-94. [pmid: 10938220].
76 Blalock S J, Currey S S, DeVellis R F, et al. Effects of educational materials concerning osteoporosis on women's knowledge, beliefs, and behavior. Am J Health Promot. 2000;14(3):161-9. [pmid: 10787768].
77 Owen N, Lee C, Naccarella L, et al. Exercise by mail: A media-based behavior change program for aerobic exercise. J Sport Psychol. 1987;9:346-57.
78 Miller Y D, Trost S G, Brown W J. Mediators of physical activity behavior change among women with young children. Am J Prev Med. 2002;23(2 Suppl):98-103. [pmid: 12133744].
79 Gillett P A, Caserta M S. Changes in aerobic power, body composition, and exercise adherence in obese post-menopausal women six months after exercise training. Menopause. 1996;3(3):126-32.
80 Chalmers I, Adams M, Dickersin K, et al. A cohort study of summary reports of controlled trials. JAMA. 1990;263(10):1401-5. [pmid: 2304219].
81 Djuric Z, DiLaura N M, Jenkins I, et al. Combining weight-loss counseling with the weight watchers plan for obese breast cancer survivors. Obesity Research. 2002;10(7):657-65. [pmid: 12105288].
82 Courneya K S, Friedenreich C M, Sela R A, et al. Correlates of adherence and contamination in a randomized controlled trial of exercise in cancer survivors: an application of the theory of planned behavior and the five factor model of personality. Annals of Behavioral Medicine. 2002;24(4):257-68. [pmid: 12434937].
83 Courneya K S, Friedenreich C M, Sela R A, et al. The Group Psychotherapy and Home-Based Physical Exercise (Group-Hope) Trial in Cancer Survivors: Physical Fitness and Quality of Life Outcomes. Psycho-Oncology. 2003;12:357-74. [pmid: 12748973].
84 Segar M L, Katch V L, Roth R S, et al. The effect of aerobic exercise on self-esteem and depressive and anxiety symptoms among breast cancer survivors. Oncology Nursing Forum. 1998;25(1):107-13. [pmid: 9460778].
85 Cunningham B A, Morris G, Cheney C L, et al. Effects of resistive exercise on skeletal muscle in marrow transplant recipients receiving total parenteral nutrition. Journal of Parenteral & Enteral Nutrition. 1986;10(6):558-63. [pmid: 3098997].
86 Burnham T R, Wilcox A. Effects of exercise on physiological and psychological variables in cancer survivors. Medicine & Science in Sports & Exercise. 2002;34(12):1863-7. [pmid: 12471288].
87 Segal R, Evans W, Johnson D, et al. Structured exercise improves physical functioning in women with stages I and II breast cancer: results of a randomized controlled trial. Journal of Clinical Oncology. 2001;19(3):657-65. [pmid: 11157015].
88 MacVicar M G, Winningham M L, Nickel J L. Effects of aerobic interval training on cancer patients' functional capacity. Nursing Research. 1989;38(6):348-51. [pmid: 2587289].
89 Winningham M L, MacVicar M G. The effect of aerobic exercise on patient reports of nausea. Oncol Nurs Forum. 1988;15(4):447-50. [pmid: 3399417].
90 Courneya K S, Mackey J R, Bell G J, et al. Randomized controlled trial of exercise training in postmenopausal breast cancer survivors: cardiopulmonary and quality of life outcomes.[comment]. Journal of Clinical Oncology. 2003;21(9):1660-8. [pmid: 12721239].
91 Segal R J, Reid R D, Courneya K S, et al. Resistance exercise in men receiving androgen deprivation therapy for prostate cancer. Journal of Clinical Oncology. 2003;21(9):1653-9. [pmid: 12721238].
92 Berglund G. Starting Again--A comparison study of a group rehabilitation program for cancer patients. Acta Oncologica. 1993;32(1):15-21. [pmid: 8466758].
93 Berglund G, Bolund C, Gustafsson U L, et al. One-year follow-up of the ‘Starting Again’ group rehabilitation programme for cancer patients. European Journal of Cancer. 1994;30A(12):1744-51. [pmid: 7880598].
94 Mock V, Dow K H, Meares C J, et al. Effects of exercise on fatigue, physical functioning, and emotional distress during radiation therapy for breast cancer. Oncology Nursing Forum. 1997;24(6):991-1000. [pmid: 9243585].
95 Mock V, Pickett M, Ropka M E, et al. Fatigue and quality of life outcomes of exercise during cancer treatment. Cancer Practice. 2001;9(3):119-27. [pmid: 11879296].
96 Pickett M, Mock V, Ropka M E, et al. Adherence to moderate-intensity exercise during breast cancer therapy. Cancer Practice. 2002;10(6):284-92. [pmid: 12406050].
97 Hillsdon M, Thorogood M, White I, et al. Advising people to take more exercise is ineffective: a randomized controlled trial of physical activity promotion in primary care. Int J Epidemiol. Aug. 2002;31(4):808-15. [pmid: 12177026].
98 Mock V, Ropka M E, Rhodes V A, et al. Establishing mechanisms to conduct multi-institutional research--fatigue in patients with cancer: an exercise intervention. Oncology Nursing Forum. 1998;25(8):1391-7. [pmid: 9766292].
99 Mock V, Burke M B, Sheehan P, et al. A nursing rehabilitation program for women with breast cancer receiving adjuvant chemotherapy. Oncology Nursing Forum. 1994;21(5):899-907. [pmid: 7937251].
100 Fairey A S, Courneya K S, Field C J, et al. Effects of Exercise Training on Fasting Insulin, Insulin Resistance, Insulin-like Growth Factors, and Binding Proteins in Postmenopausal Breast Cancer Survivors: A Randomized Controlled Trial. Cancer Epidemiology, Biomarkers & Prevention. 2003;12:721-7.
101 Dimeo F, Fetscher S, Lange W, et al. Effects of aerobic exercise on the physical performance and incidence of treatment-related complications after high-dose chemotherapy. Blood. 1997;90(9):3390-4. [pmid: 9345021].
102 Dimeo F C, Tilmann M H, Bertz H, et al. Aerobic exercise in the rehabilitation of cancer patients after high dose chemotherapy and autologous peripheral stem cell transplantation. Cancer. 1997;79(9):1717-22. [pmid: 9128987].
103 Nieman D C, Cook V D, Henson D A, et al. Moderate exercise training and natural killer cell cytotoxic activity in breast cancer patients. International Journal of Sports Medicine. 1995;16(5):334-7. [pmid: 7558532].
104 Hayes SC, D. R, Davies PS, et-al. Immunological changes after cancer treatment and participation in an exercise program.Medicine & Science in Sports & Exercise. 2003;35(1):2–9.
105 Na Y M, Kim M Y, Kim Y K, et al. Exercise therapy effect on natural killer cell cytotoxic activity in stomach cancer patients after curative surgery. Archives of Physical Medicine & Rehabilitation. 2000;81(6):777-9. [pmid: 10857523].
106 Dimeo F C, Stieglitz R D, Novelli-Fischer U, et al. Effects of physical activity on the fatigue and psychologic status of cancer patients during chemotherapy. Cancer. 1999;85(10):2273-7. [pmid: 10326708].
107 McKenzie D C, Kalda A L. Effect of upper extremity exercise on secondary lymphedema in breast cancer patients: A pilot study. Journal of Clinical Oncology. 2003;21(3):463-6. [pmid: 12560436].
108 Winningham M L, MacVicar M G, Bondoc M, et al. Effect of aerobic exercise on body weight and composition in patients with breast cancer on adjuvant chemotherapy. Oncology Nursing Forum. 1989;16(5):683-9. [pmid: 2780404].
109 Cohen LA, Boylan E, Epstein M, et al. Voluntary exercise and experimental mammary cancer. In: Jacobs MM, ed. Exercise, Fat, and Cancer. New York: Plenum Press; 1992.
110 Cohen L A, Choi K, Wang C-X. Influence of dietary fat, caloric restriction, and voluntary exercise on N-Nitrosomethylurea-induced mammary tumorigenesis in rats. Cancer Research. 1988;48:4276-83. [pmid: 3390824].
111 Hoffman-Goetz L. Exercise, natural immunity, and tumor metastasis. Med Sci Sports Exerc. 1994;26:157-63. [pmid: 8164532].
112 MacVicar M G, Winningham M L. Promoting the functional capacity of cancer patients. The Cancer Bulletin. 1986;38(5):235-9.
113 Bull F C, Jamrozik K. Advice on exercise from a family physician can help sedentary patients to become active. Am J Prev Med. 1998;15(2):85-94. [pmid: 9713663].
114 Bock B C, Marcus B H, Pinto B M, et al. Maintenance of physical activity following an individualized motivationally tailored intervention. Ann Behav Med. 2001;23(2):79-87. [pmid: 11394558].
115 Caserta M S, Gillett P A. Older women's feelings about exercise and their adherence to an aerobic regimen over time. Gerontologist. 1998;38(5):602-9. [pmid: 9803648].
116 Godin G, Desharnais R, Jobin J, et al. The impact of physical fitness and health-age appraisal upon exercise intentions and behavior. J Behav Med. 1987;10(3):241-50. [pmid: 3612781].
117 Graham-Clarke P, Oldenburg B. The effectiveness of a general practice-based physical activity intervention on patient physical activity status. Behav Change. 1994;11:132-44.
118 Edmundson E, Parcel G S, Feldman H A, et al. The effects of the Child and Adolescent Trial for Cardiovascular Health upon psychosocial determinants of diet and physical activity behavior. Prev Med. 1996;25(4):442-54. [pmid: 8812826].
119 Perry C L, Sellers D E, Johnson C, et al. The Child and Adolescent Trial for Cardiovascular Health (CATCH): intervention, implementation, and feasibility for elementary schools in the United States. Health Educ Behav. 1997;24(6):716-35. [pmid: 9408786].
120 Simons-Morton B G, McKenzie T J, Stone E, et al. Physical activity in a multiethnic population of third graders in four states. Am J Public Health. 1997;87(1):45-50. [pmid: 9065225]. [pmcid: 1380763].
121 Stone E J, Osganian S K, McKinlay S M, et al. Operational design and quality control in the CATCH multicenter Trial. Prev Med. 1996;25(4):384-99. [pmid: 8818063].
122 Nader P R, Sellers D E, Johnson C C, et al. The effect of adult participation in a school-based family intervention to improve Children's diet and physical activity: the Child and Adolescent Trial for Cardiovascular Health. Prev Med. 1996;25(4):455-64. [pmid: 8818068].
123 McKenzie T L, Stone E J, Feldman H A, et al. Effects of the CATCH physical education intervention: teacher type and lesson location. Am J Prev Med. 2001;21(2):101-9. [pmid: 11457629].
124 McKenzie T L, Nader P R, Strikmiller P K, et al. School physical education: effect of the Child and Adolescent Trial for Cardiovascular Health. Prev Med. 1996;25(4):423-31. [pmid: 8818066].
125 McKenzie TL, Strikmiller PK, Stone EJ, et al. CATCH: physical activity process evaluation in a multicenter trial. Health Educ Q. 1994;Suppl 2:S73–89.
126 Hearn M. Involving Families in Cardiovascular Health Promotion: The CATCH Feasibility Study. Journal of Health Education. 1992;23(1):22-31.
127 McKenzie T L, Feldman H, Woods S E, et al. Children's activity levels and lesson context during third-grade physical education. Res Q Exerc Sport. 1995;66(3):184-93. [pmid: 7481079].
128 Nader P R, Sallis J F, Rupp J, et al. San Diego family health project: reaching families through the schools. J Sch Health. 1986;56(6):227-31. [pmid: 3638441].
129 Nader P R, Sallis J F, Patterson T L, et al. A family approach to cardiovascular risk reduction: results from the San Diego Family Health Project. Health Educ Q. 1989;16(2):229-44. [pmid: 2732065].
130 Hilton S, Doherty S, Kendrick S K, et al. Promotion of healthy behaviour among adults at increased risk of coronary heart disease in general practice: methodology and baseline data from the Change of Heart Study. Health Education Journal. 1999;58:3-16.
131 Steptoe A, Kerry S, Rink E, et al. The impact of behavioral counseling on stage of change in fat intake, physical activity, and cigarette smoking in adults at increased risk of coronary heart disease. Am J Public Health. 2001;91(2):265-9. [pmid: 11211636]. [pmcid: 1446539].
132 Halbert J A, Silagy C A, Finucane P, et al. Recruitment of older adults for a randomized, controlled trial of exercise advice in a general practice setting. J Am Geriatr Soc. 1999;47(4):477-81. [pmid: 10203125].
133 Kreuter M W, Chheda S G, Bull F C. How does physician advice influence patient behavior? Evidence for a priming effect. Arch Fam Med. 2000;9(5):426-33. [pmid: 10810947].
134 Bull F C, Kreuter M W, Scharff D P. Effects of tailored, personalized and general health messages on physical activity. Patient Educ Couns. 1999;36(2):181-92. [pmid: 10223022].
135 Harland J, White M, Drinkwater C, et al. The Newcastle exercise project: a randomised controlled trial of methods to promote physical activity in primary care. Bmj. 1999;319(7213):828-32. [pmid: 10496829]. [pmcid: 314213].
136 Eckstrom E, Hickam D H, Lessler D S, et al. Changing physician practice of physical activity counseling. J Gen Intern Med. 1999;14(6):376-8. [pmid: 10354259]. [pmcid: 1496586].
137 Rose G. A proposed trial of heart disease prevention in industry. Trans Soc Occup Med. 1970;20(3):109-11. [pmid: 5480571].
138 Rose G, Heller R F, Pedoe H T, et al. Heart disease prevention project: a randomised controlled trial in industry. Br Med J. 1980;280(6216):747-51. [pmid: 6989437]. [pmcid: 1600632].
139 Gomel M, Oldenburg B, Simpson J M, et al. Work-site cardiovascular risk reduction: a randomized trial of health risk assessment, education, counseling, and incentives. Am J Public Health. 1993;83(9):1231-8. [pmid: 8362997]. [pmcid: 1694995].
140 Gomel M K, Oldenburg B, Simpson J M, et al. Composite cardiovascular risk outcomes of a work-site intervention trial. Am J Public Health. 1997;87(4):673-6. [pmid: 9146453]. [pmcid: 1380854].
141 Carlaw R W, Mittelmark M B, Bracht N, et al. Organization for a community cardiovascular health program: experiences from the Minnesota Heart Health Program. Health Education Quarterly. 1984;11(3):243-52. [pmid: 6520005].
142 Jacobs D R Jr, Luepker R V, Mittelmark M B, et al. Community-wide prevention strategies: evaluation design of the Minnesota Heart Health Program. J Chronic Dis. 1986;39(10):775-88. [pmid: 3760106].
143 Luepker R V, Jacobs D R, Gillum R F, et al. Population risk of cardiovascular disease: the Minnesota Heart Survey. J Chronic Dis. 1985;38(8):671-82. [pmid: 4055977].
144 Mittelmark M B, Luepker R V, Jacobs D R, et al. Community-wide prevention of cardiovascular disease: education strategies of the Minnesota Heart Health Program. Prev Med. 1986;15(1):1-17. [pmid: 3714655].
145 Chen A H, Sallis J F, Castro C M, et al. A home-based behavioral intervention to promote walking in sedentary ethnic minority women: project WALK. Womens Health. 1998;4(1):19-39. [pmid: 9520605].
146 Dale D, Corbin C, Cuddihy T. Can conceptual physical education promote physically active lifestyles?. Ped Exerc Sci. 1998;10:97-109.
147 Edye BV, Mandryk JA, Frommer MS, et al. Evaluation of a worksite programme for the modification of cardiovascular risk factors. Med J Aust. 1989;150(10):574, 6–8, 81.
148 Elder J P, Williams S J, Drew J A, et al. Longitudinal effects of preventive services on health behaviors among an elderly cohort. Am J Prev Med. 1995;11(6):354-9. [pmid: 8775655].
149 Elder JP, McGraw SA, Stone EJ, et al. CATCH: process evaluation of environmental factors and programs. Health Educ Q. 1994;Suppl 2:S107–27.
150 Keyserling T C, Samuel-Hodge C D, Ammerman A S, et al. A randomized trial of an intervention to improve self-care behaviors of African-American women with type 2 diabetes: impact on physical activity. Diabetes Care. 2002;25(9):1576-83. [pmid: 12196430].
151 Knutsen S F, Knutsen R. The Tromso Heart Study: family approach to intervention on CHD. Feasibility of risk factor reduction in high-risk persons--project description. Scand J Soc Med. 1989;17(1):109-19. [pmid: 2711141].
152 Knutsen S F, Knutsen R. Wives of coronary high-risk men--are they also at higher risk? The Tromso Heart Study. J Intern Med. 1990;228(4):333-7. [pmid: 2266341].
153 Knutsen S F, Knutsen R. The Tromso Survey: the Family Intervention study--the effect of intervention on some coronary risk factors and dietary habits, a 6-year follow-up. Prev Med. 1991;20(2):197-212. [pmid: 2057468].
154 Thelle D, Forde O, Try K, et al. The Tromso Heart Study: Methods and Main Results of the Cross-sectional study. Acta Med Scand. 1976;200:107-18. [pmid: 785953].
155 Kreuter M W, Strecher V J. Do tailored behavior change messages enhance the effectiveness of health risk appraisal? Results from a randomized trial. Health Educ Res. 1996;11(1):97-105. [pmid: 10160231].
156 Lovibond S H, Birrell P C, Langeluddecke P. Changing coronary heart disease risk-factor status: the effects of three behavioral programs. J Behav Med. 1986;9(5):415-37. [pmid: 3540308].
157 MacKeen P, Rosenberg J, Slater J, et al. A 13-year follow-up of a coronary heart disease risk factor screening and exercise program for 40-to-59-year-old men: exercise habit maintenance and physiologic status. J Cardiopul Rehabil. 1985;5:510-23.
158 Remington R D, Taylor H L, Buskirk E R. A method for assessing volunteer bias and its application to a cardiovascular disease prevention progamme involving physical activity. J Epidemiol Community Health. 1978;32(4):250-5. [pmid: 744815].
159 Taylor H L, Buskirk E R, Remington R D. Exercise in controlled trials of the prevention of coronary heart disease. Fed Proc. 1973;32(5):1623-7. [pmid: 4705210].
160 Ostwald S K. Changing employees' dietary and exercise practices: an experimental study in a small company. J Occup Med. 1989;31(2):90-7. [pmid: 2709166].
161 Owen N, Lee C, Sedgwick A. Exercise maintenance: developing self-management guidelines for community fitness courses. Aust J Sci Med Sport. 1987;1:8-12.
162 Kriska A M, Bayles C, Cauley J A, et al. A randomized exercise trial in older women: increased activity over two years and the factors associated with compliance. Med Sci Sports Exerc. 1986;18(5):557-62. [pmid: 3534509].
163 Sherman J B, Clark L, McEwen M M. Evaluation of a worksite wellness program: impact on exercise, weight, smoking, and stress. Public Health Nurs. 1989;6(3):114-9. [pmid: 2813254].
164 Smith B J, Bauman A E, Bull F C, et al. Promoting physical activity in general practice: a controlled trial of written advice and information materials. Br J Sports Med. 2000;34(4):262-7. [pmid: 10953898].
165 Carleton R A, Lasater T M, Assaf A, et al. The Pawtucket Heart Health Program: I. An experiment in population-based disease prevention. R I Med J. 1987;70(12):533-8. [pmid: 3480550].
166 Carleton R A, Lasater T M, Assaf A R, et al. The Pawtucket Heart Health Program: community changes in cardiovascular risk factors and projected disease risk. Am J Public Health. 1995;85(6):777-85. [pmid: 7762709]. [pmcid: 1615494].
167 Marcus B H, Banspach S W, Lefebvre R C, et al. Using the stages of change model to increase the adoption of physical activity among community participants. Am J Health Promot. 1992;6(6):424-9. [pmid: 10146803].
168 Levin S, Gans K M, Carleton R A. The Evolution of a Physical Activity Campaign. Fam Community Health. 1998;21(1):65-77.
169 McGraw S A, McKinlay S M, McClements L. Methods in Program Evaluation: The Process Evaluation System of the Pawtucket Heart Health Program. Evaluation Review. 1989;13:459-83.
170 Godin G, Jobin J, Bouillon J. Assessment of leisure time exercise behavior by self-report: A concurrent validity study. Can J Public Health. 1986;77:359-61. [pmid: 3791117].
171 Godin G, Shepard R J. A simple method to assess exercise behavior in the community. Can J Appl Sport Sci. 1985;10:141-6. [pmid: 4053261].
172 American College of Sports Medicine. Guidelines for Exercise Testing and Prescription. 6th ed. Philadelphia, PA: Lea & Febiger; 2000.
173 Bhambhani Y, Singh M. The effects of three training intensities on VO2 max and VE/VO2 ratio. Respiration. 1985;47:120-8. [pmid: 4001567].
174 McGavin C R, Gupta S P, McHardy G J R. Twelve-minute walking test for assessing disability in chronic bronchitis. BMJ. 1976;46(1):822-3.
175 Jette M, Sidney K, Landry F, et al. Blood pressure response to a progressive step test in normotensive males and females. Can J Appl Physiol. 1994;19:421-31. [pmid: 7849658].
176 Invergo J J, Ball T E, Looney M. Relationship of push-ups and absolute muscular endurance to bench press strengt. J Appl Sport Sci Res. 1991;5:121-5.
177 Baumgartner TA, Jackson AS. Measurement for Evaluation in Physical Education and Exercise Science. Dubuque, IA: W.C. Brown; 1995.
178 Sutherland H J, Walker P, Till J E. The development of a method for determining oncology patient's emotional distress using linear analogue scales. Cancer Nursing. 1988;11:303-8. [pmid: 3233581].
179 Yellen B S, Cella D F, Webster J, et al. Measuring fatigue and other anemia-related symptoms with the Functional Assessment of Cancer Therapy (FACT) measurement system. J Pain Symptom Manage. 1997;13:63-74. [pmid: 9095563].
180 Shacham S. A shortened version of the Profile of Mood Status States. J Pers Assess. 1983;47:305-6. [pmid: 6886962].
181 CIPS. International Skalen fur Psychiatrie. 2nd ed. Beltz: Weinheim; 1981.
182 McNair PM, Lorr M, Droppleman LF. Profile of Mood States Manual. San Diego, CA: Educational and Industrial Testing Service; 1971.
183 Piper B F, Dibble E, Gilliss N, et al. Revised Piper Fatigue Scale: psychometric evaluation in women with breast cancer. Oncol Nurs Forum. 1998;25:677-84. [pmid: 9599351].
184 Mock VL. Body image in women treated for breast cancer: Doctoral Dissertation, Catholic University of America, 1988. Dissertation Abstracts International. 48(12) B edition. (University Microfilms No.88-03894); 1988.
185 Mock V L. Body image in women treated for breast cancer. Nursing Research. 1993;42:153-7. [pmid: 8506164].
186 Roid GH, Fitts WH. Tennessee Self-Concept Scale: Revised Manual. Los Angeles: Western Psychological Services; 1988.
187 Padilla G V, Presant M M, Grant G, et al. Quality of Life Index for patients with cancer. Rew Nurs Health. 1983;6:117-26.
188 Cella D F, Tulsky D S, Gray G, et al. The functional assessment of cancer therapy scale: Development and validation of the general measure. J Clin Oncol. 1993;11:570-9. [pmid: 8445433].
189 Brady M J, Cella D F, Mo F, et al. Reliability and validity of the Functional Assessment of Cancer Therapy-Breast Quality of Life instrument. J Clin Oncol. 1997;15:974-86. [pmid: 9060536].
190 Ware JE, Snow KK, Kosinski MK, et al. SF-36 Health Survey Manual and Interpretation Guide. Boston, MA: Nimrod Press; 1993.
191 Ware J E, Donald-Sherbourne C. The MOS 36-item short form health survey (SF-36): Conceptual framework and item selection. Med Care. 1992;30:473-83. [pmid: 1593914].
192 Mor V, Laliberte L, Morris J N, et al. The Karnofsky Performance Status Scale-An examination of its reliability and validity in a research setting. Cancer. 1984;53:2002-7. [pmid: 6704925].
193 Cella DF. Manual of the Functional Assessment of Chronic Illness Therapy (FACIT) Scales. Chicago, IL: Center on Outcomes Research and Education, Northwestern University; 1997.
194 Rosenberg M. Society and Adolescent Self-Image. Princeton, NJ: Princeton University Press; 1995.
195 Curbow B, Somerfield M. Use of the Rosenberg Esteem Scale with cancer patients. J Psychosoc Oncol. 1991;9:113-31.
196 Fordyce M W. A review of research on the happiness measures: A sixty second index of happiness and mental health. Soc Indic Res. 1988;20:355-81.
197 Diener E, Emmons R A, Larsen R J, et al. The satisfaction with life scale. J Personality Assess. 1985;49:71-5.
198 Herth K. Abbreviated instrument to measure hope: Development and psychometric evaluation. J of Advanc Nurs. 1992;17:1251-9.
199 Barrett EAM. Development of an instrument to measure power as knowing participation in change. 1987, Unpublished manuscript.
200 Durin J V G A, Womersley J. Body fat assessed from total body density and its estimation from skinfold thickness: Measurements on 481 men and women aged from 16 to 72 years. Br J Nutr. 1974;32:77-97. [pmid: 4843734].
201 Grant A. Nutritional Assessment Guidelines. 2nd ed. Seattle, WA; 1979.
202 Barale K, Cheney C, Lenssen P, et al. Anthropometric measurement in a protective environment. J Am Diet Assoc. 1981;78:359-61. [pmid: 6796619].
203 Frisancho A R. New norms of upper limb fat and muscle areas for assessment of nutritional status. Am J Clin Nutr. 1981;34(11):2540-5. [pmid: 6975564].
204 Farncombe M, Daniels G, Cross L. Lymphedema: the seemingly forgotten complication. J Pain Symptom Manage. 1994;9:269-76. [pmid: 8089544].
205 Derogatis LR. SCL-90-R manual I. Administration, scoring and procedures manual for the revised version. Baltimore, MD: Clinical Psychometrics Research Unit, Johns Hopkins University School of Medicine; 1977.
206 Zigmond A S, Snaith R P. The hospital anxiety and depression scale. Acta Psychiat Scand. 1983;67:361-70. [pmid: 6880820].
207 Radloff L S. The use of the center or epidemiologic studies depression scale in adolescents and young adults. J Youth Adolesc. 1977;20:149-66.
208 Spielberger CD, Gorusch RL, Lushene RF. Manual for the State-Trait Anxiety Inventory. Palo Alto, CA: Consulting Psychologists Press; 1970.
209 Greer S, Watson M. Mental adjustment to cancer: its measurement and prognostic importance. Cancer Surv. 1987;6:439-53. [pmid: 3326657].
210 Derogatis L R. The psychosocial adjustment to illness scale (PAIS). Journal of psychosomatic research. 1986;30(1):77-91. [pmid: 3701670].
211 Derogatis LR, Spencer PM. The Brief Symptom Inventory (BSI): Administration, scoring, and procedures manual. Baltimore, Clinical Psychometric Research, 1993.
212 Beck AT. Depression: Causes and treatment. Philadelphia: University of Pennsylvania Press; 1972.
213 Wall L M. Changes in hope and power in lung cancer patients who exercise. Nursing Science Quarterly. 2000;13(3):234-42. [pmid: 11847803].
214 Sharkey A M, Carey A B, Heise C T, et al. Cardiac rehabilitation after cancer therapy in children and young adults. American Journal of Cardiology. 1993;71(16):1488-90. [pmid: 8517409].
215 Schwartz A L. Fatigue mediates the effects of exercise on quality of life. Quality of Life Research. 1999;8(6):529-38. [pmid: 10548868].
216 Schwartz A L. Exercise and weight gain in breast cancer patients receiving chemotherapy. Cancer Practice. 2000;8(5):231-7. [pmid: 11898235].
217 Schwartz A L. Daily Fatigue Patterns and Effect of Exercise in Women with Breast Cancer. Cancer Practice. 2000;8(1):16-24. [pmid: 11898235].
218 Schwartz A L, Mori M, Gao R, et al. Exercise reduces daily fatigue in women with breast cancer receiving chemotherapy. Medicine & Science in Sports & Exercise. 2001;33(5):718-23. [pmid: 11323538].
219 Decker W A, Turner-McGlade J, Fehir K M. Psychosocial aspects and the physiological effects of a cardiopulmonary exercise program in patients undergoing bone marrow transplantation (BMT) for acute leukemia (AL). Transplantation Proceedings. 1989;21(1 Pt 3):3068-9. [pmid: 2650427].
220 Dimeo F, Bertz H, Finke J, et al. An aerobic exercise program for patients with haematological malignancies after bone marrow transplantation. Bone Marrow Transplantation. 1996;18(6):1157-60. [pmid: 8971388].
221 Young-McCaughan S, Mays MZ, Arzola SM, et al. Research and commentary: Change in exercise tolerance, activity and sleep patterns, and quality of life in patients with cancer participating in a structured exercise program. Oncology Nursing Forum. Online. 2003;30(3):441–54.
222 Durak E P, Lilly P C. The application of an exercise and wellness program for cancer patients: A preliminary outcomes report. Journal of Strength and Conditioning Research. 1998;12(1):3-6.
223 Kolden G G, Strauman T J, Ward A, et al. A pilot study of group exercise training (GET) for women with primary breast cancer: feasibility and health benefits. Psycho-Oncology. 2002;11(5):447-56. [pmid: 12228878].
224 Dimeo F, Rumberger B G, Keul J. Aerobic exercise as therapy for cancer fatigue. Medicine & Science in Sports & Exercise. 1998;30(4):475-8. [pmid: 9565925].
225 Porock D, Kristjanson L J, Tinnelly K, et al. An exercise intervention for advanced cancer patients experiencing fatigue: a pilot study. Journal of Palliative Care. 2000;16(3):30-6. [pmid: 11019505].
226 Peters C, Lotzerich H, Niemeier B, et al. Influence of a moderate exercise training on natural killer cytotoxicity and personality traits in cancer patients. Anticancer Research. 1994;14:1033-6. [pmid: 8074446].
227 Ahmed RL, Schmitz K, Yee D. Effects of resistance training on lymphedema symptoms in recent breast cancer survivors. Paper presented at: Proceedings of the American Association for Cancer Research, 2003.
228 Harris S R, Niesen-Vertommen S L. Challenging the myth of exercise-induced lymphedema following breast cancer: A series of case reports. J Surg Oncol. 2000;74:95-9. [pmid: 10914817].
229 Petrek J A, Senie R T, Peters M, et al. Lymphedema in a cohort of breast carcinoma survivors 20 years after diagnosis. Cancer. 2001;92:1368-77. [pmid: 11745212].
230 Cox C E, Bass S S, McCann C R, et al. Lymphatic mapping and sentinel lymph node biopsy in patients with breast cancer. Ann Rev Med. 2000;51:525-42. [pmid: 10774480].
231 Jemal A, Murray T, Samuels A, et al. Cancer statistics 2003. CA Cancer J Clin. 2002;53:5-26. [pmid: 12469762].
232 Keyserling T C, Ammerman A S, Samual-Hodge C D, Ingram A F, Skelly A H, Elasy T A, Johnston L F, Cole A S, Henrequez-Roldan C F. A diabetes management program for African American women with type 2 diabetes. The Diabetes Educator. 2000;26(5):796-805. [pmid: 11140007].
233 Mayer J A, Jermanovich A, Wright B L, et al. Changes in health behaviors of older adults: the San Diego Medicare Preventive Health Project. Prev Med. Mar. 1994;23(2):127-33. [pmid: 8047517].