# Acknowledgments

We would like to acknowledge the assistance of Robert Jeffery, PhD, and Arthur Leon, PhD, for their input into the study questions. Tenbit Emiru, PhD, Yueh-Ysen Lin, and Kim Larrabee, MS, assisted with abstracting the articles. We also appreciate the input from Dr. Adrian Bauman, Christine Spain, Dr. Anna Schwartz, Colonel Stacey Young-McCaughan, Ted Wegleitner, Dr. Nico Pronk, and Dr. Edward Howley, who reviewed the draft. Marilyn Eells was responsible for editing and formatting this report.