# Appendix F Cancer Outcomes Tables

Table F-1 Physical activity behavior

First Author/Year | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
Study Design | | Timing | (n) Per Group | | PA Mode
Intervention Setting | | PEACE Framework Category | | | PA Frequency/ Duration
Courneya et al., 2002^82^ | All cancers possible | Behavioral | Group | Group psychotherapy | 65–75% estimated maximum heart rate | 10 weeks | Exercise (minutes)
Courneya et al., 2003^83^ | Breast | Post treatment | (11) Comp 1 | | Aerobic activity | | % performing ≥60 minutes of exercise/ week | p < .001
RCT | | Coping & Rehabilitation | (11) Intervention 1 | | 20–30 minutes 3–5 days/week | | % performing ≥150 minutes of exercise/ week | p < .001
Home
Mock, et al. 1997^94^ | Breast | Behavioral | Individual | Not applicable | Self-paced | 6 weeks or 4–6 chemotherapy cycles | Exercise level [0–10 Exercise Rating Scale] | p< .001
Mock et al. 1998^98^ | | During treatment | (24) Comp 1 | | Walking
Non-RCT | | Coping | (22) Intervention 1 | | 20–30 minutes 4–5 days/week
Home
Mock et al. 1994^99^ | Breast | Behavioral | Individual | Support group | Self-paced | 4–6 months | Exercise level [scale of 0–4 according to no minimum per day and no days per week walked] | ES 2.93
RCT | | During treatment | (5) Comp 1 | | Walking
Home | | Coping | (9) Intervention 1 | | Aerobic activity
| | | | | 10–45 minutes 4–5 days/week
Mock et al. 2001^95^ | Breast | Behavioral | Individual | Not applicable | 50–80% maximum heart rate | 6 weeks to 6 months | Exercise participation [PA self-report diary] | Not reported
Pickett et al. 2002^96^ | | During treatment | (25) Comp 1 | | Walking
RCT | | Coping | (23) Intervention 1 | | 15–30 minutes 5–6 days/week
Home
Segal et al., 2001^87^ | Breast | Behavioral & pre-planned exercise | Individual | Not applicable | 50–60% predicted maximum VO2 | 26 weeks | Exercise adherence (minutes) [self report PA logs] | Not reported
RCT | | During treatment | (41) Comp 1 | | Walking
Primary care | | Coping | (40) Intervention 1: self-directed exercise | | Duration not reported
Home | | | (42) Intervention 2: supervised preplanned exercise | | 5 days/week

Table F-2 Physical fitness: cardiovascular, strength and flexibility

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/Duration
Burnham & Wilcox, 2002^86^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Aerobic capacity ml/kg/min [treadmill] | ES 0.668
| Exercise facility | Colon | Post treatment | (6) Comp 1 | | 25–40% heart rate reserve | | Flexibility [sit and reach/ lower body] | ES 0.666
| | | Rehabilitation and health promotion | (6) Intervention 1 | | Aerobic activity
| | | | (6) Intervention 2 | | 14–32 minutes 3 days/week
| | | | | | Intervention 2:
| | | | | | 40–60% heart rate reserve
| | | | | | Aerobic activity
| | | | | | 14–32 minutes 3 days/week
Courneya et al., 2003^90^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 70–75% maximum VO2 | 15 weeks | Heart rate (peak) | p<.02
Fairey et al., 2003^100^ | Exercise facility | | Post treatment | (28) Comp 1 | | Aerobic activity | | Peak power output, Watts [cycle ergometer] | ES 0.950
| | | Rehabilitation and health promotion | (25) Intervention 1 | | 15–35 minutes 3 days/week | | Peak VO2 ml/kg/min [cycle ergometer] | ES 0.599
| | | | | | | | Power output at the ventilatory equivalent for CO2 [metabolic measurement cart] | ES 0.860
Courneya, et al., 2002^82^ | RCT | All cancers possible | Behavioral | Group | Group psychotherapy | 65–75% estimated maximum heart rate | 10 weeks | Cardiovascular endurance [modified Balke Treadmill Test] | ES 0.00
Courneya et al., 2003^83^ | Home | Breast | Post treatment | (11) Comp 1 | | Aerobic activity | | Flexibility [sit and reach test] | ES 0.024
| | | Coping and rehabilitation | (11) Intervention 1 | | 20–30 minutes 3–5 days/week
Dimeo et al., 1997^101^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 50% heart rate reserve | Not clear/day of hospital discharge | Maximum performance (km/hour) | ES 0.319
| Primary care | Germ cell | During treatment | (37) Comp 1 | | Aerobic activity
| | Sarcoma | Coping | (33) Intervention 1 | | 15 minutes 7 days/week
| | Lung
| | Adenoscarci-noma
| | Neuroblastoma
Dimeo et al., 1997^102^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | 80% maximum heart rate | 6 weeks | Physical maximum performance (km/hour) [treadmill test] | ES 0.535
| Primary care | Non-small cell lung carcinoma | Post treatment | (16) Comp 1 | | Walking
| | Sarcoma | Rehabilitation | (16) Intervention 1 | | 15–30 minutes 5 days/week
| | Semioma
| | Non-Hodgkin's lymphoma
MacVicar et al., 1989^88^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Heart rate | p<.04
| Exercise facility | | During treatment | (16) Comp 1 | | Low intensity | | Maximum test time | p<.01
| | | Coping | (11) Intervention 1 | | Non-aerobic | | VO2 maximum L/min (cycle ergometer) | p<.01
| | | | (18) Intervention 2 | | Stretching and flexibility | | Workload maximum (cycle ergometer) | p<.01
| | | | | | Duration not reported 3 days/week
| | | | | | Intervention 2:
| | | | | | 60–80% heart rate reserve
| | | | | | Aerobic interval training
| | | | | | 3 days/week
MacVicar et al., 1986^112^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | 60–85% maximum heart rate on pre-test aerobic assessment | 10 weeks | VO2 maximum L/min (cycle ergometer) | Mean change reported
| Unknown | | During treatment | (4) Comp 1 | | Aerobic activity | | | Functional capacity increased in intervention group
| | | Coping | (6) Intervention 1 | | 3 days/week
| | | | (6) Intervention 2
Mock, et al., 1997^94^ | Non-RCT | Breast | Behavioral | Individual | Not applicable | Self-paced | 6 weeks or 4–6 chemo-therapy cycles | Physical fitness [12 minute walk test] | p<.003
Mock et al., 1998^98^ | Home | | During treatment | (24) Comp 1 | | Walking
| | | Coping | (22) Intervention 1 | | 20–30 minutes 4–5 days/week
Mock et al., 1994^99^ | RCT | Breast | Behavioral | Individual | Support group | Self-paced | 4–6 months | Physical fitness [12 minute walk test] | ES 1.242
| Home | | During treatment | (5) Comp 1 | | Walking
| | | Coping | (9) Intervention 1 | | 10–45 minutes 4–5 days/week
Mock et al., 2001^95^ | RCT | Breast | Behavioral | Individual | Not applicable | 50–80% maximum heart rate | 6 weeks to 6 months | Exercise fitness [12-minute walk test] | p<.01
Pickett et al., 2002^97^ | Home | | During treatment | (25) Comp 1 | | Walking
| | | Coping | (23) Intervention 1 | | 15–30 minutes 5–6 days/ week
Nieman et al., 1995^103^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 75% maximum heart rate | 8 weeks | Heart rate | Not significant
| Unknown | | Post treatment | (8) Comp 1 | | Walking | | Leg extension strength | Not significant
| | | Survival | (8) Intervention 1 | | Strength/ resistance activity | | Physical fitness [6 minute walk distance] | p = 0.02
| | | | | | 60 minutes 3 days/week
Segal et al., 2001^87^ | RCT | Breast | Behavioral and pre-planned exercise | Individual | Not applicable | 50–60% maximum VO2 | 26 weeks | Aerobic capacity [modified Canadian Aerobic Fitness Test (mCAFT)] | Not significant
| Primary care | | During treatment | (41) Comp 1 | | Walking
| Home | | Coping | (40) Intervention 1: self-directed exercise | | Duration not reported
| | | | (42) Intervention 2: supervised preplanned exercise | | 5 days/week
Segal et al., 2003^91^ | RCT | Prostate | Pre-planned exercise | Individual | Not applicable | 60–70% one repetition maximum | 12 weeks | Muscular fitness [standard load test] | p<.009
| Exercise facility | | During treatment | (73) Comp 1 | | Strength/ resistance: 9 exercises, 2 sets each, 8–12 repetitions
| | | Coping | (82) Intervention 1 | | Duration not reported 3 days/week

Table F-3 Fatigue/tiredness

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | P A Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/ Duration
Berglund et al., 1993^92^ | Non-RCT | Breast | Pre-planned exercise | Individual | Relaxation training | Intensity not reported | 4 weeks | Tiredness [no validity/ reliability measure scale] | p<.0005
| Exercise facility | Ovarian | Post treatment | (30) Comp 1 | Information | Aerobic activity | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 months
| | Testicular | Rehabilitation | (30) Intervention 1 | Coping strategies | Strength/ resistance
| | | | | | Stretching
| | | | | | 60 minutes 1day/week
Berglund et al., 1994^93^ | RCT | Breast | Pre-planned exercise | Individual | Relaxation | Intensity not reported | 4 weeks | Tiredness [no validity/ reliability measure scale] | Not significant
| Unknown | Ovarian | Post treatment | (101) Comp 1 | Diet | Aerobic activity | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 months
| | Undefined | Rehabilitation | (98) Intervention 1 | Life coping skills | Strength training
| | | | | | Stretching
| | | | | | 60 minutes 1 day/week
Burnham & Wilcox, 2002^86^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Fatigue [Linear Analog Self-Assessment measure] | ES 0.645
| Exercise facility | Colon | Post treatment | (6) Comp 1 | | 25–40% heart rate reserve
| | | Rehabilitation and health promotion | (6) Intervention 1 | | Aerobic activity
| | | | (6) Intervention 2 | | 14–32 minutes 3 days/week
| | | | | | Intervention 2:
| | | | | | 40–60% heart rate reserve
| | | | | | Aerobic activity
| | | | | | 14–32 minutes 3 days/week
Courneya et al., 2003^90^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 70–75% maximum VO2 | 15 weeks | Fatigue [Fatigue Scale of FACT] | ES 0.063
Fairey et al., 2003^100^ | Exercise facility | | Post treatment | (28) Comp 1 | | Aerobic activity
| | | Rehabilitation and health promotion | (25) Intervention 1 | | 15–35 minutes 3 days/week
Courneya, et al., 2002^82^ | RCT | All cancers possible | Behavioral | Group | Group psychotherapy | 65–75% maximum heart rate | 10 weeks | Fatigue [Fatigue Scale of FACT] | ES 0.031
Courneya et al., 2003^83^ | Home | Breast | Post treatment | (11) Comp 1 | | Aerobic activity
| | | Coping and rehabilitation | (11) Intervention 1 | | 20–30 minutes 3–5 days/week
Dimeo et al., 1999^106^ | RCT | Solid tumors or breast carcinoma | Pre-planned exercise | Individual | Not applicable | 50% heart rate reserve | Not reported/ hospital discharge | Fatigue [Profile of Mood Status measure (POMS)] | Increase in control group p=.02, no change in treatment group
| Primary care | Metastatic breast carcinoma | During treatment | (33) Comp 1 | | Aerobic activity
| | Seminoma | Coping | (29) Intervention 1 | | 15 minutes 7 days/week
| | Sarcoma/ adenocarci-noma
| | Hodgkin's disease
| | Non-Hodgkin's lymphoma
| | Small cell lung carcinoma
Dimeo et al., 1997^102^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | 80% maximum heart rate | 6 weeks | Fatigue [personal interview] | Qualitative report of improve-ment
| Primary care | Non-small cell lung carcinoma | Post treatment | (16) Comp 1 | | Walking
| | Sarcoma | Rehabilitation | (16) Intervention 1 | | 15–30 minutes 5 days/week
| | Semioma
| | Non-Hodgkin's lymphoma
MacVicar et al., 1986^112^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | 60–85% maximum heart rate on pre-test aerobic assessment | 10 weeks | Fatigue [Profile of Mood States (POMS)] | Mean changes reported. Fatigue factors decreased in treatment and control groups.
| Unknown | | During treatment | (4) Comp 1 | | Aerobic activity
| | | Coping | (6) Intervention 1 | | 3 days/week
| | | | (6) Intervention 2
Mock, et al., 1997^94^ | Non-RCT | Breast | Behavioral | Individual | Not applicable | Self-paced | 6 weeks or 4–6 chemo-therapy cycles | Fatigue [Piper Fatigue Scale] | p<.018
Mock et al., 1998^98^ | Home | | During treatment | (24) Comp 1 | | Walking | | Fatigue [Symptom Assessment Scales (SAS)] | Correlated r=.92
| | | Coping | (22) Intervention 1 | | 20–30 minutes 4–5 days/week
Mock et al., 1994^99^ | RCT | Breast | Behavioral | Individual | Support group | Self-paced | 4–6 months | Fatigue [Symptom Assessment Scale] | Mid-treatment p<.02
| Home | | During treatment | (5) Comp 1 | | Walking
| | | Coping | (9) Intervention 1 | | 10–45 minutes 4–5 days/week
Mock et al. 2001^95^ | RCT | Breast | Behavioral | Individual | Not applicable | 50–80% maximum heart rate | 6 weeks to 6 months | Fatigue [modified Piper Fatigue Scale (PFS)] | p<.001
Pickett et al. 2002^96^ | Home | | During treatment | (25) Comp 1 | | Walking
| | | Coping | (23) Intervention 1 | | 15–30 minutes 5–6 days/week
Segal et al., 2003^91^ | RCT | Prostate | Pre-planned exercise | Individual | Not applicable | 60–70% one repetition maximum | 12 weeks | Fatigue [Functional Assessment of Cancer Therapy-Fatigue (FACT-F)] | ES 0.130
| Exercise facility | | During treatment | (73) Comp 1 | | Strength/ resistance: 9 exercises, 2 sets each, 8–12 repetitions
| | | Coping | (82) Intervention 1 | | Duration not reported 3 days/week

Table F-4 Body image / dissatisfaction

First Author/Year | Study Design | Canver Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/ Duration
Berglund et al., 1993^92^ | Non-RCT | Breast | Pre-planned exercise | Individual | Relaxation training | Intensity not reported | 4 weeks | Body image problems [no validity/ reliability measure scale] | Not significant
| Exercise facility | Ovarian | Post treatment | (30) Comp 1 | Information | Aerobic activity | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 months
| | Testicular | Rehabilitation | (30) Intervention 1 | Coping strategies | Strength/ resistance
| | | | | | Stretching
| | | | | | 60 minutes 1day/week
Berglund et al., 1994^93^ | RCT | Breast | Pre-planned exercise | Individual | Relaxation | Intensity not reported | 4 weeks | Body image problems [no validity/ reliability measure scale] | Not significant
| Unknown | Ovarian | Post treatment | (101) Comp 1 | Diet | Aerobic activity | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 months
| | Undefined | Rehabilitation | (98) Intervention 1 | Life coping skills | Strength training
| | | | | | Stretching
| | | | | | 60 minutes 1 day/week
Mock, et al., 1997^94^ | Non-RCT | Breast | Behavioral | Individual | Not applicable | Self-paced | 6 weeks or 4–6 chemo-therapy cycles | Body dissatisfaction [Symptom Assessment Scales (SAS)] | p<.033
| Home | | During treatment | (24) Comp 1 | | Walking
Mock et al., 1998^98^ | | | Coping | (22) Intervention 1 | | 20–30 minutes 4–5 days/week
Mock et al., 1994^99^ | RCT | Breast | Behavioral | Individual | Support group | Self-paced | 4–6 months | Body image [Body Image Visual Analogue Scale] | ES 0.301
| Home | | During treatment | (5) Comp 1 | | Walking | | Body image [physical self subscale of the Tennessee Self-Concept Scale] | ES 0.318
| | | Coping | (9) Intervention 1 | | 10–45 minutes 4–5 days/week

Table F-5 Quality of life

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/ Duration
Berglund et al., 1993^92^ | Non-RCT | Breast | Pre-planned exercise | Individual | Relaxation training | Intensity not reported | 4 weeks | Physical strength problems [self report] | p<.0001
| Exercise facility | Ovarian | Post treatment | (30) Comp 1 | Information | Aerobic activity | | Global health [no validity/ reliability measure scale] | p<.01
| | Testicular | Rehabilitation | (30) Intervention 1 | Coping strategies | Strength/ resistance | | QOL [scale no validity/ reliability measure] | Not significant
| | | | | | Stretching | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 months
| | | | | | 60 minutes 1day/week
Berglund et al., 1994^93^ | RCT | Breast | Pre-planned exercise | Individual | Relaxation | Intensity not reported | 4 weeks | Physical strength problems [self report] | Not significant
| Unknown | Ovarian | Post treatment | (101) Comp 1 | Diet | Aerobic activity | | QOL [scale no validity/ reliability measure] | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 months
| | Undefined | Rehabilitation | (98) Intervention 1 | Life coping skills | Strength training
| | | | | | Stretching
| | | | | | 60 minutes 1 day/week
Burnham & Wilcox, 2002^86^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | QOL [QOL Index for Cancer Patients] | ES 1.689
| Exercise facility | Colon | Post treatment | (6) Comp 1 | | 25–40% heart rate reserve
| | | Rehabilitation and health promotion | (6) Intervention 1 | | Aerobic activity
| | | | (6) Intervention 2 | | 14–32 minutes 3 days/week
| | | | | | Intervention 2:
| | | | | | 40–60% heart rate reserve
| | | | | | Aerobic activity
| | | | | | 14–32 minutes 3 days/week
Courneya et al., 2003^90^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 70–75% maximum VO2 | 15 weeks | General health [Functional Assessment of Cancer Therapy-General (FACT-G scale)] | ES 0.183
Fairey et al., 2003^100^ | Exercise facility | | Post treatment | (28) Comp 1 | | Aerobic activity | | Physical well-being [Functional Assessment of Cancer Therapy-Breast (FACT-B scale)] | ES 0.00
| | | Rehabilitation and health promotion | (25) Intervention 1 | | 15–35 minutes 3 days/week | | QOL (overall) [Functional Assessment of Cancer Therapy-Breast (FACT-B scale)] | ES 0.239
| | | | | | | | FACT-B Breast cancer subscale | ES 0.338
Courneya et al., 2002^82^ | RCT | All cancers possible | Behavioral | Group | Group psycho-therapy | 65–75% maximum heart rate | 10 weeks | Physical well-being [Functional Assessment of Cancer Therapy-General (FACT-G scale)] | ES 0.02
Courneya et al., 2003^83^ | Home | Breast | Post treatment | (11) Comp 1 | | Aerobic activity | | Functional well-being [Functional Assessment of Cancer Therapy-General (FACT-G scale)] | ES 0.049
| | | Coping and rehabilitation | (11) Intervention 1 | | 20–30 minutes 3–5 days/ week
McKenzie et al., 2003^107^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intensity not reported | 8 weeks | General health QOL [SF-36] | p<.048
| Exercise facility | | Post treatment | (7) Comp 1 | | Aerobic activity | | Physical functioning QOL [SF-36] | p<0.05
| | | Rehabilitation and health promotion | (7) Intervention 1 | | Strength/ resistance
| | | | | | Stretching
| | | | | | 30–60 minutes 3 days/week
Mock et al., 1994^99^ | RCT | Breast | Behavioral | Individual | Support Group | Self-paced | 4–6 months | Physical functioning (daily activities) [Karnofsky Performance Status Scale (KPS)] | ES 1.155
| Home | | During treatment | (5) Comp 1 | | Walking
| | | Coping | (9) Intervention 1 | | 10–45 minutes 4–5 days/week
Mock et al., 2001^95^ | RCT | Breast | Behavioral | Individual | Not applicable | 50–80% maximum heart rate | 6 weeks to 6 months | QOL emotional [MOS SF-36] | Not significant
Pickett et al., 2002^96^ | Home | | During treatment | (25) Comp 1 | | Walking | | QOL social [MOS SF-36] | Not significant
| | | Coping | (23) Intervention 1 | | 15–30 minutes 5–6 days/week | | QOL physical [MOS-SF 36 subscale] | p<.00
Segal et al., 2001^87^ | RCT | Breast | Behavioral and pre-planned exercise | Individual | Not applicable | 50–60% maximum VO2 | 26 weeks | General health QOL [SF-36] | p=.04
| Primary care | | During treatment | (41) Comp 1 | | Walking | | Physical functioning [SF-36] | p<0.04
| Home | | Coping | (40) Intervention 1: self-directed exercise | | Duration not reported | | QOL [Functional Assessment of Cancer Therapy-Breast (FACT-B scale)] | Not significant
| | | | (42) Intervention 2: supervised preplanned exercise | | 5 days/week | | QOL [Functional Assessment of Cancer Therapy-(FACT-G scale)] | Not significant
Segal et al., 2003^91^ | RCT | Prostate | Pre-planned Exercise | Individual | Not applicable | 60–70% one repetition maximum | 12 weeks | QOL health-related [Functional Assessment of Cancer Therapy-Prostate (FACT-P)] | ES 0.168
| Exercise facility | | During treatment | (73) Comp 1 | | Strength/ resistance: 9 exercises, 2 sets each, 8–12 repetitions
| | | Coping | (82) Intervention 1 | | Duration not reported 3 days/week

Table F-6 Confusion

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/ Duration
Burnham & Wilcox, 2002^86^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Confusion [Linear Analog Self-Assessment measure] | ES 0.402
| Exercise facility | Colon | Post treatment | (6) Comp 1 | | 25–40% heart rate reserve
| | | Rehabilitation and health promotion | (6) Intervention 1 | | Aerobic activity
| | | | (6) Intervention 2 | | 14–32 minutes 3 days/week
| | | | | | Intervention 2:
| | | | | | 40–60% heart rate reserve
| | | | | | Aerobic activity
| | | | | | 14–32 minutes 3 days/week
MacVicar et al., 1986^112^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | 60–85% maximum heart rate on pre-test aerobic assessment | 10 weeks | Confusion/ bewilderment [Profile of Mood States POMS] | Mean changes reported. Confusion factors decreased.
| Unknown | | During treatment | (4) Comp 1 | | Aerobic activity
| | | Coping | (6) Intervention 1 | | 3 days/week
| | | | (6) Intervention 2

Table F-7 Difficulty sleeping

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/ Duration
Mock, et al., 1997^94^ | Non-RCT | Breast | Behavioral | Individual | Not applicable | Self-paced | 6 weeks or 4–6 chemotherapy cycles | Difficulty sleeping [Symptom Assessment Scales (SAS)] | p<.027
Mock et al., 1998^98^ | Home | | During treatment | (24) Comp 1 | | Walking
| | | Coping | (22) Intervention 1 | | 20–30 minutes 4–5 days/week
Mock et al., 1994^99^ | RCT | Breast | Behavioral | Individual | Support group | Self-paced | 4–6 months | Difficulty sleeping [Symptom Assessment Scale] | p<.04
| Home | | During treatment | (5) Comp 1 | | Walking
| | | Coping | (9) Intervention 1 | | 10–45 minutes 4–5 days/week

Table F-8 Self-esteem

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/ Duration
Courneya et al., 2003^90^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 70–75% maximum VO2 | 15 weeks | Self-esteem [Rosenberg Self-Esteem Scale] | ES 0.044
Fairey et al. , 2003^100^ | Exercise Facility | | Post treatment | (28) Comp 1 | | Aerobic activity
| | | Rehabilitation and health promotion | (25) Intervention 1 | | 15–35 minutes 3 days/week
Mock et al., 1994^99^ | RCT | Breast | Behavioral | Individual | Support group | Self-paced | 4–6 months | Self-esteem/ concept [Tennessee self-concept scale] | ES 0.154
| Home | | During treatment | (5) Comp 1 | | Walking
| | | Coping | (9) Intervention 1 | | 10–45 minutes 4–5 days/week
Segar et al., 1998^84^ | RCT | Breast | Pre-planned exercise | Individual | Behavior modification | ≥60% maximum heart rate | 10 weeks | Self-esteem [Rosenberg Self-Esteem Inventory (RSE)] | Not significant
| Home | | Post treatment | (10) Comp 1 | | Aerobic activity
| Exercise facility | | Rehabilitation and health promotion | (10) Intervention 1 | | 30 minutes 4 days/week
| | | | (10) Intervention 2: exercise and behavior modification

Table F-9 Psychosocial outcomes

First Author/Year | Study Design | Cancer Dignoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intersity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency Duration
Berglund et al., 1993^92^ | Non-RCT | Breast | Pre-planned exercise | Individual | Relaxation training | Intensity not reported | 4 weeks | Activities in community [measure not reported] | p<.05
| Exercise Facility | Ovarian | Post treatment | (30) Comp 1 | Information | Aerobic activity | | Activities in the home [measure not reported] | Not significant
| | Testicular | Rehabilitation | (30) Intervention 1 | Coping strategies | Strength/ resistance | | Change of lifestyle [measure not reported] | p<.005
| | | | | | Stretching | | Participation in patient organization [measure not reported] | p<.05
| | | | | | 60 minutes 1day/week | | Satisfaction about information given [6-item scale] | p<.0001
| | | | | | | | Sick leave [actual count of participants] | Not significant
| | | | | | | | Work status [actual count of participants] | Not significant
| | | | | | | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 months
Berglund et al., 1994^93^ | RCT | Breast | Pre-planned exercise | Individual | Relaxation | Intensity not reported | 4 weeks | Cognitive functioning [physical symptoms related to breast cancer scale] | Not significant
| Unknown | Ovarian | Post treatment | (101) Comp 1 | Diet | Aerobic activity | | Communication with staff [scale] | Not significant
| | Undefined | Rehabilitation | (98) Intervention 1 | Life coping skills | Strength training | | Information problems [satisfaction (6-item scale)] | p<00001
| | | | | | Stretching | | Problems with activities at home [scale] | Not significant
| | | | | | 60 minutes 1 day/week | | Problems with activities in community | Not significant
| | | | | | | | Sick leave [actual count of participants] | Not significant
| | | | | | | | Work status [actual count of participants] | Not significant
| | | | | | | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 m onths
Courneya et al., 2003^90^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 70–75% maximum VO2 | 15 weeks | Happiness [Happiness Measure] | ES 0.302
Fairey et al., 2003^100^ | Exercise facility | | Post treatment | (28) Comp 1 | | Aerobic activity | | Social/family well-being [Functional Assessment of Cancer Therapy — Breast (FACT-B scale)] | ES 0.113
| | | Rehabilitation and health promotion | (25) Intervention 1 | | 15–35 minutes 3 days/week
Courneya et al., 2002^82^ | RCT | All cancers possible | Behavioral | Group | Group psychotherapy | 65–75% maximum heart rate | 10 weeks | Satisfaction with life [Satisfaction with Life Scale] | ES 0.028
Courneya et al., 2003^83^ | Home | Breast | Post treatment | (11) Comp 1 | | Aerobic activity | | Social/family well-being [Functional Assessment of Cancer Therapy-(FACT-G scale)] | ES 0.005
| | | Coping and rehabilitation | (11) Intervention 1 | | 20–30 minutes 3–5 days/ week | | Spiritual well-being [Functional Assessment of Cancer Therapy-(FACT-G scale)] | ES 0.00
Segal et al., 2001^87^ | RCT | Breast | Behavioral and pre-planned exercise | Individual | Not applicable | 50–60% maximum VO2 | 26 weeks | Role limitations, emotional [SF-36] | Not significant
| Primary care | | During treatment | (41) Comp 1 | | Walking | | Role limitations, physical [SF-36] | Not significant
| Home | | Coping | (40) Intervention 1: self-directed exercise | | Duration not reported | | Social Functioning [SF-36] | Not significant
| | | | (42) Intervention 2: supervised preplanned exercise | | 5 days/week
Wall, 2000^213^ | RCT | Lung | Pre-planned exercise | Individual | Not applicable | Low intensity | 7–10 days | Hope [Herth Hope Index HHI] | ES 0.280
| | | Pre treatment | (51) Comp 1 | | Aerobic activity | | Power (personal not PA related) [PKPCT - semantic differential test] | ES 0.612
| | | Buffering | (53) Intervention 1 | | Strength/ resistance
| | | | | | Duration not reported 7 days/week

Table F-10 Physiological outcomes

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Intensity
| | | PEACE Framework Category | | | PA Frequency/ Duration
Courneya et al., 2003^90^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 70–75% maximum VO2 | 15 weeks | Insulin (pmol/liter) | ES -0.300
Fairey et al., 2003^100^ | Exercise facility | | Post treatment | (28) Comp 1 | | Aerobic activity | | Glucose (mmol/liter) | ES -0.301
| | | Rehabilitation and health promotion | (25) Intervention 1 | | 15–35 minutes 3 days/week | | Insulin resistance index | ES -0.324
| | | | | | | | IGF-I (ng/ml) | ES 0.414
| | | | | | | | IGF-II (ng/ml) | ES -0.475
| | | | | | | | IGFBP-1 (ng/ml) | ES 0.025
| | | | | | | | IGFBP-3 (ng/ml) | ES 0.425
| | | | | | | | IGF-I:IGFBP-3 molar ratio | ES 0.657
Cunningham et al., 1986^85^ | RCT | Acute leukemia | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 35 days | Changes in 3-methylhistidine as a percent of admit measure | Not significant
| Primary care | | During treatment | (10) Comp 1 | | Intensity not reported | | Changes in excretion of creatinine as a percent of admit measures | p<.05
| | | Coping | (10) Intervention 1 | | Calisthenics | | Weekly nitrogen balance (G) | Not significant
| | | | (10) Intervention 2 | | 30 minutes 3 days/week | | Weekly temperature | Not significant
| | | | | | Intervention 2:
| | | | | | Intensity not reported
| | | | | | Calisthenics
| | | | | | 30 minutes 5 days/week
Dimeo et al., 1997^101^ | RCT | Breast | Pre-Planned Exercise | Individual | Not applicable | 50% heart rate reserve | Not clear/ day of hospital discharge | Blood transfusions (U) | ES 0.00
| Primary care | Germ cell | During treatment | (37) Comp 1 | | Aerobic activity | | Hematocrit | ES 0.00
| | Sarcoma | Coping | (33) Intervention 1 | | 15 minutes 7 days/week | | Hemoglobin | ES 0.198
| | Lung | | | | | | In-hospital days | ES 0.528
| | Adenoscarcinoma | | | | | | Loss of physical performance during hospitalization | ES 0.494
| | Neuroblastoma | | | | | | Platelets transfusions (U) | ES 0.430
Dimeo et al., 1997^102^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | 80% maximum heart rate | 6 weeks | Cardiac function and dimensions | Not significant
| Primary care | Non-small cell lung carcinoma | Post treatment | (16) Comp 1 | | Walking | | ECG function | Not significant
| | Sarcoma | Rehabilitation | (16) Intervention 1 | | 15–30 minutes 5 days/week | | Hemoglobin | ES 0.822
| | Semioma
| | Non-Hodgkin's lymphoma
Segal et al., 2003^91^ | RCT | Prostate | Pre-planned exercise | Individual | Not applicable | 60–70% one repetition maximum | 12 weeks | PSA levels | Not significant
| Exercise facility | | During treatment | (73) Comp 1 | | Strength/ resistance: 9 exercises, 2 sets each, 8–12 repetitions | | Testosterone | Not significant
| | | Coping | (82) Intervention 1 | | Duration not reported 3 days/week

Table F-11 Body size

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Goal of body size change | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode | | Outcomes Reported
| | | PEACE Framework Category | | | PA Frequency/ Duration
Burnham & Wilcox, 2002^86^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Decrease body weight/fat:
| Exercise facility | Colon | Post treatment | (6) Comp 1 | | 25–40% heart rate reserve | | Body fat percent | ES -0.153
| | | Rehabilitation and health promotion | (6) Intervention 1 | | Aerobic activity | | Body weight | ES 0.636
| | | | (6) Intervention 2 | | 14–32 minutes 3 days/week
| | | | | | Intervention 2:
| | | | | | 40–60% heart rate reserve
| | | | | | Aerobic activity
| | | | | | 14–32 minutes 3 days/week
Courneya et al., 2003^90^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 70–75% maximum VO2 | 15 weeks | Decrease body weight/fat:
Fairey et al., 2003^100^ | Exercise facility | | Post treatment | (28) Comp 1 | | Aerobic activity | | Body Mass Index | ES 0.103
| | | Rehabilitation and health promotion | (25) Intervention 1 | | 15–35 minutes 3 days/week | | Body weight | ES 0.015
| | | | | | | | Sum of skinfolds | ES 0.115
Courneya et al., 2002^82^ | RCT | All cancers possible | Behavioral | Group | Group psychotherapy | 65–75% maximum heart rate | 10 weeks | Decrease body weight/fat:
Courneya et al., 2003^83^ | Home | Breast | Post treatment | (11) Comp 1 | | Aerobic activity | | Body fat composition [calipers] | ES 0.101
| | | Coping and rehabilitation | (11) Intervention 1 | | 20–30 minutes 3–5 days/ week
Djuric et al., 2002^81^ | RCT | Breast | Behavioral | Individual | Diet | Moderate intensity | 12 weeks | Decrease body weight/fat:
| Community | | Post treatment | (13) Comp 1 | | PA mode not reported | | Body weight change [beam scale] | p<.05
| | | Behavioral and health promotion | (10) Intervention 1: Weight Watchers exercise points system | | 30–45 minutes 5–7 days/ week | | Body weight loss percent achieving 10% [beam scale] | p<.016
| | | | (13) Intervention 2: individualized
| | | | (11) Intervention 3: intervention 1 plus intervention 2
Segal et al., 2001^87^ | RCT | Breast | Behavioral and pre-planned exercise | Individual | Not applicable | 50–60% maximum VO2 | 26 weeks | Decrease body weight/fat:
| Primary care | | During treatment | (41) Comp 1 | | Walking | | Body weight | Not significant
| Home | | Coping | (40) Intervention 1: self-directed exercise | | Duration not reported
| | | | (42) Intervention 2: supervised preplanned exercise | | 5 days/week
Winningham et al., 1988^89^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Decrease body weight/fat:
Winningham et al., 1989^108^ | Unknown | | During treatment | (12) Comp 1 | | Intensity not reported | | Percent body fat | p<.033
| | | Coping | (14) Intervention 1 | | Stretching | | Body weight | Not significant
| | | | (16) Intervention 2 | | Duration not reported | | Lean body weight | Not significant
| | | | | | 3 days/week | | Subcutaneous body fat distribution | p<.008
| | | | | | Intervention 2: | | Sum of skinfolds | p<.0009 Not significant
| | | | | | 60–85% maximum heart rate | | ≥45 years
| | | | | | Aerobic activity | | >45 years
| | | | | | 20–30 minutes 3 days/week
Cunningham et al., 1986^85^ | RCT | Acute leukemia | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 35 days | Increase or maintain muscle mass
| Primary care | | During treatment | (10) Comp 1 | | Intensity not reported | | Body weight [percent of admission measures] | Not significant
| | | Coping | (10) Intervention 1 | | Calisthenics | | Arm fat area [percent of admission measures] | Not significant
| | | | (10) Intervention 2 | | 30 minutes 3 dats/week | | Arm muscle area [percent of admission measures] | Not significant
| | | | | | Intervention 2:
| | | | | | Intensity not reported
| | | | | | Calisthenics
| | | | | | 30 minutes 5 days/week
Dimeo et al., 1997^102^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | 80% maximum heart rate | 6 weeks | Avoid muscle loss
| Primary care | Non-small cell lung carcinoma | Post treatment | (16) Comp 1 | | Walking | | Body Mass Index | Not significant
| | Sarcoma | Rehabilitation | (16) Intervention 1 | | 15–30 minutes 5 days/week
| | Semioma
| | Non-Hodgkin's lymphoma
McKenzie et al., 2003^107^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | PA intensity not reported | 8 weeks | Avoid increases in arm volume
| Exercise facility | | Post treatment | (7) Comp 1 | | Aerobic activity | | Arm volume by circumference | ES 1.642
| | | Rehabilitation and health promotion | (7) Intervention 1 | | Strength/ resistance | | Arm volume by water displacement | ES 1.262
| | | | | | Stretching
| | | | | | 30–60 minutes 3 days/week
Segal et al., 2003^91^ | RCT | Prostate | Pre-planned exercise | Individual | Not applicable | 60–70% one repetition maximum | 12 weeks | Avoid muscle mass loss
| Exercise facility | | During treatment | (73) Comp 1 | | Strength/ resistance: 9 exercises, 2 sets each, 8–12 repetitions | | BMI | Not significant
| | | Coping | (82) Intervention 1 | | Duration not reported 3 days/week | | Body weight | Not significant
| | | | | | | | Skinfolds | Not significant
| | | | | | | | Waist circumference | Not significant

Table F-12 Pain

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/ Duration
Berglund et al., 1993^92^ | Non-RCT | Breast | Pre-planned exercise | Individual | Relaxation training | Intensity not reported | 4 weeks | Pain [no validity/ reliability measure scale] | Not significant
| Exercise facility | Ovarian | Post treatment | (30) Comp 1 | Information | Aerobic activity | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 months
| | Testicular | Rehabilitation | (30) Intervention 1 | Coping strategies | Strength/ resistance
| | | | | | Stretching
| | | | | | 60 minutes 1 day/week
Berglund et al., 1994^93^ | RCT | Breast | Pre-planned exercise | Individual | Relaxation | Intensity not reported | 4 weeks | Pain [no validity/ reliability measure scale] | p<.0001
| Unknown | Ovarian | Post treatment | (101) Comp 1 | Diet | Aerobic activity | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3,6 & 12 months
| | Undefined | Rehabilitation | (98) Intervention 1 | Life coping skills | Strength training
| | | | | | Stretching
| | | | | | 60 minutes 1 day/week
Segal et al., 2001^87^ | RCT | Breast | Behavioral and pre-planned exercise | Individual | Not applicable | 50–60% maximum VO2 | 26 weeks | Bodily pain [SF-36] | Not significant
| Primary care | | During treatment | (41) Comp 1 | | Walking
| Home | | Coping | (40) Intervention 1: self-directed exercise | | Duration not reported
| | | | (42) Intervention 2: supervised preplanned exercise | | 5 days/week

Table F-13 Vigor / vitality

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/ Duration
Burnham & Wilcox, 2002^86^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Personal energy [Linear Analog Self-Assessment measure] | ES 1.265
| Exercise facility | Colon | Post treatment | (6) Comp 1 | | 25–40% heart rate reserve
| | | Rehabilitation and health promotion | (6) Intervention 1 | | Aerobic activity
| | | | (6) Intervention 2 | | 14–32 minutes 3 days/week
| | | | | | Intervention 2:
| | | | | | 40–60% heart rate reserve
| | | | | | Aerobic activity
| | | | | | 14–32 minutes 3 days/week
Dimeo et al., 1999^106^ | RCT | Solid tumors or breast carcinoma | Pre-planned exercise | Individual | Not applicable | 50% heart rate reserve | Not reported/ hospital discharge | Vigor [Profile of Mood Status measure (POMS)] | ES 0.434
| Primary care | Metastatic breast carcinoma | During treatment | (33) Comp 1 | | Aerobic activity
| | Seminoma | Coping | (29) Intervention 1 | | 15 minutes 7 days/week
| | Sarcoma/ adenocarcinoma
| | Hodgkin's disease
| | Non-Hodgkin's lymphoma
| | Small cell lung carcinoma
MacVicar et al., 1986^112^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | 60–85% maximum heart rate on pre-test aerobic assessment | 10 weeks | Vigor/activity [Profile of Mood States (POMS)] | Mean changes reported. Vigor increased in treatment group.
| Unknown | | During treatment | (4) Comp 1 | | Aerobic activity
| | | Coping | (6) Intervention 1 | | 3 days/week
| | | | (6) Intervention 2
McKenzie et al., 2003^107^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | PA Intensity not reported | 8 weeks | Vitality QOL [SF-36] | p<.023
| Exercise facility | | Post treatment | (7) Comp 1 | | Aerobic activity
| | | Rehabilitation and health promotion | (7) Intervention 1 | | Strength/ resistance
| | | | | | Stretching
| | | | | | 30–60 minutes 3 days/week
Mock et al., 2001^95^ | RCT | Breast | Behavioral | Individual | Not applicable | 50–80% maximum heart rate | 6 weeks to 6 months | Vigor [Profile of Moods States (POMS)] | p<.00
Pickett et al., 2002^96^ | Home | | During treatment | (25) Comp 1 | | Walking
| | | Coping | (23) Intervention 1 | | 15–30 minutes 5–6 days/week
Segal et al., 2001^87^ | RCT | Breast | Behavioral and pre-planned exercise | Individual | Not applicable | 50–60% maximum VO2 | 26 weeks | Vitality QOL [SF-36] | Not significant
| Primary care | | During treatment | (41) Comp 1 | | Walking
| Home | | Coping | (40) Intervention 1: self-directed exercise | | Duration not reported
| | | | (42) Intervention 2: supervised preplanned exercise | | 5 days/week

Table F-14 Symptoms / side effects

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework category | | | PA Frequency/Duration
Berglund et al., 1994^93^ | RCT | Breast | Pre-planned exercise | Individual | Relaxation | Intensity not reported | 4 weeks | Aversions [physical symptoms related to breast cancer scale] | Not significant
| Unknown | Ovarian | Post treatment | (101) Comp 1 | Diet | Aerobic activity | | Mixed symptoms A [physical symptoms related to breast cancer scale] | Not significant
| | Undefined | Rehabilitation | (98) Intervention 1 | Life coping skills | Strength training | | Mixed symptoms B [physical symptoms related to breast cancer scale] | Not significant
| | | | | | Stretching | | Mucous membrane disturbances frequent [physical symptoms related to breast cancer scale] | Not significant
| | | | | | 60 minutes 1 day/week | | Sexual problems frequency [physical symptoms related to breast cancer scale] | Not significant
| | | | | | | | Surgery effects [physical symptoms related to breast cancer scale] | Not significant
| | | | | | | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 months
Dimeo et al., 1999^106^ | RCT | Solid tumors or breast carcinoma | Pre-planned exercise | Individual | Not applicable | 50% heart rate reserve | Not reported/ hospital discharge | Somatization [Symptom Check List SCL-90-R] | ES 0.547
| Primary Care | Metastatic breast carcinoma | During treatment | (33) Comp 1 | | Aerobic activity
| | Seminoma | Coping | (29) Intervention 1 | | 15 minutes 7 days/week
| | Sarcoma/ adenocar-cinoma
| | Hodgkin's disease
| | Non-Hodgkin's lymphoma
| | Small cell lung carcinoma
Dimeo et al., 1997^101^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 50% heart rate reserve | Not clear/ day of hospital discharge | Severity of diarrhea [toxicity of high dose chemotherapy (HDC)] | ES 0.507
| Primary Care | Germ cell | During treatment | (37) Comp 1 | | Aerobic activity | | Severity of infection [toxicity of HDC] | ES 0.225
| | Sarcoma | Coping | (33) Intervention 1 | | 15 minutes 7 days/week | | Severity of mucositis [toxicity of HDC] | ES -0.130
| | Lung | | | | | | Severity of pain [toxicity of HDC] | ES 0.849
| | Adenoscar-cinoma
| | Neuro-blastoma
Mock et al., 1994^99^ | RCT | Breast | Behavioral | Individual | Support group | Self-paced | 4–6 months | Nausea [Symptom Assessment Scale] | Not significant
| Home | | During treatment | (5) Comp 1 | | Walking | | Vomiting [Symptom Assessment Scale] | Not significant
| | | Coping | (9) Intervention 1 | | 10–45 minutes 4–5 days/week
Winningham et al., 1988^89^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1:Intensity not reported | 10 weeks | Nausea [Symptom Checklist 90-Revised SCL-90-R] | p<.032
Winningham et al., 1989^108^ | Unknown | | During treatment | (12) Comp 1 | | Stretching | | Somatization [Symptom Checklist 90-Revised SCL-90-R] | p<.04
| | | Coping | (14) Intervention 1 | | Duration not reported
| | | | (16) Intervention 2 | | 3 days/week
| | | | | | Intervention 2:60–85% maximum heart rate
| | | | | | Aerobic activity
| | | | | | 20–30 minutes 3 days/week

Table F-15 Immune parameters

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/ Duration
Dimeo et al., 1997^101^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 50% heart rate reserve | Not clear/day of hospital discharge | Duration of neutropenia (days) | ES 0.643
| Primary care | Germ cell | During treatment | (37) Comp 1 | | Aerobic activity | | Duration of thrombopenia (days) | ES 0.442
| | Sarcoma | Coping | (33) Intervention 1 | | 15 minutes 7 days/week
| | Lung
| | Adenoscar-cinoma
| | Neuroblastoma
Hayes et al., 2003^104^ | Non-RCT | Acute myeloid leukemia | Pre-planned exercise | Individual | Not applicable | Intervntion 1: | 3 months | CD3+ (helper/ suppressor T-cell) | Not significant
| Primary care | Breast | During treatment | (6) Comp 1 | | 70–90% maximum heart rate HR | | CD4+ (helper T-cells) | Not significant
| | Multiple myeloma | Rehabilitation | (6) Intervention 1 | | Aerobic activity | | CD8+ (suppressor T-cell) | Not significant
| | Non-Hodgkin's lymphoma | | | | Strength | | Lymphocytes | Not significant
| | Lymphoblastic lymphoma/ leukemia | | | | 20–40 minutes 3 days/week | | Ratio CD4+/CD8+ | Not significant
| | Rhabdomyo-sarcoma | | | | Comparison 1: | | T cell function adjusted for CD3+ | Not significant
| | | | | | Intensity not reported | | Total t-cell function | Not significant
| | | | | | Stretching | | White blood cells | Not significant
| | | | | | 20–40 minutes 3 days/week
Na, 2000^105^ | RCT | Stomach | Pre-planned exercise | Individual | Not applicable | Intensity not reported | 2 weeks | Natural killer cell cytotoxic activity | p<.05
| Primary care | | During treatment | (18) Comp | | Aerobic activity
| | | Rehabilitation | (17) Intervention | | 60–90 minutes 4–5 days/ week
Nieman et al., 1995^103^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 75% maximum heart rate | 8 weeks | E: T20: 1 (mononuclear cells to cancer cell ratio NKCA percent lysis) | ES 1.047
| Unknown | | Post treatment | (8) Comp 1 | | Aerobic activity | | E: T40:1 (mononuclear cells to cancer cell ratio NKCA percent lysis) | ES 0.636
| | | Survival | (8) Intervention 1 | | Strength/ resistance | | Lymphocytes | ES -0.799
| | | | | | 60 minutes 3 days/week | | Neutrophils | ES -0.580
| | | | | | | | Natural killer cells | ES -0.417
| | | | | | | | T cells | ES -0.765
| | | | | | | | Total leukocytes | ES -0.705

Table F-16 Mental / emotional / psychological well-being

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported | Significant Results
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework Category | | | PA Frequency/ Duration
Berglund et al., 1993^92^ | Non-RCT | Breast | Pre-planned exercise | Individual | Relaxation training | Intensity not reported | 4 weeks | Depressive symptoms [modified HAD-scale no validity/ reliability measure] | p<.01
| Exercise facility | Ovarian | Post treatment | (30) Comp 1 | Information | Aerobic activity | | Anxiety Symptoms [modified HAD- scale no validity/ reliability measure] | p<.01
| | Testicular | Rehabilitation | (30) Intervention 1 | Coping strategies | Strength/ resistance | | | *all results are from a repeated measures ANOVA from 5 time points: baseline, post, 3, 6 & 12 months
| | | | | | Stretching
| | | | | | 60 minutes 1day/week
Berglund et al., 1994^93^ | RCT | Breast | Pre-planned exercise | Individual | Relaxation | Intensity not reported | 4 weeks | Avoidance | Not significant
| Unknown | Ovarian | Post treatment | (101) Comp 1 | Diet | Aerobic activity | | Fatalistic | Not significant
| | Undefined | Rehabilitation | (98) Intervention 1 | Life coping skills | Strength training | | Fighting spirit | Not significant
| | | | | | Stretching | | Hopeless | Not significant
| | | | | | 60 minutes 1 day/week | | *all used mental adjustment to cancer scale | Not significant
| | | | | | | | Anxiety scale [modified HAD-scale] | Not significant
| | | | | | | | Anxious preoccupation [mental adjustment to cancer scale] | Not significant
| | | | | | | | Worry [physical symptoms related to breast cancer scale] | Not significant
| | | | | | | | Depression [Modified HAD-scale] | *all results are from a repeated measures ANOVA from 5 time points: baseline , post, 3, 6 & 12 months
Burnham & Wilcox, 2002^86^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Depression [Linear Analog Self-Assessment measure] | ES 1.279
| Exercise facility | Colon | Post treatment | (6) Comp 1 | | 25–40% heart rate reserve | | Anxiety [Linear Analog Self-Assessment measure] | ES 0.901
| | | Rehabilitation and health promotion | (6) Intervention 1 | | Aerobic activity | | Anger [Linear Analog Self-Assessment measure] | ES -0.114
| | | | (6) Intervention 2 | | 14–32 minutes 3 days/week
| | | | | | Intervention 2:
| | | | | | 40–60% heart rate reserve
| | | | | | Aerobic activity
| | | | | | 14–32 minutes 3 days/week
Courneya et al., 2002^82^ | RCT | All cancers possible | Behavioral | Group | Group psycho-therapy | 65–75% maximum heart rate | 10 weeks | Depression [CES-D scale] | ES 0.005
Courneya et al., 2003^83^ | Home | Breast | Post treatment | (11) Comp 1 | | Aerobic activity | | Anxiety [State-Trait Anxiety Inventory] | ES 0.000
| | | Coping and rehabilitation | (11) Intervention 1 | | 20–30 minutes 3–5 days/ week | | Emotional well-being [Functional Assessment of Cancer Therapy-General (FACT-G Scale)] | ES 0.000
Courneya et al., 2003^90^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 70–75% maximum VO2 | 15 weeks | Emotional well-being [Functional Assessment of Cancer Therapy-Breast (FACT-B scale)] | ES 0.375
Fairey et al., 2003^100^ | Exercise facility | | Post treatment | (28) Comp 1 | | Aerobic activity | | Trial Outcome Index (TOI) score [well-being with breast cancer subscale] | ES 0.200
| | | Rehabilitation and health promotion | (25) Intervention 1 | | 15–35 minutes 3 days/week
Dimeo et al., 1999^106^ | RCT | Solid tumors or breast carcinoma | Pre-planned exercise | Individual | Not applicable | 50% heart rate reserve | Not reported/ hospital discharge | Global psychologic distress [Symptom Check List SCL-90-R] | ES 0.253
| Primary Care | Metastatic breast carcinoma | During treatment | (33) Comp 1 | | Aerobic activity | | Anxiety [Symptom Check List SCL-90-R] | ES 0.278
| | Seminoma | Coping | (29) Intervention 1 | | 15 minutes 7 days/week | | Phobic anxiety [Symptom Check List SCL-90-R] | ES 0.154
| | Sarcoma/ adenocar-cinoma | | | | | | Depression [Profile of Mood States POMS] | ES 0.079
| | Hodgkin's disease | | | | | | Depression [Symptom Check List SCL-90-R] | ES 0.263
| | Non-Hodgkin's lymphoma | | | | | | Anger/hostility [Profile of Mood States POMS] | ES 0.063
| | Small cell lung carcinoma | | | | | | Hostility [Symptom Check List SCL-90-R] | ES 0.266
MacVicar et al., 1986^112^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | 60–85% maximum heart rate on pre-test aerobic assessment | 10 weeks | Total Mood Disturbance [Profile of Mood States (POMS)] | Mean changes reported. Total mood disturbance, tension/ anxiety, depression, and anger/ hostility all decreased in treatment group.
| Unknown | | During treatment | (4) Comp 1 | | Aerobic activity | | Tension/anxiety [Profile of Mood States (POMS)]
| | | Coping | (6) Intervention 1 | | 3 days/week | | Depression [Profile of Mood States (POMS)]
| | | | (6) Intervention 2 | | | | Anger/hostility [Profile of Mood States (POMS)]
McKenzie et al., 2003^107^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | PA Intensity not reported | 8 weeks | Mental health QOL [SF-36] | p<.019
| Exercise facility | | Post treatment | (7) Comp 1 | | Aerobic activity
| | | Rehabilitation and health promotion | (7) Intervention 1 | | Strength/ resistance
| | | | | | Stretching
| | | | | | 30–60 minutes 3 days/week
Mock et al., 1994^99^ | RCT | Breast | Behavioral | Individual | Support group | Self-paced | 4–6 months | Depression [Symptom Assessment Scale] | p=.01
| Home | | During treatment | (5) Comp 1 | | Walking | | Impact of medical illness on subject [Psychosocial Adjustment to Illness Scale] | ES 0.413
| | | Coping | (9) Intervention 1 | | 10–45 minutes 4–5 days/week | | Psychologic distress [Brief Symptom Inventory] | ES 0.896
| | | | | | | | Anxiety [Symptom Assessment Scale] | Not significant
Mock, et al., 1997^94^ | Non-RCT | Breast | Behavioral | Individual | Not applicable | Self-paced | 6 weeks or 4–6 chemotherapy cycles | Depression [Symptom Assessment Scales (SAS)] | p<.104
Mock et al., 1998^98^ | Home | | During treatment | (24) Comp 1 | | Walking | | Anxiety [Symptom Assessment Scales (SAS)] | p<.029
| | | Coping | (22) Intervention 1 | | 20–30 minutes 4–5 days/week
Mock et al., 2001^95^ | RCT | Breast | Behavioral | Individual | Not applicable | 50–80% maximum heart rate | 6 weeks to 6 months | Depression [Profile of Mood States (POMS)] | p<.001
Pickett et al., 2002^96^ | Home | | During treatment | (25) Comp 1 | | Walking | | Total Mood Disturbance [Profile of Moods States (POMS)] | p<.001
| | | Coping | (23) Intervention 1 | | 15–30 minutes 5–6 days/week | | Anxiety [Profile of Mood States (POMS)] | p<.001
Segal et al., 2001^87^ | RCT | Breast | Behavioral and pre-planned exercise | Individual | Not applicable | 50–60% maximum VO2 | 26 weeks | Mental health [SF-36] | Not significant
| Primary care | | During treatment | (41) Comp 1 | | Walking
| Home | | Coping | (40) Intervention 1: self-directed exercise | | Duration not reported
| | | | (42) Intervention 2: supervised preplanned exercise | | 5 days/week
Segar et al., 1998^84^ | RCT | Breast | Pre-planned exercise | Individual | Behavior modification | ≥60% maximum heart rate | 10 weeks | Depression [Beck Depression Inventory (BDI)] | p<.05
| Home | | Post treatment | (10) Comp 1 | | Aerobic activity | | Anxiety [Strait Anxiety Inventory (STAI)] | p<.04
| Exercise facility | | Rehabilitation and health promotion | (10) Intervention 1 | | 30 minutes 4 days/week
| | | | (10) Intervention 2: exercise and behavior modification