# Appendix E Evidence Tables

Evidence Table 1. General population (Studies are sorted alphabetically by first author)

Author Year | Study Design | Inclusion Criteria | Outcomes Measured | Effect Size at End of Intervention | Effect Size at Closest Followup ≥ 3 Months | Effect Size at Last Reported Followup
| Unit of Assignment
| Recruitment Setting
| # Analyzed
Bauer, et al., 1985^51^ | Tested worksite based education program and, for a subset, personal counseling versus no intervention
UK Heart Disease Prevention Project | Randomized | 1) Employed at English and Welsh factories that participated in the study. | 1) Somewhat active or greater versus sedentary | | | 4 to 7 years
| Group | 2) Male worker. | 2) Moderately active or greater versus sedentary | | | 1) Somewhat active or greater versus sedentary 0.196
| Worksite | 3) Aged 40 to 59 years. | Leisure exercise was assessed on a 4-point scale. Results were reported only for a subset of 5 intervention and 5 control worksites at 4–7 years after intervention. | | | 2) Moderately active or greater versus sedentary 0.030
| 953 | 4) All jobs except for 2 steel work plants where only office staff participated.
Belisle et al., 1987^74^ | Tested relapse prevention approach in sport center exercise program
| Randomized | Volunteers registering in beginners level exercise groups | 1) Adherence to PA, measured by mean # of sessions attended (jogging, aerobic dance, pre-ski) | 0 months | | 3 months
| Group | | | 1) 0.294 | | 1) 0.129
| Sport center
| 350
Belisle et al., 1987^74^ | Tested relapse prevention approach in sport center exercise program
| Randomized | Volunteers registering in beginners level exercise groups | 1) Adherence to PA, measured by mean # of sessions attended (jogging, aerobic dance, pre-ski) | | | 3 months
| Group | | | | | 1) 0.398
| Sport center
| 243
Blalock et al., 2000^76^ | Tested mailed general osteoporosis information packets, action plans or both
| Randomized | 1) Women | 1) Percent meeting “action” stage of exercise, measured as weight-bearing PA ≥ 3 times/week or currently trying to increase exercise level. | | | 12 months
| Individual | 2) Aged 35–43 years | | | | 1) NN
| Community | 3) Live in 3 North Carolina counties
| 408 | 4) Have a telephone number listed in a local directory
| | 5) Premenopausal
| | 6) Not have osteoporosis, be pregnant or breast-feeding, or have been advised against increasing their level of exercise or calcium intake by their physician
Bull et al., 1999^57^ | Tested brief advice from a family physician and a standard brochure or brief physician advice plus a stage matched tailored brochure versus no advice.
Bull et al. 1998 ^113^ | Non-Randomized | 1) Adult patients at the 10 participating family practices that attended the practice over a 3 week time period of recruitment. | 1) Percent of subjects “now active” (1 episode of PA in last 2 weeks). | 1 month | 6 months | 12 months
| Individual | 2) Being sedentary (reported no vigorous exercise, moderate exercise, or walking in the previous 2 weeks). | 2) Total number of exercise sessions in previous 2 weeks | 1) 1: 0.171 | 1) 1: 0.218 | 1) 1: 0.077
| Health care | 3) Exercise was not contraindicated and it was appropriate in context of the consultation to discuss exercise with the patient. | 3) Total amount of time exercising in previous 2 weeks | 2: 0.240 | 2: 0.148 | 2: 0.150
| 763 | Excluded if there was no time in the consultation to discuss PA or he/she was already active. | | 1&2 combined: 0.216 | 1&2 combined: 0.197 | 1&2 combined: 0.124
| | | | 2) IS | 2) IN | 2) NN
| | | | 3) IN | 3) IN | 3) DN
Burke, et al., 1998^65^ | Tested effect of physical activity and nutrition program in school for 11 year olds and an “enrichment” program for high risk children versus no intervention at all.
| Randomized | 989 children from 18 schools were invited to take part. It is unclear whether all children in all 18 schools were invited to participate. | 1) Change in shuttle run (# of laps) from baseline for high risk (HR) and low risk (LR) boys and girls | 0 months | | 6 months
| Group | | 2) Change in 1.5km run (# of laps) from baseline for high risk (HR) and low risk (LR) boys and girls | 1) 1:IN IS IS IS | | 1)1:IS DS IS IS
| School | | 3) Change in leisure time PA, measure in minutes/week. Based on 7-day PA diary | 2:IS IS IS | | 2:IS IN IS IS
| 720 | | | 2) 1:DN DN DN IN | | 2)1:DN DN DN DN
| | | | 2:IN DN IN DN | | 2:IS NN NN NN
| | | | 3) 1:NN | | 3) 1:NN
| | | | 2:NN | | 2:NN
Caserta & Gillett, 1998^115^ | Tested health education group or supervised exercise group in women in their 60s
Gillett et al. 1996^63^ | Randomized | INCLUSION: | 1) Differences in aerobic exercise frequency, days/week, based on 7-day Physical Activity Readiness Questionnaire (PARQ). Aerobic defined as PA at 60–80% maximum heart rate. | 0 months | 3 months | 6 months
Gillett et al. 1996^79^ | Individual | 1) Obese older women | 2) Aerobic exercise duration (minutes/session), based on 7-day PARQ. Aerobic defined as PA at 60–80% max. heart rate | 1) 1 vs 2: 0.414 | 1) 1 vs 2: -0.310 | 1) 1 vs 2: -0.611
| Community | 2) Community dwelling | 3) Predicted VO2 maximum using submaximal exercise cycle ergometry
| 110 | 3) Sedentary | | 2) 1 vs 2: -0.132 | 2) 1 vs 2: 0.199 | 2) 1 vs 2: 0.090
| | 4) Aged 60–70 yrs
| | The study included non-smokers, who reported only light exercise for the previous six months. | | 3) 1: 1.547 | 3) 1: 1.266 | 3) 1: 0.932
| | EXCLUSION: | | 2: 0.015 | 2: 0.437 | 2: 0.135
| | Women whose chronic health or mobility problems precluded vigorous walking. The following were also excluded: women with known cardiovascular, pulmonary, neurological or kidney diseases, uncontrolled hypertension, and debilitating musculoskeletal disorders.
Chen et al., 1998^145^ | Tested mailed behavior change materials and six telephone based counseling sessions in ethnic minority women versus control
| Randomized | 1) Women | 1) Self-reported minutes walked per week in the last two weeks (derived by multiplying response to times walked by minutes walked per time) | 0 months | 3 months | 28 months
| Individual | 2) Not currently exercising more than once a week or walking more than 90 minutes per week | | 1) 0.185 | 1) -0.236 | 1) -0.066
| Community | 3) Able to speak, comprehend, and read English
| 50 | 4) Free of any heart disease or other exclusionary conditions as determined by the PARQ
| | 5) Have a 6th grade education or higher
Dale et al., 1998^146^ | Tested conceptual physical education program for ninth-grade students versus traditional physical education
Dale & Corbin 2000 ^66^ | Non-randomized | Graduating classes of 1995 and 1996 at the Project Teens intervention school. (Different followup lengths for each graduating class) | 1) Differences in percent of students participating in moderate activity (e.g. walking, bicycling) at least 5 days/week, and at least 30 minutes/day. | | 12 months (Class of 1996) | 48 months
| Group | | 2) Differences in percent of students participating in vigorous activity at least 3 days/week and at least 20 minutes/day. | | 1) IN DN | 1) DN IN IN DN
| School | | 3) Differences in percent of students participating in muscle fitness activities at least 3 days/week | | 2) IN IN | 2) DN NN IS IN
| 334 | | | | 3) IN IN | 3) IN IN DN IN
| | | | | 24 months (Class of 1995)
| | | | | 1) IN IN
| | | | | 2) IN IN
| | | | | 3) IN IS
Eaton et al., 1999^50^ | Tested multiple community wide efforts including school programs, organizational activation and community activation over about 7 years
Carleton et al., 1995^166^ | Non-randomized | COMMUNITY: 2 Communities between 40,000 to 100,000 people. | 1) Percent sedentary (self report of zero days per week of sweat related physical activity) | 1) IN | | 18 months
Carleton et al., 1987^165^ | Group | INDIVIDUAL: All citizens ages 18–64 that were part of the social community, thus residents of the community, and persons who were working in or visiting the city. | | | | 1) IN
McGraw et al., 1989^169^ | Community
Marcus et al., 1992^167^ | Worksite
Levin et al., 1998^168^ | 2075
Pawtucket Heart Health Program
Eckstrom, et al., 1999^136^ | Tested effect of teaching physical activity counseling to internal medicine residents on physical activity of their patients, versus no intervention to internal medicine residents
| Randomized | 1) Patients who were already scheduled for an appointment during the 3-month physician intervention period were in the pool. Surveys were sent to every third patient on this list, to ensure that more than 10 patients of each physician would be included in the sample. | 1) Total activity: “Do you do some regular exercise/” (range, 0–12 based on frequency and duration) | | | 6 months
| Group | | | | | 1) 0.021
| Health care
| 465
Edmundson et al., 1996^118^ | Tested school food service modifications, enhanced physical education and classroom health curricula on third through fifth grades
Luepker et al., 1996^53^ | Randomized | GROUPS: | 1) Self-reported daily minutes of vigorous physical activity using Self-administered Physical Activity Checklist (SAPAC) (1 day recall of 22 physical activities) | 0 months | 12 months | 36 months
Nader et al., 1999^52^ | Group | 1) Public elementary schools | 2) Self-reported daily minutes of total physical activity using SAPAC (1 day recall of 22 physical activities) | 1)0.172 | 1) 0.155 | 1) 0.145
Perry et al., 1997^119^ | School | 2) Distance from one of the four study centers | | 2)-0.099 | 2) -0.070 | 2) -0.070
Simons-Morton et al., 1997^120^ | 3396 | 3) Ethnically diverse
Stone et al., 1996^121^ | | 4) Food service potential for intervention
Nader et al., 1996^122^ | | 5) Commitment to offering at least a 90 minutes a week physical education class and participating in a 3-year study
McKenzie et al., 2001^123^ | | 6) Willing to cooperate with random assignment to treatment or control status
McKenzie et al., 1996^124^ | | INDIVIDUALS:
McKenzie et al., 1994^125^ | | Parental consent to participate and have blood sample result at baseline.
Hearn, 1992^126^
McKenzie et al., 1995^127^
Elder et al. 1994 ^149^
CATCH
Edye et al., 1989^147^ | Tested individual counseling by occupational health professionals and 3 counseling sessions with a nurse versus periodic health screening only
| Randomized | Work for 1 of 2 Australian government organizations and fit within specific ranges for one of the following risk factors: diastolic blood pressure, cholesterol, smoking, alcohol, obesity, or lack of fitness. | 1) Net change in proportion who are not fit (lack of fitness = HR > 120 beats/minute after 2 minutes stepping up and down 20cm step × 30 per minute). | | | 36 months
| Individual | | | | | 1) IN
| Worksite
| 1937
Elder et al., 1995^148^ | Tested health risk assessment (HRA) with no feedback versus HRA with feedback, counseling, written materials, 2 phone calls, and 8 health education classes
San Diego Medicare Prevention Health Project | Randomized | Medicare beneficiaries enrolled in a risk-sharing HMO | 1) Self-reported frequency, duration, and intensity of exercise per week | 0 months | | 24 months
| Individual | | 2) Self-reported stretching minutes per week | 1) 0.164 | | 1) 0.094
| Health care | | | 2) 0.047 | | 2) 0.091
| 798
Gemson & Sloan, 1995^68^ | Tested effect of a computerized health risk appraisal with counseling
| Randomized | Merrill Lynch New York City office employees who were at least 30 years old and had been working for the company at least one year, uninterrupted. | 1) Change in self-reported PA (number of times/ week) | | | 6 months
| Individual | | | | | 1) 0.420
| Worksite
| 90
Godin et al., 1987^116^ | Tested effect of providing information on physical fitness, health age or both
| Randomized | Adults aged 20 to 60 years old | 1) Frequency of participation “in one or more physical activities, lasting 20 to 30 minutes per workout session, in your free time during the last 3 months” [SCALE 1–6: (1) never, (2) less than once a month, (3) about once a month, (4) about two or three times a month, (5) about one or two times a week, and (6) three or more times per week] | | | 3 months
| Individual | | | | | 1) 1: 0.369
| Community | | | | | 2: 0.000
| 130 | | | | | 3: 0.123
Gomel et al., 1993^139^ | Tested worksite based health risk assessment with no risk counseling (control) versus health risk assessment with counseling on results or health risk assessment with counseling on results plus 6 health education sessions, or health risk assessment with counseling on results plus health education plus incentives.
Gomel et al. 1997 ^140^ | Randomized | INCLUSION: Employees of 28 stations of ambulance service with more than 12 employees in the state of New South Wales, Australia. | 1) Aerobic capacity (O2 consumption), measured in ml × kg-1 × min-1. | 0 months | 3 months | 6 months
| Group | EXCLUSION: The exclusion criteria were an anticipated absence from work of more than 4 weeks during the 3 months following recruitment, imminent transfer to another station not included in the study, and serious health problems that would have precluded involvement in the health risk assessment. | (Measures at 3, 6, 9, and 12 months which represent different amounts of followup for the 3 intervention groups) | 1) 1:Not available | 1) 1:Not available | 1) 1:NN
| Worksite | | | 2:Not available | 2:NN | 2:Not available
| 364 | | | 3:NN | 3:Not available | 3:IN
| | | | | 6 months | 12 months
| | | | | 1) 1:NN | 1) 1:IN
| | | | | 2:Not available | 2:IN
| | | | | | 3:Not available
Graham-Clarke & Oldenburg, 1994^117^ | Tested lifestyle counseling using videos or videos and self help materials in primary care
A Fresh Start | Randomized | INCLUSION | 1) Energy expenditure (METs)/fortnight. Measured as kilocalories l × kg-1 × hr-1. | | | 12 months
| Group | 1) Both sexes | | | | 1) NN
| Health care | 2) Aged 18–69 years
| 382 | 3) Were assessed to have one or more modifiable cardiovascular disease risk factors
| | EXCLUSION:
| | Suffering from a chronic debilitating disease, were not available for 12 months of followup, or could not speak or write English
Green et al., 2002^61^ | Tested mailed tailored health improvement profile (HIP) report from physician with up to 2 pamphlets and free resource line versus same plus 1 additional mailing and 3 motivational counseling phone calls
| Randomized | INCLUSION: | 1) Change in PA, measured by self-report on the 11 item Patient-centered Assessment and Counseling for Exercise (PACE) survey. | | | 3 months
| Individual | Patients from a large suburban primary care clinic were recruited. Inactive men and women patients aged 20–64 years (Inactive = exercised <15 min per day, even if they exercise daily.)Interested in increasing exercise in the next 6 months | | | | 1) 0.245
| Health care | EXCLUSION:
| 256 | Patients who were already identified as having heart disease or diabetes were not eligible for this study and received a separate intervention. Forty-five additional patients were excluded because they had either disenrolled or moved after completing the questionnaire. Patients were also excluded if they had conditions that would make it unsafe to increase exercise.
Halbert et al., 2000^59^ | Tested advice given by an exercise specialist three times over six months in general practitioner's office to sedentary patients over age 60
Halbert et al. 1999 ^132^ | Randomized | INCLUSION: | 1) Self-reported walking, measured by frequency (sessions/week) | 0 months | | 6 months
The Exercise for Older Adults Project | Individual | 1) Community dwelling men and women aged 60 or older. | 2) Self-reported walking, measured by minutes (minutes/session) | 1) 0.243 | | 1) 0.243
| Health care | 2) Participants had to be healthy | 3) Self-reported vigorous exercise [not defined] (sessions/week) | 2) NN | | 2) NN
| 269 | 3) All subjects had to be sedentary contemplators at study entry. | 4) Self-reported vigorous exercise frequency (minutes/session) | 3) 0.243 | | 3) 0.243
| | 4) Willing to be randomized | 5) Energy expenditure (EE) based on accelerometer, measured as total per day, per day as percent of total EE, during activity per day, or during activity per kg body weight. Adjusted for study group, age, sex, years of education, and household income. | 4) 0.243 | | 4) 0.243
| | EXCLUSION: | | | | 5) NN
| | 1) Patients unable to increase their current level of exercise
| | 2) Patients walked or did forms of brisk exercise 3 or more times per week for 20 minutes or more per time
| | 3) History of stroke or myocardial infarction or history of admission for transient ischemic episode or angina in the previous six months, malignancy or other life threatening disease, inability to cooperate with the requirements of the study, having a condition in which physical activity was contraindicated, or if they were taking any beta-blocker medications.
| | 4) Plans to move away during study period
Harland et al., 1999^135^ | Tested brief or intensive motivational interviewing with or without financial incentive in primary care patients versus control
The Newcastle Exercise Project | Randomized | INCLUSION: | 1) Increase in self-reported PA score, noted as an increase 1 or more levels from baseline. Assessed by a shortened version of National Fitness Survey: level 0 (no sessions), level 1 = 1–4 sessions, level 2 = 5–11 sessions, level 3 ≥ 12 moderate sessions, level 4 > 12 moderate or vigorous sessions, level 5 (≥ 12 sessions vigorous). Activities categorized as moderate (5–7.5 kcal/min) or vigorous (> 7.5 kcal/min). | 0 months | | 9 months
| Individual | Patients aged 40 to 64 years old. | 2) Increased sessions of vigorous PA | 1) 1: 0.638 | | 1) 1: -0.005
| Health care | EXCLUSION: | 3) Increased sessions of moderate PA | 2: 0.402 | | 2: 0.042
| 442 | Patients unable to complete a sub maximal exercise test were excluded (patients with cardiovascular or respiratory disease causing raised risk), as were patients undertaking regular vigorous exercise at least 3 times a week over the previous 6 months. | | 3: 1.029 | | 3: 0.094
| | | | 4: 0.601 | | 4: 0.214
| | | | 2)1: 0.599 | | 2) 1: 0.247
| | | | 2: 0.317 | | 2: 0.383
| | | | 3: 0.981 | | 3: 0.247
| | | | 4: 0.772 | | 4: 0.383
| | | | 3) 1: 0.631 | | 3) 1: 0.075
| | | | 2: 0.402 | | 2: 0.062
| | | | 3: 0.739 | | 3: 0.011
| | | | 4: 0.584 | | 4: 0.238
Hillsdon, et al., 2002^97^ | Tested 30 minutes of brief negotiation (motivational interviewing) or direct advice in middle-aged primary care patients versus no advice at all
| Randomized | INCLUSION: | 1) Mean percent change in energy expenditure, Kilocalories/week. Based on self-reported PA, with a logbook of 36 activities and an energy cost assigned to each activity. Adjusted for baseline energy expenditure, age, gender, health status, employment, education, and home earnings. | | | 4.5 months (interventions 1 & 2 combined) 0.021
| Individual | 1) Aged 45–64 years.
| Health care | 2) Registered with two medical centers in Wellingborough, England.
| 1658 | 3).Did not undertake regular exercise to improve/maintain their health and/or fitness and had done less than 4 occasions of moderate intensity PA in the last 4 weeks.
| | EXCLUSION: They reported a long-standing illness, disability, and/or were permanently sick or disabled and not able to work. Orthopedic, arthritis, and cardiovascular diseases were the most common reasons for medical exclusions.
Howard et al., 1996^56^ | Tested a series of five school-based 40 minute cardiovascular risk education sessions versus no intervention
| Randomized | Children, grades 4 through 6 who attended the participating private parochial school. | 1) Frequency of PA ≥ 30 minutes/week, times per week. Measured by 6-item questionnaire. | | | 12 months
| Group | | 2) Percent reporting that most of their PA is running. | | | 1) -0.464
| School | | 3) Aerobic fitness score, assessed by the Canadian Aerobic Fitness Test (CAFT, 9 minute stepping exercise). Score ranges from 1 (poor) to 5 (excellent) based on recovery pulse and test duration. | | | 2) 0.597
| 98 | | | | | 3) 0.096
Kerse, et al., 1999^60^ | Tested effect of educating general practitioners about health behaviors and well-being of elderly versus no general practitioner education
| Randomized | 1) ≥65 years old | 1) Self-reported walking (minutes/day) | | | 12 months
| Group | 2) English speaking | 2) Self-reported walking (minutes/day as a 5 point scale of quintiles) | | | 1) 0.115
| Health care | 3) Community dwelling | 3) Self-reported walking (minutes/previous fortnight) | | | 2) 0.122
| 267 | 4) Attended practice in last 18 months | 4) Self-reported walking (minutes/previous fortnight as a 3 point scale of tertiles) | | | 3) 0.122
| | 5) Attended the enrolled general practitioner for 3 of the past 5 consultations | 5) Self-reported total activity (minutes/ previous fortnight) | | | 4) 0.122
| | 6) Randomly selected from among patients that could be chosen | 6) Self-reported total activity (minutes/day as a 5 point scale of quintiles) | | | 5) 0.062
| | | 7) Frequency of change in walking (minutes of walking yesterday, range decreased > 20 to increased > 20). | | | 6) 0.071
| | | | | | 7) NN
Keyserling et al., 2002^150^ | Testing 1 mailing (control) versus 4 individual clinic based counseling sessions versus 4 individual clinic based counseling sessions plus 3 community based group counseling sessions and monthly phone calls from a community diabetes educator.
Keyserling et al. 2000^232^ | Randomized | 1) African-American women aged ≥ 40 years | 1) Kilocalories/day attributed to physical activity by accelerometer | 0 months | | 6 months
The New Leaf Program | Individual | 2) Type 2 diabetes, defined as diagnosis of diabetes at ≥ 20 years with no history of ketoacidosis. | (Note: the group with the most intensive intervention is not included in these results because of insufficient followup time) | 1) 0.308 | | 1) 1:0.136
| Health care | | | | | 2:Insufficient followup
| 165
Knutsen & Knutsen, 1991^153^ | Family based advice on diet, smoking, and exercise given twice at home with two followup phone calls and a quarterly newsletter
Knutsen & Knutsen 1989^151^ | Randomized | INCLUSION: | 1) Percent self-reported physically active in leisure (not defined): mean age-adjusted. | | | 48 months
Thelle et al. 1976^154^ | Individual | 1) Men aged 30–55 and their closest family (those living in the same household). | | | | 1) men-0.068
The Tromso Survey: Family Intervention Study | Community | 2) Men with high risk for coronary heart disease without known hypertension, myocardial infarction, or symptoms of intermittent claudication or angina pectoris. | | | | women-0.070
| 1060 men | 3) Female adult living in the same household as the adult males in the Tromso Family Intervention Study | | | | Children 0.044
| 935 women | 4) Children of high-risk males in the Tromso Family Intervention Study
| 1131 children | EXCLUSION:
| | Persons with known coronary heart disease and/or diabetes mellitus or those with chest or calf pain.
Kreuter & Strecher, 1996^155^ | Tested no feedback (control) versus typical or enhanced health risk assessment feedback.
| Randomized | 1) Ages 18–75 | 1) Percent participating in aerobic exercise at least 3 times per week (based on response to questionnaire) | | | 6 months
| Individual | 2) Patient at any one of 8 Independent community-based group family medical practices | | | | 1) 1: -0.009
| Health care | | | | | 2: 0.384
| 1131
Kreuter et al., 2000^133^ | Tested tailored and personalized, personalized and general, or non-personalized general education materials mailed to adult family practice patient versus no materials at all.
Bull et al. 1999 ^134^ | Randomized | Adult patients age ≥ 18 years. | 1) Change in self-reported number of sessions per week subjects participated in > 30 minutes in 8 different categories of PA | | | 3 months
| Individual | | 2) Change in self-reported number of sessions per week subjects participated in > 30 minutes in 4 categories of moderate intensity leisure PA (sports, strengthening exercises, dancing, aerobic-type exercise) | | | 1) 1: 0.329
| Health care | | 3) Change in self-reported number of sessions per week subjects participated in > 30 minutes in 4 categories of daily living PA (childcare, work in the home, home repair, yard work) | | | 2: 0.215
| 203 | | | | | 3: 0.296
| | | | | | 2) 1: 0.198
| | | | | | 2: 0.179
| | | | | | 3: 0.298
| | | | | | 3) 1: 0.246
| | | | | | 2: -0.181
| | | | | | 3: 0.035
Linenger et al., 1991^71^ | Tested multiple environmental changes (paths, equipment, facility hours, etc.) on one Naval Air base against 2 control groups: another Naval air base and a Navy Wide sample.
| Non- randomized | 1) Active duty personnel at Naval Air Station North Island (intervention) or 1 of 2 control groups: Active duty personnel at Naval Air Station Moffett or a Navy wide sample. | 1) Change in time (minutes) for 1.5 mile run | | | 12 months
| Group | 2) Not leaving the Navy or expecting transfer orders or deployment for at least six months. Only those individuals eligible for Physical Readiness Test during the two-month testing period and those who completed surveys. | 2) Change in leisure time Kilocalories expended per week by self report (unclear how assessed) | | | 1)IS
| Other governmental agency | | | | | 2)NN
| 2372
Lombard, et al., 1995^69^ | Tested effect of frequency and structure of telephone prompting in a walking program
The Noontime Walkers Program | Randomized | Staff or faculty at a large southeastern university. No positive answers on the Physical Activity Readiness Questionnaire or physician clearance. | 1) Number of participants walking (walking = 1 day/week for ≥ 20 minutes). | 0 months | | 3 months
| Individual | | 2) Number of participants meeting American College of Sports Medicine (ACSM) cardiovascular exercise goals (walking ≥ 20 minutes/day × 3 days/week). | 1) 1: 0.814 | | 1) 1: 2.089
| School | | | 2: 1.971 | | 2: 2.089
| 135 | | | 3: 0.916 | | 3: 1.307
| | | | 4: 0 | | 4: 1.106
| | | | 2) 1: 0.814 | | 2) 1: 1.837
| | | | 2: 1.269 | | 2: 1.590
| | | | 3: 0.576 | | 3: 0.650
| | | | 4: 0 | | 4: 0.832
Lovibond, et al., 1986^156^ | Tested the effect of a basic, extended or maximal behavioral treatment program
| Randomized | 1) Worked for 3 large government departments in Sydney, Australia | 1) Mean change in aerobic capacity, measured ml/kg/minute. Based on Cooper 12-minute fitness test. | 0 months | | 6 months
| Individual | 2) Attended lunchtime meetings organized by these departments | | 1) 1: IN | | 1) 1: IN
| Worksite | 3) Aged 30 to 60 years | | 2: IN | | 2: IN
| 75 | 4) Willing to undergo a thorough medical exam | | 1 and 2 combined: IS
| | 5) Found to have a high overall risk of coronary heart disease (although free of clinical evidence of disease).
Luepker et al., 1994^49^ | Tested 5 to 6 year community-wide program of mass media, community organization and direct education
Minnesota Heart Health Project | Non-randomized | Those who spoke no English or judged mentally incompetent to participate were ineligible to complete surveys | 1) PA, percent active (“Are you regularly active in your leisure time?” - yes/no). Measured for cross-sectional and cohort surveys. Adjusted within strata and standardized across strata (adjusted for age, education, and gender). | | | 12 months
| Group | | | | | 1) IN for both cross-sectional and cohort surveys
| Community
| 4762
MacKeen et al., 1985^157^ | Tested an 18 month supervised exercise program versus no intervention
Remington et al., 1978^158^ | Randomized | INCLUSION: | 1) Mean jogging/running hours/week for preprogram 1967 and followup 1979. | | | 132 months
Taylor et al., 1973^159^ | Individual | 1) Employee (faculty/staff) of the Penn State or Member of two residential neighborhoods in Minneapolis or faculty for the Wisconsin universities | 2) Aerobic activity (hours/week). | | | 1) 0.013
Cooperative Study on Physical Activity and Cardiovascular Disease | Worksite | 2) Male | 3) Heavy Activity Metabolic Index (Kilocalories/day). | | | 2) 0.000
| Community | 3) Age 40–59 | 4) Total Leisure Activity (Kilocalories/day): Leisure time PA in followup. Data derived from Minnesota Leisure Time PA Interview | | | 3) 0.000
| 104 | 4) Possess two or more risk factors within intermediate ranges | 5) Percent of subjects not exercising to maximum on treadmill at followup. | | | 4) 0.172
| | 5) Live within 55-mile radius of the university/worksite | 6) Maximal Exercise Intensity (METs) at followup | | | 5) -0.076
| | EXCLUSION: | 7) Maximal Oxygen Uptake (mL/kg/min) at followup | | | 6) 0.368
| | 1) Men with one or no risk factor(s) within these ranges were designated normals and those with one or more risk factor(s) beyond the range of eligibility were designated medical exclusions | 8) Maximal Oxygen Uptake (L/min) at followup. | | | 7) 0.454
| | 2) Persons who were extremely active (vigorous PA) | 9) Maximal Heart Rate at followup | | | 8) 0.153
| | 3) Cardiovascular disease or disabilities | | | | 9) 0.055
Marcus, et al., 1998^73^ | Tested four mailings (baseline, one, three and six months) of individually tailored materials versus standard materials
| Randomized | INCLUSION: | 1) Self reported minutes per week of physical activity in last 7 days (calculated from days per week of activity and length of sessions) | 0 months | | 6 months
| Individual | 1) Healthy sedentary men and women (sedentary was defined as failing to meet CDC/ACSM criteria for minimum moderate PA participation 5days/week for 30 minutes or vigorous PA participation 3 days/week for 20 minutes) | 2) Percent meeting CDC/ACSM criteria | 1) 0.424 | | 1) 0.250
| Community | EXCLUSION: | | 2) 0.692 | | 2) 0.382
| 150 | 1) Coronary artery disease, alcoholism or other substance abuse, chronic med and orthopedic problems that would hinder PA
| | 2) Age < 18
| | 3) Current or planned pregnancy
Miller et al., 2002^78^ | Tested print information given to mothers of young children with/without a discussion group on barriers to physical activity in mothers with young children and activities to encourage overcoming those barriers (formation of walking groups, lobbying exercise facilities for childcare or convenient class times) versus no intervention.
| Randomized | Moms of young children who's children were enrolled in the 6 low SES, 9 medium SES, or 6 high SES child care centers that participated in the study. | 1) Percent adequately active PA (≥ 150 minutes of moderate PA per week) with odds ratios measured with 7-day recall from the Active Australia evaluation. | 0 months | | 5 months
| Group | | | 1) 1: 0.099 | | 1) 1: NN
| Community | | | 2: 0.308 | | 2: NN
| 441
Mutrie, et al., 2002^70^ | Tested written interactive materials distributed at work
Walk In to Work Out | Randomized | Employee of 3-city workplaces (large public sector organizations) who responded to a survey and were identified as contemplating or preparing to become more physically active | 1) Time spent walking to work (minutes/week) | | | 6 months
| Individual | | 2) Time spent cycling to work (minutes/week) | | | 1) IS
| Worksite | | | | | 2) NN
| 166
Nader et al., 1989^129^ | Tested twelve weekly and six approximately monthly family meetings at school versus no intervention
San Diego Family Health Project | Randomized | Inclusions: | 1) Energy expenditure, expressed as kilocalories/kg/day, measured by a standardized 7-day recall | | | 12 months
| Group | Families of 5^th^ and 6^th^ grade students at one of 12 participating elementary schools, where family is defined as any group of 1 or more children and 1 or more adults who cohabit and share family functions such as food preparation and socialization of children. | 2) Aerobic power, assessed by modified Astrand Rhyming protocol | | | 1) NN in adults and children
| School | Exclusions: | | | | 2) NN in adults and children
| 183 | Frank hypertension or medical treatment of hypertension or clinical heart disease since the project rationale dictated focusing on the “healthy” family.
O'Loughlin et al., 1996^67^ | Tested single health screening at a worksite
Coeur ensante St-Louis du Parc Project | Non-randomized | All teaching, administrative, and support staff who were employed by the selected elementary schools (grade 1–6) in St-Louis du Parc, Canada | 1) Self-reported leisure time exercise behavior score (sessions per week × intensity weight per session) | | | 4 months
| Group (but analyzed at the individual level) | | | | | 1) 0.034
| Worksite
| 260
Ostwald, 1989^160^ | Tested an all day educational seminar with physical exam, labs, and treadmill with/without three time weekly supervised exercise
| Randomized | Treatment company participants were randomized to mild, moderate, or intensive intervention where mild was the control group | 1) Percent of employees moderately to very active (based on Lifegain Health Practices Survey) | | | 5 months
| Group (but analyzed at individual level) | | 2) Percent of balanced workouts, including strength, endurance, and flexibility. | | | 1) 1: -0.268
| Worksite | | 3) Treadmill test, mean length of time in minutes. | | | 2: 0.423
| 85 | | | | | 2) 1: -0.207
| | | | | | 2: -0.297
| | | | | | 3) IN
Owen, N 1987^161^ | Tested standard 2x weekly 12 week exercise class to same class with self-management curriculum
| Non-randomized | Adults who sign up and pay $70 to take a fitness course | 1) Self reported hours exercised in last week (no further description) | | | 6 months
| Individual | | 2) Self reported exercise sessions per week (no further description) | | | 1) 0.091
| Community | | | | | 2) 0.212
| 147
Owen, N 1987^77^ | Tested single mailing or multi-mailing self-instructional training program versus no mailings (control 1) or a 12 week fitness class (control 2)
| Non-randomized | Men over 35 and women over 40. Those with preexisting health problems had to obtain medical clearance prior to starting the program | 1) Percent of subjects meeting ACSM (1978) criteria for regular, vigorous exercise. | 0 months | | 10 months
| Individual | Treatment group participants had to be willing to pay $20 to participate | 2) Minutes of vigorous exercise/week. | 1)2: 0.510 | | 1)2: -0.042
| Community | | 3) Number of aerobic exercise sessions/week. | 3: 0.061 | | 3: 0.076
| 156 | | (Results reported here for comparison to control group 1 only) | 2)2: IS | | 2)2: IN
| | | | 3: NN | | 3: IN
| | | | 3)2: IN | | 3)2: NN
| | | | 3: IN | | 3: IN
Pereira et al., 1998^64^ | Tested 2 year organized walking program (group or individual by individual's choice) versus no intervention
Kriska et al. 1986^162^ | Randomized | 1) Women aged between 50–65 | 1) Weekly Kilocalories expenditure for “total usual walking” (described as number of blocks and minutes/day for exercise + number of blocks and minutes/day for nonexercise) | 5) 0.542 | | 120 months
| Individual | 2) At least 1 year after cessation of menses | 2) Weekly Kilocalories expenditure for usual walking for exercise | | | 1) 0.371
| Community | 3) Abstention from HRT | 3) Weekly Kilocalories expenditure for sport and recreation | | | 2) 0.371
| 196 | 4) Freedom from physical handicaps that might preclude walking | 4) Weekly Kilocalories expenditure for past-year exercise | | | 3) 0.121
| | | 5) Pafferberg sport and recreation index | | | 4) 0.113
| | | 6) Pafferberg sport and recreation index with walking excluded | | | 5) 0.212
| | | | | | 6) 0.180
Perklo-Makela, 1999^72^ | Tested 2½ months of aerobic training and work issue lectures
| Randomized | Female farmers, 25–45 years of age with moderate musculoskeletal symptoms that had not yet affected their work ability | 1) Leisure-time physical activity (not defined)/week, reported as percent participating less than once a week, once a week, or ≥ 2 times a week | 0 months | 12 months | 36 months
| Individual | | | 1) ≥2 times/wk 0.538 | 1) ≥2 times/wk 0.385 | 1) ≥2 times/wk 0.155
| Health care | | | ≥1 time/wk 0.805 | ≥1 time/wk 0.527 | ≥1 time/wk 0.103
| 105 | | | Overall statistically significant | Overall statistically significant
Sherman et al., 1989^163^ | Tested 30 day worksite-based wellness programs consisting of classes, blood pressure screening, and behavior modification programs versus no intervention
| Non-randomized | Company employee of the small (n=1), medium (n=1), and large (n=1) companies that participated | 1) Percent of participants reporting an increase, decrease, or no change in level of exercise | 0 months | | 3 months
| Individual | | | 1) 0.246 | | 1) -0.069
| Worksite
| 85
Smith et al., 2000^164^ | Tested prescription for exercise from a general practitioner with/without mailed booklet versus no advice at all
The Active Practice project | Non-randomized | INCLUSION: Active and inactive 25–65 year old patients of selected practices | 1) Mean change in PA, mean time in minutes/week preceding survey. [Sum of minutes (≥ 10 minutes) walking and moderate and vigorous PA reported]. | 6 weeks | | 7 months
| Individual | EXCLUSION: | 2) Percent of subjects increasing PA > 60 minutes per week compared with baseline | 1) 1: IN | | 1) 1: IN
| Health care | 1) Patients with poor English | 3) Percent of subjects attaining 3344 Kjoules/week of PA. (This outcome was only reported by ‘treatment received’ not by intention to treat) | 2: IN | | 2: IN
| 1101 | 2) Not supplying a telephone contact # | | 2) 1: 0.132 | | 2) 1: 0.101
| | 3) A contraindication to exercise | | 2: 0.167 | | 2: 0.251
| | 4) Not coming to see the doctor themselves | | 3) 1: IN | | 3) 1: IN
| | 5) Reporting a health problem at followup that prevented 30 minutes of moderate activity | | 2: DN | | 2: IN
| | 6) Being in poor mental state at followup (e.g., intoxicated)
Steptoe et al.,2000^75^ | Tested routine counseling versus behaviorally oriented counseling in primary care patients with coronary risk factors
Steptoe et al. 1999 ^58^ | Randomized | INCLUSION: | 1) Change in number of PA episodes (past 4 weeks) PA described as brisk walking, dancing and aerobics, heavy gardening and housework, lasting ≥ 20 minutes. | 0–4 months | | 8 months
Steptoe et al. 2001^131^ | Group | 1) Patients with at least 1 of the 3 risk factors: Total cholesterol between 6.5 and 9 mmol/l; regular smoking of more than 1 cigarette a day; BMI of 25–35 combined with low physical activity. | | 1)0.426 | | 1)0.437
Hilton et al. 1999^130^ | Health care | 2) Lack of physical activity was defined as fewer than 12 sessions per month of PA at a vigorous level, making the individual breathless, for at least 20 minutes continuously.
| 511 | 3) 18–69 years old, be available for 12 months and have adequate written and spoken English.
| | EXCLUSION:
| | 1) Active followup and/or medication for coronary heart disease, history of cardiovascular disease or peripheral vascular disease (including angina, myocardial infarction, cerebrovascular accident, or transient ischemic attacks), chronic illness including diabetes, thyroid disease, musculo-skeletal, neurological, or respiratory disorders likely to interfere with exercising (patients with asthma were included at the general practitioner discretion),
| | 2) A special diet, lipid-lowering drugs, pregnancy or breastfeeding
| | 3) Serious or terminal illness
| | 4) Psychiatric problems likely to interfere with adherence to the study protocol
Stevens et al.,1998^62^ | Tested in person consultation with an exercise development officer and a personalized 10-week program to increase regular physical activity versus mailing on local ‘leisure centers’
| Randomized | Patients at one particular health clinic, aged 45–74, who returned questionnaire, were physically inactive and not excluded on a medical basis (e.g. being registered as disabled or having heart disease). Physically inactive was defined as less than either of the current recommendations of 20–30 min. moderate intensity activity sessions or 12–20 min. vigorous intensity activity sessions per month. | 1) Mean number of occasions of moderate physical activity in the four weeks before followup | | | 8 months
| Individual | | 2) Mean number of occasions of vigorous physical activity in the four weeks before followup | | | 1)0.306
| Health care | | 3) Mean number of occasions of moderate or vigorous physical activity in the four weeks before followup | | | 2)0.041
| 415 | | | | | 3)0.281

* Number corresponds to outcome number. Months refers to number of months following the end of the intervention. When an effect size could be calculated, it is given. Where the effect size could not be calculated the following code is used to refer to the reported outcomes: IS=statistically significant increase in physical activity, IN=non-statistically significant increase in physical activity, NN=no change in physical activity, DN=non-statistically significant decrease in physical activity, and DS=statistically significant decrease in physical activity. Where there is more than one intervention, the different interventions are noted as #: for example “1:IN 2:IN” represents the results of two interventions. If more than one number or symbol appears for each intervention, the numbers and symbols relate to the results for subgroups. The data is only reported by subgroup when that is the only way the information is presented in the paper.

Evidence Table 2. Cancer survivors (Studies are sorted alphabetically by first author)

First Author/Year | Study Design | Cancer Diagnoses | Intervention Type | Sampling Individual/Group | Non Exercise Intervention Elements | PA Intensity | Length of Intervention | Outcomes Reported
| Intervention Setting | | Timing | (n) Per Group | | PA Mode
| | | PEACE Framework | | | PA Frequency/ Duration
Berglund et al., 1993^92^ | Non-RCT | Breast | Pre-planned exercise | Individual | Relaxation training | Intensity not reported | 8 weeks | Activities in community
| Primary care | Ovarian | Post treatment | (30) Comp 1 | Information | Aerobic activity | | Activities in the home
| | Testicular | Rehabilitation | (30) Intervention 1 | Coping strategies | Strength/ resistance | | Anxiety symptoms
| | | | | | Stretching | | Body image problems
| | | | | | 30–60 minutes 3 days/week | | Change of lifestyle
| | | | | | | | Depressive symptoms
| | | | | | | | Global health
| | | | | | | | Pain
| | | | | | | | Participation in patient organization
| | | | | | | | Physical strength problems
| | | | | | | | Physical training
| | | | | | | | Quality of life
| | | | | | | | Satisfaction about information given
| | | | | | | | Sick leave
| | | | | | | | Tiredness
| | | | | | | | Work status
Berglund et al., 1994^93^ | RCT | Breast | Pre-planned exercise | Individual | Relaxation | Low intensity | 7 weeks | Anxiety
| Unknown | Ovarian | Post treatment | (101) Comp 1 | Diet | Aerobic activity | | Anxious preoccupation
| | Undefined | Rehabilitation | (98) Intervention 1 | Life coping skills | Strength training | | Aversions
| | | | | | Duration not reported 1 day/week | | Avoidance
| | | | | | | | Body image problems
| | | | | | | | Cognitive functioning
| | | | | | | | Communication with staff
| | | | | | | | Depression
| | | | | | | | Fatalistic
| | | | | | | | Fighting spirit
| | | | | | | | Hopeless
| | | | | | | | Information problems
| | | | | | | | Mixed symptoms A
| | | | | | | | Mixed symptoms B
| | | | | | | | Mucous membrane disturbances frequency
| | | | | | | | Pain
| | | | | | | | Physical strength problems
| | | | | | | | Physical training
| | | | | | | | Problems with activities at home
| | | | | | | | Problems with activities in community
| | | | | | | | Quality of life
| | | | | | | | Sexual problems frequency
| | | | | | | | Sick leave
| | | | | | | | Surgery effects
| | | | | | | | Tiredness
| | | | | | | | Work status
| | | | | | | | Worry
Burnham & Wilcox, 2002^86^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Aerobic capacity ml/kg/min
| Unknown | Colon | Post treatment | (6) Comp 1 | | 25–40% heart rate reserve | | Anger
| | | Rehabilitation and health promotion | (6) Intervention 1 | | Aerobic activity | | Anxiety
| | | | (6) Intervention 2 | | 14–32 minutes 3 days/week | | Body fat percent
| | | | | | Intervention 2: | | Body weight
| | | | | | 40–60% heart rate reserve | | Confusion
| | | | | | Aerobic activity | | Depression
| | | | | | 14–32 minutes 3 days/week | | Fatigue
| | | | | | | | Flexibility
| | | | | | | | Personal energy
| | | | | | | | Quality of life
Courneya, et al., 2002^82^ | RCT | All cancers possible | Behavioral | Group | Group psychotherapy | 65–75% maximum heart rate | 10 weeks | Anxiety
Courneya et al., 2003^83^ | Unknown | Breast | Post treatment | (11) Comp 1 | | Aerobic activity | | Attitude
| | | Coping and rehabilitation | (11) Intervention 1 | | 20–30 minutes 3–5 days/week | | Behavioral beliefs
| | | | | | | | Body fat composition
| | | | | | | | Cardiovascular endurance
| | | | | | | | Control beliefs
| | | | | | | | Depression
| | | | | | | | Exercise adherence, continuous
| | | | | | | | Exercise adherence, dichotomous
| | | | | | | | Fatigue
| | | | | | | | Flexibility
| | | | | | | | Intention to exercise
| | | | | | | | Normative beliefs
| | | | | | | | Perceived behavioral control
| | | | | | | | Personality
| | | | | | | | Quality of life
| | | | | | | | Satisfaction with life
| | | | | | | | Subjective norms
Courneya et al., 2003^90^ | RCT | Breast | Pre-planned exercise | Individual | No | 70–75% maximum VO2 | 15 weeks | Body Mass Index
Fairey et al., 2003^100^ | Unknown | | Post treatment | (28) Comp 1 | | Aerobic activity | | Body weight
| | | Rehabilitation and health promotion | (25) Intervention 1 | | 15–35 minutes 3 days/week | | Breast cancer subscale
| | | | | | | | Emotional well-being
| | | | | | | | Fatigue
| | | | | | | | General health
| | | | | | | | Glucose (mmol/liter)
| | | | | | | | Happiness
| | | | | | | | Heart rate (peak)
| | | | | | | | IGF-1:IGFBP-3 molar ratio
| | | | | | | | IGFBP-1 (ng/ml)
| | | | | | | | IGFBP-3 (ng/ml)
| | | | | | | | IGF-I (ng/ml)
| | | | | | | | IGF-II (ng/ml)
| | | | | | | | Insulin (pmol/liter)
| | | | | | | | Insulin Resistance Index
| | | | | | | | Peak power output, Watts
| | | | | | | | Peak VO2 ml/kg/min
| | | | | | | | Physical well-being
| | | | | | | | Power output at the ventilatory equivalent for CO_2_
| | | | | | | | Quality of life
| | | | | | | | Self esteem
| | | | | | | | Social/family wellbeing
| | | | | | | | Sum of skinfolds
| | | | | | | | Trial outcome index score
Cunningham et al., 1986^85^ | RCT | Acute leukemia | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 35 days | Arm fat area
| Primary care | | During treatment | (10) Comp 1 | | Intensity not reported | | Arm muscle area
| | | Coping | (10) Intervention 1 | | Physical therapy exercises | | Body weight
| | | | (10) Intervention 2 | | 30 minutes 3 days/week | | Calorie intake percent of estimated nutrient needs
| | | | | | Intervention 2: | | Changes in excretion of creatinine as a percent of admission measures
| | | | | | Intensity not reported | | Protein intake percent of estimated nutrient needs of admission measure
| | | | | | Physical therapy exercises | | Weekly nitrogen balance (G)
| | | | | | 30 minutes 5 days/week | | Weekly temperature
Dimeo et al., 1997^101^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 50% heart rate reserve | Not clear/day of hospital discharge | Blood transfusions (U)
| Primary care | Germ cell | During treatment | (37) Comp 1 | | Aerobic activity | | Duration of neutropenia (days)
| | Sarcoma | Coping | (33) Intervention 1 | | 30 minutes 7 days/week | | Duration of thrombopenia (days)
| | Lung | | | | | | Heart rate percent estimated maximum
| | Adenoscarcinoma | | | | | | Heart rate (maximal)
| | Neuroblastoma | | | | | | Hematocrit
| | | | | | | | Hemoglobin
| | | | | | | | In-hospital days
| | | | | | | | Loss of physical performance during hospitalization
| | | | | | | | Physical max performance (km/h)
| | | | | | | | Platelets transfusions (U)
| | | | | | | | Severity of diarrhea
| | | | | | | | Severity of infection
| | | | | | | | Severity of mucositis
| | | | | | | | Severity of pain
| | | | | | | | Vigor
Dimeo et al., 1997^102^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | 80% maximum heart rate | 6 weeks | Body Mass Index
| Primary care | Non-small cell lung carcinoma | Post treatment | (16) Comp 1 | | Walking | | Cardiac function and dimensions
| | Sarcoma | Rehabilitation | (16) Intervention 1 | | 15–30 minutes 5 days/week | | Complications
| | Semioma | | | | | | ECG function
| | Non-Hodgkin's lymphoma | | | | | | Fatigue
| | | | | | | | Hemoglobin
| | | | | | | | Physical maximum performance (km/hr)
Dimeo et al., 1999^106^ | RCT | Solid tumors or breast carcinoma | Pre-planned exercise | Individual | Not applicable | 50% heart rate reserve | Not reported/ hospital discharge | Anger/hostility
| Primary care | Metastatic breast carcinoma | During treatment | (33) Comp 1 | | Aerobic activity | | Anxiety
| | Seminoma | Coping | (29) Intervention 1 | | 15 minutes 7 days/week | | Depression
| | Sarcoma/ adenocarcinoma | | | | | | Fatigue
| | Hodgkin's disease | | | | | | Global psychologic distress
| | Non-Hodgkin's lymphoma | | | | | | Hostility
| | Small cell lung carcinoma | | | | | | Interpersonal sensitivity
| | | | | | | | Obsessive compulsive traits
| | | | | | | | Phobic anxiety
| | | | | | | | Somatization
| | | | | | | | Vigor
Djuric et al., 2002^81^ | RCT | Breast | Behavioral | Individual | Diet | Moderate intensity | 12 weeks 84 +/- contacts | Attendance at sessions/telephone counseling
| Community | | Post treatment | (13) Comp 1 | | PA mode not reported | | Body weight change
| | | Health promotion | (10) Comp 2 | | 30–45 minutes 5–7 days/ week | | Body weight loss percent achieving 10%
| | | | (13) Comp 3 | | | | Dietary intakes (kcal/d) energy and fat
| | | | (11) Intervention 1 | | | | Self-report PA
Hayes et al., 2003^104^ | Non-RCT | Acute myeloid leukemia | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 3 months | CD3+ (helper/suppressor T-cell)
| Primary care | Breast | During treatment | (6) Comp 1 | | 70–90% maximum heart rate | | CD4+ (helper T-cells)
| | Multiple myeloma | Rehabilitation | (6) Intervention 1 | | Aerobic activity | | CD8+ (suppressor T-cell)
| | Non-Hodgkin's lymphoma | | | | Strength | | Lymphocytes
| | Lymphoblastic lymphoma/ leukemia | | | | 20–40 minutes 3 days/week | | Ratio CD4+/CD8+
| | Rhabdomyo-sarcoma | | | | Comparison 1: | | T cell function adjusted for CD3+
| | | | | | Intensity not reportedv | | Total T-cell function
| | | | | | Stretching | | White blood cells
| | | | | | 20–40 minutes 3 days/week
MacVicar et al., 1986^112^ | Non-RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1 and 2: | 10 weeks | Anger/hostility
| Unknown | | During treatment | (4) Comp 1 | | 60–85% maximum heart rate on pre-test aerobic assessment | | Confusion/bewilderment
| | | Coping | (6) Intervention 1 (healthy controls) | | Aerobic activity duration not reported | | Depression
| | | | (6) Intervention 2 (cancer survivors) | | 3 days/week | | Fatigue
| | | | | | | | Tension/anxiety
| | | | | | | | Total mood disturbance
| | | | | | | | Vigor
| | | | | | | | VO2 maximum
MacVicar et al., 1989^88^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Heart rate
| Unknown | | During treatment | (16) Comp 1 | | Low intensity | | Maximum test time
| | | Coping | (9) Intervention 1 | | Non-aerobic | | VO2 maximum
| | | | (18) Intervention 2 | | Stretching and flexibility | | Workload maximum
| | | | | | Duration not reported 3 days/week
| | | | | | Intervention 2
| | | | | | 60–80% heart rate reserve
| | | | | | Aerobic activity
| | | | | | 3 days/week
McKenzie et al., 2003^107^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | Intensity not reported | 8 weeks | Arm volume by circumference
| Unknown | | Post treatment | (7) Comp 1 | | Aerobic activity | | Arm volume by water displacement
| | | Rehabilitation and health promotion | (7) Intervention 1 | | Strength/ resistance | | General health quality of life
| | | | | | Stretching | | Mental health quality of life
| | | | | | 30–60 minutes 3 days/week | | Physical functioning quality of life
| | | | | | | | Vitality quality of life
Mock et al., 1994^99^ | RCT | Breast | Behavioral | Individual | Not applicable | Self-paced | 4–6 months | Anxiety
| Home | | During treatment | (5) Comp 1 | | Walking | | Body image
| | | Coping | (9) Intervention 1 | | 10–45 minutes 4–l5 days/week | | Depression
| | | | | | | | Difficulty sleeping
| | | | | | | | Exercise level
| | | | | | | | Fatigue
| | | | | | | | Impact of Medical lllness on subject
| | | | | | | | Nausea
| | | | | | | | Physical functioning
| | | | | | | | Physical functioning (daily activities)
| | | | | | | | Psychologic distress
| | | | | | | | Self-esteem/concept
| | | | | | | | Vomiting
Mock, et al., 1997^94^ | Non-RCT | Breast | Behavioral | Individual | Not applicable | Self-paced | 6 weeks | Anxiety
Mock et al., 1998^98^ | Home | | During treatment | (24) Comp 1 | | Walking | | Body dissatisfaction
| | | Coping | (22) Intervention 1 | | 20–30 minutes 4–5 days/week | | Depression
| | | | | | | | Difficulty sleeping
| | | | | | | | Exercise level
| | | | | | | | Fatigue
| | | | | | | | Physical functioning
Mock et al., 2001^95^ | RCT | Breast | Behavioral | Individual | Not applicable | 50–80% maximum heart rate | 6 weeks | Anxiety
Pickett et al., 2002^96^ | Home | | During treatment | (25) Comp 1 | | Walking | | Depression
| | | Coping | (23) Intervention 1 | | Aerobic activity | | Exercise participation
| | | | | | 15–30 minutes 5–6 days/week | | Exercise tolerance
| | | | | | | | Fatigue
| | | | | | | | Physical activity level
| | | | | | | | Quality of life
| | | | | | | | Total mood disturbance
| | | | | | | | Vigor
Na, 2000^105^ | RCT | Stomach | Pre-planned exercise | Individual | Not applicable | Intensity not reported | 2 weeks | Natural Killer cell cytotoxic activity (NKCA)
| Hospital/ primary care | | During treatment | (18) Comp | | Aerobic activity
| | | Rehabilitation | (17) Intervention | | 60–80 minutes 4–5 days/ week
Nieman et al., 1995^103^ | RCT | Breast | Pre-planned exercise | Individual | Not applicable | 75% maximum heart rate | 8 weeks | E: T20: 1 (mononuclear cells to cancer cell ratio NKCA or % lysis)
| Unknown | | Post treatment | (8) Comp 1 | | Walking | | E: T40:1 (mononuclear cells to cancer cell ratio NKCA % lysis)
| | | Survival | (8) Intervention 1 | | Strength/ resistance | | Heart rate
| | | | | | 60 minutes 3 days/week | | Leg extension strength
| | | | | | | | Lymphocytes
| | | | | | | | Neutrophils
| | | | | | | | NK cell cytotoxic activity % lysis
| | | | | | | | NK cells
| | | | | | | | Physical functioning
| | | | | | | | T-cells
| | | | | | | | Total leukocytes
Segal et al., 2001^87^ | RCT | Breast | Behavioral and pre- planned exercise | Individual | Not applicable | 50–60% maximum VO2 | 26 weeks | Aerobic capacity
| Primary carev | | During treatment | (41) Comp 1 | | Walking | | Physical functioning
| | | Coping | (40) Intervention 1: Self-directed exercise | | Duration not reported 5 days/week | | General health quality of life
| | | | (42) Intervention 2: Supervised exercise | | | | Quality of life
| | | | | | | | Mental health
| | | | | | | | Role limitations, emotional
| | | | | | | | Role limitations, physical
| | | | | | | | Body weight
| | | | | | | | Bodily pain
| | | | | | | | Vitality quality of life
| | | | | | | | Social functioning
Segal et al., 2003^91^ | RCT | Prostate | Pre-planned exercise | Individual | Not applicable | 60–70% one repetition maximum | 12 weeks | Muscular fitness
| Primary care | | During treatment | (73) Comp 1 | | Strength/ resistance: 8 exercises, 2 sets each, 8–12 repetitions | | Fatigue
| | | Coping | (82) Intervention 1 | | Duration not reported 3 days/week | | Quality of life health-related
| | | | | | | | PSA levels
| | | | | | | | Testosterone
| | | | | | | | Body Mass Index
| | | | | | | | Body weight
| | | | | | | | Skinfolds
| | | | | | | | Waist circumference
Segar et al., 1998^84^ | RCT | Breast | Pre-planned exercise | Individual | Behavior modification | ≥60% maximum heart rate | 10 weeks | Anxiety
| Home | | Post treatment | (10) Comp 1 | | Aerobic activity | | Depression
| | | Rehabilitation and health | (10) Intervention 1 | | 30 minutes 4 days/week | | Exercise adherence (min)
| | | | (10) Intervention 2: Exercise plus behavior modification | | | | Self-esteem
Wall, 2000^213^ | RCT | Lung | Pre-planned exercise | Individual | Not applicable | Intensity not reported | 7–10 days | Hope [Herth Hope Index HHI]
| | | Pre- treatment | (51) Comp 1 | | Aerobic activity | | Power (personal not PA related)
| | | Buffering | (53) Intervention 1 | | Strength/ resistance
| | | | | | Duration not reported 7 days/week
Winningham et al., 1988^89^ | RCT | Breast | Pre-planned Exercise | Individual | Not applicable | Intervention 1: | 10 weeks | Percent body fat
Winningham et al., 1989^108^ | Unknown | | During treatment | (12) Comp 1 | | Intensity not reported | | Body weight
| | | Coping | (14) Intervention 1 | | Stretching | | Lean body weight
| | | | (16) Intervention 2 | | Duration not reported | | Nausea
| | | | | | 3 days/week | | Somatization
| | | | | | Intervention 2: | | Subcutaneous body fat distribution
| | | | | | 60–85% maximum heart rate | | Sum of skinfolds
| | | | | | Aerobic activity
| | | | | | 20–30 minutes 3 days/week