# Appendix D Characteristics of Physical Activity Interventions in the Studies of the General Population

(Studies are sorted by intervention setting)

Author/Year | Groups | Intervention Setting | Intervention Length | Intervention Tailoring | PA Location | Behavioral Components | Theory
| | Intervention Mode | | Additional Intervention Elements | PA Intensity | Environmental Components
| | Intervention Delivery | | | PA Frequency/Duration
| | | | | PA Mode
Hillsdon et al., 2002^97^ | 1 | Primary/health care | 1 30-minute session in person | Stage of change | Not specified | Written feedback/verbal encouragement | Motivational Interviewing
| | Home/telephone | 6 3-minute motivational interviewing phone consultations over 34 weeks | None | Not specified | Benefits and barriers
| | In person | | | Not specified | Assessment of motivation and confidence
| | Telephone | | | Not specified | Exploring concerns about taking up regular PA
| | Health promotion specialist | | | | Helping with decision making
| | Unknown telephone caller | | | | None
| 2 | Primary/health care | 1 30-minute session in person | None | Not specified | Education on why one should exercise | Health Belief Model
| | Home/telephone | 6 3-minute phone consultations over 34 weeks to give direct advice | None | Moderate Intensity | None
| | In person | | | 5 days/week 30 minutes
| | Telephone | | | Aerobic activity
| | Health promotion specialist
| | Unknown telephone caller
Bull et al., 1998^113^ | 1 | Primary/health care | 1 3-minute physician advice session | None | Not specified | Education on why one should exercise | Transtheoretical Model
Bull et al., 1999^57^ | | In person | 1 mailed standardized pamphlet | None | Moderate Intensity | Education on normal response to exercise | Social Cognitive Theory
| | Mail | | | 5 days/week 30 minutes | Benefits and barriers
| | Family physician | | | Not specified | Written feedback/verbal encouragement
| | Pamphlet | | | | Self efficacy enhancement
| | | | | | Problem solving
| | | | | | Education on how to exercise
| | | | | | Injury concerns were discussed
| | | | | | None
| 2 | Primary/health care | 1 3-minute physician advice session | Stage of change | Not specified | Education on normal response to exercise | Transtheoretical Model
| | In person | 1 mailed tailored pamphlet | Other psychological variables | Moderate intensity | Education on why one should exercise | Social Cognitive Theory
| | Mail | | None | 5 days/week 30 minutes | Benefits and barriers
| | Family physician | | | Not specified | Self efficacy enhancement
| | Pamphlet | | | | Education on how to exercise
| | | | | | Written feedback/verbal encouragement
| | | | | | Problem solving
| | | | | | None
Steptoe et al., 2000^75^ | Control | Primary/health care | 1 contact: ‘usual care’ in a primary care clinic | None | Not specified | Benefits and barriers | None
Steptoe et al., 1999^58^ | | In person | | Diet | Moderate to vigorous | Written feedback/verbal encouragement
Steptoe et al. 2001^131^ | | Nurse | | Smoking cessation | 12 sessions per month | Suggestions about different activities
Hilton et al., 1999^130^ | | | | | Not specified | Education on why one should exercise
| | | | | | None
| 1 | Primary care/health care | 3–6 contacts: | Stage of change | Not specified | Skill building | Transtheoretical Model
| | In person | 1 ‘usual care’ visit with a nurse in a primary care clinic | Diet | Moderate intensity | Incentives and contracts
| | Nurse | 2–3 20-minute counseling sessions | Smoking cessation | 12 sessions per month | Self monitoring
| | | 1–2 phone consultations to encourage behavior change | | Not specified | Goal setting
| | | | | | Relapse prevention
| | | | | | Benefits and barriers
| | | | | | Education on why one should exercise
| | | | | | None
Kreuter & Strecher, 1996^155^ | 1 | Primary/health care | 1 physician office visit | None | Not specified | Written feedback/verbal encouragement | None
| | Computerized feedback system | 1 mailing | Diet | Not specified | Education on why one should exercise
| | Mail | | Smoking cessation | Not specified | None
| | Physician | | | Not specified
| | Mailing
| 2 | Primary/health care | 1 physician office visit | Risk factor status | Not specified | Written feedback/verbal encouragement | Health Belief Model
| | Computerized feedback system | 1 mailing | Stage of change | Not specified | Benefits and barriers | Transtheoretical Model
| | Mail | | Other psychological variables | Not specified | Relapse prevention
| | Physician | | Diet | Not specified | Education on why one should exercise
| | Mailing | | Smoking cessation | | None
Halbert et al., 1999^132^ | Control | Primary/health care | 20-minute diet counseling session with exercise specialist | None | Not specified | None | None
Halbert et al., 2000^59^ | | Not specified | May have received exercise advice from physician | Diet | Not specified | None
| | Possibly physician advice | | | Not specified
| | Exercise specialist | | | Not specified
| 1 | Primary/health care | 3 visits with the exercise specialist (baseline, 3 months, 6 months) | Individualized based on progress, enthusiasm, health | Not specified | Benefits and barriers | None
| | In person | May have received exercise advice from physician | None | Moderate Intensity | Self efficacy enhancement
| | Possibly physician advice | | | 3+ days/week 20+ minutes | Goal setting
| | Exercise specialist | | | Aerobic | Self monitoring
| | | | | | Education on why one should exercise
| | | | | | None
Harland et al., 1999^135^ | Control | Primary/health care | 1 contact: | Results of baseline fitness testing | Not specified | Written feedback/verbal encouragement | None
| | In person | Test results packet with information on health habits, leaflets on local exercise opportunities, and brief advice targeted by test results | Diet | Not specified | Benefits and barriers
| | Not specified | | Smoking cessation | Not specified | Education on why one should exercise
| | | | | Not specified | Information on local exercise opportunities
| | | | | | None
| 1 | Primary/health care or exercise facility (participant choice) | 2 contacts: | Results of baseline fitness testing | Not specified | Benefits and barriers | Motivational Interviewing
| | In person | Test results packet with information on health habits, leaflets on local exercise opportunities, and brief advice targeted by test results plus 1 40-minute motivational interview within 2 weeks | Stage of change | Not specified | Education on why one should exercise | Transtheoretical Model
| | Health visitor | | Diet | Not specified | Written feedback/verbal encouragement
| | | | Smoking cessation | Not specified | None
| 2 | Primary/health care or exercise facility (participant choice) | 2 contacts: | Results of baseline fitness testing | Not specified | Benefits and barriers | Motivational Interviewing
| | In person | Test results packet with information on health habits, leaflets on local exercise opportunities, and brief advice targeted by test results plus 1 40-minute motivational interview within 2 weeks plus 30 vouchers entitling free access to exercise facility | Stage of change | Not specified | Incentives and contracts | Transtheoretical Model
| | Health visitor | | Diet | Not specified | Written feedback/verbal encouragement
| | | | Smoking cessation | Not specified | Education on why one should exercise
| | | | | | Accessibility
| 3 | Primary/health care or exercise facility (participant choice) | 6 contacts in 3 months: | Results of baseline fitness testing | Not specified | Benefits and barriers | Motivational Interviewing
| | In person | Test results packet with information on health habits, leaflets on local exercise opportunities, and brief advice targeted by test results plus 5 40-minute motivational interview over 12 weeks | Stage of change | Not specified | Written feedback/verbal encouragement | Transtheoretical Model
| | Mail | | Diet | Not specified | Education on why one should exercise
| | Health visitor | | Smoking cessation | Not specified | None
| 4 | Primary/health care or exercise facility (participant choice) | 6 contacts in 3 months: | Results of baseline fitness testing | Not specified | Incentives and contracts | Motivational Interviewing
| | In person | Test results packet with information on health habits, leaflets on local exercise opportunities, and brief advice targeted by test results plus 5 40-minute motivational interview over 12 weeks PLUS 30 vouchers entitling free access to exercise facility | Stage of change | Not specified | Benefits and barriers | Transtheoretical Model
| | Mail | | Diet | Not specified | Written feedback/verbal encouragement
| | Health visitor | | Smoking cessation | Not specified | Education on why one should exercise
| | | | | | Accessibility
Kerse et al., 1999^60^ | 1 | Primary/health care | Not specified (Intervention to doctors was 5 sessions over 2–3 months. Intervention to patients (from doctors) not described) | None | Not specified | Not specified | None
| | In person | | None | Not specified | None
| | Not specified | | | Not specified
| | | | | Not specified
Eckstrom et al., 1999^136^ | 1 | Primary/health care | Not specified | Stage of change | Not specified | Not specified | Transtheoretical Model
| | In person | | None | Not specified | None
| | Physician advice | | | Not specified
| | | | | Not specified
Graham-Clarke & Oldenburg, 1994^117^ | 1 | Primary/health care | 1 video | Stage of change | Not Specified | Education on why one should exercise | Transtheoretical Model
A Fresh Start | | In person | 1 health risk assessment | Risk factor status | Not specified | Benefits and barriers
| | General practitioner | | Diet | Not specified | Self monitoring
| | | | Smoking cessation | Not specified | Goal setting
| | | | | | Skill building
| | | | | | Education on normal response to exercise
| | | | | | Education on how to exercise
| | | | | | Relapse prevention
| | | | | | None
| 2 | Primary/health care | 1 Health Risk Assessment | Stage of change | Not specified | Education on why one should exercise | Transtheoretical Model
| | In person | 1 video | Risk factor status | Not specified | Benefits and barriers
| | General practitioner | 1 set of self-help booklets | Diet | Not specified | Self monitoring
| | | | Smoking cessation | Not specified | Goal setting
| | | | | | Skill building
| | | | | | Education on normal response to exercise
| | | | | | Education on how to exercise
| | | | | | Relapse prevention
| | | | | | None
Green et al., 2002^61^ | Control | Primary/health care | 1 mailing | Risk factor status | Not specified | None | None
| | Mailing | | Diet | Not specified | None
| | Physician signed letter | | Smoking cessation | Not specified
| | | | | Not specified
| 1 | Primary/health care | 5 contacts in 3 months: | Risk factor status | Not specified | Benefits and barriers | Transtheoretical Model
| | Phone call | 2 mailings | Diet | Moderate intensity | Goal setting
| | Mail | 3 motivational counseling phone calls (20–30 minutes each) | Smoking cessation | Frequency not reported 30 minutes | Problem solving
| | Telephone | | | Not specified | Social support
| | Physician | | | | None
| | Behavioral health specialist
Keyserling et al., 2002^150^ | Control | Primary/health care | 1 mailing | None | Not specified | None | None
Keyserling et al., 2000^232^ | | Mail | | Diet | Not specified | None
| | American Diabetes Association pamphlets | | | Not specified
| | | | | Not specified
| 1 | Primary/health care | 4 individual clinic based counseling sessions in 6 months | Individualized counseling | Not specified | Benefits and barriers | Behavior Change Theory
| | In person | | Disability status (chair exercises for non-ambulatory participants) | Moderate intensity | Goal setting
| | Counselor | | Diet | 7 days/week 30 minutes | Self-monitoring
| | | | | Aerobic and non-aerobic activity | Education on why one should exercise
| | | | | | Written feedback/verbal encouragement
| | | | | | Problem solving
| | | | | | None
(Note: this group is NOT included in the analysis because they had no 3 month followup) | 2 | Primary health care | 19 contacts over 12 months: | Individualized counseling | Not specified | Social Support | Behavior Change Theory
| | Community | 4 individual clinic based counseling sessions in 6 months | Disability status (chair exercises for non-ambulatory participants) | Moderate intensity | Benefits and barriers
| | In person | 3 group sessions over 12 months | Diet | 7 days/week 30 minutes | Goal setting
| | Telephone | 12 monthly calls from community diabetes educator | | Aerobic and non-aerobic activity | Self-monitoring
| | Counselors | | | | Education on why one should exercise
| | Community Diabetes Educators | | | | Written feedback/verbal encouragement
| | | | | | Problem solving
| | | | | | None
Smith et al., 2000^164^ | 1 | Primary/health care | 1 physician's visit with physical activity advice | None | Not specified | None | None
| | In person | | None | Not specified | None
| | General practitioner | | | Not specified
| | | | | Not specified
| 2 | Primary/health care | 2 contacts in 6–10 weeks: | Stage of change | Not specified | None | Transtheoretical Model
| | In person | 1 physician's visit with physical activity advice | None | Not specified | None
| | Mail | 1 stage matched brochure mailed home 2 weeks later | | Not specified
| | General practitioner | | | Not specified
| | Booklet
Knutsen & Knutsen, 1989^151^ | 1 | Primary/health care | 2 years: | None | Not specified | Education on why one should exercise | None
Knutsen & Knutsen, 1991^152^ | | Home | 1 letter | Diet | Not specified | Education on available community opportunities for physical activity
Thelle et al., 1976^154^ | | In person | 2 home visits (1 from a physician, 1 from a dietician) | Smoking cessation | Not specified | None
| | Mail | 2 phone calls | | Not specified
| | Unknown letter writer | 8 newsletters
| | Home-visit physicians | Offer of repeated lipid testing at 2 years
| | Newsletters
Luepker et al., 1994^49^ | 1 | Community | 5 years: | None | Not specified | Written feedback/verbal encouragement | Social Learning Theory
Jacobs et al., 1986^142^ | | Worksite | Community wide interventions with multiple individual programs | Diet | Not specified | Skill building | Diffusion of innovation theory
Mittelmark et al., 1986^144^ | | School | | Smoking cessation | Not specified | Education on why one should exercise
Carlaw et al., 1984^141^ | | Telephone | | | Not specified | Modeling
| | In person | | | | Social support
| | Mass media | | | | Incentives and contracts
| | Not specified | | | | Social marketing
| | | | | | None
Miller et al., 2002^78^ | 1 | Community | 1 mailing | None | Not specified | Benefits and barriers | None
| | Mail | | None | Not specified | Education on why one should exercise
| | Mail | | | Not specified | None
| | | | | Not specified
| 2 | Community | 1 discussion session to explore barriers to physical activity participation in moms with young children | None | Not specified | Benefits and barriers | None
| | Preschools/childcare center | 1 mailing | None | Not specified | Social support / networking
| | In person | 1 phone call after group discussion | | Not specified | Provision of equipment
| | Mail | Postings on bulletin boards at childcare centers as to physical activity opportunities | | Not specified | Social advocacy
| | Mail | Other intervention activities less well defined | | | Capacity building
| | Other moms | | | | Lobbying exercise providers to provide childcare or convenient class times
| | | | | | Formation of walking groups
| | | | | | Education on why one should exercise
| | | | | | Accessibility
Caserta & Gillett, 1998^115^ | 1 | Community | 64 classes in 16 weeks | None | Not specified | Social support | None
Gillet et al., 1996^63^ | | In person | | None | Vigorous intensity | Education on normal response to exercise
Gillet & Caserta, 1996^79^ | | Experienced geriatric nurse practitioner | | | 3 days/week 30 minutes | Education on why one should exercise
| | | | | Aerobic and non-aerobic activity | Self monitoring
| | | | | | Written feedback/verbal encouragement
| | | | | | Accessibility
| 2 | Community | 16 classes in 16 weeks | None | Home | Self monitoring | None
| | In Person | | None | Vigorous intensity | Education on normal response to exercise
| | Experienced geriatric nurse practitioner | | | 3–5 days/week 30 minutes | Written feedback/verbal encouragement
| | | | | Aerobic activity | Education on why one should exercise
| | | | | | None
Elder et al., 1995^148^ | 1 | Community | 11+ contacts in 24 months: | Individualized by exercise preferences or goals | Not specified | Goal setting | Social Learning Theory
Mayer et al., 1994^233^ | | In person/phone | Health risk assessment feedback counseling | Risk factor status | Moderate | Written feedback/verbal encouragement | Kanfer's model of Self-Control & Self-Change Model
| | Counselors were students in public health/health sciences. Classroom facilitators were project coordinator, students, & retired health professionals. | 1 set written materials | Diet | 30 minutes 3x weekly | Skill building
| | | 2 followup phone calls at 5 month intervals | Home safety | Aerobic | Education on why one should exercise
| | | 8 health education classes | Motor vehicle safety | | Problem solving
| | | | | | Self-monitoring
| | | | | | Self-evaluation
| | | | | | Self-reinforcement
| | | | | | None
Godin et al., 1987^116^ | 1 | Community | 2 contacts: | None | Not specified | None | None
| | In person | 1 lab visit for fitness test | None | Not specified | None
| | Not specified | 1 lab visit to hear results of test | | Not specified
| | | | | Not specified
| 2 | Community | 2 contacts: | Individualized | Not specified | None | None
| | In person | 1 lab visit for fitness test and health age appraisal | None | Not specified | None
| | Not specified | 1 lab visit to hear results | | Not specified
| | | | | Not specified
| 3 | Community | 2 contacts: | Individualized | Not specified | None | None
| | In person | 1 lab visit for health age appraisal | None | Not specified | None
| | Not specified | 1 lab visit to hear results | | Not specified
| | | | | Not specified
Owen et al., 1987^161^ | Control | Community | 24 classes over 12 weeks | Schedule/time preference | Exercise facility | None | None
| | In person | | None | Moderate intensity | None
| | Certified fitness instructors | | | 2 days/week 60 minutes
| | | | | Aerobic
| 1 | Community | 24 classes over 12 weeks | Schedule/time preference | Exercise facility | Benefits and barriers | None
| | In person | 1 meeting with certified fitness instructor | None | Home | Education on why one should exercise
| | Certified fitness instructors | 2 homework assignments | | Moderate intensity | Goal setting
| | | | | 2 days/week 60 minutes | Problem solving
| | | | | Aerobic | Education on normal response to exercise
| | | | | | Self-management
| | | | | | Self monitoring
| | | | | | Planning a personal schedule of programmed exercise
| | | | | | Resuming exercise safely after time off
| | | | | | Planning future exercise patterns
| | | | | | Gradual fading of instructor guidance
| | | | | | Education on how to exercise
| | | | | | None
Owen et al., 1987^77^ | Control 1 | Community | No intervention: control group was made up of those who were offered an intervention but then refused intervention | Not applicable | Not applicable | Not applicable | Not applicable
| | Not applicable | | Not applicable | Not applicable | Not applicable
| | Not applicable | | | Not applicable
| | | | | Not applicable
(This second external comparison group is not included in the results or evidence table) | Control 2 | Community | 24 fitness classes in 12 weeks (2 days/ week) | None | Community | “Program contained elements derived from behavioral theories and emphasized training in self-management methods” ^77^ | None
| | In person | | None | Not specified | None
| | Qualified fitness instructor | | | 2 days/week
| | | | | Aerobic and non-aerobic activity
| 2 | Community | 2 mailings in 12 weeks | None | Not specified | Planning strategies | None
| | Mail | | None | Not specified | Setting up environmental cues to exercise
| | Not specified | | | Not specified | Self-reinforcement
| | | | | Aerobic and non-aerobic activity | Self-talk strategies
| | | | | | Education on normal response to exercise
| | | | | | Education on why one should exercise
| | | | | | Benefits and barriers
| | | | | | Relapse prevention
| | | | | | Incentives and contracts
| | | | | | Self monitoring
| | | | | | Problem solving
| | | | | | None
| 3 | Community | 7 mailings in 12 weeks (The only difference between groups 2 and 3 was spreading out the mailings differently) | None | Not specified | Planning strategies | None
| | Mail | | None | Not specified | Setting up environmental cues to exercise
| | Not specified | | | Not specified | Self-reinforcement
| | | | | Aerobic and non-aerobic activity | Self-talk strategies
| | | | | | Education on normal response to exercise
| | | | | | Education on why one should exercise
| | | | | | Benefits and barriers
| | | | | | Relapse prevention
| | | | | | Incentives and contracts
| | | | | | Self monitoring
| | | | | | Problem solving
| | | | | | None
Pereira et al., 1998^64^ | 1 | Community | 16+ contacts in 2 years: | Preference of walking alone or in a group | Community | Social support | None
Kriska et al., 1986^162^ | | Mail | 16 group walking sessions in 1^st^ 8 weeks followed by ‘frequent’ social gatherings, phone calls, letters, and occasional home visits over the remainder of the 2 year intervention | None | Moderate intensity | Goal setting
| | Telephone | | | 7 miles walked per week | Incentives and contracts
| | In person | | | Aerobic activity | Problem solving
| | Exercise leader | | | | Written feedback/verbal encouragement
| | Unknown caller | | | | None
| | Peers
| | Unknown home visitor
Eaton et al., 1999^50^ | 1 | Community | 7 years: | Reading level | Community, schools, worksites, churches | Social support | Social Learning Theory
Carleton et al., 1995^166^ | | Worksite | Community wide intervention with 3 specific physical activity interventions: Exercity, Get Fit, and Imagine Action | Stage of change | Moderate intensity | Skill building | Transtheoretical Model
Carleton et al., 1987^165^ | | School | | Diet | 3–5 days/week 15–60 minutes | Education on why one should exercise
McGraw et al., 1989^169^ | | Religious institutions | | Smoking cessation | Aerobic activity | Maintenance strategies
Marcus et al., 1992^167^ | | In person | | | | Self monitoring
Levin et al., 1998^168^ | | Mail | | | | Goal setting
Pawtucket Heart Health Program | | Volunteer peers | | | | Self-reinforcement
| | Local media | | | | Written feedback/verbal encouragement
| | Health educators and counselors | | | | Benefits and barriers
| | Community recreation programs | | | | Relapse prevention
| | | | | | Problem solving
| | | | | | Incentives and contracts
| | | | | | Self efficacy enhancement
| | | | | | Accessibility
Belisle et al., 1987^74^ | Control | Community/sports center | 20 contacts in 10 weeks | None | Exercise facility | Skill building | None
| | In person | | None | Not specified | Injuries
| | Exercise leader | | | Not specified | Importance of regular program attendance
| | | | | 3 days/week 45–50 minutes | Education on normal response to exercise
| | | | | Aerobic and non-aerobic activity | Education on why one should exercise
| | | | | | Accessibility
| 1 | Community/sports center | 20 contacts in 10 weeks: | None | Exercise facility | Relapse prevention | Relapse Prevention Model
| | In person | Health education content is the only difference between the 2 groups | None | Not specified | Problem solving
| | Exercise leader | | | Not specified | Self monitoring
| | | | | 3 days/week 45–50 minutes | Education on why one should exercise
| | | | | Aerobic and non-aerobic activity | Energy expenditure of various activities
| | | | | | Keeping record/habit maintenance
| | | | | | Critical situations
| | | | | | Awareness of abstinence violation effect
| | | | | | Education on normal response to exercise
| | | | | | Self management
| | | | | | Skill building
| | | | | | Accessibility
Belisle et al., 1987^74^ | Control | Community/sports center | 11–14 contacts in 10 weeks | None | Exercise facility | Skill building | None
| | In person | | None | Not specified | Injuries
| | Exercise leader | | | Not specified | Importance of regular program attendance
| | | | | 3 days/week 45–50 minutes | Education on normal response to exercise
| | | | | Aerobic and non-aerobic activity | Education on why one should exercise
| | | | | | Accessibility
| 1 | Community/sports center | 11–14 contacts in 10 weeks | None | Exercise facility | Relapse prevention | Relapse Prevention Model
| | In person | | None | Not specified | Problem solving
| | Exercise leader | | | Not specified | Self monitoring
| | | | | 3 days/week 45–50 minutes | Education on why one should exercise
| | | | | Aerobic and non-aerobic activity | Energy expenditure of various activities
| | | | | | Keeping record/habit maintenance
| | | | | | Critical situations
| | | | | | Awareness of abstinence violation effect
| | | | | | Education on normal response to exercise
| | | | | | Self management
| | | | | | Skill building
| | | | | | Accessibility
Kreuter et al., 2000^133^ | 1 | Primary care/home | 1 mailing (general, not personalized) | None | Not specified | Education on why one should exercise | Transtheoretical Model
Bull et al. 1999 ^134^ | | Mail | | Diet | Not specified | Ways to begin and maintain physical activity
| | Mail | | Smoking cessation | Not specified | Benefits and barriers
| | | | | Aerobic activity | Following a 3 month physical activity plan
| | | | | | None
| 2 | Primary care/home | 1 mailing general advice, personalized by having name of patient printed on top of first page | Generic material but personalized using the patient's name | Not specified | Education on why one should exercise | Transtheoretical Model
| | Mail | | Diet | Not specified | Ways to begin and maintain physical activity
| | Mail | | Smoking cessation | Not specified | Benefits and barriers
| | | | | Aerobic activity | Following a 3 month physical activity plan
| | | | | | None
| 3 | Primary care/home | 1 mailing | Stage of change | Not specified | Education on why one should exercise | Transtheoretical Model
| | Mail | Personalized and individualized advice according to answers to physical activity survey | Exercise preferences and goals | Not specified | Ways to begin and maintain physical activity
| | Mail | | Diet | Not specified | Benefits and barriers
| | | | Smoking cessation | Not specified | Following a 3 month physical activity plan
| | | | | | Caloric expenditure of preferred activity
| | | | | | Specific physical activity goal set by patient
| | | | | | Types of physical activity patient preferred
| | | | | | None
Marcus et al., 1998^73^ | Control | Home | 4 mailings in 6 months: General self-help | None | Not specified | Education on why it is important to exercise | None
Bock et al., 2001^114^ | | Mail | | None | Not specified | Skill building
| | AHA self-help manuals | | | Not specified | Goal setting
| | | | | Not specified | Education on how to exercise safely
| | | | | | Relapse prevention
| | | | | | How to use rewards
| | | | | | None
| 1 | Home | 4 mailings in 6 months: | Stage of change | Not specified | Education on why it is important to exercise | Transtheoretical Model
| | Mail | Tailored stage matched self-help | None | Moderate intensity | Modeling
| | Computerized feedback system | | | 5 days/week 30 minutes | Written feedback/verbal encouragement
| | Individualized self-help materials | | | Aerobic activity | Incentives and contracts
| | | | | | Self efficacy enhancement
| | | | | | Benefits and barriers
| | | | | | Social support
| | | | | | None
Blalock et al., 2000^76^ | Control | Home | 1 mailing | None | Not specified | Education on why one should exercise | None
| | Mail | | Diet | Not specified | None
| | Brochure | | | Not specified
| | | | | Not specified
| 1 | Home | 2 mailings | None | Not specified | Education on why one should exercise (information only) | None
| | Mail | | Diet | Not specified
| | Brochure | | | Not specified
| | | | | Not specified
| 2 | Home | 2 mailings | None | Not specified | Action plan behavioral focus | Precautions adoption process model
| | Mail | | Diet | Not specified | Education on why one should exercise
| | Brochure | | | Not specified | Goal setting
| | | | | Not specified | Benefits and barriers
| | | | | | None
| 3 | Home | 2 mailings | None | Not specified | Information PLUS action plan with behavioral focus | Precaution adoption process model
| | Mail | | Diet | Not specified | Education on why one should exercise
| | Brochure | | | Not specified | Goal setting
| | | | | Not specified | Benefits and barriers
| | | | | | None
Chen et al., 1998^145^ | Control | Home | 1 mailing | None | Not specified | Incentives and contracts | None
| | Mail | 1 5 minute phone call | None | Moderate intensity | Education on why one should exercise
| | Telephone | | | Not specified | Benefits and barriers
| | Not specified | | | Aerobic activity | Education on how to exercise
| | | | | | None
| 1 | Home | 6 20–30 minute phone calls | Individual tailoring | Not specified | Self-efficacy | Social Cognitive Theory
| | Mail | 6 mailings over 5 weeks | None | Moderate intensity | Education on how to exercise
| | Telephone | | | 3–5 days/week 30–60 minutes | Goal setting
| | Trained telephone counselors | | | Aerobic activity | Social support
| | | | | | Skill building
| | | | | | Benefits and barriers
| | | | | | Relapse prevention
| | | | | | Incentives and contracts
| | | | | | Education on why one should exercise
| | | | | | Problem solving
| | | | | | Written feedback/verbal encouragement
| | | | | | None
Burke et al., 1998^65^ | Control | School | 2 10 week school terms | None | School | None | None
| | Not specified | | None | Not specified | None
| | Not specified | | | 3–5 days/week not specified
| | | | | Not specified
| 1 | School | 2 10 week school terms | Fitness levels | School | There were 6 classroom lessons to ‘establish a rationale’ for the physical activity program. It is likely that the content was behavioral, but the specifics are not provided. | None
| | In person | ‘WASPAN’ program only | Diet | Not specified | None
| | Teachers | | | 3–5 days/week 15–25 minutes/ session
| | | | | Not specified
| 2 | School | 2 10 week school terms | Fitness levels | School | Goal setting | None
| | In person | ‘WASPAN’ program PLUS enrichment, which involved parents for monitoring and encouragement | Exercise preferences | Home | Written feedback/verbal encouragement
| | Teachers | | Diet | Not specified | There were 6 classroom lessons to ‘establish a rationale’ for the physical activity program. It is likely that the content was behavioral, but the specifics are not provided.
| | Parents | | | 3–5 days/week 15–25 minutes | None
| | | | | Not specified
Dale et al., 1998^146^ | Control | School | 1 school year (Traditional PE) | None | School | None | None
Dale & Corbin, 2000^66^ | | In person | | None | Not specified | None
| | Teachers | | | Not specified
| | | | | Not specified
| 1 | School | 5 contacts a week for 1 school year: | None | School | Skill building | None
| | In person | Concept based PE: 1 weekly classroom health education session, 1 weekly session in gymnasium, 3 weekly sessions of sports activities | None | Moderate Intensity | Education on why one should exercise
| | Teachers | | | 5 days/week duration not reported | Education on normal response to exercise
| | | | | Aerobic activity | Self monitoring
| | | | | | Goal setting
| | | | | | Written feedback/verbal encouragement
| | | | | | None
Howard et al., 1996^56^ | 1 | School | 5 40-minute health education sessions over 5 weeks | None | Not specified | Education on normal response to exercise | None
| | In person | | Diet | Not specified | Education on why one should exercise
| | Not specified | | Smoking cessation | Not specified | None
| | | | | Not specified
Lovibond et al., 1986^156^ | Control | Worksite | 17 contacts in 6 months: | None | Not specified | Education on normal response to exercise | Social Learning Theory
| | In person | 4 individual counseling sessions (did NOT include CHD risk projections or behavioral components. These sessions focused on health education) | Diet | Not specified | Education on why one should exercise
| | Mail | 12 group sessions | Smoking cessation | Not specified | Written feedback/verbal encouragement
| | Therapist | 1 mailing | | Not specified | Goal setting
| | | | | | Social support
| | | | | | Modeling
| | | | | | Social reinforcement
| | | | | | Problem solving
| | | | | | None
| 1 | Worksite | 17 contacts in 6 months: | Risk factor status | Not specified | Education on normal response to exercise | Social Learning Theory
| | In person | 4 individual counseling sessions (more personalized than control group, including CHD risk projections. But no behavioral components.) | Diet | Not specified | Education on why one should exercise
| | Mail | 12 group sessions | Smoking cessation | Not specified | Social reinforcement
| | Therapist | 1 mailing | | Not specified | Written feedback/verbal encouragement
| | | | | | Stimulus control
| | | | | | Goal setting
| | | | | | Self monitoring
| | | | | | None
| 2 | Worksite | 17 contacts in 6 months: | Risk factor status | Not specified | Education on normal response to exercise | Social Learning Theory
| | In person | 4 individual counseling sessions (personalized, including CHD risk projections. Behaviorally based.) | Individual needs | Not specified | Education on why one should exercise
| | Mail | 12 group sessions | Diet | Not specified | Social reinforcement
| | Therapist | 1 mailing | Smoking cessation | Not specified | Written feedback/verbal encouragement
| | | | | | Contingency management
| | | | | | Stimulus control
| | | | | | Goal setting
| | | | | | Self monitoring
| | | | | | None
Edmundson et al., 1996^118^ | Control | School | 3 PE classes per week for 2.5 –3 school years | None | School | Not specified | None
Luepker et al., 1996^53^ | | In person | | None | Not specified | Not specified
Nader et al., 1999^52^ | | Physical education teachers | | | 3 days/week 30 minutes
Perry et al., 1997^119^ | | | | | Not specified
Simons-Morton et al., 1997^120^
Stone et al., 1996^121^
Nader et al., 1996^122^
McKenzie et al., 2001^123^
McKenzie et al., 1996^124^
McKenzie et al., 1994^125^
Hearn, 1992^126^
McKenzie et al., 1995^127^
Elder et al. 1994 ^149^
| 1 | School | 3 PE classes per week for 2.5 –3 school years | Language | School | Self efficacy enhancement | Social Cognitive Theory
| | Home | Home program for ½ of intervention schools | Diet | Home | Provision of equipment | Social Learning Theory
| | In person | Plus, changes in health education and school lunch program | Smoking cessation | Moderate intensity | Education on normal response to exercise
| | Sent home through student | | | 3+ days/week 30 minutes | Education on why one should exercise
| | Classroom teachers | | | Aerobic activity | Skill building
| | Physical education teachers | | | | Incentives and contracts
| | | | | | Social support
| | | | | | Written feedback/verbal encouragement
| | | | | | Self monitoring
| | | | | | Modeling/rehearsing
| | | | | | Social norm setting
| | | | | | Accessibility
Nader et al., 1989^129^ | 1 | School | 18 contacts in 1 year: | Language | School | Self monitoring | Social Learning Theory
Nader et al., 1986^128^ | | Telephone | 12 weekly sessions then 4 monthly sessions then 2 bi-monthly sessions | Diet | Vigorous intensity | Goal setting
| | Mail | | | 1 day/week 25 minutes | Behavioral rehearsal modeling
| | In person | | | Aerobic activity | Self-regulation skills
| | Family-oriented newsletter with mail-in contest | | | | Incentives and contracts
| | Trained graduate students | | | | Written feedback/verbal encouragement
| | | | | | Social support
| | | | | | Problem solving
| | | | | | Benefits and barriers
| | | | | | Self efficacy
| | | | | | Education on normal response to exercise
| | | | | | Education on why one should exercise
| | | | | | Education on how to exercise
| | | | | | Accessibility
Stevens et al., 1998^62^ | Control | Community | 1 mailing | None | Not specified | Education on why one should exercise | None
| | Mail | | None | Not specified | None
| | Mail | | | Not specified
| | | | | Not specified
| 1 | Exercise facility | 3 contacts in 10 weeks: | Personalized exercise prescription | Not specified | Self monitoring | None
| | In person | 1 mailing | None | Not specified | Education on why one should exercise
| | Mail | 2 in person consultations with exercise development officer | | Not specified | Education on normal response to exercise
| | Exercise development officer | | | Not specified | Access to fitness facility
Bauer et al., 1985^51^ | 1 | Worksite | 5 or 6 years: | None | Not specified | Not specified | None
Rose, 1970^137^ | | Not specified | Worksite wide interventions with multiple individual programs and more personalized intervention for men at higher risk for coronary heart disease | Diet | Moderate intensity | Not specified
Rose et al., 1980^138^ | | Not specified | | Smoking cessation | 7 days/week 20 minutes
| | Nurses | | | Aerobic activity
Gomel et al., 1993^139^ | Control | Worksite | 1 30 minute health risk assessment no counseling on results | None | Not specified | None | None
Gomel et al., 1997^140^ | | In person | | None | Not specified | None
| | Unknown contact | | | Not specified
| | | | | Not specified
| 1 | Worksite | 1 50 minute health risk assessment with counseling on results | None | Not specified | None | None
| | In person | | Diet | Not specified | None
| | Unknown contact | | Smoking cessation | Not specified
| | | | | Not specified
| 2 | Worksite | 1–7 contacts in 10 weeks: | Stage of change | Not specified | Benefits and barriers | Transtheoretical Model
| | In person | 1 50-minute health risk assessment with counseling on results | Risk factor status | Not specified | Self monitoring
| | Unknown contact | Up to 6 group health education classes | Diet | Not specified | Goal setting
| | | | Smoking cessation | Not specified | Relapse prevention
| | | | | | Problem solving
| | | | | | Written feedback/verbal encouragement
| | | | | | None
| 3 | Worksite | 1–7 contacts in 10 weeks: | Stage of change | Not specified | Incentives and contracts | Transtheoretical Model
| | In person | 1 50-minute health risk assessment with counseling on results | Risk factor status | Not specified | Self monitoring
| | Unknown contact | Up to 6 group health education classes | Diet | Not specified | Goal setting
| | | Incentives | Smoking cessation | Not specified | Relapse prevention
| | | | | | Benefits and barriers
| | | | | | Problem solving
| | | | | | Written feedback/verbal encouragement
| | | | | | None
Gemson & Sloan, 1995^68^ | Control | Worksite | 1 physicians visit | None | Not specified | None | None
| | In person | | None | Not specified | None
| | Physician | | | Not specified
| | | | | Not specified
| 1 | Worksite | 1 mailing | Risk factor status | Not specified | None | None
| | Mail | 1 physicians visit | Diet | Not specified | None
| | In person | | Smoking cessation | Not specified
| | Computerized feedback system | | | Not specified
| | Physician
Lombard et al., 1995^69^ | Control | Worksite | 1 contact in 3 months | None | Worksite | Social support | None
| | In person | | None | Moderate intensity | Self-monitoring
| | Research assistant | | | 3 days/week 20 minutes | None
| | Researcher | | | Aerobic activity
| 1 | Worksite | 37 contacts in 3 months: | None | Worksite | Social support | None
| | In person | Frequent prompting support - ‘touching base’ by phone | None | Moderate intensity | Self monitoring
| | Telephone | | | 3 days/week 20 minutes | None
| | Research assistant | | | Aerobic activity
| | Researcher
| 2 | Worksite | 37 contacts in 3 months: | None | Worksite | Social support | None
| | In person | Frequent prompting support - ‘verbal encouragement and feedback’ by phone | None | Moderate intensity | Goal setting
| | Telephone | | | 3 days/week 20 minutes | Written feedback/verbal encouragement
| | Research assistant | | | Aerobic activity | Self monitoring
| | Researcher | | | | None
| 3 | Worksite | 13 contacts in 3 months: | None | Worksite | Social support | None
| | In person | Less frequent prompting support - ‘touching base’ by phone | None | Moderate intensity | Self monitoring
| | Telephone | | | 3 days/week 20 minutes | None
| | Research assistant | | | Aerobic activity
| | Researcher
| 4 | Worksite | 13 contacts in 3 months: | None | Worksite | Social support | None
| | In person | Frequent prompting support - ‘verbal encouragement and feedback’ by phone | None | Moderate intensity | Goal setting
| | Telephone | | | 3 days/week 20 minutes | Written feedback/verbal encouragement
| | Research assistant | | | Aerobic activity | Self monitoring
| | Researcher | | | | None
MacKeen et al., 1985^157^ | 1 | Worksite | 1.5 years | None | Not specified | None | None
Remington et al., 1978^158^ | | Community | | None | Vigorous intensity | Accessibility
Taylor et al., 1973^159^ | | In person | | | 3+ days/week 60 minutes
| | Unknown supervisor | | | Aerobic and non aerobic activity
Mutrie et al., 2002^70^ | 1 | Worksite | 1 contact to encourage walking to commute to work | None | Community | Self efficacy enhancement | Transtheoretical Model
| | Mail | | None | Worksite | Decisional balance
| | Packet | | | Not specified | Consciousness raising
| | | | | Not specified | Practical information to implement intervention
| | | | | Aerobic activity | Provision of equipment
| | | | | | Safety
O'Loughlin et al., 1996^67^ | 1 | Worksite | 1 contact in 3 months | None | Not specified | Education on why one should exercise | None
| | In person | | Diet | Not specified | Written feedback/verbal encouragement
| | Not specified | | Smoking cessation | Not specified | Goal setting
| | | | | Not specified | None
Ostwald 1989^160^ | Control | Worksite | One all-day seminar | None | Not specified | Education on why one should exercise | None
| | In person | Monthly newsletter for 3 months | Diet | Not specified | Written feedback/verbal encouragement
| | Mail | One physical exam | | Not specified | None
| | Not specified | | | Not specified
| 1 | Worksite | One all-day seminar | None | Exercise facility | Education on why one should exercise | None
| | In person | Monthly newsletter for 3 months | Diet | Not specified | Written feedback/verbal encouragement
| | Mail | One physical exam | | Not specified | Accessibility
| | Not specified | Treadmill test | | Not specified
| | | More extensive interpretation of tests than for control group
| 2 | Worksite | 1 all-day seminar | Individualized exercise prescription | Exercise facility | Education on why one should exercise | None
| | In person | Monthly newsletter for 3 months | Diet | Not specified | Written feedback or verbal encouragement
| | Mail | 1 physical exam | | Three times per week | Provision of equipment
| | Exercise physiologist | Treadmill test | | Aerobic | Education on normal response to exercise
| | | More extensive interpretation of tests than for control group | | | Skill building
| | | 3 months supervised exercise | | | Education on how to exercise
| | | | | | Accessibility
Sherman et al., 1989^163^ | 1 | Worksite | 30 days | None | Not specified | None | None
| | Not specified | | Diet | Not specified
| | Not specified | | Smoking cessation | Not specified
| | | | | Not specified
Perklo-Makela, 1999^72^ | 1 | Public health agency | 10–20 contacts over 2.5 months | None | Municipal health center | None | None
| | In person | | None | Not specified | Accessibility (class provided)
| | Physiotherapist | | | 1–2 days/week duration not reported
| | Occupational health nurse | | | Aerobic and non-aerobic activity
| | Occupational physician
| | Psychologist
| | Agricultural advisor
Linenger et al., 1991^71^ | 1 | Government agency | Environmental changes made early in the year between baseline and followup measures. Changes maintained to end of evaluation and beyond. Length of intervention unknown. | None | Exercise facility/Naval Air Base | Social support | None
| | Local environmental changes | | Diet | Not specified | Benefits and barriers
| | Not specified | | Smoking cessation | Not specified | Stressed the expectancy of improved performance and improved appearance for future transfer and promotion
| | | | | Aerobic activity | Incentives and contracts
| | | | | | Written feedback/verbal encouragement
| | | | | | Accessibility
| | | | | | Distance (new facilities built, activity groups formed, hours of facilities extended, point of decision prompts)
Edye et al., 1989^147^ | Control | Worksite | 2–4 medical screening visits (depending on risk level) over 3 years | None | Not specified | None | None
| | Not specified | Physician advice to be physically active at each visit | Diet | Not specified | None
| | Not specified | | Smoking cessation | Not specified
| | | | | Not specified
| 1 | Worksite | 2–4 medical screening visits (depending on risk level) over 3 years | None | Not specified | Verbal encouragement | None
| | In person | Physician advice to be physically active at each visit | Diet | Not specified | Education on why one should exercise
| | Physician | 3 counseling visits with a nurse over 3 month period | Smoking cessation | Not specified | None
| | Nurse | | | Not specified

If no details are listed for the control intervention, that study had no physical activity intervention for the control group