# Appendix C Abstraction Forms

## Data abstraction form for general population

If there was only one comparison group, the following three pages were completed.

If there was more than one comparison group, they were identified as intervention groups starting with #1 up to #6. For each intervention, they completed the next three pages.

There could be more than one outcome measure identified. The following page would be completed for each outcome identified.

## Data abstraction form for cancer population

If there was only one comparison group, the following three pages were completed.

If there was more than one comparison group, they were identified as intervention groups starting with #1 up to #6. For each interventionm they completed the next three pages.