# Appendix B Exact Search Strings

## Specific Search Strategy

Number | Search Term | Number of References
1 | Search exercise[mh] | 25,076
2 | Search physical activity | 64,325
3 | Search #1 OR #2 | 83,789
4 | Search randomized controlled trial[pt] | 168,406
5 | Search randomized controlled trials[mh] | 25,643
6 | Search controlled clinical trial[pt] | 62,062
7 | Search intervention studies[mh] | 2,295
8 | Search clinical trial[pt] | 345,151
9 | Search #4 OR #5 OR #6 OR #7 OR #8 | 367,880
10 | Search #3 AND #9 | 6,790

## Search Strategy Used on 12/20/02

Number | Search Term | Number of References
1 | Exercise [mh] | 24,623
2 | Physical activity | 63,673
3 | Search #1 OR #2 | 82,795
4 | Cancer | 1,456,200
5 | Search #3 AND #4 | 1,647
6 | Randomized controlled trial [pt] | 166,627
7 | Randomized controlled trials [mh] | 24,988
8 | Search #6 OR #7 | 187,507
9 | Search #5 AND #8 | 47
10 | Controlled clinical trial [pt] | 61,833
11 | Search #5 AND #10 | 10
12 | Intervention studies [mh] | 2,272
13 | Search #5 AND #12 | 8
14 | Clinical trial [pt] | 341,915
15 | Search #5 AND #14 | 54
16 | Search #9 OR #11 OR #15 | 70

## Search Approach Used for Cancer Part of Review—Completed on 9/17/03—Resulting in 81 Papers

Number | Search Term
1 | Exercise[mh]
2 | Motor activity[mh]
3 | Physical activity[tw]
4 | Search #1 OR #2 or #3
5 | Randomized controlled trial[pt]
6 | Randomized controlled trials[mh]
7 | Controlled clinical trial[pt]
8 | Intervention studies[mh]
9 | Clinical trial[pt]
10 | Search #5 OR #6 OR #7 OR #8 OR #9
11 | Cancer[mh]
12 | Search #4 AND #10 AND #11