# Appendix A Technical Expert Panel Members

Technical Expert Panel Members and Areas of Expertise

TEP Member | Area of Expertise
Russ Pate | Schools, Adolescents
University of Southern California
Rod Dishman | Worksite, Adults
University of Georgia
Deborah Rohm Young | Churches, Adolescents
University of Maryland
Andrea Dunn | Community, Adults
The Cooper Institute
Greg Heath | Community
Centers for Disease Control
Karen B. Eden | Health care, environment or public policy
Oregon Health and Science University
Kerry Courneya | Cancer patients and survivors
University of Alberta
Brian Saelens | Environment or Public policy
Children's Hospital Medical Center, Cincinnati, Ohio
Bess Marcus | Adults
Brown University
National Coalition for Promoting Physical Activity - | Consumers
Kathy Spangler, President
National Cancer Institute Representatives
Louise Masse
Rick Troiano