# Appendixes

Appendix A Technical Expert Panel Members

Appendix B Exact Search Strings

Appendix C Abstraction Forms

Appendix D Characteristics of Physical Activity Interventions in the Studies of the General Population

Appendix E Evidence Tables

Appendix F Cancer Outcomes Tables