# Appendix F. Evidence Tables Continued

Evidence Table 1. Included provider studies

Article ID | Research Design and Quality | Prevention Category | Prevention Target | Intervention | Follow-up Period | Ns Practices Providers Patients | Group Assignment | Outcomes
First Author
Country
ID# 001 | Three year evaluation, before-after study | Simple | MMR immunization, cholesterol screening | Adjusted capitation rates | Three years 1987-1990 | Practices: 418 for MMR, 271 for cholesterol | Group 1) Capitation rates adjusted by quality of care performance measures; audit determines following year cap rate | Significant finding for adjusted capitation:
Morrow et al., 1995^47^ | Score = 2 | | | | | | | 1) Increase in percent of charts in office in compliance p<.05
US | | | | | | | | 2) Increase in percent of offices with <90% compliance p<.05
ID#003 | RCT | Simple | Cancer screening | Performance bonus - target outcome | 18 months | Practices: 52 (<100 MDs, 1200 charts) | Group 1) Control n=26 | No significant differences between groups for:
Hillman et al., 1998^45^ | Score = 3 | | | | | | Group 2) Performance bonus - target outcome. 20% of capitation for three highest aggregate compliance scores; 10% for next three highest and three offices most improved n=26 | * Percent of charts in compliance with breast exam indicators
US | | | | | | | | * Percent of charts in compliance with mammography indicators
| | | | | | | | * Percent of charts in compliance with pap smear indicators
| | | | | | | | * Percent of charts in compliance with colorectal exam indicators
| | | | | | | | * All groups showed improvement over time p<.001.
| | | | | | | | * Sub-group analysis: Group practices had greater # of charts in compliance with indicators p=.048
ID#004 | RCT | Simple | Flu immunization | Performance bonus - target outcome | One flu season | Practices: 54 | Group 1) Control n=27 | Significant findings for performance bonus - target outcome:
Kouides et al., 1998^49^ | Score = 3 | | | | | | Group 2) Performance bonus - target outcome. 10% additional reimbursement per shot provided if ≤ 70% immunization rate. 20% if ≤85% - n=27 | 1) change in percent immunized, p=.03
US | | | | | | | | 2) by regression, 7.1% of increase in documented immunization due to intervention, p=.05
ID#005 | RCT | Simple | Child immunizations – up to date (UTD) coverage of scheduled shots | Group 2) performance bonus - target outcome. | 8 months | MDs: 60 (patients from 2948 to 3019) | Group 1) Control n=15 | Significant findings for performance bonus - target outcome:
Fairbrother et al., 1999^43^ | Score = 3 | | | Group 3) per-input bonus | | | Group 2) Performance bonus - target outcome and feedback $1000 for 20% increase in UTD, $2500 for 40%, $5000 for reaching 80% coverage. n=15 | 1) Percent of children documented UTD. p<.01
US | | | | | | | Group 3) Per-input bonus and feedback. $5 per administered shot and $15 per office visit with completed coverage n=15 | 2) Percent vaccines administered outside the practice p<.05
| | | | | | | Group 4) Feedback only n=15 | * No significant differences for percent missed opportunity to immunize
ID#006 | RCT | Simple | Child immunizations – up to date (UTD) coverage of scheduled shots | Group 2) performance bonus - target outcome. | 16 months | MDs: 57 (patients from 2792 to 2866) | Group 1) Control n=24 enrolled, n=21 completed | Significant findings for performance bonus - target outcome:
Fairbrother et al., 2001^44^ | Score = 3 | | | Group 3) per-input bonus | | | Group 2) Performance bonus - target outcome and feedback $1000 for 35% increase in UTD, $2500 for 45%, $5000 for reaching 80% cover-age, $7500 reaching 90%. n=26 enrolled, n=24 completed | 1) Percent of children documented UTD. p<.05
US | | | | | | | Group 3) Per-input bonus and feedback. $5 per administered shot and $15 per office visit with completed coverage n=14 enrolled, n=12 completed | 2) Percent vaccines administered outside the practice p<.01
| | | | | | | | Significant findings for performance bonus - per input:
| | | | | | | | 1) Percent of children documented UTD. p<.01
| | | | | | | | * No significant difference for percent missed opportunity to immunize
ID#007 | RCT | Simple | Well child, including immunizations | Performance bonus - target outcome | 18 months | Practices: 49 | Group 1) Control n=17 enrolled, n=15 completed | No significant differences between groups for:
Hillman et al., 1999^46^ | Score = 3 | | | | | | Group 2) Performance bonus - target outcome plus feedback; 20% of capitation for three highest aggregate compliance scores; 10% for next three highest and three offices most improved. n=19 enrolled and completed | * Total compliance score
US | | | | | | | Group 3) Feedback only n=17 enrolled, n=15 completed | * Immunization compliance score
| | | | | | | | * Other preventive care indicators compliance
| | | | | | | | * Sub-group analysis
| | | | | | | | 1) Group practices had higher immunization rates than solo p<.05
| | | | | | | | 2) Pediatricians had higher overall compliance scores than other MDs p<.05
ID#008 | Time series | Simple | Child immunizations | Performance bonus/ sanction - target payment | 1986-1992 | Practices: 95 | Target payment - lump sum payment at 70% and 90% coverage levels; implemented 1990 | * No change in trend from new contract for immunization rates for two and five year olds. Trend stabilized in 1991
Ritchie et al., 1992^51^ | Score = 2 | | | | | General Practitioners: 313 | | * Removed seasonal pattern for five year olds (school-based)
UK | | | | | | | | * Both two and five year olds – General practitioners and practices performing below 70% improved after 1990
| | | | | | | | * Only practice size showed relationship - solo more likely to not reach target levels
| | | | | | | | * Target payments may have helped achieve an accelerated immunization schedule
ID#011 | RCT | Simple | Cancer screening | Performance bonus - target behavior | First of three year study | Practices: 61 (Providers: 95, Patients 11,4426) | Group 1) Control – education only n=23 enrolled and completed | No significant difference for performance bonus - target behavior:
Grady et al.,^48^ | Score = 2 | | | | | | Group 2) Education and chart sticker cues n=21 enrolled, n=18 completed | * Mammography referral rate
US | | | | | | | Group 3) Education, chart sticker cues, feedback, token bonus of $50 for 50% mammography referral rate, n=21 enrolled, n=20 completed | * Mammography completion
| | | | | | | | * Mammography compliance
ID#018 | Three-year evaluation, before-after study | Simple | Prenatal care | Fee increase | 1985-1987 | Patients: 1985 - 1332, 1986 - 1396, 1987 - 1532 | Group 1) Raised fees for delivery from $265 to $795 and prenatal visits from $17 to $21 | No significant change for raised fees for:
Fox & Phua^50^ | Score = 2 | | | | | | | * Number of prenatal visits
US | | | | | | | | * Average number of prenatal visits dropped. Baltimore City dropped from 6.82 to 4.71
| | | | | | | | * Large increase in prenatal care out-state areas

Evidence Table 2. Included consumer studies data

Article ID | Prevention Definition | Theoretical Incentive Definition | Functional Incentive Definition | Economic Definition | Theory/ Justification | Prevention Target | Intervention | Incentive Condition | Confounders | Direct Test of Incentive Uptake or Desirability
Author
Country
#074 | Complex | Reward | Adhering | Income behavior | None | Breast-feeding | Coupon | Required behavior: complete educational program and self-reported breast feeding levels. | Unknown contribution from education, incentive, social support, and incentive to social support. | No
Sciacca et al., 1995^66^
US
#032 | Complex | Barrier removal - structural | Adhering | Purchasing behavior | None | Smoking cessation | Free/reduced medical | Required behavior - pick up patches from pharmacy | | No
Dey et al., 1999^102^
UK
#071 | Complex | Barrier removal - attitudinal | Adhering | Income behavior | Behavioralist | Obesity prevention | Lottery | Required behavior - return postcard that was attached to the newsletter | | No
Jeffery & French, 1999^74^
US
#072 | Complex | Reward | Adhering | Income behavior | Behavioralist | Weight loss | Cash | Required behavior - attend supervised exercised sessions | | No
Jeffery et al., 1998^97^
US
#078 | Complex | Reward | Adhering | Income behavior | Behavioralist | Exercise | Lottery | Required behavior - attend exercise sessions. Travel lottery chances based on how many sessions attended | | No
Wing et al., 1996^91^
US
#091 | Complex | Barrier removal - structural | Adhering | Purchasing behavior | None | Smoking cessation | Free/reduced medical | Required behavior - purchase gum | | Yes - uptake
Hughes et al., 1991^76^
US
#107 | Complex | Reward/ negative reinforcement/ punishment | Adhering | Purchasing behavior | Behavioralist | Weight loss | Monetary contract (forfeit money to be successful) | Required behavior - attend weight loss educational sessions | | Yes - uptake
Follick et al., 1984^109^ | | | | | | | | | | *No reporting of contract payments
US
#104 | Complex | Negative reinforcement/ punishment | Adhering/ outcome | Purchasing behavior | Behavioralist | Weight loss | Monetary contract | Required behavior - attendance. Required Outcome - calorie restriction and weight loss goals | | No.
Jeffery et al., 1978^106^ | | | | | | | | | | *“Subjects weren't unhappy with it.”
US | | | | | | | | | | * Weight loss goal subjects most likely to forfeit money
#089 | Complex | Barrier removal - structural | Facilitating | Purchasing behavior | None | Nutrition | Coupon | Required behavior - purchase food | | Yes - uptake
Anderson et al., 2001^102^ | | | | | | | | | | *87% redeemed at least some coupons, 58% redeemed all
US
#061 | Complex | Reward | Outcome | Income behavior | None | Cholesterol level | Lottery | Required out-come - to participate in lottery, lower serum cholesterol by 20%, or be under 200, within 6 months | | No
Francisco et al., 1994^93^ | | | | | | | | | | *only 6 of 29 lottery eligible agreed in survey the lottery was important to their behavior
US
#069 | Complex | Reward | Outcome | Income behavior | Behavioralist | Weight loss | Cash | Required outcome - lose weight and maintain loss | | No
Jeffery, Forster, French et al., 1993^105^
US
#102 | Complex | Negative reinforcement/ punishment | Outcome | Purchasing behavior | Behavioralist | Weight Loss | Monetary contracts | Required outcome - weight loss | | Yes - desirability
Jeffery et al., 1984^107^
US
#103 | Complex | Reward/ punishment | Outcome | Purchasing behavior | Behavioralist | Weight loss | Monetary contract (forfeit money to be successful) | Required outcome - weight loss | | Yes - desirability
Jeffery et al., 1983^108^
US
#108 | Complex | Reward | Outcome | Income behavior | None | Smoking cessation | Cash | Required outcome - abstinence | | No
Windsor et al., 1988^96^
US
#062 | Complex | Reward | Outcome | Income behavior | Prochaska - no justification of chosen rewards | CVD prevention | Lottery + competition | Required behavior: self-reported progress toward or meeting lifestyle change goals | Unknown contribution from incentive, positive or negative team peer pressure, positive or negative effect of results reported publicly within the worksite | No
Gomel et al., 1993^69^
New Zealand
#065 | Complex | Reward | Outcome | Income behavior | Prochaska, Bandura - no justification of chosen rewards | Smoking cessation | Cash + competition | Required outcome: lab-verified abstinence | Unknown contribution from incentive, positive or negative team peer pressure, positive or negative effect of results reported publicly within the worksite | No
Koffman et al., 1998^68^
US
#066 | Complex | Negative reinforcement/ punishment | Outcome | Purchasing behavior | Behavioralist | Smoking cessation/ obesity | Monetary contract: | Required outcome: lab-verified smoking reduction goals or weight loss goals | | No
Jeffery, Forster, Baxter et al., 1993^98^
US
#079 | Complex | Reward | Outcome | Income behavior | Behavioral change - no justification of chosen rewards | Smoking cessation | Cash | Required outcome: lab-verified abstinence | Unknown contribution from incentive, social support, and incentive to social support | No
Donatelle et al., 2000^67^
US
#082 | Complex | Barrier removal - attitudinal | Participating | Income behavior | None | Exercise | Coupon | Required behavior - attend 40 minute motivational interviews | | No
Harland et al., 1999^99^ | | | | | | | | | | *44% of group offered up to six vouchers used vouchers vs. 27% of group offered only one voucher
UK
#105 | Complex | Reward | Participating | Income behavior | Behavioralist | Smoking cessation | Cash | Required out-come - reduce CO levels to 50% of baseline | | Yes - uptake and desirability
Stitzer & Bigelow, 1983^75^ | | | | | | | | | | *No reporting on payments made
US
#084 | Complex | Reward | Participating | Income behavior | None | Smoking cessation | Gift + competition | Required behavior: Turkey buffet to work-sites with highest recruitment rate; pooled kitty to split among quitters at work-site with the highest proportion of quitters | Unknown contribution from competition, positive or negative team peer pressure. Recruitment procedures differed at each site | No
Gottlieb & Nelson, 1990^71^
US
#109 | Complex | Reward | Participating | Income behavior | Deci & Ryan Intrinsic/ Extrinsic motivation; Bandura's self-efficacy | Smoking cessation | Gift + lottery | Required behavior: return unit progress reports of self-help program | | No
Curry et al., 1991^72^
US
#110 | Complex | Reward | Participating/ outcome | Income behavior | None | Smoking cessation | Cash + competition | Required behavior: team with greatest percent of initial participants completing program; highest quit rate at 6 months; highest abstinence rate at 6 months | Unknown contribution from incentive, positive or negative team peer pressure, positive or negative effect of results reported publicly within the worksite | No
Klesges et al., 1987^70^
US
#096 | Simple | Reward | Participating | Income behavior | Social learning theory | Cholesterol level | Lottery | Required behavior - show up for retest | | No.
Owen et al., 1990^73^ | | | | | | | | | | *Only 156 of the 1001 who showed for retest turned in lottery coupon
Australia
#075 | Simple | Reward | Participating | Income behavior | None | AIDS prevention | 1) Cash | Required behavior - attend educational sessions | | Yes - desirability
Deren et al., 1994^52^ | | | | | | | 2) Coupon
US
#076 | Simple | Reward | Participating | Purchasing behavior | None/test if money-savings will overcome barriers such as embarrassment | STD prevention | Coupon | Required behavior - purchase package of 12 condoms | | No
Dahl et al., 1999^101^
US
#077 | Simple | Reward | Participating | Income behavior | Extrinsic/ Intrinsic motivation; focus group determined size of meaningful rewards | HIV/STD prevention | 1) Cash | Required behavior - attend one 90 minute group education session and one 60 minute individual session | | Yes - desirability
Kamb et al., 1998^64^ | | | | | | | 2) Coupon
US
#092 | Simple | Reward | Participating | Income behavior | None | Smoking cessation | Lottery | Required behavior - attend non-smoking clinic | | Yes - uptake
Emont & Cummings, 1992^92^ | | | | | | | | | | *only one participant reported the prize was a significant factor
US
#043 | Simple | Punishment | Adhering | Income behavior | None | Immunization | Must come to WIC offices monthly to pick up allotment of vouchers (normal every 2 months) | Required behavior - immunize child | | No
Birkhead et al., 1995^57^ | | | | | | | | | | *Only 8 of 178 children dropped out during the disincentive
US
#049 | Simple | Punishment | Adhering | Income behavior | None | Immunization | Lose AFDC benefits provided to non-immunized child | Required Behavior - provide proof of immunization | | No
Kerpelman et al., 2000^58^ | | | | | | | | | | *17 sanctions warnings, 11 actual sanctions affecting 8 of 1500 families
US
#053 | Simple | Barrier removal | Adhering | Purchasing behavior | Health belief model, Anderson's framework of utilization | Followup of abnormal pap | 1) Coupon | Required behavior: for voucher, attend at least one followup visit. No requirement for free bus passes | Unknown contributions of incentive vs. intensive contact. Non-equivalent sites | No
Kaplan et al., 2000^100^ | | | | | | | 2) Free/ reduced medical
US
#034 | Simple | Reward | Adhering | Income behavior | None | Immunization | 1) Coupon | Required Behaviors - | | Yes - desirability
Yokley & Glenwick, 1984^62^ | | | | | | | 2) Lottery | 1) Leave child at clinic for shots and day care period,
US | | | | | | | | 2) Bring child in for shots
#038 | Simple | Reward | Adhering | Income behavior | Reasoned action and behavioral | Tuberculosis screening | 1) Cash | Required behavior - return for a reading of the Mantoux test | | Yes - desirability
Malotte et al., 1999^54^ | | | | | | | 2) Coupon 1
US | | | | | | | 3) Coupon 2
#048 | Simple | Reward | Adhering | Income behavior | Carter et al. decision model for factors considered important by elderly | Immunization | Lottery | Required behavior - receive shot at clinic | | No
Moran et al., 1996^63^
US
#054 | Simple | Reward | Adhering | Income Behavior | None | Followup: post-partum exam | Gift | Required behavior - attend post-partum appointment | | No
Stevens-Simon et al., 1994^56^
US
#055 | Simple | Reward | Adhering | Income behavior | None/jewelry chosen by focus group | Followup: post-partum exam | 1) Coupon | Required behavior - attend post-partum appointment on assigned day | | No
Smith et al., 1990^55^ | | | | | | | 2) Gift | | | *Child-based formula incentive was more effective
US
#094 | Simple | Reward | Adhering | Income behavior | None | Prenatal care | 1) Coupon | Required behavior - attend prenatal and postpartum check | | Yes - uptake and desirability
Laken & Ager, 1995^65^ | | | | | | | 2) Coupon + lottery
US
#106 | Simple | Reward | Adhering | Income behavior | Theory of reasoned action | Tuberculosis screening | 1) Cash 1 | Required behavior - return for skin test reading | | Yes - desirability
Malotte et al., 1998^53^ | | | | | | | 2) Cash 2
US
#044 | Simple | Punishment | Adhering | Income behavior | None | Immunization | Must come to WIC offices monthly to pick up allotment of vouchers (normal every 3 months) | Required behavior - immunize child | | No
Hutchins et al., 1999^110^
US
#029 | Simple | Barrier removal - structural | Facilitating | Purchasing behavior | None | Followup: cancer screening | Coupon | Required behavior - return completed fecal occult blood test within 3 months | | Yes - uptake
Freedman & Mitchell, 1994^59^
US
#037 | Simple | Barrier removal - structural | Facilitating | Purchasing behavior | None | Immunization | Free/reduced medical | Required behavior - receive flu shot | | Yes - uptake
Satterthwaite,1997^104^
New Zealand
#047 | Simple | Barrier removal - structural | Facilitating | Purchasing behavior | None | Immunization | Free/reduced medical | Required behavior - receive flu shot | | Yes - uptake
Nexoe et al., 1997^78^
Denmark
#051 | Simple | Barrier removal - structural | Facilitating | Income behavior - cognitive problem if didn't earn income | Health belief model, reasoned action | Followup: cancer screening | Coupon | Nothing required - mailed with followup reminder; may be used for other purposes | | No
Marcus et al., 1992^60^ | | | | | | | | | | *Self-report 33% used bus passes
US
#052 | Simple | Barrier removal - structural | Facilitating | Purchasing behavior | None | Followup: cancer screening | Free/reduced medical | Required behavior - attend at least one followup visit | | No
Marcus et al., 1998^61^ | | | | | | | | | | *Vouchers used by 41.7% of those eligible
US
#095 | Simple | Barrier removal - structural | Facilitating | Purchasing behavior | None | Prenatal care | 1) Coupon | Required behavior - attend first prenatal clinic visit | | No
Melnikow et al., 1997^77^ | | | | | | | 2) Gift | | | *Only 1 of 24 taxi vouchers re-deemed. Log regression for confounders showed no significance
US
#042 | Simple | Reward | Participating | Income behavior | None | Cancer screening - mammography | Gift | Required behavior - complete mammography | | No
Mayer et al., 1994^94^ | | | | | | | | | | *Only 10% redeemed coupon for the kit
US
#050 | Simple | Reward | Participating | Income behavior | None | Cancer screening - mammography | Gift | Required behavior - complete mammography | | No
Mayer & Kellogg, 1989^95^ | | | | | | | | | | *Only 75% eligible collected the kit
US

Evidence Table 3. Included consumer studies outcomes

Article ID | Prevention Definition | Prevention Target | Intervention | Incentive Condition | Group Assignment | Outcomes
Author
Country
#074 | Complex | Breast feeding | Gifts and raffles of high frequency and considerable value - from $15 hair cuts to raffle for trip for two on Grand Canyon Railway. SO Partner also received incentives for attending. | Required behavior: complete educational program and self-reported breastfeeding levels | Group 1) Control - usual education n=29 completed | Significant Findings:
Sciacca et al., 1995^66^ | | | | | Group 2) Education with a significant other (partner, parent, etc) plus incentives, n=26 completed | * Differences between groups in exclusive breast feeding and exclusive formula feeding behaviors at discharge, two week, six week, and three month post-partum from p=.000 to p=.023
US
#032 | Complex | Smoking cessation | Free nicotine patches for 12 weeks | Required behavior - pick up patches from pharmacy | Group 1) counseling and prescription, n=39 | No significant difference between groups
Dey et al., 1999^103^ | | | | | Group 2) Counseling and free patch, n=58 | * Rate of self-reported abstinence
UK | | | | | | * Lab-confirmed abstinence
#071 | Complex | Obesity prevention | Lottery: $100, one per month for a 1/10 chance over three years | Required behavior - return postcard that was attached to the newsletter | Group 1) Control, standard behavioral therapy (SBT), n=414 | Significant Findings:
Jeffery & French, 1999^74^ | | | | | Group 2) SBT + monthly educational newsletter, n=197 | * Response rate of returned postcards (direct measure of incentive) Group 2 - 65%, Group 3 - 71%, p<.05
US | | | | | Group 3) SBT + newsletter + lottery, n=198 | * No significant differences for weight gain or behavior changes, though change was in the right direction
#072 | Complex | Weight loss | Cash Incentive: Graduated payments of $1 to $3 per exercise session, paid monthly, 222 total possible walks, $266 potential total per person | Required behavior - attend supervised exercised sessions | Group 1) Control. Standard behavioral therapy (SBT), n=40 | No significant findings for incentives
Jeffery et al., 1998^97^ | | | | | Group 2) SBT + Supervised exercise, n=41 | * Self-reported exercise behavior
US | | | | | Group 3) SBT + personal trainer, n=42 | * Body weight
| | | | | Group 4) SBT + incentive, n=37 | * Exercise session attendance
| | | | | Group 5) SBT + trainer + incentive, n=36
#078 | Complex | Exercise | Lottery: one $50 gift certificate (unknown type) at each exercise session and one $2,000 travel certificate | Required behavior - attend exercise sessions. | Group 1) 24 week programs with group meetings and three supervised exercise sessions per week, n=16 | No significant difference between groups
Wing et al., 1996^91^ | | | | Travel lottery chances based on how many sessions attended | Group 2) Plus Incentive, n=21 | * Weight loss
US | | | | | | * Attendance at exercise sessions
#091 | Complex | Smoking cessation | Free or reduced price for nicotine gum; $0, $6 or $20 vs full price of $24 | Required behavior - purchase gum | Group 1) Free gum, n=32 | Significant Findings:
Hughes et al., 1991^76^ | | | | | Group 2) $6/box gum, n=36 | * Decreased cost increased several measures of incidence of obtaining gum and long term use, p<.05 to p<.006
US | | | | | Group 3) $20/box gum, n=38 | * Price elasticity higher for $6 vs $20 (.45) than free vs $6 (.21)
| | | | | | * Decreased cost had non-significant trend to increase cessation
#107 | Complex | Weight loss | Contract: Return $5 per session, 14 session | Required behavior - attend weight loss educational sessions | Group 1) Weight loss program, n=24 | Significant Findings:
Follick et al., 1984^109^ | | | Cash: Forfeit money split between subjects who hadn't forfeited | | Group 2) Program + monetary contract, n=24 | * Number of sessions attended per participant, Group 1 - 6.04, Group 2 - 9.42, p<.01
US | | | | | | * No difference in weight loss between groups
#104 | Complex | Weight loss | Contract: return $200, $20 per week for 10 weeks, deposited if 1) attended meetings, 2) met calorie restriction goal, or 3) met weight loss goal | Required behavior - attendance | Group 1) Control - no contract, n=3 | Significant Findings:
Jeffery et al., 1978^106^ | | | | Required outcome - calorie restriction and weight loss goals | Group 2) Weight contract, n=7 | * Weight and calorie contracts groups lost more weight than the attendance group, p<.05
US | | | | | Group 3) Calorie contract, n=10 | * Attendance did not differ between groups
| | | | | Group 4) Attendance contract, n=7 | * Calorie group more likely to keep detailed diary, p<.025
#089 | Complex | Nutrition | Coupons: fresh produce from farmers' markets, $20 total | Required behavior - purchase food | Group 1) Control - no intervention, n=97 completed | Significant Findings:
Anderson et al., 2001^102^ | | | | | Group 2) Education, n=123 completed | * Groups 3 and 4 more likely to have visited the farmer's market, p<.001
US | | | | | Group 3) Coupons, n=114 completed | * Coupons increased fruit and vegetable consumption, p<.01
| | | | | Group 4) Education + coupons, n=121 completed | * Education “improved” attitudes and beliefs regarding fruit and vegetable consumption p<.01
#061 | Complex | Cholesterol level | Lottery: Five $100 cash prizes. 5 in 29 chance if all participants make goal | Required out-come - to participate in lottery, lower serum cholesterol by 20%, or be under 200, within six months | Group 1) Control - health fair and follow-up test, n=34 completed | Significant Findings:
Francisco et al., 1994^93^ | | | | | Group 2) health fair, test, and chance for lottery entry, n=29 | * Change in cholesterol level:
US | | | | | | Group 1 - 11.3% decrease, Group 2 - 13.2% decrease, p=.035
#069 | Complex | Weight loss | Cash Incentive: minimum of $12.50 to maximum of $25 per week depending on percent of goal attained, 20 weeks total | Required outcome - lose weight and maintain loss | Group 1) Control - no treatment | No significant findings for incentives.
Jeffery, Forster, French et al., 1993^105^ | | | | | Group 2) Standard behavioral therapy (SBT), n=40 | * Change in BMI, completion of food records, quality of diet, nutrition knowledge
US | | | | | Group 3) SBT + food provision, n=40
| | | | | Group 4) SBT + incentive, n=40
| | | | | Group 5) SBT + food provision + incentive, n=41
#102 | Complex | Weight loss | Contract 1: return $30 for every 5 pound reduction, total of $150 | Required outcome - weight loss | Group assignment stratified by population source, 2×3 factorial design: 3 contract types and 2 long-term maintenance enhancements | Significant Findings:
Jeffery et al., 1984^107^ | | | Contract 2: return $5, $10, $20, $40, $75 for successive five pound reductions | | | * Percent weight change higher for constant contract (10.8%) vs control (8.5%), p<.03, and increasing contract (12.8%) vs control (8.5%), p<.001
US
#103 | Complex | Weight loss | Contracts: refunds of $1, $5, or $10 per pound ($30, $150, or $300 total). Forfeit money split between participants who made goal | Required outcome - weight loss | 2×3 factorial design. Contract levels of $30, $150, and $300, and group or individual contracts. | No significant difference between contract sizes:
Jeffery et al., 1983^108^ | | | | | | * Weight loss
US | | | | | | * Group contracts lost more weight than individual, p<.05
#108 | Complex | Smoking cessation | Cash Incentive of $25 at six weeks and $25 at six months | Required outcome - abstinence | Group 1) Control - self help program, n= 95 | No difference in cessation rates between groups for incentives
Windsor et al., 1988^96^ | | | | | Group 2) Self-help+skills training/social support, n=94
US | | | | | Group 3) Self-help + incentive, n=95
| | | | | Group 4) Self-help+skills training/ social support + incentive, n=94
#062 | Complex | CVD prevention | Lottery + Competition: Two lottery draws for $40, $40 for meeting 3threemonth goal, 1/4 chance at $1,000 prize for station with highest percent meeting goals | Required behavior: self-reported progress toward or meeting lifestyle change goals | Group 1) Control - health risk assessment n=115 completed | Significant Findings
Gomel et al., 1993^69^ | | | | | Group 2) hra+risk factor education n=70 completed | * BMI, body fat percent, mean blood pressure, aerobic capacity, quit rates - Group 4 usually had strong response within six months but relapsed to initial levels by 12 months
New Zealand | | | | | Group 3) hra+behavioral counseling n=102 completed
| | | | | Group 4) hra+counseling+incentive n=77
#065 | Complex | Smoking cessation | Prize + competition: workers paid $50 to participate, rewarded $15/month of abstinence for up to five months, plus first place team wins up to $1,980 (split five ways), 1/13 chance to win | Required outcome: lab-verified abstinence | Group 1) Control - traditional non-smoking program. Worksite n=29 | Significant Findings:
Koffman et al., 1998^68^ | | | | | Group 2) Multifaceted program. Worksite n=80 | * Group 3 quit rates significantly higher than Group 2 at end of 6 month program, p=.02
US | | | | | Group 3) Multifaceted program + incentive. Worksite n=68 | * Biochem confirmed quit rates were not significantly different between Groups 2 and 3 at six months past program
#066 | Complex | Smoking cessation/ obesity | Monetary contract: money withheld from paycheck, minimum of $5 per check. If goal met, money returned to employee | Required outcome: lab-verified smoking reduction goals or weight loss goals | Group 1) Control - no treatment, n=16, 645 employees | Significant Findings:
Jeffery, Forster, Baxter et al., 1993^98^ | | | | | Group 2) 11 bi-weekly behavior modification sessions + incentive, n=16, 597 employees | Group 2 significantly greater smoking abstinence at end of program, p=.03.
US
#079 | Complex | Smoking cessation | Cash: $50 per month for each abstinent month, max of ten months, pre-term + two months post-partum | Required outcome: lab-verified abstinence | Group 1) Control - education, n=108 | Significant Findings:
Donatelle et al., 2000^67^ | | | | | Group 2) education + incentives + social support from significant other | * Biochem confirmed quit rates p<.0001 at eight months, p<.0009 at two months post-partum
US
#082 | Complex | Exercise | Coupons: One free use of fitness center, up to six possible | Required behavior - attend 40 minute motivational interviews | Group 1) Control - baseline health risk assessment, n=91 completed | No significant difference attributable to vouchers.
Harland et al., 1999^99^ | | | | | Group 2) baseline hra + 1 interview, n=96 completed | * Increased self-report physical activity
UK | | | | | Group 3) baseline hra + 1 interview and voucher, n=88 completed | * Increased self-report moderate activity
| | | | | Group 4) baseline hra + 6 interviews, n=88 completed | * Increased self-report vigorous activity
| | | | | Group 5) baseline hra + 6 interviews and vouchers | * Regression analysis showed interaction effect between vouchers and interview, p=.01
| | | | | | * No lasting effects at 12 month followup
#105 | Complex | Smoking cessation | Cash Incentive of $0, $1, $5, or $10 per day, ten payment periods | Required out-come - reduce CO levels to 50% of baseline | Group 1) $0 payment group | Significant Findings:
Stitzer & Bigelow, 1983^75^ | | | | | Group 2) $1 payment group | * CO levels decreased in orderly fashion as pay increased, p<.001
US | | | | | Group 3) $5 payment group | * Number of daytime cigarettes also decreased in orderly fashion, p<.001
| | | | | Group 4) $10 payment group | * Percent of targets met increased in orderly fashion, p<.01
#084 | Complex | Smoking cessation | Prize + Competition: Cold turkey buffet; participants (smokers and non-smoking supporters) were charged a $5 incentive fee which was pooled and refunded to winning worksites | Required behavior: Turkey buffet to work-sites with highest recruitment rate; pooled kitty to split among quitters at work-site with the highest proportion of quitters | Group 1) Control/ Comparison - non-competition sites, n=6 | Significant Findings:
Gottlieb & Nelson, 1990^71^ | | | | | Group 2) Competition sites, n=6 | * 70% of employees in Group 2 participated in program vs 17% of employees in Group 1, p<.001
US | | | | | | * 28% of smokers in Group 2 participated vs 6% of smokers in Group 1, p<.001
#109 | Complex | Smoking cessation | Gift: ceramic coffee mug at the end of first two program units. | Required behavior: return unit progress reports of self-help program | Group 1) Control - self-help program, n=305 | Significant Findings:
Curry et al., 1991^72^ | | | Lottery: All-expense-paid one-week trip for two to Hawaii, expense-paid weekend at San Juan Island resort, weekend at a deluxe hotel in downtown Seattle. Bonus entries for returning second two program units. | | Group 2) Intrinsic motivation - personalized feedback + program, n=304 | * Extrinsic more likely to complete first unit, p=.0001, and complete at least one activity in more than one of the last six units, p=.039
US | | | | | Group 3) Extrinsic motivation - financial incentives + program, n=304 | * Intrinsic more likely to show continuous abstinence, p=.004
| | | | | Group 4) Intrinsic + extrinsic + program, n=304 | Compared to extrinsic groups, intrinsic OR was 2.67
#110 | Complex | Smoking cessation | Prize + Competition: within site competition between teams, prizes of $5 to $15 per participant | Required behavior: team with greatest percent of initial participants completing program; highest quit rate at six months; highest abstinence rate at six months | Group 1) Control/ Comparison - non-competition sites, n= not reported | Significant Findings:
Klesges et al., 1987^70^ | | | | | Group 2) Competition sites, n=not reported | * Higher cessation rates for Group 2, 39% vs 16%, p<.01, at end of program
US | | | | | | * Six-month followup, no significant difference between groups
#096 | Simple | Cholesterol level | Lottery: microwave oven | Required behavior - show up for retest | Group 1) Control - no reminder of retest, n=1659 | No significant differences between groups:
Owen et al., 1990^73^ | | | | | Group 2) Reminder letter for retest, n=1648 | * Percent returning for retest
Australia | | | | | Group 3) Reminder letter + lottery ticket, n=1629 | * Cholesterol levels
| | | | | | * BMI
| | | | | | * Weight
#075 | Simple | AIDS prevention | 1) Cash incentive, three possible ($35 total) versus | Required behavior - attend educational sessions | Group 1) Money orders, n=1455 | Significant Findings:
Deren et al., 1994^52^ | | | 2) Grocery gift certificates, three possible ($35 total) | | Group 2) Grocery gift certificates, n=551 | * Difference in percent returning to initial session: Group 1- 83%, Group 2 - 66%, p<.001
US | | | | | | * Difference in percent attending at least one session: Group 1 - 50%, Group 2 - 36%, p<.01
#076 | Simple | STD prevention | “High value” coupons - 75% off purchase price | Required behavior - purchase package of 12 condoms | Group 1) Control - 10% off coupons | Significant Findings:
Dahl et al., 1999^101^ | | | | | Group 2) High value coupons, 75% off | * Widespread disbursement redemption rate: 0 control coupons vs 13 high value coupons, p<.01
US | | | | | | * No difference between in-store coupon redemption rates
#077 | Simple | HIV/STD prevention | 1) Cash incentive, two possible ($15 each) versus | Required behavior - attend one 90 minute group education session and one 60 minute individual session | Group 1) coupon incentives, n=160 | Significant Findings:
Kamb et al., 1998^64^ | | | 2) Coupons for goods and services, two possible ($15 each) | | Group 2) cash incentives, n=198 | * Difference in education participation rate, Group session: Group 1 - 46%, Group 2 - 67%, p<.0001 Both sessions: Group 1 - 37%, Group 2 - 55%, p<.0001
US | | | | | | * More enrolled in Group 2 - 31%, than Group 1 - 23%, p=.002
#092 | Simple | Smoking cessation | Lottery: dinner for two at a local restaurant | Required behavior - attend non-smoking clinic | Group 1) Control - received registration material for off-site cessation program, n=34 sites | No significant difference between groups in participation rates
Emont & Cummings, 1992^92^ | | | | | Group 2) Lottery ticket plus registration package, n=33 sites
US
#043 | Simple | Immunization | Must come to WIC offices monthly to pick up allotment of vouchers (normal every two months) | Required behavior - immunize child | Group 1) education and “referral”, n=281 | Significant Findings:
Birkhead et al., 1995^57^ | | | | | Group 2) education and escort to immunization, n=377 | * Increased immunization rate, Group 2 - RR 1.58, Group 3 - RR 1.44
US | | | | | 3) education and voucher disincentive, n=178 | * Shorter time to vaccination, Group 1- 45 days, Group 2 - 14 days, p<.001,Group 3 - 26 days, p<.001
#049 | Simple | Immunization | Lose AFDC benefits provided to nonimmunized child | Required Behavior - provide proof of immunization | Group 1) Control - usual care, n=1000 | Significant Findings:
Kerpelman et al., 2000^58^ | | | | | Group 2) Subject to sanction, n=1500 | * Group 2 had statistically significant (p<.05) and clinically meaningful higher coverage (6–7% points) for all five vaccines for all five years
US
#053 | Simple | Followup of abnormal pap | 1) Fee bus passes mailed out with reminders | Required behavior: for voucher, attend at least one followup visit. No requirement for free bus passes | Group 1) Control - usual follow-up | No significant differences between groups
Kaplan et al., 2000^100^ | | | 2) Voucher for $15 off a $40 clinic fee, redeemable by those at higher risk | | Group 2) Incentives and intensive contact
US
#034 | Simple | Immunization | 1) Free day care | Required Behaviors - | Group 1) Control (combined pure control n=119 completed, and attention control, n=108 completed) | Significant Findings (at two week followup):
Yokley & Glenwick, 1984^62^ | | | 2) Lottery of $25, $50, and $100 cash prizes | 1) Leave child at clinic for shots and day care period | Group 2) general prompt, n=124 | * Increased number of children receiving shots - Group 1 - 11 children, Group 4 - 20 children, Group 5 - 27 children, p<.05
US | | | | 2) Bring child in for shots | Group 3) personalized prompt, n=119 | * Increased number of children attending clinic - Group 1 - 13 children, Group 4 - 22 children, Group 5 - 32 children, p<.05
| | | | | Group 4) personal prompt + increased access (day care) n=125 | * Increased total number of shots - Group 1 - 22, Group 4 - 38, p<.05, Group 5 - 46, p<.05
| | | | | Group 5) personal prompt + lottery incentive n=120
#038 | Simple | Tuberculosis screening | 1) Cash Incentive of $10 | Required behavior - return for a reading of the Mantoux test | Group 1) Control, n=215 | Significant Findings:
Malotte et al., 1999^54^ | | | 2) Grocery gift certificate $10 | | Group 2) Cash incentive, n=217 | * Percent returned on time for reading: Group 1 - 49%, Group 2 - 95%, OR 19.2, CI 9.9–37.3, p<.001, Group 3 - 86%, OR 6.2, CI 3.9–9.8, p<.001, Group 4 - 83%, OR 4.9, CI 3.1–7.6, p<.001. Group 5 - 47%
US | | | 3) Free bus passes or fast food coupons for total of $10. | | Group 3) Grocery incentive, n=217 | * Group 2 vs Group 3, p=.002. Group 2 vs Group 4, p<.001
| | | | | Group 4) Choice of bus pass or fast food chain coupons, n=218
| | | | | Group 5) 5–10 minute motivational education session, n=214
#048 | Simple | Immunization | Lottery: Three $50 grocery gift certificates | Required behavior - receive shot at clinic | Group 1) Control, n=202 | Significant Findings:
Moran et al., 1996^63^ | | | | | Group 2) Educational brochure, n=198 | * Percent receiving shot, Group 1 - 20%, Group 2 - 36%, OR 2.29, CI 1.45–3.61, p=.0004, Group 3 - 29%, OR 1.68, CI 1.05 – 2.68, p=.0308, Group 4 - 26%, OR 1.41, non-significant
US | | | | | Group 3) Lottery incentive, n=198 | * For patients with no prior immunization history, only brochure was effective, p=.0002
| | | | | Group 4) Brochure + lottery, n=199
#054 | Simple | Followup: post-partum exam | Gift: Gerry Cuddler (unknown value) | Required behavior - attend post-partum appointment | Group 1) Control - appointment recommendation, n=132 | Significant Findings:
Stevens-Simon et al., 1994^56^ | | | | | Group 2) Recommendation and coupon for gift, n=108 | * Compliance at eight weeks; Group 1 - 52%, Group 2 - 71%, p=.002
US | | | | | | * Compliance at 12 weeks: Group 1 - 65%, Group 2 - 82%, p=.003
#055 | Simple | Followup: post-partum exam | 1) Coupon for infant formula (unknownn value) | Required behavior - attend post-partum appointment on assigned day | Group 1) Control, n=192 | Significant Findings:
Smith et al., 1990^55^ | | | 2) gift of jewelry (unknown value) | | Group 2) Infant formula coupon, n=149 | * Adherence rate: Group 1 - 22%, Group 2 - 37%, p<.003, Group 3 - 23%
US | | | | | Group 3) Jewelry gift, n=193 | * Controlling for ethnicity, Group B significance dropped to p=.07 for blacks
#094 | Simple | Prenatal care | 1) $5 department store gift certificate | Required behavior - attend prenatal and postpartum check | Group 1) Control - usual care, n=101 | No significant differences between groups for:
Laken & Ager, 1995^65^ | | | 2) $5 gift certificate + $100 raffle | | Group 2) Gift certificates for each prenatal appointment, n=51 | * Percent missed prenatal appointments
US | | | | | Group 3) Gift certificates for each visit + raffle, n=53 | * Percent attending post-partum appointment
| | | | | | * Length of gestation
| | | | | | * Birth weight
#106 | Simple | Tuberculosis screening | Cash Incentive 1) $5 | Required behavior - return for skin test reading | 2×3 factorial design. Education or no education by $0, $5, and $10 cash incentive | Significant Findings:
Malotte et al., 1998^53^ | | | Cash Incentive 2) $10 | | | * Odds ratio for $5 incentive = 11.2, $10 incentive = 24.5
US | | | | | | * Education was not significant
#044 | Simple | Immunization | Must come to WIC offices monthly to pick up allotment of vouchers (normal every three months) | Required behavior - immunize child | Group 1) Control - no immunization referral, n=2 sites | Significant findings:
Hutchins et al., 1999^110^ | | | | | Group 2) On-site nurse referral and incentive, n= 2 sites | * For enrolled children, coverage increased 10% at first birthday and 23% at second birthday for intervention groups. Control groups decreased 4% and 9% respectively, p<.05
US | | | | | Group 3) On-site clinic referral and incentive, n= 1 site | * For active WIC participants, increases for intervention groups was 52% by second year vs 2% for the control group
| | | | | Group 4) Off-site referral and incentive, n= 2 sites
#029 | Simple | Followup: cancer screening | Free postage | Required behavior - return completed fecal occult blood test within three months | Group 1) Control - return at next visit, n=49 | Significant Findings:
Freedman & Mitchell, 1994^59^ | | | | | Group 2) Return envelope provided, n=46 | * Increase in adherence rate, p=.003
US | | | | | Group 3) Stamped return envelope provided, n= 51 | Adherence rate: Group 1 - 37%, Group 2 - 57%, Group 3 - 71%
#037 | Simple | Immunization | Free flu shots (unknown value) | Required behavior - receive flu shot | Group 1) Control - usual care, n=930 | Significant Findings:
Satterthwaite, 1997^104^ | | | | | Group 2) Invitation letter, n=931 | * Increase in vaccination rate, p<0.001
New Zealand | | | | | Group 3) Invitation letter and free shot, n=930 | Vaccination rate: Group 1 - 17%, Group 2 - 27%, Group 3 - 45%
#047 | Simple | Immunization | Free flu shots ($40–$60 value) | Required behavior - receive flu shot | Group 1) Control - usual care, n=195 | Significant Findings:
Nexoe et al., 1997^78^ | | | | | Group 2) Invitation letter, n=195 | * Increase in vaccination rate, p<0.01
Denmark | | | | | Group 3) Invitation letter and free shot, n=195 | Vaccination rate: Group 1 - 25%, Group 2 - 49%, Group 3 - 72%
#051 | Simple | Followup: cancer screening | Free bus transportation ($2.00 to $2.90 value) | Nothing required - mailed with followup reminder; may be used for other purposes | 2×2×2 factorial table assignment totaling 8 groups. | Significant Findings:
Marcus et al., 1992^60^ | | | | | Three intervention factors: | * Improved loss-to-followup - transportation incentive p<.05, OR 1.48, CI 1.06 – 2.06
US | | | | | 1) personalized followup | * Sub-group - more likely for county (vs non-county) patients, p<.05, more severe pap score, p<.01, and non-insured, p<.01
| | | | | 2) educational video
| | | | | 3) transportation incentives
#052 | Simple | Followup: cancer screening | Voucher: $20 to $25 off clinic visit fee, about 2/3 price reduction, redeemable by non-insured patients, about 70% of pop | Required behavior - attend at least one followup visit | Group 1) Control, n=377 | Significant Findings:
Marcus et al., 1998^61^ | | | | | Group 2) Intensive contact follow-up, n=335 | * Improved loss-to-followup - Group 2 - OR 1.56, CI 1.12 – 2.17, p<.01, Group 3 - OR 1.50, CI 1.09 – 2.05, p<.01
US | | | | | Group 3) Voucher incentive, n=396 | * Regression analysis showed no interaction effect between two intervention factors
| | | | | Group 4) Intensive + incentive, n=345
#095 | Simple | Prenatal care | 1) Taxicab voucher | Required behavior - attend first prenatal clinic visit | Group 1) Control - usual care, n=35 | Significant Findings:
Melnikow et al., 1997^77^ | | | 2) Gift: baby blanket | | Group 2) Blanket incentive, n=35 | * Compliance with first appointment, Group 1 - 66%, Group 2 - 54%, Group 3 - 82%, Unadjusted OR 0.32 (CI 0.12 – 0.88)
US | | | | | Group 3) Taxi voucher, n=34 | * No significance difference for Group 2, blanket incentive
#042 | Simple | Cancer screening - mammography | Gift: Stay-fit Nutrition Kit (brochures and educational material valued at $2) | Required behavior - complete mammography | Group 1) Control - reminder postcard, n=91 | No significant difference, and change in wrong direction
Mayer et al., 1994^94^ | | | | | Group 2) Postcard and gift coupon, n=96 | * Percent difference in appointment keeping rate
US
#050 | Simple | Cancer screening - mammography | Gift: Stay-fit Nutrition Kit (brochures and educational material valued at $2) | Required behavior - complete mammography | Group 1) Control - information, n=49 | Significant Findings:
Mayer & Kellogg, 1989^95^ | | | | | Group 2) Information and coupon for gift package, n=47 | * Increase in appointment keeping rate, p<0.05
US | | | | | | Appointment rate:
| | | | | | Group 1 - 59%, Group 2 - 81%

Evidence Table 4. Provider populations

Article ID | Research Design | Prevention Category | Prevention Target | Provider Population | Group Size | Patient Population
First Author
Country
#001 | 3 year evaluation, before/after Study | Simple | MMR immunization, cholesterol screening | Primary care providers of a commercial IPA-HMO in northeastern US | Offices suggested to be majority solo practice (1–2 MDs) | HMO general population with office visits in northeastern US
Morrow et al., 1995^47^
US
#003 | RCT | Simple | Cancer screening | Primary care providers of a Philadelphia Medicaid IPA-HMO | Of practices, 31 solo, 21 group. | Medicaid covered women with office visits in Philadelphia
Hillman et al., 1998^45^
US
#004 | RCT | Simple | Flu immunization | Solo and group practices accepting Medicare in Monroe County, New York | Of practices, 28 solo, 28 group | Medicare patients with office visits - target lists by provider in Monroe County, NY
Kouides et al., 1998^49^ | | | | | Group sizes:
US | | | | | 2 MD = 11
| | | | | 3 MD = 6
| | | | | 4 MD = 5
| | | | | above 4 MD = 6
#005 | RCT | Simple | Child immunizations - up to date (UTD) coverage of scheduled shots | New York urban primary care practices servicing primarily Medicaid | | Medicaid covered children with office visits in urban NY
Fairbrother et al., 1999^43^
US
#006 | RCT | Simple | Child immunizations - up to date coverage of scheduled shots | New York urban primary care practices servicing primarily Medicaid | | Medicaid covered children with office visits in urban NY
Fairbrother et al., 2001^44^
US
#007 | RCT | Simple | Well child, including immunizations | Primary care providers of a Philadelphia Medicaid IPA-HMO | Of practices, 21 solo, 28 group | Medicaid covered children with office visits in Philadelphia
Hillman et al., 1999^46^
US
#008 | Time series | Simple | Child immunizations | General practice providers in Grampian, Scotland | Of practices, 23 solo, 71 group | Primary and preschool children in Grampian, Scotland
Ritchie et al., 1992^51^
UK
#011 | RCT | Simple | Cancer screening | GPs, family practice, internal medicine - small urban community practices in Dayton, Ohio, and Springfield, Massachusetts | Of practices, 39 solo, 56 group. | Women 50+; consecutive appointments
Grady et al., 1997^48^ | | | | | Group sizes:
US | | | | | 2 MD = 21; 3 MD = 5; 4 MD = 25; 5 MD =5
#018 | 3 year evaluation, before/after study | Simple | Prenatal care | Maryland providers of obstetric services | | Women continuously enrolled in Medicaid for one year and who delivered in final four months of the fiscal year
Fox & Phua, 1995^50^
US

Evidence Table 5. Consumer populations

Article ID | Research Design and Quality | Definition of Prevention | Prevention Target | Participants | Setting | Intervention | Follow-up Period
Author
Country
#029 | RCT | Simple | Cancer screening - fecal occult blood test | Consecutive patients at an internal medicine teaching clinic | Internal medicine teaching clinic | Free postage | 15 months
Freedman & Mitchell, 1994^59^ | Score = 4
US
#047 | RCT | Simple | Immunization | GP patients with medical indication for immunization | Solo practices | Free flu shots ($40–$60 value) | 1995 flu season
Nexoe et al., 1997^78^ | Score = 4
Denmark
#037 | RCT | Simple | Immunization | GP patients over 65 | 16 Auckland GP clinics | Free flu shots (unknown value) | One flu season
Satterthwaite, 1997^104^ | Score = 3
New Zealand
#043 | RCT | Simple | Immunization | Not immunized children, 12–59 months, of mothers enrolled in WIC | 6 New York city WIC offices with clinics | Must come to WIC offices monthly to pick up allotment of vouchers (normal every two months) | 8 months
Birkhead et al., 1995^57^ | Score = 3
US
#050 | RCT | Simple | Cancer screening - mammography | San Diego general population, TV recruitment for low-cost community program - 35+ years old, no previous mammogram | Mammography facilities in San Diego | Gift: stay-fit nutrition kit (brochures and educational material valued at $2) | 1 month
Mayer & Kellogg, 1989^95^ | Score = 2
US
#042 | RCT | Simple | Cancer screening - mammography | Women 50+ who were due for an annual mammography | Mammography facility in San Diego | Gift: stay-fit nutrition kit (brochures and educational material valued at $2) | 2 months
Mayer et al., 1994^94^ | Score = 2
US
#055 | RCT | Simple | Post-partum exam | Teen mothers who delivered at a Houston City-county hospital, low SES | Teen health clinic of a Houston-city county hospital | 1) Coupon for infant formula (unknown value) | 1 year
Smith et al., 1990^55^ | Score = 2 | | | | | 2) Gift of jewelry (unknown value)
US
#054 | RCT | Simple | Post-partum exam | Consecutively enrolled pregnant teens participating in the Colorado Adolescent Maternity Program, low SES | Unclear type of clinic setting | Gift: Gerry Cuddler (unknown value) | 12 weeks; unclear study period
Stevens-Simon et al., 1994^56^ | Score = 4
US
#032 | RCT | Complex | Smoking cessation | Patients, aged 25–64, smoke more than 15 cigarettes per day and expressed interest to quit | East Lancashire GP clinics | Free nicotine patches for 12 weeks | 12 weeks NRT + 2 weeks followup
Dey et al., 1999^103^ | Score = 2
UK
#076 | Quasi-experimental | Simple | STD prevention | Sexually active young adults, age 18–30; convenience populations from public gathering places and drug stores | Distributed at | “High value” coupons - 75% off purchase price | 4 months
Dahl et al., 1999^101^ | Score = 2 | | | | 1) public gathering places, “widespread disbursement” and
US | | | | | 2) drug stores “in-store disbursement”
#077 | Quasi-experimental | Simple | HIV/STD prevention | Patients attending five inner-city STD clinics | Atlanta, Georgia, STD clinics | 1) Cash incentive, 2 possible ($15 each) versus | 3 weeks;
Kamb et al., 1998^64^ | Score = 2 | | | | | 2) Coupons for goods and services, 2 possible ($15 each) | 2 years
US
#082 | RCT | Complex | Exercise | Patient list of GP located in SES disadvantaged area, 40–64 year olds not previously engaged in an exercise program | Fitness facilities and community centers | Coupons: 1 free use of fitness center, up to 6 possible | 18 months
Harland et al., 1999^99^ | Score = 2
UK
#061 | RCT | Complex | Cholesterol level | Voluntary participants with Cholesterol >200 at a health fair for a Kansas School District Union | Worksite fitness program | Lottery: 5 $100 cash prizes. | 6 months
Francisco et al., 1994^93^ | Score = 2 | | | | | 5 in 29 chance if all participants make goal
US
#049 | RCT | Simple | Immunization | Families with preschool children receiving AFDC, in Muscogee, Georgia | General community; government offices | Lose AFDC benefits provided to non-immunized child | 4 years
Kerpelman et al., 2000^58^ | Score = 2
US
#075 | Quasi-experimental | Simple | AIDS Prevention | Intravenous drug users (IDU) and sexual partners of IDUs recruited in Harlem and Cleveland outreach programs | Neighborhood AIDS outreach sites | 1) Cash incentive, 3 possible ($35 total) versus | Harlem: May - Dec 1989
Deren et al., 1994^52^ | Score = 2 | | | | | 2) Grocery gift certificates, 3 possible ($35 total) | Cleveland: Apr 1989 to Nov 1990
US
#051 | RCT | Simple | Followup of abnormal pap | Female patients of Los Angeles county primary health care clinics. Low SES, 69% non-white, majority Hispanic | Mixed settings, county hospital outpatient clinics, community clinics, University clinics, 12 in all | Free bus transportation ($2.00 to $2.90 value) | 2 years
Marcus et al., 1992^60^ | Score = 3
US
#052 | RCT | Simple | Followup of abnormal pap | Female patients of Los Angeles county primary health care clinics. Low SES, 84% Hispanic | Two county hospitals with two outpatient clinics each | Voucher: $20 to $25 off clinic visit fee, about 2/3 price reduction, redeemable by non-insured patients, about 70% of population | 44 months
Marcus et al., 1998^61^ | Score = 3
US
#034 | RCT | Simple | Immunization | Immunization deficient pre-school children of a public health clinic in a medium-sized Midwest city | Urban public health clinic | 1) Free day care | 3 months
Yokley & Glenwick, 1984^62^ | Score = 1 | | | | | 2) 1 Lottery of $25, $50, and $100 cash prizes
US
#038 | RCT | Simple | Tuberculosis screening | Active drug users from Long Beach, California, with no previous TB history | Urban store-front research facility in downtown | 1) Cash Incentive of $10 | 2 years
Malotte et al., 1999^54^ | Score = 3 | | | | | 2) Grocery gift certificate $10
US | | | | | | 3) Free bus passes or fast food coupons for total of $10
#048 | RCT | Simple | Immunization | Patients, seen within last 18 months, high - risk for flu, of an urban community health center, generally lower SES | Urban community health center | Lottery : 3 $50 grocery gift certificates | 1991-92 flu season
Moran et al., 1996^63^ | Score = 2
US
#078 | RCT | Complex | Exercise | Overweight women, age 25–55, recruited from Minneapolis general population through newspaper ads | Community center and park grounds | Lottery: one $50 gift certificate (unknown type) at each exercise session and one $2,000 travel certificate | 24 weeks
Wing et al., 1996^91^ | Score = 2
US
#071 | RCT | Complex | Obesity prevention | Men and women of Twin City metro area, recruited through newspaper and flyers. Also targeted women on WIC | Health department sites and community settings | Lottery: $100, one per month for a 1 in 10 chance over three years | 3 years
Jeffery & French, 1999^74^ | Score = 3
US
#072 | RCT | Complex | Weight loss | General population at two sites, Minneapolis/St. Paul, Minnesota, and Pittsburgh, Pennsylvania, recruited through media advertising | Community centers | Cash Incentive: Graduated payments of $1 to $3 per exercise session, paid monthly, 222 total possible walks, $266 potential total per person | 18 months
Jeffery et al., 1998^97^ | Score = 3
US
#069 | RCT | Complex | Weight loss | General population at two sites, Minneapolis/St. Paul, Minnesota, and Pittsburgh, Pennsylvania, recruited through media advertising | Unclear | Cash incentive: minimum of $12.50 to maximum of $25 per week depending on percent of goal attained, 20 weeks total | 18 months
Jeffery, Wing et al., 1993^142^ | Score = 3
US
#044 | RCT | Simple | Immunization | Chicago WIC population, majority black, Hispanic, and receiving other federal assistance | Chicago WIC sites, four run by Chicago department of health, three by community agencies | Must come to WIC offices monthly to pick up allotment of vouchers (normal every three months) | 2 years
Hutchins et al., 1999^110^ | Score = 2
US
#062 | RCT | Complex | CVD prevention | Employees of 28 ambulance services. 85% male, average of 32 years old, 25% with greater than high school education | Worksite | Lottery + competition: two lottery draws for $40, $40 for meeting three month goal, 1 in 4 chance at $1,000 prize for station with highest percent meeting goals | 18 months
Gomel et al., 1993^69^ | Score =2
New Zealand
#065 | Quasi-experimental | Complex | Smoking cessation | Aerospace industry workers in California, regular tobacco users. 57% male, average of 38 years old, 75% white, 65% with greater than high school education | Worksite | Cash + competition: workers paid $50 to participate, rewarded $15/month of abstinence for up to five months, plus first place team wins up to $1,980 (split five ways), 1 in 13 chance to win | 12 months
Koffman et al., 1998^68^ | Score = 2
US
#066 | RCT | Complex | Smoking cessation/ obesity | Employees of 32 diverse worksites from the Minneapolis/St. Paul, Minnesota, area - from manufacturing to public sector to insurance industry | Worksite | Monetary contract: money withheld from paycheck, minimum of $5 per check; if goal is met, money returned to employee | 3 years
Jeffery, Forster, French et al., 1993^105^ | Score = 2
US
#074 | RCT | Complex | Breast-feeding | Pregnant women without other children, Flagstaff, Arizona WIC clinic patients | WIC clinics | Gifts and raffles of high frequency and considerable value - from $15 hair cuts to raffle for trip for two on Grand Canyon Railway | 3 months post partum
Sciacca et al., 1995^66^ | Score = 2
US
#084 | Quasi-experimental | Complex | Smoking cessation | Employees of Texas Department of Human Services located in Austin, Houston, and San Antonio | Worksite | Prize + competition: Cold turkey buffet; participants (smokers and non-smoking supporters) were charged a $5 incentive fee which was pooled and refunded to winning worksites | Unclear
Gottlieb & Nelson, 1990^71^ | Score = 2
US
#079 | RCT | Complex | Smoking cessation | Pregnant smokers (“even a puff”) over age 15, WIC eligible | WIC program offices | Cash: $50 per month for each abstinent month, maximum of 10 months, pre-term + 2 months post-partum
Donatelle et al., 2000^67^ | Score = 3
US
#053 | Quasi-experimental | Simple | Followup of abnormal pap | Low SES, majority Hispanic, female patients of Los Angeles County Department of Health Services (LACDHS) | LACDHS clinics | 1) Free bus passes mailed out with reminders
Kaplan et al., 2000^100^ | Score = 1 | | | | | 2) Voucher for $15 off a $40 clinic fee, redeemable by those at higher risk
US
#109 | RCT | Complex | Smoking cessation | Smoking members of GHCPS, 65% women, recruited through GHCPS's bi-monthly health magazine | Homes of members of Group Health Cooperative of Puget Sound | Gift: Ceramic coffee mug at the end of first two program units. | 12 months
Curry et al., 1991^72^ | Score = 3 | | | | | Lottery: All-expense-paid one-week trip for two to Hawaii, expense-paid weekend at San Juan Island resort, weekend at a deluxe hotel in downtown Seattle
US | | | | | | Bonus entries for returning second two program units
#110 | Quasi-experimental | Complex | Smoking cessation | Employees of firms of diverse industries, ranging from 50 to 380 employees, 53% male | Worksite | Prize + competition: within site competition between teams, prizes of $5 to $15 per participant | 6 months
Klesges et al., 1987^70^ | Score = 2
US
#089 | RCT | Complex | Nutrition | Pregnant, lactating, or mothers of young children, WIC and population from a local Genesee County, Michigan food program agency | WIC and CSFP offices, local farmer's market | Coupons: fresh produce from farmers' markets, $20 total | 5 months
Anderson et al., 2001^102^ | Score = 2
US
#091 | RCT | Complex | Smoking cessation | Patients, presenting for appointments, from rural family practices, 18 years or older, daily smokers not identified as ready to quit | Rural family practices, teaching facilities, University of Vermont | Free or reduced price for nicotine gum; $0, $6 or $20 vs. full price of $24 | 6 months
Hughes et al., 1991^76^ | Score = 2
US
#092 | Quasi-experimental | Simple | Smoking cessation | Employees of 68 auto dealerships in western New York state, 3/4 male, mean age 35 | Worksite | Lottery: dinner for two at a local restaurant | Unclear
Emont & Cummings, 1992^92^ | Score = 2
US
#094 | RCT | Simple | Prenatal care | Low SES prenatal care patients of a local clinic, Detroit, Michigan | Urban clinic | 1) $5 department store gift certificate | Unclear
Laken & Ager, 1995^65^ | Score = 3 | | | | | 2) $5 gift certificate + $100 raffle
US
#095 | RCT | Simple | Prenatal care | Newly confirmed pregnant women who intended to use a system of clinics in northern California, low SES, 45% non-white | Family planning clinics | 1) Taxicab voucher | 2 years
Melnikow et al., 1997^77^ | Score = 3 | | | | | 2) Gift: baby blanket
US
#096 | RCT | Simple | Cholesterol level | Respondents to a community-based screening program with elevated cholesterol | 12 regional government health education service sites, one worksite | Lottery: microwave oven | 4 months
Owen et al., 1990^73^ | Score = 2
Australia
#102 | RCT | Complex | Weight loss | Overweight men and women recruited from self-referred (through media) and community sources | Unclear | Contract 1: Return $30 for every 5 pound reduction, total of $150. | 16 week program plus 1 year maintenance
Jeffery et al., 1984^107^ | Score = 2 | | | | | Contract 2: Return $5, $10, $20, $40, $75 for successive 5 pound reductions
US
#103 | RCT | Complex | Weight loss | Overweight middle-class men, aged 35 – 57, ineligible for MRFIT, a community population sample, recruited by letter | Unclear | Contracts: Refunds of $1, $5, or $10 per pound ($30, $150, or $300 total). Forfeit money split between participants who made goal | 15 week education program plus 1year followup
Jeffery et al., 1983^108^ | Score = 3
US
#104 | RCT | Complex | Weight loss | Overweight men and women recruited by media from the general population | Unclear | Contract: Return $200, $20 per week for 10 weeks, deposited if 1) attended meetings, 2) met calorie restriction goal, or 3) met weight loss goal | 10 weeks
Jeffery et al., 1978^106^ | Score = 2
US
#105 | RCT | Complex | Smoking cessation | Smokers, 83% female, recruited from bulletins posted in a large metropolitan hospital | Urban hospital | Cash Incentive of $0, $1, $5, or $10 per day | 6 weeks
Stitzer & Bigelow, 1983^75^ | Score = 3
US
#106 | RCT | Simple | Tuberculosis screening | Active drug users from Long Beach, California, with no previous TB history | Urban store-front research facility in downtown | Cash Incentive 1) $5 | 17 months
Malotte et al., 1998^53^ | Score = 3 | | | | | Cash Incentive 2) $10
US
#107 | RCT | Complex | Weight loss | Employees of a general hospital, 85% female, from 10% to 113% overweight | Worksite | Contract: Return $5 per session, 14 sessions | 18 weeks
Follick et al., 1984^109^ | Score = 3 | | | | | Cash: Forfeit money split between subjects who hadn't forfeited
US
#108 | RCT | Complex | Smoking cessation | Employees of University of Alabama, regular smokers | Worksite | Cash Incentive of $25 at 6 weeks and $25 at 6 months | 3 years
Windsor et al., 1988^96^ | Score = 2
US

Evidence Table 6. Description of provider incentives

Article ID | Intervention | Tournament vs. All Qualify | Bonused for Outcome or Behavior | Penalty | Individual Performance Known to Group? | Adequacy | Pay out
Author
Country
#001 | Capitation rates adjusted by quality of care performance measures; audit determines following year cap rate | All qualify | Outcome | No | Yes | Unknown | Unknown
Morrow et al., 1995^47^
US
#003 | Performance bonus - target outcome. 20% of capitation for three highest aggregate compliance scores; 10% for next three highest and three offices most improved | Tournament | Indirect | No | Yes | 1) $570 – $1,260 per site; $775 average | $13,175
Hillman et al., 1998^45^ | | | | | | 2) 17 sites received at least one bonus
US | | | | | | 3) 6–9 of 26 sites
#004 | Performance bonus - target outcome. 10% additional reimbursement per shot provided if ≤ 70% immunization rate. 20% if ≤85% | All qualify | Outcome | No | No | $242 average bonus | $4,362
Kouides et al., 1998^49^
US
#005 | Group 2) performance bonus - target outcome $1,000 for 20% increase in UTD, $2,500 for 40%, $5,000 for reaching 80% coverage. | All qualify | Outcome | No | Unknown | Unknown | Unknown
Fairbrother et al., 1999^43^ | Group 3) Per-input bonus $5 per administered shot and $15 per office visit with completed coverage
US
#006 | Group 2) performance bonus - target outcome $1,000 for 20% increase in UTD, $2,500 for 40%, $5,000 for reaching 80% coverage. | All qualify | Outcome | No | Unknown | Unknown. | Unknown
Fairbrother et al., 2001^44^ | Group 3) Per-input bonus $5 per administered shot and $15 per office visit with completed coverage | | | | | Hypothetical calculation showed MDs wouldn't qualify with 80% level even if no missed opportunities to provide shots
US
#007 | Performance bonus - target outcome. 20% of capitation for three highest aggregate compliance scores; 10% for next three highest and three offices most improved; $500 minimum | Tournament | Indirect | No | Yes | $772 – $4,682 per site; average bonus $2,000. 13 of 19 sites received at least one bonus; 16 sites received two | Unknown
Hillman et al., 1999^46^
US
#008 | Target payment - lump sum payment at 70% and 90% coverage levels; implemented 1990 | All qualify | Outcome | Yes | Yes | Unknown | Unknown
Ritchie et al., 1992^51^
UK
#011 | Performance bonus - target behavior; token bonus of $50 for 50% mammography referral rate | All qualify | Outcome | No | Yes | Very small token | Unknown
Grady et al., 1997^48^
US
#018 | Raised fees for delivery from $265 to $795 and prenatal visits from $17 to $21 | All qualify | Behavior | No | Not applicable | Unknown | Unknown
Fox & Phua, 1995^50^
US

Evidence Table 7. Reported cost of interventions

Article ID | Definition of Prevention | Prevention Target | Intervention | Incentive Condition | Group Assignment | Outcomes | Cost-Effectiveness
Author
Country
#029 | Simple | Cancer screening - fecal occult blood test | Free postage | Required behavior: return completed fecal occult blood test within three months | Group 1) Control - return at next visit, n=49 | Significant findings: | Cost per completed kit:
Freedman & Mitchell, 1994^59^ | | | | | Group 2) Return envelope provided, n=46 | * Increase in adherence rate, p=.003 | Group 1 - $2.24
US | | | | | Group 3) Stamped return envelope provided, n= 51 | Adherence rate: | Group 2 - $1.61
| | | | | | Group 1 - 37% | Group 3 - $1.71
| | | | | | Group 2 - 57%
| | | | | | Group 3 - 71%
#047 | Simple | Immunization | Free flu shots ($40–$60 value) | Required behavior: receive flu shot | Group 1) Control - usual care, n=195 | Significant findings: | Cost per prevented death:
Nexoe et al., 1997^78^ | | | | | Group 2) Invitation letter, n=195 | * Increase in vaccination rate, p<0.01 | Group 2 - $3,990
Denmark | | | | | Group 3) Invitation letter and free shot, n=195 | Vaccination rate: | Group 3 - $17,860
| | | | | | Group 1 - 25%
| | | | | | Group 2 - 49%
| | | | | | Group 3 - 72%
#034 | Simple | Immunization | 1) Free day care | Required behaviors: | Group 1) Control (combined pure control n=119 completed, and attention control, n=108 completed) | Significant findings (at 2 week followup): | Cost per target child receiving shot after 3 months:
Yokley & Glenwick, 1984^62^ | | | 2) Lottery of $25, $50, and $100 cash prizes | 1) Leave child at clinic for shots and day care period, | Group 2) general prompt, n=124 | * Increased number of children receiving shots: | Group 2 $3.64,
US | | | | 2) Bring child in for shots | Group 3) personalized prompt, n=119 | Group 1 - 11 children | Group 3 $2.27,
| | | | | Group 4) personal prompt + increased access (day care) n=125, | Group 4 - 20 children | Group 4 $6.28
| | | | | Group 5) personal prompt + lottery incentive n=120 | Group 5 - 27 children, p<.05. | Group 5 $6.91
| | | | | | * Increased number of children attending clinic:
| | | | | | Group 1 - 13 children
| | | | | | Group 4 - 22 children
| | | | | | Group 5 - 32 children p<.05.
| | | | | | * Increased total number of shots:
| | | | | | Group 1 - 22
| | | | | | Group 4 - 38, p<.05
| | | | | | Group 5 - 46, p<.05
#048 | Simple | Immunization | Lottery: Three $50 grocery gift certificates | Required behavior: receive shot at clinic | Group 1) Control, n=202 | Significant findings: | Cost per additional immunization:
Moran et al., 1996^63^ | | | | | Group 2) Educational brochure, n=198 | * % receiving shot: | $3.45 for brochure, $8.74 for incentive
US | | | | | Group 3) Lottery incentive, n=198 | Group 1 - 20%
| | | | | Group 4) brochure + lottery, n=199 | Group 2 - 36%, OR 2.29, CI 1.45–3.61, p=.0004, Group 3 - 29%, OR 1.68, CI 1.05 – 2.68, p=.0308, Group 4 - 26%, OR 1.41, non-significant
| | | | | | * For patients with no prior immunization history, only brochure was effective, p=.0002
#044 | Simple | Immunization | Must come to WIC offices monthly to pick up allotment of vouchers (normal every three months) | Required behavior: immunize child | Group 1) Control - no immunization referral, n=2 sites | Significant findings: | Cost per additional up-to-date child:
Hutchins et al., 1999^110^ | | | | | Group 2) On-site nurse referral and incentive, n= 2 sites | * For enrolled children, coverage increased 10% at first birthday and 23% at second birthday for intervention groups. Control groups decreased 4% and 9% respectively, p<.05. | Year 1:
US | | | | | Group 3) On-site clinic referral and incentive, n= 1 site | * For active WIC participants, increase for intervention groups was 52% by second year vs. 2% for the control group | off-site = $51
| | | | | Group 4) Off-site referral and incentive, n= 2 sites | | on-site = $111
| | | | | | | nurse = $164
| | | | | | | Year 2:
| | | | | | | off-site = $13
| | | | | | | on-site = $7
| | | | | | | nurse = $21
#062 | Complex | CVD prevention | Prize + competition: Two lottery draws for $40, $40 for meeting three month goal, 1 in 4 chance at $1,000 prize for station with highest percent meeting goals | Required behavior: self-reported progress toward or meeting lifestyle change goals | Group 1) Control - health risk assessment (hra) n=115 completed | Significant Findings: | In active phase Group 4 least cost-effective. Not effective by 12 month maintenance stage.
Gomel et al., 1993^69^ | | | | | Group 2) hra + risk factor education n=70 completed | * BMI, body fat %, mean blood pressure, aerobic capacity, quit rates - Group 4 usually had strong response within 6 months but relapsed to initial levels by 12 months | Reported under separate study.^143^
New Zealand | | | | | Group 3) hra + behavioral counseling n=102 completed
| | | | | Group 4) hra + counseling + incentive n=77
#091 | Complex | Smoking cessation | Free or reduced price for nicotine gum; $0, $6, or $20 vs. full price of $24 | Required behavior: purchase gum | Group 1) Free gum, n=32 | Significant findings: | Financial gain to insurance company per subject enrolled:
Hughes et al., 1991^76^ | | | | | Group 2) $6/box gum, n=36 | * Decreased cost increased several measures of incidence of obtaining gum and long-term use, p<.05 to p<.006 | Free - $1,120
US | | | | | Group 3) $20/box gum, n=38 | *Price elasticity higher for $6 vs. $20 (.45) than free vs. $6 (.21) | $6/box - $280
| | | | | | * Decreased cost had non-significant trend to increase cessation | $20/box - $413