# Appendix E. Algorithm

Domain Elements | Score (1–5 (poor -appropriate) | Importance Category
Study Data Structure: ___ Cross-Section ___ Cross Section/Time Series
1. Is there an appropriate control group in the data? | | 1
2. Can the treatment be viewed as independent of factors unobserved to the researcher or did the researcher employ appropriate methods to correct for selection/attrition/omitted variable bias in the treatment? | | 1
3. Does the study's conclusions follow from the statistical estimates? | | 1
4. Is the set of control variables appropriate? | | 2
5. How closely does the study's objective(s) match the research issue of interest? | | 2
6. How representative of the relevant population is the sample population? | | 2
7. Are the outcome variables reliable measures of the outcome of interest? | | 2
8. Are the treatment variables reliable measures of the intervention of interest? | | 2
9. Are the statistical methods for estimating the effect of the treatment appropriate given the nature of the data? | | 2
10. How precise are the coefficient estimates? | | 2
11. Are the standard errors appropriately calculated given the estimation methodology and the structure of the data? | | 2
Study Category

Study Category:

1. Very Informative (a score of at least 4 in all importance category 1 segments and a mean of 4 across the remaining segments)

2. Informative but questions remain on generalizablity of findings (mean score of 3.5 across all categories and at least a 3 in all categories)

3. Not Informative (all other)