# Appendix B. Exact Search Strings

## Literature Search Strategy—MEDLINE^®^

Number | Search History | Results
1 | Reimbursement, Incentive | 687
2 | Capitation Fee | 3628
3 | Physician Incentive Plans | 1096
4 | Physician's Practice Patterns | 12718
5 | incent$ | 6243
6 | Income | 30787
7 | Reimbursement Mechanisms | 18969
8 | Fees, Medical | 4601
9 | Cost Sharing | 1684
10 | Choice Behavior | 14434
11 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 | 86379
12 | Preventive Health Services | 149047
13 | Preventive Medicine | 12582
14 | Primary Prevention | 68204
15 | Health Promotion | 20460
16 | Health Behavior | 41883
17 | Patient Compliance | 23515
18 | Prenatal Care | 11371
19 | 12 or 13 or 14 or 15 or 16 or 17 or 18 | 323248
20 | 11 and 19 | 4649
21 | Limit to English language | 4400
22 | Limit to year 1966-2002, human, non-dentistry | 3804