# Appendix A. Technical Expert Panel Members and Reviewers

## Technical Expert Panel Members

We are indebted to the Technical Expert Panel Members for providing both consultation during the development of this project and feedback on the initial draft.

- Douglas Conrad, PhD, MBA, MHA
- Director, Center for Health Management Research
- University of Washington
- Seattle, WA

- James Fries, MD
- Professor of Medicine
- Stanford University School of Medicine
- Palo Alto, CA

- Nicole Lurie, MD, MSPH
- Senior Natural Scientist and Alcoa Professor of Policy Analysis
- RAND
- Arlington, VA

- Dave Meltzer, MD, PhD
- Section of General Internal Medicine
- Harris Graduate School of Public Policy Studies
- University of Chicago, Department of Economics
- Chicago, IL

- Paul Shekelle, MD, PhD, MPH
- Southern California Evidence Based Practice Center
- RAND
- Santa Monica, CA

## Reviewers

We are grateful for the constructive feedback provided by the following individuals who reviewed the initial draft of this report. Acknowledgements are made with the explicit statement that this does not constitute endorsement of the report.

- David Atkins, MD
- Agency for Healthcare Research and Quality
- Rockville, MD

- Brian S. Armour, PhD
- Centers for Disease Control and Prevention
- Atlanta, GA
- James Bare
- American Academy of Family Physicians
- Leawood, KS

- Charles M. Cutler, MD, MS
- American Association of Health Plans
- Washington, DC

- Peter Franks, MD
- Family and Community Medicine
- University of California - Davis
- Davis, CA

- Jonathan D. Klein, MD, MPH
- Pediatric Adolescent Medicine
- University of Rochester
- Rochester, NY

- Thomas G. McGuire, PhD
- Department of Health Care Policy
- Harvard Medical School
- Boston, MA

- C. Tracy Orleans, PhD
- Robert Wood Johnson Foundation
- Princeton, NJ