# Listing of Excluded Studies

(reason for exclusion is provided in italics following each reference)

Baranowski T, Simons-Morton B, Hooks P, Henske J, Tiernan K, Dunn J K, Burkhalter H, Harper J, Palmer J. ((1990)). A center-based program for exercise change among black-American families. Health Education Quarterly.
Multi-component intervention
Bond L, Davie G, Carlin J B, Lester R, Nolan T. ((2002)). Increases in vaccination coverage for children in child care 1997 to 2000: an evaluation of the impact of government incentives and initiatives. Australian & New Zealand Journal of Public Health.
Not randomized, controlled
Bowers T G, Winett R A, Frederiksen L W. ((1987)). Nicotine fading behavioral contracting and extended treatment: effects on smoking cessation. Addictive Behaviors.
Multi-component intervention
Breen N, Feuer E J, Depuy S, Zapka J. ((1997)). The effect of Medicare reimbursement for screening mammography on utilization and payment. National Cancer Institute Breast Cancer Screening Consortium. Public Health Reports.
Not randomized, controlled
Cherkin D C, Grothaus L, Wagner E H. ((1990)). The effect of office visit copayments on preventive care services in an HMO. Inquiry.
System incentives
Coleman T, Wynn A T, Barrett S, Wilson A, Adams S. ((2001)). Intervention study to evaluate pilot health promotion payment aimed at increasing general practitioners' antismoking advice to smokers. BMJ.
Not randomized, controlled
Cox, C. C., Hooper, J., & Telleen, K. (2000). Private sector worksite health promotion programs in Missouri: a comparison with national survey findings and Healthy People recommendations. American Journal of Health Promotion., 14(3), 174–178, iii.
Not randomized, controlled
Fletcher S W, Harris R P, Gonzalez J J, Degnan D, Lannin D R, Strecher V J, Pilgrim C, Quade D, Earp J A, Clark R L. ((1993)). Increasing mammography utilization: a controlled study. Journal of the National Cancer Institute.
Multi-component intervention
Fries J F, Bloch D A, Harrington H, Richardson N, Beck R. ((1993)). Two-year results of a randomized controlled trial of a health promotion program in a retiree population: the Bank of America Study.[comment]. American Journal of Medicine.
Not on target
Glanz K, Lew R A, Song V, Murakami-Akatsuka L. ((2000)). Skin cancer prevention in outdoor recreation settings: effects of the Hawaii SunSmart Program. Effective Clinical Practice.
Multi-component intervention
Glasgow R E, Hollis J F, Pettigrew L, Foster L, Givi M J, Morrisette G. ((1991)). Implementing a year-long worksite-based incentive program for smoking cessation. American Journal of Health Promotion.
Not randomized, controlled
Hahn D L. ((1999)). The delivery of clinical preventive services: acute care intervention. Journal of Family Practice.
Not randomized, controlled
System incentive
Hickson G B, Altemeier W A, Perrin J M. ((1987)). Physician reimbursement by salary or fee-for-service: effect on physician practice behavior in a randomized prospective study. Pediatrics.
Not on target
Hoekstra E J, LeBaron C W, Johnson-Partlow T. ((1999)). Does reminder-recall augment the impact of voucher incentives on immunization rates among inner-city infants enrolled in WIC? Special Supplemental Program for Women Infants and Children. Journal of Pediatrics.
Not on target
Hueston W J, Mainous A G, Farrell J B. ((1994)). Childhood immunization availability in primary care practices. Effects of programs providing free vaccines to physicians.[comment]. Archives of Family Medicine.
Not on target
Hughart N, Vivier P, Ross A, Strobino D, Holt E, Hou W, Guyer B. ((1997)). Are immunizations an incentive for well-child visits?. Archives of Pediatrics & Adolescent Medicine.
Not on target
Jason L A, Jayaraj S, Blitz C C, Michaels M H, Klett L E. ((1990)). Incentives and competition in a worksite smoking cessation intervention. American Journal of Public Health.
Multi-component intervention
Jason L A, Lesowitz T, Michaels M, Blitz C, Victors L, Dean L, Yeager E, Kimball P. ((1989)). A worksite smoking cessation intervention involving the media and incentives. American Journal of Community Psychology.
Multi-component intervention
Jeffery R W, French S A. ((1997)). Preventing weight gain in adults: design methods and one year results from the Pound of Prevention study. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity.
Duplicate
Jeffery R W, Pheley A M, Forster J L, Kramer F M, Snell M K. ((1988)). Payroll contracting for smoking cessation: a worksite pilot study. American Journal of Preventive Medicine.
Multi-component intervention
Jeffrey R W, Forster J L, Baxter J E, French S A, Kelder S H. ((1993)). An empirical evaluation of the effectiveness of tangible incentives in increasing participation and behavior change in a worksite health promotion program. American Journal of Health Promotion.
Duplicate
Katz K S, El-Mohandes P A, Johnson D M, Jarrett P M, Rose A, Cober M. ((2001)). Retention of low income mothers in a parenting intervention study. Journal of Community Health.
Not on target
Keeler E B, Sloss E M, Brook R H, Operskalski B H, Goldberg G A, Newhouse J P. ((1987)). Effects of cost sharing on physiological health health practices and worry. Health Services Research.
System incentives
Kouides R W, Lewis B, Bennett N M, Bell K M, Barker W H, Black E R, Cappuccio J D, Raubertas R F, LaForce F M. ((1993)). A performance-based incentive program for influenza immunization in the elderly. American Journal of Preventive Medicine.
Not randomized, controlled
Krieger J W, Connell F A, LoGerfo J P. ((1992)). Medicaid prenatal care: a comparison of use and outcomes in fee-for-service and managed care. American Journal of Public Health.
System incentive
LeBaron C W, Starnes D, Dini E F, Chambliss J W, Chaney M. ((1998)). The impact of interventions by a community-based organization on inner-city vaccination coverage: Fulton County Georgia 1992-1993.[comment]. Archives of Pediatrics & Adolescent Medicine.
Multicomponent intervention
Leibowitz A, Manning W G, Keeler E B, Duan N, Lohr K N, Newhouse J P. ((1985)). Effect of cost-sharing on the use of medical services by children: interim results from a randomized controlled trial. Pediatrics.
System incentive
Ludwig-Beymer P, Hefferan C. ((2001)). Evaluation of Baby Advocate a childhood immunization reminder system. Journal of Nursing Care Quality.
Not randomized, controlled
Lurie N, Manning W G, Peterson C, Goldberg G A, Phelps C A, Lillard L. ((1987)). Preventive care: do we practice what we preach?. American Journal of Public Health.
System incentive
Maheu M M, Gevirtz R N, Sallis J F, Schneider N G. ((1989)). Competition/cooperation in worksite smoking cessation using nicotine gum. Preventive Medicine.
Multi-component intervention
Manning W G, Leibowitz A, Goldberg G A, Rogers W H, Newhouse J P. ((1984)). A controlled trial of the effect of a prepaid group practice on use of services. New England Journal of Medicine.
System incentive
Merkel P A, Caputo G C. ((1994)). Evaluation of a simple office-based strategy for increasing influenza vaccine administration and the effect of differing reimbursement plans on the patient acceptance rate. Journal of General Internal Medicine.
Not randomized, controlled
Oldenburg B, Owen N, Parle M, Gomel M. ((1995)). An economic evaluation of four work site based cardiovascular risk factor interventions. Health Education Quarterly.
Duplicate
Pescatello L S, Murphy D, Vollono J, Lynch E, Bernene J, Costanzo D. ((2001)). The cardiovascular health impact of an incentive worksite health promotion program. American Journal of Health Promotion.
Multi-component intervention
Poole K, Kumpfer K, Pett M. ((2001)). The impact of an incentive-based worksite health promotion program on modifiable health risk factors. American Journal of Health Promotion.
Multi-component intervention
Reid G S, Robertson A J, Bissett C, Smith J, Waugh N, Halkerston R. ((1991)). Cervical screening in Perth and Kinross since introduction of the new contract.[comment]. BMJ.
Not randomized, controlled
Schwab R A, Radakovich R, Tate K. ((2002)). Does payment improve follow-up of pelvic inflammatory disease?. Missouri Medicine.
Not on target
Solanki G, Schauffler H H, Miller L S. ((2000)). The direct and indirect effects of cost-sharing on the use of preventive services. Health Services Research.
Not randomized, controlled
Stachnik T, Brown B, Hinds W, Mavis B, et al. ((1990)). Goal setting social support and financial incentives in stress management programs: A pilot study of their impact on adherence. American Journal of Health Promotion.
Not randomized, controlled
Stein A D, Karel T, Zuidema R. ((1999)). Carrots and sticks: Impact of an incentive/disincentive employee flexible credit benefit plan on health status and medical costs. American Journal of Health Promotion.
System incentive
Stevens M M, Paine-Andrews A, Francisco V T. ((1996)). Improving employee health and wellness: A pilot study of the employee-driven Perfect Health Program. American Journal of Health Promotion.
Not randomized, controlled
Strecher V J, Becker M H, Kirscht J P, Eraker S A, Graham-Tomasi R P. ((1985)). Evaluation of a minimal-contact smoking cessation program in a health care setting. Patient Education & Counseling.
Multi-component intervention
Taylor V, Thompson B, Lessler D, Yasui Y, Montano D, Johnson K M, Mahloch J, Mullen M, Li S, Bassett G, Goldberg H I. ((1999)). A clinic-based mammography intervention targeting inner-city women. Journal of General Internal Medicine.
Multi-component intervention
Unti L M, Coyle K K, Woodruff B A, Boyer-Chuanroong L. ((1997)). Incentives and motivators in school-based hepatitis B vaccination programs. Journal of School Health.
Not on target