# References and Included Studies

1 Institute of Medicine. Crossing the quality chasm: a new health system for the 21st century. Washington, D.C.: National Academy Press; 2001.
2 Casalino L, Gillies R R, Shortell S M, et al. (2003). External incentives, information technology, and organized processes to improve health care quality for patients with chronic diseases. JAMA.
3 McGinnis J M, Foege W H. (1993). Actual causes of death in the United States. JAMA.
4 Bowman M A, Dignan M, Crandall S, et al. (2000). Changes in functional status related to health maintenance visits to family physicians. Journal of Family Practice.
5 Philipson T. Economic Epidemiology and Infectious Diseases. In: Newhouse JP, ed. Handbook of health economics. Vol 1B. Handbooks in Economics, vol. 17. Amsterdam; New York and Oxford: Elsevier Science North-Holland; 2000:1761–99.
6 Dowd B E. (1982). Financing preventive care in HMOs: a theoretical analysis. Inquiry.
7 Kenkel D S. (1994). The Demand for Preventative Medical Care. Applied Economics.
8 Mullahy J. (1999). It'll Only Hurt a Second? Microeconomic Determinants of Who Gets Flu Shots. Health Economics.
9 Cherkin D C, Grothaus L, Wagner E H. (1990). The effect of office visit copayments on preventive care services in an HMO. Inquiry.
10 Lillard L, W. Manning, et al. Preventive Medical Care: Standards, Usage, and Efficacy. Santa Monica, CA: Rand Corporation; 1986.
11 Gruber J, Koszegi B. (2001). Is Addiction “Rational”? Theory and Evidence. Quarterly Journal of Economics.
12 Harris R P, Helfand M, Woolf S H, et al. (2001). Current methods of the U.S. Preventive Services Task Force. A review of the process. American Journal of Preventive Medicine.
13 Kahneman D, Tversky A. (1979). Prospect Theory: An Analysis of Decision under Risk. Econometrica.
14 Kenkel DS. Prevention. Handbook of health economics. In: Culyer AJ & Newhouse JP, eds. Handbooks in Economics. Vol 17. Amsterdam; New York and Oxford: Elsevier Science North-Holland; 2000:1B: 1675–720.
15 Ippolito P M, Mathios A D. (1990). Information, Advertising and Health Choices: A Study of the Cereal Market. Rand Journal of Economics.
16 Ippolito P M, Mathios A D. (1995). Information and Advertising: The Case of Fat Consumption in the United States. American Economic Review.
17 Viscusi W K. (1990). Do Smokers Underestimate Risks?. Journal of Political Economy.
18 Viscusi W K. (1991). Age Variations in Risk Perceptions and Smoking Decisions. Review of Economics and Statistics.
19 Viscusi WK. Smoking: Making the risky decision. New York; Oxford; Toronto and Melbourne: Oxford University Press: x, 170; 1992.
20 Schoenbaum M. (1997). Do smokers understand the mortality effects of smoking? Evidence from the Health and Retirement Survey. American Journal of Public Health.
21 Hellinger F J. (1996). The impact of financial incentives on physician behavior in managed care plans: a review of the evidence. Medical Care Research and Review.
22 Russell L. Is Prevention Better than Cure? Washington DC: Brookings Institution; 1986.
23 Tengs T, Graham JD. The opportunity costs of haphazard social investments in life-saving. In: Hahn RW, ed. Risks, Costs, and Lives Saved: Getting Better Results from Regulation. New York: Oxford University Press; 1996:167–82.
24 Hensrud D D. (2000). Clinical preventive medicine in primary care: background and practice: 1. Rationale and current preventive practices. Mayo Clinic Proceedings.
25 Adams E K. (2001). Factors affecting physician provision of preventive care to Medicaid children. Health Care Financing Review.
26 Dudley RA, Miller RH, Korenbrot TY, et al. The impact of financial incentives on quality of health care. Milbank Quarterly. 1998;76(4):649–86, 511.
27 Lohr K N, Schroeder S A. (1990). A strategy for quality assurance in Medicare. New England Journal of Medicine.
28 Achat H, McIntyre P, Burgess M. (1999). Health care incentives in immunisation. Australian & New Zealand Journal of Public Health.
29 Armour B S, Pitts M M, Maclean R, et al. (2001). The effect of explicit financial incentives on physician behavior. Archives of Internal Medicine.
30 Bains N, Pickett W, Hoey J. (1998). The use and impact of incentives in population-based smoking cessation programs: a review. American Journal of Health Promotion.
31 Briss P A, Rodewald L E, Hinman A R, et al. (2000). Reviews of evidence regarding interventions to improve vaccination coverage in children, adolescents, and adults. The Task Force on Community Preventive Services. American Journal of Preventive Medicine.
32 Chaix-Couturier C, Durand-Zaleski I, Jolly D, et al. (2000). Effects of financial incentives on medical practice: results from a systematic review of the literature and methodological issues. International Journal for Quality in Health Care.
33 Giuffrida A, Gosden T, Forland F, et al. Target payments in primary care: effects on professional practice and health care outcomes. Cochrane Database of Systematic Reviews.
34 Giuffrida A, Torgerson D J. (1997). Should we pay the patient? Review of financial incentives to enhance patient compliance. BMJ.
35 Gosden T, Forland F, Kristiansen I S, et al. Capitation, salary, fee-for-service and mixed systems of payment: effects on the behaviour of primary care physicians. Cochrane Database of Systematic Reviews.
36 Hulscher M E, Wensing M, Grol R P, et al. (1999). Interventions to improve the delivery of preventive services in primary care. American Journal of Public Health.
37 Stone E G, Morton S C, Hulscher M E, et al. (2002). Interventions that increase use of adult immunization and cancer screening services: a meta-analysis. Annals of Internal Medicine.
38 Bandura A. Social learning theory. Englewood Cliffs, N.J: Prentice-Hall; 1977.
39 Rosenstock I. The health belief model: Explaining health behavior through expectancies. In: Glanz K Lewis FM, & Rimer BK, eds. Health Belief and Health Education. San Francisco: Jossey Bass Publishers; 1990.
40 Frame P S. (1992). Health maintenance in clinical practices: strategies and barriers. American Family Physicia.
41 Downs S H, Black N. (1998). The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. Journal of Epidemiology & Community Health.
42 West S, King V, Carey T, et al. Systems to Rate the Strength of Scientific Evidence. Rockville, MD: Agency for Healthcare Research and Quality; 2002. 47.
43 Fairbrother G, Hanson K L, Friedman S, et al. (1999). The impact of physician bonuses, enhanced fees, and feedback on childhood immunization coverage rates.[comment]. American Journal of Public Health.
44 Fairbrother G, Siegel M J, Friedman S, et al. (2001). Impact of financial incentives on documented immunization rates in the inner city: results of a randomized controlled trial. Ambulatory Pediatrics.
45 Hillman A L, Ripley K, Goldfarb N, et al. (1998). Physician financial incentives and feedback: failure to increase cancer screening in Medicaid managed care. American Journal of Public Health.
46 Hillman A L, Ripley K, Goldfarb N, et al. (1999). The use of physician financial incentives and feedback to improve pediatric preventive care in Medicaid managed care. Pediatrics.
47 Morrow R W, Gooding A D, Clark C. (1995). Improving physicians' preventive health care behavior through peer review and financial incentives. Archives of Family Medicine.
48 Grady K E, Lemkau J P, Lee N R, et al. (1997). Enhancing mammography referral in primary care. Preventive Medicine.
49 Kouides R W, Bennett N M, Lewis B, et al. (1998). Performance-based physician reimbursement and influenza immunization rates in the elderly. The Primary-Care Physicians of Monroe County. American Journal of Preventive Medicine.
50 Fox M H, Phua K L. (1995). Do increases in payments for obstetrical deliveries affect prenatal care?. Public Health Reports.
51 Ritchie L D, Bisset A F, Russell D, et al. (1992). Primary and preschool immunisation in Grampian: progress and the 1990 contract. BMJ.
52 Deren S, Stephens R, Davis W R, et al. (1994). The impact of providing incentives for attendance at AIDS prevention sessions. Public Health Reports.
53 Malotte C K, Rhodes F, Mais K E. (1998). Tuberculosis screening and compliance with return for skin test reading among active drug users. American Journal of Public Health.
54 Malotte C K, Hollingshead J R, Rhodes F. (1999). Monetary versus nonmonetary incentives for TB skin test reading among drug users. American Journal of Preventive Medicine.
55 Smith P B, Weinman M L, Johnson T C, et al. (1990). Incentives and their influence on appointment compliance in a teenage family-planning clinic. Journal of Adolescent Health Care.
56 Stevens-Simon C, O'Connor P, Bassford K. (1994). Incentives enhance postpartum compliance among adolescent prenatal patients. Journal of Adolescent Health.
57 Birkhead G S, LeBaron C W, Parsons P, et al. (1995). The immunization of children enrolled in the Special Supplemental Food Program for Women, Infants, and Children (WIC). The impact of different strategies. JAMA.
58 Kerpelman L C, Connell D B, Gunn W J. (2000). Effect of a monetary sanction on immunization rates of recipients of aid to families with dependent children. JAMA.
59 Freedman J D, Mitchell C K. (1994). A simple strategy to improve patient adherence to outpatient fecal occult blood testing. Journal of General Internal Medicine.
60 Marcus A C, Crane L A, Kaplan C P, et al. (1992). Improving adherence to screening follow-up among women with abnormal Pap smears: results from a large clinic-based trial of three intervention strategies. Medical Care.
61 Marcus A C, Kaplan C P, Crane L A, et al. (1998). Reducing loss-to-follow-up among women with abnormal Pap smears. Results from a randomized trial testing an intensive follow-up protocol and economic incentives. Medical Care.
62 Yokley J M, Glenwick D S. (1984). Increasing the immunization of preschool children; an evaluation of applied community interventions. Journal of Applied Behavior Analysis.
63 Moran W P, Nelson K, Wofford J L, et al. (1996). Increasing influenza immunization among high-risk patients: education or financial incentive?. American Journal of Medicine.
64 Kamb M L, Rhodes F, Hoxworth T, et al. (1998). What about money? Effect of small monetary incentives on enrollment, retention, and motivation to change behaviour in an HIV/STD prevention counselling intervention. The Project RESPECT Study Group. Sexually Transmitted Infections.
65 Laken M P, Ager J. (1995). Using incentives to increase participation in prenatal care. Obstetrics & Gynecology.
66 Sciacca J P, Phipps B L, Dube D A, et al. (1995). Influences on breast-feeding by lower-income women: an incentive-based, partner-supported educational program. Journal of the American Dietetic Association.
67 Donatelle R J, Prows S L, Champeau D, et al. (2000). Randomised controlled trial using social support and financial incentives for high risk pregnant smokers: significant other supporter (SOS) program. Tobacco Control.
68 Koffman D M, Lee J W, Hopp J W, et al. (1998). The impact of including incentives and competition in a workplace smoking cessation program on quit rates. American Journal of Health Promotion.
69 Gomel M, Oldenburg B, Simpson J M, et al. (1993). Work-site cardiovascular risk reduction: a randomized trial of health risk assessment, education, counseling, and incentives. American Journal of Public Health.
70 Klesges R C, Glasgow R E, Klesges L M, et al. (1987). Competition and relapse prevention training in worksite smoking modification. Health Education Research.
71 Gottlieb N H, Nelson A. (1990). A systematic effort to reduce smoking at the worksite. Health Education Quarterly.
72 Curry S J, Wagner E H, Grothaus L C. (1991). Evaluation of intrinsic and extrinsic motivation interventions with a self-help smoking cessation program. Journal of Consulting & Clinical Psychology.
73 Owen N, James R, Henrikson D, et al. (1990). Community cholesterol screenings: The impact of follow-up letters and incentives on retest rates and biometric changes in follow-up screenings. American Journal of Health Promotion.
74 Jeffery R W, French S A. (1999). Preventing weight gain in adults: the pound of prevention study. American Journal of Public Health.
75 Stitzer M L, Bigelow G E. (1983). Contingent payment for carbon monoxide reduction: Effects of pay amount. Behavior Therapy.
76 Hughes J R, Wadland W C, Fenwick J W, et al. (1991). Effect of cost on the self-administration and efficacy of nicotine gum: A preliminary study. Preventive Medicine.
77 Melnikow J, Paliescheskey M, Stewart G K. (1997). Effect of a transportation incentive on compliance with the first prenatal appointment: a randomized trial. Obstetrics & Gynecology.
78 Nexoe J, Kragstrup J, Ronne T. (1997). Impact of postal invitations and user fee on influenza vaccination rates among the elderly. A randomized controlled trial in general practice. Scandinavian Journal of Primary Health Care.
79 Gray B. (2001). Do Medicaid physician fees for prenatal services affect birth outcomes?. Journal of Health Economics.
80 Oleske D M, Branca M L, Schmidt J B, et al. (1998). A comparison of capitated and fee-for-service Medicaid reimbursement methods on pregnancy outcomes. Health Services Research.
81 Lynch M L. (1994). The uptake of childhood immunization and financial incentives to general practitioners. Health Economics.
82 Hughes D, Yule B. (1992). The effect of per-item fees on the behaviour of general practitioners. Journal of Health Economics.
83 Balkrishnan R, Hall M A, Mehrabi D, et al. (2002). Capitation payment, length of visit, and preventive services: evidence from a national sample of outpatient physicians. American Journal of Managed Care.
84 Wee C C, Phillips R S, Burstin H R, et al. (2001). Influence of financial productivity incentives on the use of preventive care. American Journal of Medicine.
85 Carey T, Weis K, Homer C. (1990). Prepaid versus traditional Medicaid plans: effects on preventive health care. Journal of Clinical Epidemiology.
86 Lave J R, Ives D G, Traven N D, et al. (1995). Participation in health promotion programs by the rural elderly. American Journal of Preventive Medicine.
87 Lave J R, Ives D G, Traven N D, et al. (1996). Evaluation of a health promotion demonstration program for the rural elderly. Health Services Research.
88 Ives D G, Lave J R, Traven N D, et al. (1994). Impact of Medicare reimbursement on influenza vaccination rates in the elderly. Preventive Medicine.
89 Ohmit S E, Furumoto-Dawson A, Monto A S, et al. (1995). Influenza vaccine use among an elderly population in a community intervention. American Journal of Preventive Medicine.
90 Morrissey J P, Harris R P, Kincade-Norburn J, et al. (1995). Medicare reimbursement for preventive care. Changes in performance of services, quality of life, and health care costs. Medical Care.
91 Wing R R, Jeffery R W, Pronk N, et al. (1996). Effects of a personal trainer and financial incentives on exercise adherence in overweight women in a behavioral weight loss program. Obesity Research.
92 Emont S L, Cummings K M. (1992). Using a low-cost, prize-drawing incentive to improve recruitment rate at a work-site smoking cessation clinic. Journal of Occupational Medicine.
93 Francisco V T, Paine A L, Fawcett S B, et al. (1994). An experimental evaluation of an incentive program to reduce serum cholesterol levels among health fair participants. Archives of Family Medicine.
94 Mayer J A, Clapp E J, Bartholomew S, et al. (1994). Facility-based inreach strategies to promote annual mammograms. American Journal of Preventive Medicine.
95 Mayer J A, Kellogg M C. (1989). Promoting mammography appointment making. Journal of Behavioral Medicine.
96 Windsor R A, Lowe J B, Bartlett E E. (1988). The effectiveness of a worksite self-help smoking cessation program: a randomized trial. Journal of Behavioral Medicine.
97 Jeffery R W, Wing R R, Thorson C, et al. (1998). Use of personal trainers and financial incentives to increase exercise in a behavioral weight-loss program. Journal of Consulting & Clinical Psychology.
98 Jeffery R W, Forster J L, Baxter J E, et al. (1993). An empirical evaluation of the effectiveness of tangible incentives in increasing participation and behavior change in a worksite health promotion program. American Journal of Health Promotion.
99 Harland J, White M, Drinkwater C, et al. (1999). The Newcastle exercise project: a randomised controlled trial of methods to promote physical activity in primary care. BMJ.
100 Kaplan C P, Bastani R, Belin T R, et al. (2000). Improving follow-up after an abnormal pap smear: results from a quasi-experimental intervention study. Journal of Womens Health & Gender-Based Medicine.
101 Dahl D W, Gorn G J, Weinberg C B. (1999). Encouraging use of coupons to stimulate condom purchase. American Journal of Public Health.
102 Anderson J V, Bybee D I, Brown R M, et al. (2001). 5 a day fruit and vegetable intervention improves consumption in a low income population. Journal of the American Dietetic Association.
103 Dey P, Foy R, Woodman M, et al. (1999). Should smoking cessation cost a packet? A pilot randomized controlled trial of the cost-effectiveness of distributing nicotine therapy free of charge. British Journal of General Practice.
104 Satterthwaite P. (1997). A randomised intervention study to examine the effect on immunisation coverage of making influenza vaccine available at no cost. New Zealand Medical Journal.
105 Jeffery R W, Forster J L, French S A, et al. (1993). The Healthy Worker Project: a work-site intervention for weight control and smoking cessation. American Journal of Public Health.
106 Jeffery R W, Thompson P D, Wing R R. (1978). Effects on weight reduction of strong monetary contracts for calorie restriction or weight loss. Behaviour Research & Therapy.
107 Jeffery R W, et al. (1984). Effectiveness of monetary contracts with two repayment schedules of weight reduction in men and women from self-referred and population samples. Behavior Therapy.
108 Jeffery R W, Gerber W M, Rosenthal B S, et al. (1983). Monetary contracts in weight control: effectiveness of group and individual contracts of varying size. Journal of Consulting & Clinical Psychology.
109 Follick M J, Fowler J L, Brown R A. (1984). Attrition in worksite weight-loss interventions: the effects of an incentive procedure. Journal of Consulting & Clinical Psychology.
110 Hutchins S S, Rosenthal J, Eason P, et al. (1999). Effectiveness and cost-effectiveness of linking the special supplemental program for women, infants, and children (WIC) and immunization activities. Journal of Public Health Policy.
111 Debrock L, Arnould R J. (1992). Utilization control in HMOs. Quarterly Review of Economics and Finance.
112 Grumbach K, Osmond D, Vranizan K, et al. (1998). Primary care physicians' experience of financial incentives in managed-care systems. New England Journal of Medicine.
113 Bailit Health Purchasing. Provider Incentive Models for improving quality of care: National Health Care Purchasing Institute; March 2002.
114 Bailit Health Purchasing, Sixth Man Consulting. The growing case for using physician incentives to improve health care quality: National Health Care Purchasing Institute; December 2001.
115 Stachnik T, Brown B, Hinds W, et al. (1990). Goal setting, social support and financial incentives in stress management programs: A pilot study of their impact on adherence. American Journal of Health Promotion.
116 Deci E, Ryan R. Intrinsic motivation and self-determination in human behavior. New York: Plenum Press; 1985.
117 Glied S. (1998). Getting the incentives right for children. Health Services Research.
118 Davis M M, Lantos J D. (2000). Ethical Considerations in the Public Policy Laboratory. JAMA.
119 LeBaron C W, Starnes D, Dini E F, et al. (1998). The impact of interventions by a community-based organization on inner-city vaccination coverage: Fulton County, Georgia, 1992-1993. Archives of Pediatrics & Adolescent Medicine.
120 Breen N, Feuer E J, Depuy S, et al. (1997). The effect of Medicare reimbursement for screening mammography on utilization and payment. National Cancer Institute Breast Cancer Screening Consortium. Public Health Reports.
121 Pegram v Heidrick: 530 US 211; 2000.
122 Glasgow R E, Orleans C T, Wagner E H, et al. (2001). Does the Chronic Care Model Serve Also as a Template for Improving Prevention?. The Milbank Quarterly.
123 Tengs T O, Adams M E, Pliskin J S, et al. (1995). Five-hundred life-saving interventions and their cost-effectiveness. Risk Anal.
124 Coffield A B, Maciosek M V, McGinnis J M, et al. (2001). Priorities among recommended clinical preventive services. American Journal of Preventive Medicine.
125 Fontanesi J, De Guire M, Holcomb K, et al. (2001). The cost to immunize during well-child visits. American Journal of Medical Quality.
126 Mischel W, Cantor N, Feldman S. Principles of self-regulation: The nature of willpower and self-control. In: Higgins ET & Kruglanski AW, eds. Social Psychology: Handbook of Basic Principles. New York: The Guilford Press; 1996.
127 Gollwitzer PM, Moskowitz GB. Goal effects on action and cognition. In: Higgins ET & Kruglanski AW, eds. Social Psychology: Handbook of Basic Principles. New York: The Guilford Press; 1996.
128 Bandura A. (2001). Social cognitive theory: An agentic perspective. Annual Review of Psychology.
129 Scwarzer R, Fuchs R. Self-efficacy and health behavior. In: Connor M & Norman PO, eds. Predicting Health Behavior: Research and Practice with Social Cognition Models. Buckingham: Open University Press; 1995.
130 Olson JM, Roese NJ, Zanna MP. Expectancies. In: Higgins ET & Kruglanski AW, eds. Social Psychology: Handbook of Basic Principles. New York: The Guilford Press; 1996.
131 Hammond K R, Summers D A. (1972). Cognitive control. Psychological Review.
132 Balzer W K, Hammer L B, Sumner K E, et al. (1994). Effects of cognitive feedback on components, display format, and elaboration of performance. Organizational Behavior and Human Decision Processes.
133 Te'eni D. (1990). Direct manipulation as a source of cognitive feedback: a human-computer experiment with a judgment task. International Journal of Man-Machine Studies.
134 Poses R M, Cebul R D, Wigton R S, et al. (1992). Controlled trial using computerized feedback to improve physicians' diagnostic judgments. Academic Medicine.
135 Wigton R S, Poses, Roy M, Collins, Marjeanne, Cebul, Randall D. (1990). Teaching old dogs new tricks: Using cognitive feedback to improve physician's diagnostic judgments on simulated cases. Academic Medicine.
136 Wigton RS. Applications of judgment analysis and cognitive feedback to medicine. In: Brehmer, A & Joyce CRB, eds. Human Judgment: The SJT View: Elsevier Science Publishers B.V.; 1988:227–45.
137 Pine II BJ. Mass-customizing products and services. Mass Customization. Boston: Harvard Business School Press; 1999:171–212.
138 Schafer JB, Konstan, J., and Reidl, J. Recommended systems in e-commerce. Paper presented at: Proceedings of the ACM on Electronic Conference; November, 1999.
139 Johnson P E, Veazie P J, O'Connor P J, et al. (2002). Understanding Variation in Chronic Disease Outcomes. Health Care Management Science.
140 Prochaska JO, DiClemente CC. Toward a Comprehensive Model of Change. Treating Addictive Behaviors: Processes of Change. New York:: Plenum Press; 1986.
141 Glasgow R E, Orleans C T, Wagner E H, et al. (2001). Does the Chronic Care Model Serve Also as a Template for Improving Prevention?. The Milbank Quarterly.
142 Jeffery R W, Wing R R, Thorson C, et al. (1993). Strengthening behavioral interventions for weight loss: a randomized trial of food provision and monetary incentives. Journal of Consulting & Clinical Psychology.
143 Oldenburg B, Owen N, Parle M, et al. (1995). An economic evaluation of four work site based cardiovascular risk factor interventions. Health Education Quarterly.