# Acknowledgments

We would like to thank Marilyn Eells for editing and formatting this report.