# Appendixes

Appendix A. Excerpts from: Social Security Administration Office of Disability. Disability Evaluation Under Social Security, 2003. SSA Pub. No. 64-039. Social Security Administration: Baltimore, MD

Appendix B. Search Strategies

Appendix C. Instructions for Title and Abstract Screening

Appendix D. Decision Rules for Full-text Screening

Appendix E. Evidence Table/Data Abstraction Templates

Appendix F. Evidence Tables