# Acronyms/Abbreviations Used in the Evidence Tables

4-AP | 4-aminopyridine
9-HPT | 9-Hole Peg Test
ACTH | adrenocorticotropic hormone
ADL | activities of daily living
AE | adverse event
AI | Ambulation Index
ANOVA | analysis of variance
APOE | apolipoprotein E
ASQ | Anxiety Scale Questionnaire
AUC | area under curve
AZA | azathioprine
BAEP | brainstem auditory evoked potential
BB | Box-and-Block Test
BDI | Beck Depression Inventory
B/I | baseline
BMS | benign MS
BTX | botulinum toxin
CBT | cognitive-behavioral therapy
CDQ | Clinical Depression Questionnaire
CHF | congestive heart failure
CI | confidence interval
CNA | certified nursing assistant
CNS | central nervous system
Cop1 | copolymer 1 = glatiramer acetate
CPMS | chronic progressive MS
CSF | cerebrospinal fluid
CT | computed tomography
CYCLO | cyclophosphamide
DBP | diastolic blood pressure
DEX | Dysexecutive Syndrome Questionnaire
DSM-IV | Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition
DSS | Disability Status Scale
DTR | deep tendon reflex
EADL | Extended Activities of Daily Living Scale
EDSS | Expanded Disability Status Scale
EEG | electroencephalogram
EMG | electromyogram
EMQ | Everyday Memory Questionnaire
ENS | electrical neuromuscular stimulation
FIM | Functional Independence Measure
FIS | Fatigue Impact Scale
FLAIR | fluid-attenuated inversion recovery
FSS | Fatigue Severity Scale
GA | glatiramer acetate = copolymer 1
GEMS | Global Evaluation-MS
GHQ-28 | General Health Questionnaire-28
GI | gastrointestinal
GNDS | Guy's Neurological Disability Scale
GP | general practitioner
HIV | human immunodeficiency virus
HPLP-II | Health Promoting Lifestyle Profile II
HMO | health maintenance organization
hr | hour(s)
HRSD | Hamilton Rating Scale for Depression
IECS | Internal-External Control Scale
IFNβ-1a | interferon beta-1a
IFNβ-1b | interferon beta-1b
IgG | immunoglobulin-G
IgM | immunoglobulin-M
IL-2 | interleukin-2
IM | intramuscular
IQR | interquartile range
ISS | Incapacity Status Scale
ITMS | intrathecal IgM synthesis
ITT | intention-to-treat
IV | intravenous
LHS | London Handicap Scale
MAQ | Memory Aids Questionnaire
MEP | motor evoked potential
MFIS | Modified Fatigue Impact Scale
MIU | million International Units
MMPI | Minnesota Multiphasic Personality Inventory
MMSE | Mini Mental State Examination
mo | month(s)
MP | methylprednisolone
MRD | Minimal Record of Disability
MRI | magnetic resonance imaging
MS | multiple sclerosis
MSFC | Multiple Sclerosis Functional Composite
MS-FS | MS-Specific Fatigue Scale
MSIS | MS-Impairment Scale
MSQLI | MS Quality of Life Inventory
MTX | mitoxantrone
NA | not applicable
nIFNβ | natural interferon beta
NPV | negative predictive value
NR | not reported
NRS | Neurologic Rating Scale
NS | not statistically significant
NSAID | non-steroidal anti-inflammatory drug
PAIS-SR | Psychological Adjustment to Illness Scale - Self-Report
PASAT | Paced Auditory Serial Addition Test
PEX | plasma exchange
PFC | Problem-Focused Coping score from Ways of Coping Checklist
PO | per os (by mouth)
POMS | Profile of Mood States
PPMS | primary progressive MS
PPV | positive predictive value
PRQ | Personal Resources Questionnaire
QOL | quality of life
RCT | randomized controlled trial
ROM | range of motion
RR | risk ratio
RRMS | relapsing-remitting MS
SBP | systolic blood pressure
SC | subcutaneous
SCI | spinal cord injury
SD | standard deviation
SDDR | Standard Day Dependency Record
SDDRE | Standard Day Dependency Record-Essential Subscale
SDDRO | Standard Day Dependency Record-Occasions Subscale
SDMT | Symbol Digit Modalities Test
SE | standard error
SEAB | Self-Efficacy for Adjustment Behaviors Scale
SEG | supportive-expressive group therapy
SEP | somatosensory evoked potential
SES | Self-Esteem Scale
SET | Tempelaar Social Experience Checklist
SF-36 | Medical Outcomes Study 36-Item Short-Form Health Survey
SIP | Sickness Impact Profile
SN | sensitivity
SNRS | Scripps Neurological Rating Scale
SP | specificity
SPMS | secondary progressive MS
SSDI | Social Security Disability Insurance
SSI | Supplemental Security Income
STAI | State-Trait Anxiety Inventory
STAI-S | State-Trait Anxiety Inventory-State
STAI-T | State-Trait Anxiety Inventory-Trait
STAXI | State-Trait Anger Expression Inventory
THC | tetrahydrocannabinol
UTI | urinary tract infection
VAMC | Veterans Affairs Medical Center
VAS | visual analog scale
VEP | visual evoked potential
VFS | Visual Faces Scale
WBC | white blood cell
wk | week(s)
WMS VR | Wechsler Memory Scale Visual Reproduction
yr | year(s)