# References Cited in the Evidence Tables

Achiron A, Gabbay U, Gilad R, et al. Intravenous immunoglobulin treatment in multiple sclerosis. Effect on relapses. Neurology. 1998;50(2):398-402. [pmid: 9484361].
Barkhof F, Filippi M, Miller DH, et al. Comparison of MRI criteria at first presentation to predict conversion to clinically definite multiple sclerosis. Brain. 1997;120(Pt 11):2059-69. [pmid: 9397021].
Bass B, Weinshenker B, Rice GP, et al. Tizanidine versus baclofen in the treatment of spasticity in patients with multiple sclerosis. Can J Neurol Sci. 1988;15(1):15-9. [pmid: 3345456].
Bastianello S, Pozzilli C, D'Andrea F, et al. A controlled trial of mitoxantrone in multiple sclerosis: serial MRI evaluation at one year. Can J Neurol Sci. 1994;21(3):266-70. [pmid: 8000984].
Beatty WW, Blanco CR, Wilbanks SL, et al. Demographic, clinical and cognitive characteristics of multiple sclerosis patients who continue to work. J Neurol Rehab. 1995;9:167-73.
Beukelman DR, Kraft GH, Freal J. Expressive communication disorders in persons with multiple sclerosis: a survey. Arch Phys Med Rehab. 1985;66(10):675-7.
Bornstein MB, Miller A, Slagle S, et al. A pilot trial of Cop 1 in exacerbating-remitting multiple sclerosis. New Engl J Med. 1987;317(7):408-14. [pmid: 3302705].
Bornstein MB, Miller A, Slagle S, et al. A placebo-controlled, double-blind, randomized, two-center, pilot trial of Cop 1 in chronic progressive multiple sclerosis. Neurology. 1991;41(4):533-9. [pmid: 2011253].
Brar SP, Smith MB, Nelson LM, et al. Evaluation of treatment protocols on minimal to moderate spasticity in multiple sclerosis. Arch Phys Med Rehab. 1991;72(3):186-9.
Brex PA, Miszkiel KA, O'Riordan JI, et al. Assessing the risk of early multiple sclerosis in patients with clinically isolated syndromes: the role of a follow up MRI. J Neurol Neurosurg Psych. 2001;70(3):390-3.
British and Dutch Multiple Sclerosis Azathioprine Trial Group. Double-masked trial of azathioprine in multiple sclerosis. Lancet. 1988;2(8604):179-83. [pmid: 2899660].
Canadian Burden of Illness Study Group. Burden of illness of multiple sclerosis: Part I: Cost of illness. Can J Neurol Sci. 1998a;25(1):23-30. [pmid: 9532277].
Canadian Burden of Illness Study Group. Burden of illness of multiple sclerosis: Part II: Quality of life. Can J Neurol Sci. 1998b;25(1):31-8. [pmid: 9532278].
Canadian Cooperative Multiple Sclerosis Study Group. The Canadian cooperative trial of cyclophosphamide and plasma exchange in progressive multiple sclerosis. Lancet. 1991;337(8739):441-6. [pmid: 1671468].
Canadian MS. A randomized controlled trial of amantadine in fatigue associated with multiple sclerosis. Can J Neurol Sci. 1987;14(3):273-8. [pmid: 2889518].
Cartlidge NE, Hudgson P, Weightman D. A comparison of baclofen and diazepam in the treatment of spasticity. J Neurol Sci. 1974;23(1):17-24. [pmid: 4850175].
CHAMPS Study Group. MRI predictors of early conversion to clinically definite MS in the CHAMPS placebo group. Neurology. 2002;59(7):998-1005. [pmid: 12370452].
Chapman J, Sylantiev C, Nisipeanu P, et al. Preliminary observations on APOE epsilon4 allele and progression of disability in multiple sclerosis. Arch Neurol. 1999;56(12):1484-7. [pmid: 10593303].
Cohen JA, Cutter GR, Fischer JS, et al. Benefit of interferon beta-1a on MSFC progression in secondary progressive MS. Neurology. 2002;59(5):679-87. [pmid: 12221157].
Cohen RA, Fisher M. Amantadine treatment of fatigue associated with multiple sclerosis. Arch Neurol. 1989;46(6):676-80. [pmid: 2730380].
Comi G, Filippi M, Barkhof F, et al. Effect of early interferon treatment on conversion to definite multiple sclerosis: a randomised study. Lancet. 2001;357(9268):1576-82. [pmid: 11377645].
Cottrell DA, Kremenchutzky M, Rice GP, et al. The natural history of multiple sclerosis: a geographically based study. 6. Applications to planning and interpretation of clinical therapeutic trials in primary progressive multiple sclerosis. Brain. 1999a;122(Pt 4):641-7. [pmid: 10219777].
Cottrell DA, Kremenchutzky M, Rice GP, et al. The natural history of multiple sclerosis: a geographically based study. 5. The clinical features and natural history of primary progressive multiple sclerosis. Brain. 1999b;122(Pt 4):625-39. [pmid: 10219776].
Crawford JD, McIvor GP. Group psychotherapy: benefits in multiple sclerosis. Arch Phys Med Rehab. 1985;66(12):810-3.
Currier RD, Haerer AF, Meydrech EF. Low dose oral methotrexate treatment of multiple sclerosis: a pilot study. [erratum appears in J Neurol Neurosurg Psychiatry 1994 Apr;57(4):528]. J Neurol Neurosurg Psych. 1993;56(11):1217-8.
Cutter NC, Scott DD, Johnson JC, et al. Gabapentin effect on spasticity in multiple sclerosis: a placebo-controlled, randomized trial. Arch Phys Med Rehab. 2000;81(2):164-9.
Dalton CM, Brex PA, Jenkins R, et al. Progressive ventricular enlargement in patients with clinically isolated syndromes is associated with the early development of multiple sclerosis. J Neurol Neurosurg Psych. 2002;73(2):141-7.
Dalton CM, Brex PA, Miszkiel KA, et al. Application of the new McDonald criteria to patients with clinically isolated syndromes suggestive of multiple sclerosis. Ann Neurol. 2002;52(1):47-53. [pmid: 12112046].
De Castro S, Cartoni D, Millefiorini E, et al. Noninvasive assessment of mitoxantrone cardiotoxicity in relapsing remitting multiple sclerosis. J Clin Pharmacol. 1995;35(6):627-32. [pmid: 7665724].
Dyck I, Jongbloed L. Women with multiple sclerosis and employment issues: a focus on social and institutional environments. Can J Occup Therapy. 2000;67(5):337-46.
Edgley K, Sullivan M, Dehoux E. A survey of multiple sclerosis: determinants of employment status. Can J Rehabil. 1991;4:127-32.
European Study Group on Interferon beta-1b in Secondary Progressive MS. Placebo-controlled multicentre randomised trial of interferon beta-1b in treatment of secondary progressive multiple sclerosis. Lancet. 1998;352(9139):1491-7. [pmid: 9820296].
Eyssette M, Rohmer F, Serratrice G, et al. Multi-centre, double-blind trial of a novel antispastic agent, tizanidine, in spasticity associated with multiple sclerosis. Curr Med Res Opinion. 1988;10(10):699-708.
Fazekas F, Deisenhammer F, Strasser-Fuchs S, et al. Randomised placebo-controlled trial of monthly intravenous immunoglobulin therapy in relapsing-remitting multiple sclerosis. Austrian Immunoglobulin in Multiple Sclerosis Study Group. Lancet. 1997a;349(9052):589-93. [pmid: 9057729].
Fazekas F, Deisenhammer F, Strasser-Fuchs S, et al. Treatment effects of monthly intravenous immunoglobulin on patients with relapsing-remitting multiple sclerosis: further analyses of the Austrian Immunoglobulin in MS study. Mult Scler. 1997b;3(2):137-41. [pmid: 9291168].
Feldman RG, Kelly-Hayes M, Conomy JP, et al. Baclofen for spasticity in multiple sclerosis. Double-blind crossover and three-year study. Neurology. 1978;28(11):1094-8. [pmid: 362234].
Filippi M, Horsfield MA, Morrissey SP, et al. Quantitative brain MRI lesion load predicts the course of clinically isolated syndromes suggestive of multiple sclerosis. Neurology. 1994;44(4):635-41. [pmid: 8164816].
Fischer JS, Priore RL, Jacobs LD, et al. Neuropsychological effects of interferon beta-1a in relapsing multiple sclerosis. Multiple Sclerosis Collaborative Research Group. Ann Neurol. 2000;48(6):885-92. [pmid: 11117545].
Foley FW, Bedell JR, LaRocca NG, et al. Efficacy of stress-inoculation training in coping with multiple sclerosis. J Consult Clin Psychol. 1987;55(6):919-22. [pmid: 3693660].
Ford HL, Johnson MH, Rigby AS. Variation between observers in classifying multiple sclerosis. J Neurol Neurosurg Psych. 1996;61(4):418.
Francabandera FL, Holland NJ, Wiesel-Levison P, et al. Multiple sclerosis rehabilitation: inpatient vs. outpatient. Rehab Nurs. 1988;13(5):251-3.
Freal JE, Kraft GH, Coryell JK. Symptomatic fatigue in multiple sclerosis. Arch Phys Med Rehab. 1984;65(3):135-8.
Fredrikson S. Nasal spray desmopressin treatment of bladder dysfunction in patients with multiple sclerosis. Acta Neurol Scand. 1996;94(1):31-4. [pmid: 8874590].
Freeman JA, Langdon DW, Hobart JC, et al. The impact of inpatient rehabilitation on progressive multiple sclerosis. Ann Neurol. 1997;42(2):236-44. [pmid: 9266735].
Freeman JA, Thompson AJ, Fitzpatrick R, et al. Interferon-beta1b in the treatment of secondary progressive MS: impact on quality of life. Neurology. 2001;57(10):1870-5. [pmid: 11723278].
From A, Heltberg A. A double-blind trial with baclofen (Lioresal) and diazepam in spasticity due to multiple sclerosis. Acta Neurol Scand. 1975;51(2):158-66. [pmid: 1090103].
Fuhr P, Borggrefe-Chappuis A, Schindler C, et al. Visual and motor evoked potentials in the course of multiple sclerosis. Brain. 2001;124(Pt 11):2162-8. [pmid: 11673318].
Gambi D, Rossini PM, Calenda G, et al. Dantrolene sodium in the treatment of spasticity caused by multiple sclerosis or degenerative myelopathies: a double-blind, crossover study in comparison with placebo. Curr Therapeutic Res. 1983;33:835-40.
Geisler MW, Sliwinski M, Coyle PK, et al. The effects of amantadine and pemoline on cognitive functioning in multiple sclerosis. Arch Neurol. 1996;53(2):185-8. [pmid: 8639070].
Genevie L, Kallos JE, Struening EL. Job retention among people with multiple sclerosis. J Neurol Rehab. 1987;1:131-5.
Ghezzi A, DiFalco MLC, et al. Clinical controlled randomized trial of azathioprine in multiple sclerosis. In: Gonsette RE, Delmotte P, eds. Recent Advances in Multiple Sclerosis Therapy. Amsterdam: Elsevier, 1989.
Ghezzi A, Martinelli V, Torri V, et al. Long-term follow-up of isolated optic neuritis: the risk of developing multiple sclerosis, its outcome, and the prognostic role of paraclinical tests. J Neurol. 1999;246(9):770-5. [pmid: 10525973].
Gillson G, Richard TL, Smith RB, et al. A double-blind pilot study of the effect of Prokarin on fatigue in multiple sclerosis. Mult Scler. 2002;8(1):30-5. [pmid: 11936486].
Goodkin DE, Bailly RC, Teetzen ML, et al. The efficacy of azathioprine in relapsing-remitting multiple sclerosis. Neurology. 1991;41(1):20-5. [pmid: 1985289].
Goodkin DE, Hertsgaard D, Rudick RA. Exacerbation rates and adherence to disease type in a prospectively followed-up population with multiple sclerosis. Implications for clinical trials. Arch Neurol. 1989;46(10):1107-12. [pmid: 2679508].
Goodkin DE, Rudick RA, VanderBrug Medendorp S, et al. Low-dose (7. 5 mg) oral methotrexate reduces the rate of progression in chronic progressive multiple sclerosis. Ann Neurol. 1995;37(1):30-40. [pmid: 7818255].
Grima DT, Torrance GW, Francis G, et al. Cost and health related quality of life consequences of multiple sclerosis. Mult Scler. 2000;6(2):91-8. [pmid: 10773854].
Grønning M, Hannisdal E, Mellgren SI. Multivariate analyses of factors associated with unemployment in people with multiple sclerosis. J Neurol Neurosurg Psych. 1990;53(5):388-90.
Gulick EE, Yam M, Touw MM. Work performance by persons with multiple sclerosis: conditions that impede or enable the performance of work. Internat J Nurs Stud. 1989;26(4):301-11.
Hammond SR, McLeod JG, Macaskill P, et al. Multiple sclerosis in Australia: socioeconomic factors. J Neurol Neurosurg Psych. 1996;61(3):311-3.
Hartung HP, Gonsette R, König N, et al. Mitoxantrone in progressive multiple sclerosis: a placebo-controlled, double-blind, randomised, multicentre trial. Lancet. 2002;360(9350):2018-25. [pmid: 12504397].
Hauser SL, Dawson DM, Lehrich JR, et al. Intensive immunosuppression in progressive multiple sclerosis. A randomized, three-arm study of high-dose intravenous cyclophosphamide, plasma exchange, and ACTH. New Engl J Med. 1983;308(4):173-80. [pmid: 6294517].
Hauser SL, Doolittle TH, Lopez-Bresnahan M, et al. An antispasticity effect of threonine in multiple sclerosis. Arch Neurol. 1992;49(9):923-6. [pmid: 1520082].
Hilton P, Hertogs K, Stanton SL. The use of desmopressin (DDAVP) for nocturia in women with multiple sclerosis. J Neurol Neurosurg Psych. 1983;46(9):854-5.
Hoogstraten MC, van der Ploeg RJ, vd Burg W, et al. Tizanidine versus baclofen in the treatment of spasticity in multiple sclerosis patients. Acta Neurol Scand. 1988;77(3):224-30. [pmid: 3376747].
Hoverd PA, Fowler CJ. Desmopressin in the treatment of daytime urinary frequency in patients with multiple sclerosis. J Neurol Neurosurg Psych. 1998;65(5):778-80.
Hyman N, Barnes M, Bhakta B, et al. Botulinum toxin (Dysport) treatment of hip adductor spasticity in multiple sclerosis: a prospective, randomised, double blind, placebo controlled, dose ranging study. J Neurol Neurosurg Psych. 2000;68(6):707-12.
IFNB Multiple Sclerosis Study Group. Interferon beta-1b is effective in relapsing-remitting multiple sclerosis. I. Clinical results of a multicenter, randomized, double-blind, placebo-controlled trial. Neurology. 1993;43(4):655-61. [pmid: 8469318].
IFNB Study Group, the University of British Columbia MS/MRI Analysis Group. Interferon beta-1b in the treatment of multiple sclerosis: final outcome of the randomized controlled trial. Neurology. 1995;45(7):1277-85. [pmid: 7617182].
IFNB Study Group, the University of British Columbia MS/MRI Analysis Group. Neutralizing antibodies during treatment of multiple sclerosis with interferon beta-1b: experience during the first three years. Neurology. 1996;47(4):889-94. [pmid: 8857714].
Jacobs L, Rudick R, Simon J. Extended observations on MS patients treated with IM interferon-beta1a (Avonex): implications for modern MS trials and therapeutics. J Neuroimmunol. 2000;107(2):167-73. [pmid: 10854652].
Jacobs LD, Cookfair DL, Rudick RA, et al. Intramuscular interferon beta-1a for disease progression in relapsing multiple sclerosis. The Multiple Sclerosis Collaborative Research Group (MSCRG) [erratum appears in Ann Neurol 1996 Sep;40(3):480]. Ann Neurol. 1996;39(3):285-94. [pmid: 8602746].
Jacobs LD, Wende KE, Brownscheidle CM, et al. A profile of multiple sclerosis: the New York State Multiple Sclerosis Consortium. Mult Scler. 1999;5(5):369-76. [pmid: 10516782].
Johnson KP, Brooks BR, Cohen JA, et al. Extended use of glatiramer acetate (Copaxone) is well tolerated and maintains its clinical effect on multiple sclerosis relapse rate and degree of disability. Copolymer 1 Multiple Sclerosis Study Group. Neurology. 1998;50(3):701-8. [pmid: 9521260].
Johnson KP, Brooks BR, Cohen JA, et al. Copolymer 1 reduces relapse rate and improves disability in relapsing-remitting multiple sclerosis: results of a phase III multicenter, double-blind, placebo-controlled trial. 1995 [classical article]. Neurology. 2001;57(12 Suppl 5):S16-24. [pmid: 11902590].
Jongbloed L. Factors influencing employment status of women with multiple sclerosis. Can J Rehab 1996;9(213–22).
Kappos L, Polman C, Pozzilli C, et al. Final analysis of the European multicenter trial on IFNbeta-1b in secondary-progressive MS. Neurology. 2001;57(11):1969-75. [pmid: 11739811].
Khatri BO, McQuillen MP, Harrington GJ, et al. Chronic progressive multiple sclerosis: double-blind controlled study of plasmapheresis in patients taking immunosuppressive drugs. Neurology. 1985;35(3):312-9. [pmid: 3974889].
Killestein J, Hoogervorst EL, Reif M, et al. Safety, tolerability, and efficacy of orally administered cannabinoids in MS. Neurology. 2002;58(9):1404-7. [pmid: 12011290].
Kinn AC, Larsson PO. Desmopressin: a new principle for symptomatic treatment of urgency and incontinence in patients with multiple sclerosis. Scand J Urol Nephrol. 1990;24(2):109-12. [pmid: 2192444].
Kornblith AB, La Rocca NG, Baum HM. Employment in individuals with multiple sclerosis. Internat J Rehab Res. 1986;9(2):155-65.
Koziol JA, Wagner S, Sobel DF, et al. Predictive value of lesions for relapses in relapsing-remitting multiple sclerosis. Am J Neuroradiol. 2001;22(2):284-91. [pmid: 11156770].
Krupp LB, Coyle PK, Doscher C, et al. Fatigue therapy in multiple sclerosis: results of a double-blind, randomized, parallel trial of amantadine, pemoline, and placebo. Neurology. 1995;45(11):1956-61. [pmid: 7501140].
Larcombe NA, Wilson PH. An evaluation of cognitive-behaviour therapy for depression in patients with multiple sclerosis. Brit J Psych. 1984;145:366-71.
LaRocca N, Kalb R, Kendall P, et al. The role of disease and demographic factors in the employment of patients with multiple sclerosis. Arch Neurol. 1982;39(4):256. [pmid: 7073539].
Leary SM, Miller DH, Stevenson VL, et al. Interferon beta-1a in primary progressive MS: an exploratory, randomized, controlled trial. Neurology. 2003;60(1):44-51. [pmid: 12525716].
Lee A, Patterson V. A double-blind study of L-threonine in patients with spinal spasticity. Acta Neurol Scand. 1993;88(5):334-8. [pmid: 8296531].
Levine IM, Jossmann PB, DeAngelis V. Liorseal, a new muscle relaxant in the treatment of spasticity--a double-blind quantitative evaluation. Dis Nerv System. 1977;38(12):1011-5.
Lincoln NB, Dent A, Harding J, et al. Evaluation of cognitive assessment and cognitive intervention for people with multiple sclerosis. J Neurol Neurosurg Psych. 2002;72(1):93-8.
Liu C, Blumhardt LD. Randomised, double blind, placebo controlled study of interferon beta-1a in relapsing-remitting multiple sclerosis analysed by area under disability/time curves. J Neurol Neurosurg Psych. 1999;67(4):451-6.
Liu C, Blumhardt LD. Benefits of glatiramer acetate on disability in relapsing-remitting multiple sclerosis. An analysis by area under disability/time curves. The Copolymer 1 Multiple Sclerosis Study Group. J Neurol Sci. 2000;181(12):33-7. [pmid: 11099709].
Liu C, Blumhardt LD. Randomized, double-blind, placebo-controlled study of subcutaneous interferon beta-1a in relapsing-remitting multiple sclerosis: a categorical disability trend analysis. Mult Scler. 2002;8(1):10-4. [pmid: 11936481].
Livesley E. Effects of electrical neuromuscular stimulation on functional performance in patients with multiple sclerosis. Physiotherapy. 1992;78(12):914-7.
Mendoza RJ, Pittenger DJ, Weinstein CS. Unit management of depression of patients with multiple sclerosis using cognitive remediation strategies: a preliminary study. Neurorehab Neural Repair. 2001;15(1):9-14.
Milanese C, La Mantia L, Salmaggi A, et al. Double blind controlled randomized study on azathioprine efficacy in multiple sclerosis. Preliminary results. Ital J Neurol Sci. 1988;9(1):53-7. [pmid: 3281916].
Millefiorini E, Gasperini C, Pozzilli C, et al. Randomized placebo-controlled trial of mitoxantrone in relapsing-remitting multiple sclerosis: 24-month clinical and MRI outcome. J Neurol. 1997;244(3):153-9. [pmid: 9050955].
Miller DM, Rudick RA, Cutter G, et al. Clinical significance of the multiple sclerosis functional composite: relationship to patient-reported quality of life. Arch Neurol. 2000;57(9):1319-24. [pmid: 10987899].
Mohr DC, Boudewyn AC, Goodkin DE, et al. Comparative outcomes for individual cognitive-behavior therapy, supportive-expressive group psychotherapy, and sertraline for the treatment of depression in multiple sclerosis. J Consult Clin Psychol. 2001;69(6):942-9. [pmid: 11777121].
Mohr DC, Likosky W, Bertagnolli A, et al. Telephone-administered cognitive-behavioral therapy for the treatment of depressive symptoms in multiple sclerosis. J Consult Clin Psychol. 2000;68(2):356-61. [pmid: 10780138].
Mondrup K, Pedersen E. The effect of the GABA-agonist, progabide, on stretch and flexor reflexes and on voluntary power in spastic patients. Acta Neurol Scand. 1984a;69(4):191-9. [pmid: 6377801].
Mondrup K, Pedersen E. The clinical effect of the GABA-agonist, progabide, on spasticity. Acta Neurol Scand. 1984b;69(4):200-6. [pmid: 6377802].
Morrissey SP, Miller DH, Kendall BE, et al. The significance of brain magnetic resonance imaging abnormalities at presentation with clinically isolated syndromes suggestive of multiple sclerosis. A 5-year follow-up study. Brain. 1993;116(Pt 1):135-46. [pmid: 8453454].
Mueller ME, Gruenthal M, Olson WL, et al. Gabapentin for relief of upper motor neuron symptoms in multiple sclerosis. Arch Phys Med Rehab. 1997;78(5):521-4.
Multiple Sclerosis Study Group. Efficacy and toxicity of cyclosporine in chronic progressive multiple sclerosis: a randomized, double-blinded, placebo-controlled clinical trial. Ann Neurol. 1990;27(6):591-605. [pmid: 2193613].
Newman PM, Nogues M, Newman PK, et al. Tizanidine in the treatment of spasticity. Eur J Clin Pharmacol. 1982;23(1):31-5. [pmid: 6751834].
Nielsen JF, Sinkjaer T, Jakobsen J. Treatment of spasticity with repetitive magnetic stimulation; a double-blind placebo-controlled study. Mult Scler. 1996;2(5):227-32. [pmid: 9050361].
Nortvedt MW, Riise T, Myhr KM, et al. Quality of life as a predictor for change in disability in MS. Neurology. 2000;55(1):51-4. [pmid: 10891905].
Noseworthy JH, O'Brien PC, Petterson TM, et al. A randomized trial of intravenous immunoglobulin in inflammatory demyelinating optic neuritis. Neurology. 2001;56(11):1514-22. [pmid: 11402108].
O'Hara L, Cadbury H, De SL, et al. Evaluation of the effectiveness of professionally guided self-care for people with multiple sclerosis living in the community: a randomized controlled trial. Clin Rehab. 2002;16(2):119-28.
Optic Neuritis Study Group. The 5-year risk of MS after optic neuritis: experience of the optic neuritis treatment trial. 1997. Neurology. 2001;57(12 Suppl 5):S36-45. [pmid: 11902594].
O'Riordan JI, Thompson AJ, Kingsley DP, et al. The prognostic value of brain MRI in clinically isolated syndromes of the CNS. A 10-year follow-up. Brain. 1998;121(Pt 3):495-503. [pmid: 9549525].
Ørsnes GB, Sørensen PS, Larsen TK, et al. Effect of baclofen on gait in spastic MS patients. Acta Neurol Scand. 2000;101(4):244-8. [pmid: 10770520].
Patten SB, Metz LM. Interferon beta-1a and depression in relapsing-remitting multiple sclerosis: an analysis of depression data from the PRISMS clinical trial. Mult Scler. 2001;7(4):243-8. [pmid: 11548984].
Patti F, Ciancio MR, Reggio E, et al. The impact of outpatient rehabilitation on quality of life in multiple sclerosis. J Neurol. 2002;249(8):1027-33. [pmid: 12195449].
Patti F, L'Episcopo MR, Cataldi ML, et al. Natural interferon-beta treatment of relapsing-remitting and secondary-progressive multiple sclerosis patients. A two-year study. Acta Neurol Scand. 1999;100(5):283-9. [pmid: 10536913].
Patzold U, Hecker H, Pocklington P. Azathioprine in treatment of multiple sclerosis. Final results of a 41/2-year controlled study of its effectiveness covering 115 patients. J Neurol Sci. 1982;54(3):377-94. [pmid: 7047686].
Penn RD, Savoy SM, Corcos D, et al. Intrathecal baclofen for severe spinal spasticity. New Engl J Med. 1989;320(23):1517-21. [pmid: 2657424].
Petajan JH, Gappmaier E, White AT, et al. Impact of aerobic training on fitness and quality of life in multiple sclerosis. Ann Neurol. 1996;39(4):432-41. [pmid: 8619521].
Pliskin NH, Hamer DP, Goldstein DS, et al. Improved delayed visual reproduction test performance in multiple sclerosis patients receiving interferon beta-1b. Neurology. 1996;47(6):1463-8. [pmid: 8960728].
Pozzilli C, Brunetti M, Amicosante AM, et al. Home based management in multiple sclerosis: results of a randomised controlled trial. J Neurol Neurosurg Psych. 2002;73(3):250-5.
Prasad RS, Smith SJ, Wright H. Lower abdominal pressure versus external bladder stimulation to aid bladder emptying in multiple sclerosis: a randomized controlled study. Clin Rehab. 2003;17(1):42-7.
PRISMS Study Group, the University of British Columbia MS/MRI Analysis Group. Randomised double-blind placebo-controlled study of interferon beta-1a in relapsing/remitting multiple sclerosis. PRISMS (Prevention of Relapses and Disability by Interferon beta-1a Subcutaneously in Multiple Sclerosis) Study Group. [erratum appears in Lancet 1999 Feb 20;353(9153):678]. Lancet. 1998;352(9139):1498-504. [pmid: 9820297].
Rao SM, Leo GJ, Ellington L, et al. Cognitive dysfunction in multiple sclerosis. II. Impact on employment and social functioning. Neurology. 1991;41(5):692-6. [pmid: 1823781].
Rice GP. Tizanidine vs. baclofen in the treatment of spasticity in patients with multiple sclerosis. Can J Neurol Sci. 1989;16(4):451. [pmid: 2804809].
Rice GP, Filippi M, Comi G. Cladribine and progressive MS: clinical and MRI outcomes of a multicenter controlled trial. Cladribine MRI Study Group. Neurology. 2000;54(5):1145-55. [pmid: 10720289].
Rinne U. Tizanidine treatment of spasticity in multiple sclerosis and chronic myelopathy. Curr Therapeutic Res. 1980;28:827-36.
Romine JS, Sipe JC, Koziol JA, et al. A double-blind, placebo-controlled, randomized trial of cladribine in relapsing-remitting multiple sclerosis. Proc Assoc Am Physic. 1999;111(1):35-44.
Rossini PM, Pasqualetti P, Pozzilli C, et al. Fatigue in progressive multiple sclerosis: results of a randomized, double-blind, placebo-controlled, crossover trial of oral 4-aminopyridine. Mult Scler. 2001;7(6):354-8. [pmid: 11795455].
Rovaris M, Comi G, Ladkani D, et al. Short-term correlations between clinical and MR imaging findings in relapsing-remitting multiple sclerosis. Am J Neuroradiol. 2003;24(1):75-81. [pmid: 12533330].
Rozin R, Schiff Y, Cooper G, et al. Vocational rehabilitation of multiple sclerosis (MS) patients. I. Analysis of clinical and demographic factors. Internat Rehab Med. 1982;4(2):75-9.
Rozin R, Schiff Y, Kahana E, et al. Vocational status of multiple sclerosis patients in Israel. Arch Phys Med Rehab. 1975;56(7):300-4.
Rudick RA, Breton D, Krall RL. The GABA-agonist progabide for spasticity in multiple sclerosis. Arch Neurol. 1987;44(10):1033-6. [pmid: 3632375].
Rudick RA, Fisher E, Lee JC, et al. Brain atrophy in relapsing multiple sclerosis: relationship to relapses, EDSS, and treatment with interferon beta-1a. Mult Scler. 2000;6(6):365-72. [pmid: 11212130].
Rudick RA, Goodkin DE, Jacobs LD, et al. Impact of interferon beta-1a on neurologic disability in relapsing multiple sclerosis. The Multiple Sclerosis Collaborative Research Group (MSCRG). Neurology. 1997;49(2):358-63. [pmid: 9270562].
Runmarker B, Andersson C, Odén A, et al. Prediction of outcome in multiple sclerosis based on multivariate models. J Neurol. 1994;241(10):597-604. [pmid: 7836963].
Sachais BA, Logue JN, Carey MS. Baclofen, a new antispastic drug. A controlled, multicenter trial in patients with multiple sclerosis. Arch Neurol. 1977;34(7):422-8. [pmid: 327987].
Sastre-Garriga J, Tintoré M, Rovira A, et al. Conversion to multiple sclerosis after a clinically isolated syndrome of the brainstem: cranial magnetic resonance imaging, cerebrospinal fluid and neurophysiological findings. Mult Scler. 2003;9(1):39-43. [pmid: 12617267].
Sawa GM, Paty DW. The use of baclofen in treatment of spasticity in multiple sclerosis. Can J Neurol Sci. 1979;6(3):351-4. [pmid: 385132].
Scheinberg L, Holland N, Larocca N, et al. Multiple sclerosis; earning a living. NY State J Med. 1980;80(9):1395-400.
Schiffer RB, Herndon RM, Rudick RA. Treatment of pathologic laughing and weeping with amitriptyline. New Engl J Med. 1985;312(23):1480-2. [pmid: 3887172].
Schiffer RB, Wineman NM. Antidepressant pharmacotherapy of depression associated with multiple sclerosis. Am J Psych. 1990;147(11):1493-7.
Schmidt RT, Lee RH, Spehlmann R. Treatment of spasticity in multiple sclerosis: comparison of dantrolene sodium and diazepam. Trans Am Neurol Assoc. 1975;100:235-7. [pmid: 1226625].
Schmidt RT, Lee RH, Spehlmann R. Comparison of dantrolene sodium and diazepam in the treatment of spasticity. J Neurol Neurosurg Psych. 1976;39(4):350-6.
Schwartz CE, Coulthard-Morris L, Cole B, et al. The quality-of-life effects of interferon beta-1b in multiple sclerosis. An extended Q-TWiST analysis. Arch Neurol. 1997;54(12):1475-80. [pmid: 9400356].
Sipe JC, Romine JS, Koziol JA, et al. Cladribine in treatment of chronic progressive multiple sclerosis. Lancet. 1994;344(8914):9-13. [pmid: 7912347].
Smith C, Birnbaum G, Carter JL, et-al. Tizanidine treatment of spasticity caused by multiple sclerosis: results of a double-blind, placebo-controlled trial. US Tizanidine Study Group. Neurology 1994;44(11 Suppl 9):S34–42; discussion S42–3.
Smolenski C, Muff S, Smolenski-Kautz S. A double-blind comparative trial of new muscle relaxant, tizanidine (DS 103-282), and baclofen in the treatment of chronic spasticity in multiple sclerosis. Curr Med Res Opinion. 1981;7(6):374-83.
Snow BJ, Tsui JK, Bhatt MH, et al. Treatment of spasticity with botulinum toxin: a double-blind study. Ann Neurol. 1990;28(4):512-5. [pmid: 2252363].
Solari A, Filippini G, Gasco P, et al. Physical rehabilitation has a positive effect on disability in multiple sclerosis patients. Neurology. 1999;52(1):57-62. [pmid: 9921849].
SPECTRIMS Study Group. Randomized controlled trial of interferon- beta-1a in secondary progressive MS: Clinical results. Neurology. 2001;56(11):1496-504. [pmid: 11402106].
Stevenson VL, Leary SM, Losseff NA, et al. Spinal cord atrophy and disability in MS: a longitudinal study. Neurology. 1998;51(1):234-8. [pmid: 9674808].
Stien R, Nordal HJ, Oftedal SI, et al. The treatment of spasticity in multiple sclerosis: a double-blind clinical trial of a new anti-spastic drug tizanidine compared with baclofen. Acta Neurol Scand. 1987;75(3):190-4. [pmid: 3554879].
Strasser-Fuchs S, Fazekas F, Deisenhammer F, et al. The Austrian Immunoglobulin in MS (AIMS) study: final analysis. Mult Scler. 2000;6 Suppl 2:S9-13. [pmid: 11188778].
Stuifbergen AK, Becker H, Blozis S, et al. A randomized clinical trial of a wellness intervention for women with multiple sclerosis. Arch Phys Med Rehab. 2003;84(4):467-76.
Tintoré M, Rovira A, Río J, et al. New diagnostic criteria for multiple sclerosis - application in first demyelinating episode. Neurology. 2003;60(1):27-30. [pmid: 12525713].
Trotter JL, Clifford DB, McInnis JE, et al. Correlation of immunological studies and disease progression in chronic progressive multiple sclerosis. Ann Neurol. 1989;25(2):172-8. [pmid: 2521993].
United Kingdom Tizanidine Trial Group. A double-blind, placebo-controlled trial of tizanidine in the treatment of spasticity caused by multiple sclerosis. Neurology. 1994;44(11 Suppl 9):S70-8. [pmid: 7970014].
Vahtera T, Haaranen M, Viramo-Koskela AL, et al. Pelvic floor rehabilitation is effective in patients with multiple sclerosis. Clin Rehab. 1997;11(3):211-9.
Valiquette G, Herbert J, Maede-D'Alisera P. Desmopressin in the management of nocturia in patients with multiple sclerosis. A double-blind, crossover trial. Arch Neurol. 1996;53(12):1270-5. [pmid: 8970454].
van de Wyngaert FA, Beguin C, D'Hooghe MB, et al. A double-blind clinical trial of mitoxantrone versus methylprednisolone in relapsing, secondary progressive multiple sclerosis. Acta Neurol Belg. 2001;101(4):210-6. [pmid: 11851027].
Verdier-Taillefer MH, Sazdovitch V, Borgel F, et al. Occupational environment as risk factor for unemployment in multiple sclerosis. Acta Neurol Scand. 1995;92(1):59-62. [pmid: 7572062].
Villar LM, Masjuan J, González-Porqué P, et al. Intrathecal IgM synthesis predicts the onset of new relapses and a worse disease course in MS. Neurology. 2002;59(4):555-9. [pmid: 12196648].
Wassem R, Dudley W. Symptom management and adjustment of patients with multiple sclerosis: a 4-year longitudinal intervention study. Clin Nurs Res. 2003;12(1):102-17. [pmid: 12583502].
Weinshenker BG, Penman M, Bass B, et al. A double-blind, randomized, crossover trial of pemoline in fatigue associated with multiple sclerosis. Neurology. 1992;42(8):1468-71. [pmid: 1641137].
Weinstein A, Schwid SI, Schiffer RB, et al. Neuropsychologic status in multiple sclerosis after treatment with glatiramer. Arch Neurol. 1999;56(3):319-24. [pmid: 10190822].
Wiles CM, Newcombe RG, Fuller KJ, et al. Controlled randomised crossover trial of the effects of physiotherapy on mobility in chronic multiple sclerosis. J Neurol Neurosurg Psych. 2001;70(2):174-9.
Zajicek J, Fox P, Sanders H, et al. Cannabinoids for treatment of spasticity and other symptoms related to multiple sclerosis (CAMS study): multicentre randomised placebo-controlled trial. Lancet. 2003;362:1517-26. [pmid: 14615106].
Zipoli V, Portaccio E, Siracusa G, et al. Interobserver agreement on Poser's and the new McDonald's diagnostic criteria for multiple sclerosis. Mult Scler. 2003;9:481-5. [pmid: 14582774].