# Appendix F. Evidence Tables

Evidence Table 1a. Diagnostic reliability of McDonald criteria

Study | Study Design | Patients | Clinical Presentation | Additional Data Used for Diagnosis | Results | | | | Comments/Quality Scoring
Barkhof, Filippi, Miller, et al., 1997 | Prospective cohort study | Total no. at start: 91 | Clinically isolated syndrome suggestive of MS and not attributable to other diseases; among those completing study (n = 74), presenting symptom was optic neuritis in 40 patients, spinal cord syndrome in 22, and brainstem/ cerebellum syndrome in 12 | Baseline MRIs performed at a median of 4 wk (range, 1–20 wk) after onset of symptoms | This study examined various MRI lesion characteristics and used regression analysis to determine the utility of each characteristic with regard to diagnosis. Because previous criteria have demonstrated significant sensitivity, but low specificity, the authors then developed a model with greater positive predictive value based on the results of regression analysis. | | | | This study is a thorough, prospective analysis of MRI characteristics with regard to their diagnostic utility, using prospective regression analysis to assess the predictive value of each parameter. On the basis of the findings, a model was developed using the four most predictive parameters. This model became the basis for the MRI criteria used in the McDonald criteria. This study thus does not directly assess the performance of the McDonald criteria, but serves as the basis for the MRI portion of the McDonald criteria. The only significant criticism is that the criteria are based on T2 lesions and gadolinium enhancement without analysis of FLAIR images, sagittal images, or images obtained from higher-strength magnets. These issues were appropriately addressed by the authors.
| Duration of follow up: Minimum of 2 yr; median follow up among patients not diagnosed with MS at end of study was 39 mo (range, 23–96 mo) | Dropouts: 17 (7 lost to follow up; 10 given definitive diagnosis other than MS and excluded from analysis) | | Clinically definite MS was diagnosed when clinical signs or symptoms developed in other areas of the central nervous system after a period of at least 1 month, and when other diagnoses had been excluded by appropriate clinical tests | 1) By regression analysis, the four dichotomized MRI parameters that demonstrated the greatest diagnostic utility were presence of 1 or more gadolinium-enhancing lesions, 1 or more infratentorial lesions, 1 or more juxtacortical lesions, and 3 or more periventricular lesions. The final regression model based on the presence of 3 or more of these 4 parameters demonstrated the following characteristics: | | | | QUALITY ASSESSMENT:
| Location: 3 sites in Europe (1 each in The Netherlands, Italy, and UK) | Completed: 74 | | 1) MRI - not used in the diagnosis of clinically definite MS | Sensitivity - 82% | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | Age: NR | | 2) CSF- not used in the diagnosis of clinically definite MS | Specificity - 78% | | | | Follow up > 80%?: Yes
| | | | 3) VEP - not used in the diagnosis of clinically definite MS | Accuracy - 80%
| | | | MRIs were analyzed during a single session by consensus of two observers who were unaware of the clinical findings | PPV - 75%
| | | | | NPV - 84%
Brex, Miszkiel, O'Riordan, et al., 2001 | Prospective cohort study | Total no. at start: 81 | Clinically isolated syndrome (defined as the occurrence of a presumed inflammatory demyelinating event of acute onset in the CNS in a patient with no history suggestive of an earlier demyelinating episode); presenting symptom was optic neuritis in 45 patients, brain stem syndrome in 16, spinal cord syndrome in 6, and optic tract lesion in 1; age 16–50 at presentation; appropriate investigations ruled out alternative diagnoses | Baseline MRIs performed at a median of 5 wk (range, 1–12 wk) after onset of symptoms | 1) Contrast enhancing lesion at baseline was the most predictive initial MRI characteristic with positive predictive value of 52%, specificity of 80%, and sensitivity of 61%. | | | | This study does not directly assess the utility of MRI as specifically used in the McDonald criteria, but it contributes to the idea that MRI scans performed serially augment the clinical criteria of Poser.
| Duration of follow up: Median, 12 mo; range, 11–19 mo | Dropouts: 13 | | MRI - performed as part of the initial baseline evaluation and again after 3 mo, with and without contrast enhancement | 2) A single T2 lesion on baseline scan had highest sensitivity (89%) but poor specificity (36%). | | | | QUALITY ASSESSMENT:
| Location: London, UK | Completed: 68 attended all 3 study visits and were included in analysis | | Clinical assessment at 1 yr | 3) The combination of T2 lesions on baseline scan and new T2 lesions on follow-up scan yielded positive predictive value of 55%, sensitivity of 83%, and specificity of 76%. | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | Age at presentation: Mean, 31; range, 17–50 | | | 4) The combination of enhancing lesions on T1 images of both examinations had the highest positive predictive value (70%) and specificity (94%), but had a very low sensitivity (39%). | | | | Follow up > 80%?: Yes -- 84%
CHAMPS Study Group, 2002 | Prospective cohort study | Total no. at start: 190 | First occurrence of an isolated, well-defined neurological event consistent with demyelination and involving the optic nerve (unilateral optic neuritis; n = 97), spinal cord (incomplete transverse myelitis; n = 42), or brain stem or cerebellum (n = 51); ≥ 2 clinically silent T2-hyperintense brain MRI lesions (≥ 3 mm in size, at least one characteristic of MS [periventricular or ovoid]); onset of symptoms 14 days or less before start of IV corticosteroid and 27 days or less before randomization (see under “Patients”); age 18–50 | Baseline MRI performed ≥ 4 days after patient completed initial IV corticosteroid therapy (commenced within 14 days of symptom onset and lasted 3 days), but while patient still receiving oral prednisone (lasted 15 days after IV therapy stopped); median time from onset of symptoms = 18 days, range = 8–39 days | 1) Overall, 27% of patients (51/190) developed clinically definite MS by 18 mo. | | | | This study does examine the impact of MRI data in the diagnosis of clinically definite MS - including various MRI criteria. It serves as background information regarding the utility of the addition of MRI criteria in the McDonald criteria.
| Duration of follow up: 18 mo | Dropouts: NR | | MRI - performed ≥ 4 days after initial corticosteroid therapy (see above) and at 6, 12, and 18 months for those patients not meeting the primary study endpoint of clinically definite MS due to recurrence | 2) The best predictive model for clinically definite MS by 18 mo consisted only of whether patients had ≥ 2 enhancing lesions. None of the other MRI characteristics at their optimized cut-points improved the model fit. | | | | QUALITY ASSESSMENT:
| Location: 50 sites in the US and Canada | Completed: NR | | | 3) A higher percentage of those patients meeting the Barkhof criteria (≥ 9 T2 lesions) developed clinically definite MS (31%) by 18 mo than did patients who did not meet the criteria (16%) (RR = 1.94, 95% CI = 1.02 to 3.72). | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | Age (mean ± SD): 33 ± 7 | | | 4) The highest risk of clinically definite MS was seen among those with ≥ 2 enhancing lesions, with 52% of these patients reaching clinically definite MS by 18 mo compared with 24% of those with < 2 enhancing lesions (RR = 2.16, 95% CI = 1.35 to 3.46). | | | | Follow up > 80%?: Uncertain (dropouts not clearly reported
| | Patients were enrolled in an RCT comparing interferon beta-1a (30 μg weekly by IM injection; n = 193) vs. placebo (n = 190); all were treated with a course of corticosteroids before the start of the trial. Only placebo patients are considered in this publication.
Comi, Filippi, Barkhof, et al., 2001 | Prospective cohort study | Total no. at start: 309 | Clinical syndrome indicating unifocal or multifocal involvement of the CNS; first neurological episode suggesting MS in the previous 3 mo; 1 or more abnormalities on neurological exam; positive brain MRI (presence of ≥ 4 white-matter lesions on T2-weighted scans or presence of ≥ 3 white-matter lesions if at least one of these was intratentorial or contrast enhancing); age 18–40 | Baseline MRI performed as part of pre-study screening, within 3 mo of first neurological episode suggesting MS | 1) 34% of patients treated with interferon β-1a (52/154) and 45% of patients treated with placebo (69/154) converted to clinically definite MS during the 2-yr study. | | | | This was a placebo-controlled treatment trial in patients with clinically isolated syndromes. The study does include a small amount of data regarding the predictive value of initial evaluations in the diagnosis of MS. Although MRI was used prospectively, the report does not contain data regarding the diagnostic performance of serial MRI studies. This study therefore does not answer question 1a directly but provides some background information regarding the utility of MRI in the diagnosis of MS.
| Duration of follow up: 2 yr | Dropouts: 31 | | 1) MRI - performed as part of the initial baseline evaluation and again at 12 and 24 mo | 2) The only baseline clinical and MRI variables that were significantly predictive of outcome were multifocal onset (odds ratio 1.99 [95% CI, 1.14 to 3.46]; p = 0.015) and T2 lesion number > 8 (3.64 [1.30 to 10.2]; p = 0.014). | | | | QUALITY ASSESSMENT:
| Location: 57 sites in 14 European countries | Completed: 278 | | 2) CSF - performed only in those patients with initial manifestations suggestive of spinal cord lesion | | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | Age: Mean, 28.5 | | | | | | | Follow up > 80%?: Yes - 90%
| | Patients were enrolled in an RCT comparing interferon β-1a (22 μg weekly by SC injection; n = 154) vs. placebo (n = 155); patients were offered open-label interferon after conversion to clinically definite MS
Dalton, Brex, Jenkins, et al., 2002 | Prospective cohort study | Total no. at start: 55 | Clinically isolated syndrome suggestive of MS, defined as a single event of acute onset in the CNS suggestive of demyelination. In study population, 38 had unilateral optic neuritis, 11 brain stem syndrome, 5 spinal cord syndrome, and 1 a hemianopia due to an MRI lesion in the optic tract. | Baseline MRIs conducted within 3 mo of onset of symptoms | 14/55 patients (25%) developed clinically definite MS and 4 (7%) probable MS according to Poser criteria during the 1-yr follow up. 27 of 55 patients met McDonald criteria for MS at 1 yr. | | | | This study provides minimal data on the relative sensitivity of the Poser and McDonald criteria. This was not the primary purpose of the study, but it does demonstrate increased sensitivity of the McDonald criteria.
| Duration of follow up: Median, 12 mo (range, 11–16 mo) | Dropouts: 0 | Exclusion criteria: History of neurological symptoms suggestive of demyelination; age < 17 or > 50 | MRI - performed at baseline, 3 mo later, and approximately 1 yr after presentation | | | | | MRI data focused on ventricular volume changes.
| Location: London, UK | Completed: 55 | | | | | | | QUALITY ASSESSMENT:
| | Age: Mean, 29.6; range, 21–41 | | | | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | | | | | | | | Follow up > 80%?: Yes - 100%
Dalton, Brex, Miszkiel, et al., 2002 | Prospective cohort study | Total no. at start: 119 | Clinically isolated syndrome, defined as an acute isolated event affecting one region of the CNS and presumed to be demyelinating, with no previous history of possible demyelinating events. In study population, 87 had acute unilateral optic neuritis, 2 bilateral consecutive optic neuritis, 19 brain stem syndrome, 10 spinal cord syndrome, and 1 demyelinating optic tract lesion. Maximal symptoms and signs evident within 14 days of symptom onset. Alternative diagnoses excluded. Age 16–50. | Baseline MRIs conducted within 3 mo of onset of symptoms | 1) Clinically definite MS was present in 7% of patients (7/95) at 3 mo, 20% (16/79) at 1 yr, and 38% (19/50) at 3 yr follow up. | | | | This study specifically evaluates the performance of the McDonald criteria in comparison with the Poser criteria. This is a preliminary report of a 3-yr study in which fewer than 80% of patients had completed the 1-yr evaluation. The study demonstrates a significant increase in sensitivity of the McDonald criteria.
| Duration of follow up: 3 mo to 3 yr (follow up ongoing - see under “Patients,” at right) | Follow up ongoing at time of publication: 95 patients studied at 3 mo, 79 at 1 yr, and 50 at 3 yr | | MRI of the brain was performed at baseline, 3 mo, 1 yr, and 3 yr. MRI of the spinal cord was performed at baseline, 1 yr, and 3 yr. | 2) Performance of the McDonald criteria at 3-mo evaluation for predicting the development of clinically definite MS at 1 yr: | | | | QUALITY ASSESSMENT:
| Location: London, UK | Dropouts: 1 (died of asthmatic attack) | | | Sensitivity = 73% | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | Completed: Follow up ongoing; see above | | | Specificity = 87% | | | | Follow up > 80%?: No - at the time of this report the study was ongoing with fewer than 80% of patients having had 1-yr evaluations
| | Age: Median at onset, 31; range, 16–50 | | | PPV = 58%
| | | | | NPV = 93%
| | | | | Accuracy = 84%
| | | | | 3) Performance of the McDonald criteria at 1-yr evaluation for predicting the development of clinically definite MS at 3 yr:
| | | | | Sensitivity = 94%
| | | | | Specificity = 83%
| | | | | PPV = 77%
| | | | | NPV = 96%
| | | | | Accuracy = 87%
Filippi, Horsfield, Morrissey, et al., 1994 | Prospective cohort study | Total no. at start: 129 | Clinically isolated syndrome of the optic nerves (n = 40), brainstem (n = 16), or spinal cord (n = 28) suggestive of MS; syndrome fully developed within 14 days of symptom onset; age 10–50 at presentation; appropriate studies (including initial MRI) ruled out alternative diagnoses | Baseline MRIs were conducted within 60 days of onset of symptoms in 69/84 patients (82%), later in remaining 15 patients | 1) During 5-yr follow up, 34 patients (40%) developed clinically definite MS: 18 of 40 (45%) with initial optic neuritis, 10 of 28 (36%) with initial spinal cord syndrome, and 6 of 16 (38%) with initial brainstem syndrome. 4 patients (5%) developed clinically probable MS - 2 with initial optic neuritis and one each with spinal cord or brainstem syndrome. | | | | The MRI criteria used here are similar to those used in the McDonald criteria but not precisely the same. This study supports the use of MRI findings in the diagnosis, but does not directly compare with the MRI criteria adopted in the McDonald criteria.
| Duration of follow up: Mean ± SD, 63 ± 11 mo; range, 43–84 mo | Dropouts: 40 of original cohort not included in this 5-yr follow up | | 1) MRI - repeat MRI scans were performed after a mean of 63 mo. Quantitative semi-automated computer assessment of T2 lesion load was performed in a manner shown to have an intrarater reproducibility of 6%. | 2) 52 patients with abnormal MRI at presentation with median total brain lesion volume 0.83 cm^3^ (range, 0.09–52.41), with median infratentorial lesion volume of 0 cm^3^ (range, 0–1.82) | | | | Additional reports on this study population are provided in Morrissey, Miller, Kendall, et al., 1993; and O'Riordan, Thompson, Kingsley, et al., 1998, below.
| Location: London, UK | Completed: 89 re-examined and re-scanned at 5-yr follow up; 84 had complete data available (initial MRI unavailable at follow up for 5) | | 2) Clinical examination - patients were re-examined after a mean of 63 mo with assessment of EDSS. MS was diagnosed solely on clinical grounds using Poser criteria. | 3) Patients developing MS had significantly higher total and infratentorial lesion loads at presentation than those who did not: median total lesion volumes were 1.15 cm^3^ (range, 0–52.41) versus 0 cm^3^ (range, 0–25.6), p < 0.0001; the median infratentorial lesion volumes were 0 cm^3^ (range, 0–1.82) versus 0 cm^3^ (range, 0–0.59), p < 0.0001. | | | | QUALITY ASSESSMENT:
| | Age at baseline presentation: Mean, 31; range, 13–50 | | | 4) Lesion load of 1.23 cm^3^ at presentation afforded the highest probability of separating patients developing MS from those who did not. Patients then divided into three groups: Group A - patients with total lesion volume ≥ 1.23 cm^3^, Group B - patients with abnormal MRI but total lesion volume < 1.23 cm^3^, and Group C - patients with normal MRI at baseline. Results: | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | | | | Group A - 19 of 21 (90%) patients developed MS (18 clinically definite, 1 clinically probable) | | | | Follow up > 80%?: Yes - 84%
| | | | | Group B - 17 of 31 (55%) developed MS (15 definite and 2 probable)
| | | | | Group C - 2 of 32 (6%) developed MS (1 definite and 2 probable)
| | | | | 5) 18 of 20 (90%) patients with infratentorial lesions developed MS (all clinically definite), whereas 44 of 64 (69%) without such lesions did not.
| | | | | 6) A significant correlation was found between total and infratentorial lesion load on the initial MRI (Spearman rank correlation coefficient = 0.649; p < 0.0001).
Ghezzi, Martinelli, Torri, et al., 1999 | Prospective cohort study | Total no. at start: 112 | Acute isolated optic neuritis | Baseline paraclinical tests performed within 6 mo of onset of optic neuritis; mean interval, 45 ± 24 days | 36% of patients (37/102) developed clinically definite MS in 2.3 ± 1.6 yr of follow up after initial attack of optic neuritis. | | | | This study evaluated the utility of paraclinical tests in predicting those patients with clinically isolated syndromes who would progress to develop clinically definite MS. The data presented provide background information regarding the utility of paraclinical tests, but do not directly evaluate the McDonald criteria in that the paraclinical tests were not applied in the same manner as used in the McDonald criteria.
| Duration of follow up: Mean ± SD, 6.3 ± 2.2 yr; median, 5 yr | Dropouts: 10 lost to follow up | | 1) MRI - performed at baseline only - details not delineated | Number of patients developing MS in relation to the results of paraclinical tests performed at baseline: | | | | QUALITY ASSESSMENT:
| Location: Gallarate, Italy | Completed: 102 | | 2) CSF IgG Index was the parameter utilized; definition of abnormal not stated | | MS+ | Ms- | P-value | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | Age: Mean ± SD, 29.2 ± 9.0 | | 3) VEP - Multiple Evoked Potential studies were performed at baseline. No details regarding technique were presented. | 1) MRI: | | | 0.0001 | Follow up > 80%?: Yes - 91%
| | | | | Negative | 37 | 34
| | | | | Positive | 0 | 31
| | | | | 2) CSF: | | | 0.19
| | | | | Negative | 22 | 29
| | | | | Positive | 12 | 31
| | | | | 3) VEP: | | | 0.95
| | | | | Negative | 10 | 16
| | | | | Positive | 26 | 48
| | | | | 4) BAEP, median nerve SEP, and upper limb MEP: | | | 0.7
| | | | | Negative | 2 | 7
| | | | | Positive | 17 | 31
| | | | | 5) BAEP, median and tibial nerve
| | | | | SEP: | | | 0.02
| | | | | Negative | 9 | 5
| | | | | Positive | 6 | 21
Morrissey, Miller, Kendall, et al., 1993 | Prospective cohort study | Total no. at start: 132 | Clinically isolated syndrome of the optic nerves (n = 44), brainstem (n = 17), or spinal cord (n = 28) suggestive of MS; syndrome acute or subacute in onset; age 10–50 at presentation; appropriate studies (including initial MRI) ruled out alternative diagnoses | Baseline MRIs were conducted within 60 days of onset of symptoms in 74/89 patients (83%), later in remaining 15 patients | After 5 yr, progression to clinically definite MS occurred in 41 of 57 (72%) of patients who had had abnormal initial scans, but in only 2 of 36 (6%) patients whose initial scan was normal (P < 0.0001). | | | | This study provides background information regarding the utility of MRI in the diagnosis of MS but does not utilize MRI in the same manner as the McDonald criteria and therefore does not answer Question 1a specifically.
| Duration of follow up: Mean, 63.6 mo; range, 43–84 mo | Dropouts: 43 of original cohort not included in 5-yr follow up | | 1) MRI - performed at baseline and a mean of 1.3 yr later and again at 5.3 yr - all scans were unenhanced | | | | | Additional reports on this study population are provided in Filippi, Horsfield, Morrissey, et al., 1994, above; and O'Riordan, Thompson, Kingsley, et al., 1998, below.
| Location: London, UK | Completed: 89 re-examined and re-scanned at 5-yr follow up | | 2) CSF - not performed in patients with clinically isolated optic neuritis, but was performed in patients with isolated spinal cord or brainstem syndromes | | | | | QUALITY ASSESSMENT:
| | Age at baseline presentation: Mean, 31.3; range, 13–50 | | | | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | | | | | | | | Follow up > 80%?: No - 67%
Optic Neuritis Study Group, 1997 | Prospective cohort study | Total no. at start: 388 | Acute unilateral optic neuritis with visual symptoms of 8 days or less; no previous history of optic neuritis or ophthalmoscopic signs of optic atrophy in the affected eye; no evidence of a systemic disease other than MS that might be associated with the optic neuritis; no previous treatment with corticosteroids for MS or for optic neuritis in the opposite eye; age 18–46 yr | Baseline MRIs performed “on study entry” (within 8 days of onset of acute symptoms) | 1) 27% of patients (106/388) developed clinically definite MS with 5 yr, and an additional 9% (35 patients) developed probable MS. | | | | This study provides background information regarding the utility of MRI in the diagnosis of MS, but the utilization of MRI did not include serial studies as is the case for the McDonald criteria, and therefore this report does not provide direct data on the performance of the McDonald criteria.
| Duration of follow up: 5 yr | Dropouts: 47 | Patients with a diagnosis of clinically definite or probable MS were excluded | MRI - brain MRI was performed at baseline according to standardized protocols | 2) The presence of MRI abnormalities at the time of optic neuritis was the single most important predictor of the development of clinically definite MS by 5 yr. The probability of clinically definite MS was 16% in the 202 patients with no MRI abnormalities, 37% in the 60 patients with 1–2 MRI abnormalities, and 51% in the 89 patients with ≥ 3 MRI abnormalities. | | | | QUALITY ASSESSMENT:
| Location: 15 sites in the US | Completed: 341 followed up for 5 yr | | | | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | Age (mean ± SD): 32 ± 7 | | | | | | | Follow up > 80%?: Yes - 88%
| | Patients were participants in an RCT comparing IV methylprednisolone vs. oral prednisone vs. oral placebo
O'Riordan, Thompson, Kingsley, et al., 1998 | Prospective cohort study | Total no. at start: 129 | Clinically isolated syndrome (defined as an acute or subacute episode suggestive of demyelination affecting the optic nerves [n = 42], brainstem [n = 16], or spinal cord [n = 23]); age 10–50 at presentation; appropriate studies (including initial MRI) ruled out alternative diagnoses | Not clear when baseline MRIs conducted | 1) Patients with a normal baseline MRI (n = 27): Only 3 patients (11%) progressed to clinically definite MS, all of whom had benign disease. 2 additional patients (7%) had clinically probable MS. Of these 5 patients, 4 had 10-yr follow-up MRIs and all had developed new lesions. 22 patients of these original 27 (81%) were still classified as having clinically isolated syndromes. | | | | The MRI criteria used here are similar to those used in the McDonald criteria but not precisely the same. This study supports the use of MRI findings in the diagnosis, but does not directly compare with the MRI criteria adopted in the McDonald criteria.
| Duration of follow up: Mean, 9.7 yr | Dropouts: 48 of original cohort not included in this 10-yr follow up | | 1) MRI - baseline and follow-up scans up to the 5-yr scans were performed on a 0.5 T scanner using SE2000/60 sequences. 10-yr scans were performed on a 1.5 T scanner and used conventional dual spin echo technique. All scans were evaluated only for the presence of hyperintense lesions. Scans were considered abnormal only if one or more asymptomatic lesions characteristic for demyelination were present. The number of lesions compatible with demyelination was recorded. All scans were read with the baseline and 5-yr scans side-by-side for comparison. | 2) Patients with abnormal MRI at baseline (n = 54): After 10 yr, only 7 patients (13%) still had a diagnosis of clinically isolated syndrome, 2 patients (4%) had clinically probable MS, and 45 patients (83%) had progressed to clinically definite MS. Of those with clinically definite MS, 21 patients (39%) had benign disease, 11 patients (20%) relapsing/remitting disease with an EDSS of > 3, and 13 patients (24%) developed secondary progressive MS. | | | | Additional reports on this study population are provided in Filippi, Horsfield, Morrissey, et al., 1994; and Morrissey, Miller, Kendall, et al., 1993, above.
| Location: London, UK | Completed: 81 re-examined and re-scanned at 10-yr follow up | | 2) Diagnosis of MS was made solely on the basis of Poser criteria after 10 yr of follow up | For those with an abnormal baseline MRI, the presence of infratentorial lesions did not confer any greater risk for the subsequent development of clinically definite MS. | | | | QUALITY ASSESSMENT:
| | Age at baseline presentation: Mean, 32.3; range, 17–49 | | | | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | | | | | | | | Follow up > 80%?: No - 81 patients at 10-yr follow up of 129 patients in original cohort = 63%
Sastre-Garriga, Tintoré, Rovira, et al., 2003 | Prospective cohort study | Total no. at start: 59 | Episode of clinical brainstem dysfunction suggestive of inflammatory demyelination; clinical assessment within 3 mo of onset of symptoms; age < 50; other possible diagnoses excluded | Mean time between onset of symptoms and initial MRI 29 days | 1) Paty MRI criteria: | | | | Clinical diagnosis of MS was made based on the occurrence of neurological symptoms lasting over 24 hr without the requirement of objective findings on neurological examination. This definition is more sensitive but less specific than most clinical criteria in use, including the Poser criteria. Additionally, this study evaluated the ability of baseline parameters to predict the subsequent development of MS. These parameters were not performed serially to assess their correlation with clinical diagnosis.
| Duration of follow up: Mean, 37 mo | Dropouts: 8 (excluded because follow-up shorter than 12 mo) | | 1) MRI - 1.0 or 1.5 T scanners including transverse proton density and T2-weighted conventional spin echo or fast spin echo, and T1-weighted spin echo. T1 images were repeated after administration of gadolinium. Sagittal T2 or transverse T2 FLAIR were also performed on most patients. A blinded neuroradiologist recorded the number and sites of abnormalities. The MRI diagnostic criteria of Paty, Fazekas, and Barkhof were then studied. | Sensitivity = 89% | | | | QUALITY ASSESSMENT:
| Location: Barcelona, Spain | Completed: 51 | | 2) CSF - presence of oligoclonal bands were assessed, but not used in the diagnosis of MS | Specificity = 52% | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: No - symptomatic recurrence did not require objective examination abnormalities
| | Age: Mean at assessment, 29; range, 14–49 | | 3) VEP - values of VEP and SEP results were assessed but not used in the diagnosis of MS | PPV = 50% | | | | Follow up > 80%?: Yes - 86%
| | | | | NPV = 89%
| | | | | Accuracy = 65%
| | | | | 2) Fazekas MRI criteria:
| | | | | Sensitivity = 89%
| | | | | Specificity = 48%
| | | | | PPV = 48%
| | | | | NPV = 89%
| | | | | Accuracy = 63%
| | | | | 3) Barkhof MRI criteria:
| | | | | Sensitivity = 78%
| | | | | Specificity = 61%
| | | | | PPV = 52%
| | | | | NPV = 83%
| | | | | Accuracy = 67%
| | | | | 4) CSF - presence of oligoclonal bands:
| | | | | Sensitivity = 100%
| | | | | Specificity = 42%
| | | | | PPV = 44%
| | | | | NPV = 100%
| | | | | Accuracy = 63%
| | | | | 5) Evoked potential studies - no statistically significant differences for baseline VEP or SSEP parameters were found between patients who did and those who did not convert to MS
Tintoré, Rovira, Río, et al., 2003 | Cohort study; data collected prospectively, McDonald criteria applied retrospectively | Total no. at start: 139 | Clinically isolated syndrome suggestive of CNS demyelination involving the optic nerve (41.5%), brainstem (24.5%), spinal cord (28%), or combinations of the above (6%), and not attributable to other diseases; age < 50 yr | Baseline MRIs completed within 3 mo of onset of symptoms | 1) At 1 yr, 15 patients (11%) had a second clinical attack and therefore fulfilled the requirement for dissemination in time and space necessary for clinically definite MS according to the Poser criteria. Of these 15 patients, 10 also fulfilled the radiologic conditions of dissemination in time and space. | | | | This article precisely and specifically evaluates Question 1a.
| Duration of follow up: Mean, 39 ± 17.2 mo; range, 12–77 mo; all patients were followed up for at least 1 yr (inclusion criterion), 122 for at least 2 yr, and 86 for at least 3 yr | Dropouts: 17 by 2 yr; 53 by 3 yr | Analysis included only patients with clinical and MRI examinations within 3 mo of onset of symptoms and clinical follow up of at least 12 mo | 1) MRI - standard MRI techniques used after the first demyelinating event and 12 mo later | 2) Fifty-one patients (37%) fulfilled MRI requirements for dissemination in time and space and therefore were considered to have MS according to the McDonald criteria. Ten of these 51 patients (20%) had a second clinical event during the first year of follow up. In total, 56 of 139 patients (40%) fulfilled the McDonald criteria for MS either by MRI or clinically. | | | | QUALITY ASSESSMENT:
| Location: Barcelona, Spain | Completed: 139 were followed up for at least 1 yr (inclusion criterion), 122 for at least 2 yr, and 86 for at least 3 yr | | 2) CSF - the presence of oligoclonal bands was assessed after the first demyelinating event | 3) The McDonald criteria showed a sensitivity of 74%, specificity of 85%, PPV of 80%, NPV of 80%, and accuracy of 80% in predicting conversion to clinically definite MS: | | | | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes
| | Age: Mean, 30; range, 13–49 | | | Clinically definite MS | | | | Follow up > 80%?: Yes - 100% (first yr)
| | | | | at 3 yr | + | -
| | | | | McDonald | + | 28 | 7
| | | | | criteria
| | | | | at 1 yr | - | 10 | 41
| | | | | 4) In the first year the Poser criteria allowed the diagnosis of clinically definite MS in 11% compared with 37% with the McDonald criteria.

Evidence Table 1b. Inter-rater reliability of diagnosis with McDonald and Poser criteria

Study | Study Design | Patients & Physicians | Patients' Clinical Presentation | Diagnostic Criteria and Data Available | Results | Comments/Quality Scoring
Ford, Johnson, and Rigby, 1996 | Cross-sectional diagnostic test study (retrospective) | Patients: | Patients had been diagnosed according to Poser criteria as having clinically definite MS, laboratory-supported definite MS, clinically probable MS, laboratory-supported probable MS, or suspected MS, or as “unable to classify”; all were outpatients at study clinic | 1) Diagnostic criteria used: Poser | Overall, there was substantial agreement between the two observers in classifying multiple sclerosis according to the Poser criteria (κ = 0.65, 95% CI = 0.52 to 0.78). There was poor agreement in the historical data used to classify the cases (κ = 0.30, 95% CI = 0.03 to 0.57). | This study was a retrospective review of case records and therefore the evaluators lacked the ability to examine patients themselves and therefore variation in clinical judgment occurred. The authors note that “retrospective analysis may also underestimate the extent of variation between observers.”
| Single-center | N = 85 | | 2) Data available for diagnosis: Diagnoses made entirely on basis of data contained in case records of patients; precise data contained in these unclear | | This study specifically utilized Poser criteria for diagnosis.
| Setting: General neurology outpatient clinic | Age: Mean, 46; range, 23–74 | | | | The authors note that possible sources of observed disagreement likely include lack of adequate documentation contained in medical records.
| Location: Leeds, UK | Physicians: | | | | QUALITY ASSESSMENT:
| | N = 2 (both neurologists) | | | | Evaluating physicians blinded to one another's diagnosis?: Yes
| | | | | | Did study sample include an appropriate spectrum of patients (not just “difficult” cases)?: Yes
Zipoli, Portaccio, Siracusa, et al., 2003 | Cross-sectional diagnostic test study | Patients: | All cases consecutively admitted for diagnostic assessment at study site between Sep 2001 and June 2002 and prospectively followed up for ≥ 6 mo; data collected via chart review | 1) Diagnostic criteria used: | Poser criteria: | This study specifically addressed the inter-rater reliability of the Poser and McDonald criterion. It thus provides data directly answering Question 1b.
| Single-center | N = 44 | Patients' (preexisting) diagnoses as follows: | Poser | Diagnosis of MS: κ = 0.57 | The primary difficulty in the McDonald criteria appeared to be decreased agreement in MRI interpretation - specifically in those patients with high lesion loads. The authors commented that this study utilized neurologist evaluators not neuroradiologists and previous studies have correlated level or radiographic training with agreement in interpretation. Judging dissemination in time was of particular difficulty in those patients with clinically isolated symptoms. The authors suggested that neuroradiologists be encouraged to interpret scans in MS patients with the McDonald MRI criteria in mind - providing specific information regarding lesion location and timing.
| Setting: University department of neurology | Age (mean ± SD): 31 ± 7.5 | 41 MS (15 relapsing-remitting, 2 secondary progressive, 5 primary progressive, 19 presenting with first clinical attack) | McDonald | Dissemination in time: κ = 0.69 | QUALITY ASSESSMENT:
| Location: Florence, Italy | Physicians: | 1 cerebral autosomal dominant arteriopathy with subcortical infarcts and leuko-encephalopathy | 2) Data available for diagnosis: | Dissemination is space: κ = 0.46 | Evaluating physicians blinded to one another's diagnosis?: Yes
| | N = 4 neurologists | 1 migraine with aura | Family and patient clinical history | Diagnosis of clinically definite MS: κ = 0.39 | Did study sample include an appropriate spectrum of patients (not just “difficult” cases)?: Yes
| | | 1 Leber's hereditary optic neuropathy | Complete neurological exam | Diagnosis of clinically probable MS: κ = 0.37
| | | | Lab tests (blood counts, etc.) | McDonald criteria:
| | | | Occurrence of new or worsening symptoms | Diagnosis of MS (all categories): κ = 0.52
| | | | Brain MRI | Diagnosis of MS: κ = 0.52
| | | | Spinal cord MRI (when appropriate) | Diagnosis of possible MS: κ = 0.49
| | | | CSF examination | Diagnosed not MS: κ = 0.64
| | | | Evoked potentials
| | | | “Other examinations performed for the differential diagnosis”

Evidence Table 2. Predictors of physical and mental impairments at 12 months

Study | Selected Inclusion/ Exclusion Criteria | Study Design | Patients | Possible Predictors Considered | Results | | | | | Comments/Quality Scoring
Chapman, Sylantiev, Nisipeanu, et al., 1999 | Inclusion: Clinically definite MS; relapsing-remitting course | Prospective, population-based, cohort study | Total no. at start: 47 | Presence of APOE ε4 allele | 1) Significant interaction of genotype with change in disability over 2-yr time period (P = 0.02): | | | | | For all missing data, the last observation was carried forward in the statistical analyses. Information about the number of observations that were carried forward was not provided.
| Exclusion: None | Duration of follow up: Follow up conducted every 3 mo for a period of 2 yr | APOE ε4: | | APOE ε4: Mean EDSS deteriorated to 4.00 ± 0.63 | | | | | QUALITY ASSESSMENT:
| | | N = 9 heterozygous for APOE ε4 allele | | Non-APOE ε4: Mean EDSS stable at 2.74 ± 0.31 | | | | | Study described as “population-based”?: No
| | | N = 1 homozygous for APOE ε4 allele | | 2) No significant difference (P > 0.35) for the three possible predictors: | | | | | Sample of patients assembled at a common point in the course of their disease?: Yes
| | | N = 37 without allele | | a. Duration of illness at entry: | | | | | Sample of patients assembled at an early point in the course of their disease?: Yes
| | | Completed: | | APOE ε4: 48 ± 12 mo | | | | | Follow up > 80%?: Yes
| | | N = 8 APOE ε4 | | Non-APOE ε4: 57 ± 10 mo | | | | | Outcomes assessed using a widely used scale?: Yes
| | | N = 33 Non-APOE ε4 | | b. Exacerbation rate over previous 2 yr: | | | | | Outcomes assessed in a blind fashion?: Unclear
| | | Dropouts: | | APOE ε4: 1.05 ± 0.05 per yr | | | | | If subgroups with different prognoses identified:
| | | N = 2 APOE ε4 | | Non-APOE ε4: 1.12 ± 0.06 per yr | | | | | a) was there adjustment for important prognostic factors? No
| | | N = 4 Non-APOE ε4 | | c. EDSS score: | | | | | b) was there independent validation?: NA
| | | Age (mean): | | APOE ε4: 3.10 ± 0.45
| | | APOE ε4: 34.0 ± 1.4 | | Non-APOE ε4: 2.62 ± 0.25
| | | Non-APOE ε4: 36.0 ± 2.3 years | | 3) Exacerbation characteristics:
| | | Baseline measures of physical and mental functioning: | | Mean EDSS before peak:
| | | APOE ε4: | | APOE ε4: 3.67 ± 1.30
| | | EDSS Mean: 3.10 ± 0.45 | | Non-APOE ε4: 2.00 ± 0.54
| | | EDSS Range: 1.5–6.0 | | Mean EDSS at peak:
| | | Exacerbation rate, per year: 1.05 ± 0.05 | | APOE ε4: 4.67 ± 1.30
| | | Non-APOE ε4: | | Non-APOE ε4: 3.37 ± 0.44
| | | EDSS Mean: 2.62 ± 0.25 | | Mean EDSS at resolution of exacerbation:
| | | EDSS Range: 0–6.0 | | APOE ε4: 4.50 ± 1.26
| | | Exacerbation rate, per year: 1.12 ± 0.06 | | Non-APOE ε4: 2.04 ± 0.52
| | | | | Borderline significant interaction (P = 0.049, 1-tailed) between groups for EDSS scores at peak and at resolution, indicating impaired recovery in APOE ε4 carriers
Cottrell, Kremen-chutzky, Rice, et al., 1999a | Inclusion: Primary progressive MS | Prospective, population-based, cohort study | Total no. at start: Original cohort, 216; 2^nd^ cohort, 165 | DSS at time 0 - evaluated in relation to 3 different groups of patients: | Probability of progression to next DSS level within 1 year (original cohort, n = 216): | | | | | QUALITY ASSESSMENT:
and | Exclusion: None specified | Duration of follow up: Original cohort followed up for mean of 23 yr; follow-up time for 2^nd^ cohort NR | Dropouts: NR | a) Original cohort; | DSS | | | | | Study described as “population-based”?: Yes
Cottrell, Kremen-chutzky, Rice, et al., 1999b | | | Completed: NR | b) Simulated group of patients at DSS 3, 4, or 5 who had progressed one level in the last yr and had reached DSS 3 by 5 yr; | Level | Probability | Median | N entering | | Sample of patients assembled at a common point in the course of their disease?: Yes
| | | Age: Mean age at onset, 38.5 in original cohort, 38.9 in 2^nd^ cohort | c) Simulated group of patients at DSS 4, 5, or 6 who had progressed one level in the last year and had reached DSS 4 by 10 yr | 1 | 0.87 | 0.6 yr | 190 | | Sample of patients assembled at an early point in the course of their disease?: Yes
| | | Baseline measures of physical and mental functioning: Mean DSS score at presentation (4) reported for 2^nd^ cohort only | Prognostic factors considered: | 2 | 0.26 | 1.9 yr | 182 | | Follow up > 80%?: NR
| | | | Sex | 3 | 0.31 | 1.8 yr | 179 | | Outcomes assessed using a widely used scale?: No
| | | | Age of onset | 4 | 0.40 | 1.3 yr | 171 | | Outcomes assessed in a blind fashion?: Unclear
| | | | System involved at onset | 5 | 0.33 | 1.6 yr | 163 | | If subgroups with different prognoses identified:
| | | | Number of systems | 6 | 0.04 | 4.0 yr | 174 | | a) was there adjustment for important prognostic factors? Yes
| | | | Rate of early disability | 7 | 0.10 | 3.9 yr | 131 | | b) was there independent validation?: No
| | | | | 8 | 0.02 | 11.5 yr | 125
| | | | | 9 | 0.08 | 7.2 yr | 48
| | | | | Multiple regression (accelerated failure time) analysis of prognostic factors for DSS 8:
| | | | | Factor | Regression Coefficient | SE | P-value | Effect Tested
| | | | | Sex | 0.037 | 0.078 | 0.63 | M vs. F
| | | | | Age at onset | -0.001 | 0.004 | 0.15 | Linear
| | | | | Years to DSS 3 | 0.067 | 0.011 | 0.0001 | Linear
| | | | | No. of systems | -0.457 | 0.19 | 0.01 | 3 vs. 1
| | | | | No. of systems | -0.09 | 0.08 | 0.27 | 2 vs. 1
| | | | | Origin of case | -0.08 | 0.1 | 0.41 | Middlesex vs. Non- Middlesex
Fuhr, Borggrefe-Chappuis, Schindler, et al., 2001 | Inclusion: Clinically definite MS; relapsing-remitting or secondary progressive course; EDSS score ≥2 and ≤ 6.5; MRI during last 12 mo consistent with MS diagnosis; MRI during 2 wk before entry showing at least one gadolinium-enhancing lesion | Prospective case series | Total no. at start: 30 | Combined motor evoked potentials (MEPs) and visual evoked potentials (VEPs), sum of Z-transformed latencies at baseline | | | Δ EDSS 0 to 24 mo | | | Table in “Results” column, as well as predictive value information, calculated by abstractor using data from Figure 2.0 for sum of Z-transformed latencies at T_0_
| Exclusion: Chronic steroid or immunosuppressive drug treatment during past 6 mo; acute steroid treatment for a relapse during past 4 wk | Duration of follow up: 2 yr | 25 relapsing-remitting | | Sum of Z- transformed latencies | | > 0 | ≤ 0 | | QUALITY ASSESSMENT:
| | | 5 secondary progressive | | | > 0 | 9 | 3 | | Study described as “population-based”?: No
| | | Completed: 30 | | | ≤ 0 | 8 | 7 | | Sample of patients assembled at a common point in the course of their disease?: Unclear
| | | Dropouts: 0 | | Sensitivity = 9/17 (53%) | | | | | Sample of patients assembled at an early point in the course of their disease?: Unclear
| | | Age: Median 37.5 (range, 26–50) | | Specificity = 7/10 (70%) | | | | | Follow up > 80%?: Yes
| | | Sex: | | PPV = 9/11 (82%) | | | | | Outcomes assessed using a widely used scale?: Yes
| | | Male: 6 (20%) | | NPV = 7/15 (47%) | | | | | Outcomes assessed in a blind fashion?: No
| | | Female: 24 (80%) | | Prevalence = 12/27 (44%) | | | | | If subgroups with different prognoses identified:
| | | Baseline measures of physical and mental functioning: | | Median EDSS at entry: 4.65 (range, 2–6.5) | | | | | a) was there adjustment for important prognostic factors? NA
| | | Median EDSS at entry: 4.65 (range, 2–6.5) | | Median EDSS at end of study: 5.1 (range, 2–9) | | | | | b) was there independent validation?: NA
| | | Mean disease duration at entry: 9.2 years (range, 1.5–22 years)
Goodkin, Hertsgaard, and Rudick, 1989 | Inclusion: Definite or probable MS | Prospective, clinic-based, cohort study | Total no. at start: 425 | Disease type (determined from patient history and neurological records) | Change in EDSS score at 2 yr (mean ± SD) (P = 0.1296): | | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Duration of follow up: 1–5 yr (mean 2.6 yr) | 336 definite MS | Disease types: | S = 0.108 ± 1.275 | | | | | Study described as “population-based”?: No
| | | 89 probable MS | S = stable | RRS = 0.098 ± 1.693 | | | | | Sample of patients assembled at a common point in the course of their disease?: Yes
| | | Completed: 254 definite MS | RRS = relapsing remitting stable | RRP = 0.717 ± 2.340 | | | | | Sample of patients assembled at an early point in the course of their disease?: Yes
| | | Dropouts: | RRP = relapsing remitting progressive | CP = 0.689 ± 1.301 | | | | | Follow up > 80%?: Yes
| | | 82 definite MS | CP = chronic progressive | No significant difference was found among the various disease types for changes in EDSS over the 2-yr time period | | | | | Outcomes assessed using a widely used scale?: Yes
| | | 89 probable MS | | No significant difference in exacerbation rates by disease type | | | | | Outcomes assessed in a blind fashion?: Unclear
| | | Age: No mean reported | | | | | | | If subgroups with different prognoses identified:
| | | Baseline measures of physical and mental functioning: | | | | | | | a) was there adjustment for important prognostic factors? NA
| | | EDSS at entry (mean ± SD) (P < 0.0001): | | | | | | | b) was there independent validation?: NA
| | | S = 4.054 ± 6.025
| | | RRS = 2.646 ± 3.878
| | | RRP = 3.760 ± 2.770
| | | CP = 5.844 ± 3.163
| | | Disease type at entry (N):
| | | S = 80
| | | RRS = 155
| | | RRP = 48
| | | CP = 142
Koziol, Wagner, Sobel, et al., 2001 | Inclusion: MS; relapsing-remitting disease course | Prospective, population-based, RCT | Total no. at start: 50 | 1) Presence of enhancing lesions on MRI | 1) Enhancing lesions in 3 consecutive monthly MRI images immediately preceding exacerbation: | | | | | Prevalence not provided; calculated using equation:
| Exclusion: Not evaluable at 12 mo | Duration of follow up: Examinations performed every month for 12 mo | N = 24 placebo | 2) Occurrence of new enhancing lesions on MRI | PPV = 0.21 (0.121–0.306) | | | | | Prevalence = SN/(SN + PPV (1-SP))
| | | N = 26 Cladribine | 3) Occurrence of new hypointense lesions (“black holes”) on MRI | NPV = 0.89 (0.859–0.923) | | | | | QUALITY ASSESSMENT:
| | | Completed: 50 | | Sensitivity = 0.36 (0.220–0.508) | | | | | Study described as “population-based”?: Yes
| | | Dropouts: 0 | | Specificity = 0.85 (0.778–0.903) | | | | | Sample of patients assembled at a common point in the course of their disease?: Unclear
| | | Age (mean): | | Prevalence = 0.69 | | | | | Sample of patients assembled at an early point in the course of their disease?: Unclear
| | | Placebo: 40.1 yr (range 31–52) | | 2) New enhancing lesions in 3 consecutive monthly MRI images immediately preceding exacerbation: | | | | | Follow up > 80%?: Yes
| | | Cladribine: 44.0 yr (range 31–52) | | PPV = 0.23 (0.124–0.357) | | | | | Outcomes assessed using a widely used scale?: Yes
| | | Baseline measures of physical and mental functioning: | | NPV = 0.89 (0.857–0.920) | | | | | Outcomes assessed in a blind fashion?: Unclear
| | | EDSS: | | Sensitivity = 0.31 (0.180–0.459) | | | | | If subgroups with different prognoses identified:
| | | Placebo: | | Specificity = 0.89 (0.841–0.929) | | | | | a) was there adjustment for important prognostic factors? NA
| | | Mean = 3.8 | | Prevalence = 0.64 | | | | | b) was there independent validation?: NA
| | | Range = 2.5–6.5 | | 3) New black holes in 3 consecutive monthly MRI images immediately preceding exacerbation:
| | | Cladribine: | | PPV = 0.20 (0.041–0.426)
| | | Mean = 3.9 | | NPV = 0.89 (0.855–0.916)
| | | Range = 2–6.5 | | Sensitivity = 0.19 (0.085–0.321)
| | | SNRS: Placebo: | | Specificity = 0.94 (0.911–0.959)
| | | Mean = 75.8 | | Prevalence = 0.42
| | | Range = 54–98 | | 4) Conclusion - presence of possible predictors 1, 2 and/or 3 (MRI imaging-derived markers) are not useful in predicting exacerbations within 6 mo, but absence of predictors is associated with fewer relapses
| | | Cladribine:
| | | Mean = 76.1
| | | Range = 41–93
Nortvedt, Riise, Myhr, et al., 2000 | Inclusion: Clinical or laboratory-supported definite relapsing-remitting MS; EDSS ≤ 5.5; ≥ 2 relapses during 2 yr preceding enrollment; stable disease at inclusion | Prospective, not population-based, based on subjects in a double-blind RCT | Total no. at start: 97 | Quality of life as reported by SF-36 Health Survey | Mean change in EDSS over 12 mo: Increase of 0.19 (range: -1 to 2.5) | | | | | QUALITY ASSESSMENT:
| Exclusion: Age < 18 or > 50; pregnant or lactating women; interferon treatment; immunosuppressive treatment during the previous year; steroid treatment during the month before inclusion; chronic progressive course; liver or renal disease; other serious concomitant disease | Duration of follow up: 12 mo | Completed: 91 | | Baseline EDSS score was not correlated to change in EDSS score (P = 0.65) | | | | | Study described as “population-based”?: No
| | | Dropouts: 6 lost to follow-up before 12 mo | | Increased EDSS | | | | | Sample of patients assembled at a common point in the course of their disease?: Yes
| | | Age: | | Initial QOL | over 12 mo | | | | Sample of patients assembled at an early point in the course of their disease?: No
| | | Mean: 34 | | Poor/Fair | 16/38 (42%) | | | | Follow up > 80%?: Yes
| | | Range: 21–48 | | Good/Very Good/Excellent | 12/53 (23%) | | | | Outcomes assessed using a widely used scale?: Yes
| | | Baseline measures of physical and mental functioning: | | Relative risk = 1.9 (CI, 1.0 to 3.5) | | | | | Outcomes assessed in a blind fashion?: No
| | | Mean EDSS: 2.9 (range 0–5.5) | | The risk of experiencing a worsening EDSS score was 1.9 (95% CI, 1.0 to 3.5) for those who evaluated their health as poor or fair compared to good, very good, or excellent. | | | | | If subgroups with different prognoses identified:
| | | Mean disease duration: 6.9 years | | No other measure in the SF-36 was predictive of EDSS worsening, after adjusting for multiple comparisons. | | | | | a) was there adjustment for important prognostic factors? No
| | | Baseline QOL ratings (n): | | | | | | | b) was there independent validation?: NA
| | | Poor = 5
| | | Fair = 33
| | | Good = 43
| | | Very good = 9
| | | Excellent = 1
Rovaris, Comi, Ladkani, et al., 2003 | Inclusion: Age 18–50; clinically definite MS for at least 1 yr; relapsing-remitting disease course; EDSS 0.0–5.0; ≥ 1 documented relapse in preceding 2 yr; ≥ 1 contrast-enhancing lesion on screening brain MRI images; clinically relapse-free and without steroid treatment in the 30 days before study | Cohort derived from subjects in a RCT | Total no. at start: 239 (119 received 20 mg glatiramer acetate [GA]; 120 received placebo) | Overall burden (volume) of T2-hyperintense at baseline (T2BLV) or T1-hypointense (T1BLV) lesions | Spearman rank correlation coefficients between measure and EDSS Score (p value): | | | | | Details of multivariate modeling, including validation, not provided
| Exclusion: None specified | Duration of follow up: 9 mo | Placebo group: | | All Patients (n = 239) | | | | | QUALITY ASSESSMENT:
| | | Completed: 113 | | Measure | Baseline | Change | | | Study described as “population-based”?: No
| | | Dropouts: 7 | | T2BLV | 0.28 (< 0.001) | 0.16 (0.02) | | | Sample of patients assembled at a common point in the course of their disease?: No
| | | Age: 34.0 ± 7.5 years | | T1BLV | 0.19 (0.003) | 0.18 (0.006) | | | Sample of patients assembled at an early point in the course of their disease?: No
| | | GA group: | | Multivariate regression reported to show that number of relapses during the study period was correlated with the number of relapses in the 2 yr before randomization (p = 0.005); when number of contrast-enhancing lesions at baseline was added, it was significant (p < 0.001). | | | | | Follow up > 80%?: Yes
| | | Completed: 112 | | | | | | | Outcomes assessed using a widely used scale?: Yes
| | | Dropouts: 7 | | | | | | | Outcomes assessed in a blind fashion?: Unclear
| | | Age: 34.1 ± 7.4 years | | | | | | | If subgroups with different prognoses identified:
| | | Baseline measures of physical and mental functioning: | | | | | | | a) was there adjustment for important prognostic factors? Yes
| | | Disease duration (mean ± SD): | | | | | | | b) was there independent validation?: No
| | | Placebo: 7.9 ± 5.5 yr
| | | GA: 8.3 ± 5.5 yr
| | | Prior 2-yr relapse rate (mean ± SD):
| | | Placebo: 2.5 ± 1.4
| | | GA: 2.8 ± 1.8
| | | EDSS score (mean ± SD):
| | | Placebo: 2.4 ± 1.2
| | | GA: 2.3 ± 1.1
| | | No. of enhancing lesions (mean ± SD):
| | | Placebo: 4.4 ± 7.1
| | | GA: 4.2 ± 4.8
Runmarker, Andersson, Odén, et al., 1994 | Inclusion: Definite or probable MS; relapsing-remitting course; acute onset | Prospective, population-based, cohort study | Total no. at start: 308 | 1) Age at onset (Age) | (Probability of event = EXP(Σ coeff × value) | | | | | QUALITY ASSESSMENT:
| Exclusion: Progressive course from onset; lack of sufficient patient data | Duration of follow up: 25 yr | 255 with definite or probable disease | 2) Sex (1 = female) | Model 1 - analysis from onset, start of progressive disease as endpoint (n = 200): | | | | | Study described as “population-based”?: Yes
| | | 200 with sufficient data for analysis and non-progressive disease at onset | 3) Degree of remission after relapse (Remis, 1 = incomplete) | Factor | Coeff | SE | Risk Ratio | | Sample of patients assembled at a common point in the course of their disease?: Yes
| | | Completed: 200 | 4) Mono- or polyregional symptoms (Region, 1 = polyregional) | Constant | -4.550 | 0.5446 | | | Sample of patients assembled at an early point in the course of their disease?: Yes
| | | Dropouts (from original cohort): | 5) Type of affected nerve fibers (1 = afferent with origin inside CNS, 2 = efferent or mixed) (Type 1 or Type 2) | Age | 0.04748 | 0.01611 | 1.049 | | Follow up > 80%?: Yes
| | | 4 lost to follow up | 6) Number of affected neurological systems (# Sys) | Sex | 0.8388 | 0.6150 | 2.314 | | Outcomes assessed using a widely used scale?: Yes
| | | 63 died before end of 25-yr follow up | 7) Time since onset (Time since onset) | Remis | 0.2659 | 0.2028 | 1.305 | | Outcomes assessed in a blind fashion?: Unclear
| | | Age (at onset): | | Type 1 | 0.1639 | 0.3886 | 1.178 | | If subgroups with different prognoses identified:
| | | < 19: 25 | | Type 2 | 0.4954 | 0.2822 | 1.641 | | a) was there adjustment for important prognostic factors? Yes
| | | 20–29: 71 | | Region | 0.07666 | 0.3971 | 1.080 | | b) was there independent validation?: Yes
| | | 30–39: 65 | | (Age) × (Sex) | -0.04222 | 0.01895 | 0.959
| | | 40–49: 32 | | (Remis) × (Region) | 1.046 | 0.5329 | 2.846
| | | ≥ 50: 7 | | Model 2 - analysis from onset, DSS 6 as endpoint:
| | | Baseline measures of physical and mental functioning: NR | | Factor | Coeff | SE | Risk Ratio
| | | | | Constant | -4.917 | 0.4323
| | | | | Age | 0.02498 | 0.009119 | 1.025
| | | | | Type 1 | 0.6290 | 0.4145 | 1.876
| | | | | Type 2 | 0.7872 | 0.3327 | 2.197
| | | | | Region | 0.7978 | 0.2639 | 2.221
| | | | | Model 3 - analysis from end of 5^th^ calendar year, start of progressive disease as endpoint (n = 151):
| | | | | Factor | Coeff | SE | Risk Ratio
| | | | | Constant | -2.921 | 0.4767
| | | | | Sex | -0.07462 | 0.2891 | 0.928
| | | | | # Sys | -0.8975 | 0.4228 | 0.408
| | | | | Remis | 0.6295 | 0.4108 | 1.877
| | | | | Type 1 | 0.3800 | 0.5765 | 1.462
| | | | | Type 2 | -0.08682 | 0.4639 | 0.917
| | | | | (# Sys) × (Remis) | 0.3330 | 0.1284 | 1.395
| | | | | (# Sys) × (Type 1) | 0.8177 | 0.4592 | 2.265
| | | | | (# Sys) × (Type 2) | 0.8991 | 0.4277 | 2.457
| | | | | (Sex) × (Remis) | -0.9739 | 0.4610 | 0.378
| | | | | Model 4 - analysis from end of 5^th^ calendar year after onset, DSS 6 as endpoint:
| | | | | Factor | Coeff | SE | Risk Ratio
| | | | | Constant | -4.258 | 0.4007
| | | | | # Sys | -0.05465 | 0.09212 | 0.947
| | | | | Remis | -0.3798 | 0.3717 | 0.684
| | | | | Type 1 | 1.004 | 0.4760 | 2.729
| | | | | Type 2 | 0.6038 | 0.3927 | 1.829
| | | | | Region | 0.7181 | 0.4292 | 2.051
| | | | | (# Sys) × (Remis) | 0.4114 | 0.1324 | 1.509
| | | | | Model 5 - model for the relationship between age at onset, current age, and the risk of start of progressive course:
| | | | | Factor | Coeff | SE | Risk Ratio
| | | | | Constant | -7.572 | 1.211
| | | | | Time since onset | 0.3569 | 0.08758 | 1.429
| | | | | Age at onset | 0.1631 | 0.05984 | 1.177
| | | | | (Time since onset)^2^ | -0.007357 | 0.002389 | 0.993
| | | | | (Age at onset)^2^ | -0.001447 | 0.0007719 | 0.999
| | | | | Remis | 0.3588 | 0.1774 | 1.432
| | | | | (Time since onset) × (Age at onset) | -0.006126 | 0.001816 | 0.994
Stevenson, Leary, Losseff, et al., 1998 | Inclusion: Patients recruited from previous cohort - patients had clinically definite MS; control subjects - healthy (non-MS) | Prospective, not population-based, case series | Total no. at start: 41 (28 patients, 13 controls) | Baseline cross-sectional area of spinal cord | Change in cord size, patients vs. controls: | | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Duration of follow up: 1 yr | Patient disease types: | | Mean change in cord area, mm^2^(%): | | | | | Study described as “population-based”?: No
| | | 12 primary progressive (PPMS); | | Controls: -0.77 (-0.92) | | | | | Sample of patients assembled at a common point in the course of their disease?: No
| | | 6 secondary progressive (SPMS); | | Patients: -2.26 (-3.71) | | | | | Sample of patients assembled at an early point in the course of their disease?: No
| | | 6 relapsing-remitting (RRMS); | | p = 0.05 (% change, p = 0.03) | | | | | Follow up > 80%?: Yes
| | | 4 benign (BMS) | | Patient subgroups: | | | | | Outcomes assessed using a widely used scale?: Yes
| | | Completed: 41 | | Number of patients with definite change in EDSS: | | | | | Outcomes assessed in a blind fashion?: Unclear
| | | Dropouts: 0 | | PPMS: 2/12 | | | | | If subgroups with different prognoses identified:
| | | Age: | | SPMS: 2/6 | | | | | a) was there adjustment for important prognostic factors? No
| | | Control: 46.3 (range 30–59); | | RRMS: 1/6 | | | | | b) was there independent validation?: No
| | | Patients: 45.1 (range 27–65) | | BMS: 3/4
| | | Baseline measures of physical and mental functioning: | | Mean change in cord area, mm^2^ (%):
| | | Mean disease duration in years (range): | | PPMS: -3.52 (-5.2), p ≤ 0.001
| | | PPMS: 10.9 (4–22) | | SPMS: -0.26 (-0.7), p = NS
| | | SPMS: 19.3 (17–24) | | RRMS: -2.98 (-3.8), p ≤ 0.001
| | | RRMS: 5.6 (2–9) | | BMS: -0.41 (-0.8), p = NS
| | | BMS: 17.3 (13–22) | | Compared with 20 patients without definite increase in EDSS over 12 months, the 8 patients with definite increase in EDSS had similar cord area at baseline (p = 0.69) and similar change in cord area during the year (p = 0.51).
| | | Median EDSS (range):
| | | PPMS: 5.75 (3.0–8.5)
| | | SPMS: 7.25 (6.0–8.0)
| | | RRMS: 3.25 (1.5–6.5)
| | | BMS: 2.25 (2.0–3.0)
| | | Mean cord size (mm^2^):
| | | PPMS: 71.98
| | | SPMS: 57.03
| | | RRMS: 83.97
| | | BMS: 71.35
| | | Control: 80.95
Trotter, Clifford, McInnis, et al., 1989 | Inclusion: Definite MS (chronic progressive or stable); age 20–50 | Prospective, not population-based, case series | Total no. at start: 42 | 1) Concanavalin A suppressor assay | IL-2 baseline vs. Δ EDSS over 18 months | | | | | Multiple comparisons, not addressed. A priori cutpoints for test results not provided. Results not provided for normal controls separate from non-progressing MS patients. Only 12 patients with IL-2 and 18-mo EDSS reported of the original patient series.
| Exclusion: Chronic progressive MS with an increase over the prior year of > 8 points on MRD or > 3 points on EDSS | Duration of follow up: 18 mo | 30 chronic progressive MS (CPMS; 15 untreated [placebo] patients); 10 stable MS patients; 12 normal control subjects | 2) Mitogen stimulation | R = 0.66 | | | | | QUALITY ASSESSMENT:
| | | Completed: 37 | 3) Phenotyping of peripheral blood mononuclear cells | P = 0.01 | | | | | Study described as “population-based”?: No
| | | Dropouts: 5 from CPMS placebo group | 4) Interleukin-2 levels | Illustrative 2 × 2 table (derived from Figure 5; retrospectively selected cutpoint of 40 U/mL) | | | | | Sample of patients assembled at a common point in the course of their disease?: Nor
| | | Age, mean ± SD (range): | | | | Δ EDSS over 18 mo | | | Sample of patients assembled at an early point in the course of their disease?: No
| | | Total CPMS patients: 41.3 ± 8.9 (22–57); | | | | ≥ 1 | < 1 | | Follow up > 80%?: Yes
| | | Untreated CPMS patients (subset): 40.4 ± 10.2 (22–57); | | IL-2 (U/mL) | > 40 | 4 | 0 | | Outcomes assessed using a widely used scale?: Yes
| | | Stable MS patients: 36.2 ± 13.1 (26–60); | | | ≤ 40 | 2 | 6 | | Outcomes assessed in a blind fashion?: Unclear
| | | Normal controls: 36.2 ± 10.4 (26–58) | | Sensitivity = 67% | | | | | If subgroups with different prognoses identified:
| | | Baseline measures of physical and mental functioning: | | Specificity = 100% | | | | | a) was there adjustment for important prognostic factors? NA
| | | EDSS: | | PPV = 100% | | | | | b) was there independent validation?: NA
| | | Untreated CPMS (n = 9): 5.7 ± 1.2 (3.0–7.0); | | NPV = 75%
| | | Stable MS (n = 10): 5.9 ± 0.9 (3.5–6.5) | | Prevalence 50%
| | | | | No other measures correlated with prognosis
Villar, Masjuan, González-Porqué, et al., 2002 | Inclusion: MS diagnosis, | Prospective case series | Total no. at start: 22 | Presence of ITMS | Mean EDSS score at end of follow-up period: | | | | | QUALITY ASSESSMENT:
| Exclusion: | Duration of follow up (months): | 21 relapsing-remitting | | Group 1: 1.70 ± 0.23 | | | | | Study described as “population-based”?: Yes/No
| | Overall: | 1 primary progressive | | Group 2: 0.79 ± 0.22 | | | | | Sample of patients assembled at a common point in the course of their disease?: Yes
| | Mean: 21.6 ± 2.28 | Group 1: 10 | | P = 0.02 | | | | | Sample of patients assembled at an early point in the course of their disease?: No
| | Range: 6–36 | Group 2: 12 | | Probability of progression of at least 1 unit in the EDSS after at least 1 yr of evolution (n = 18; those who made it to at least 1 yr of follow-up): | | | | | Follow up > 80%?: Yes
| | Group 1 (intrathecal IgM synthesis [ITMS]) (mean): 18.00 ± 2.83 | Completed: 22 | | Group 1: 50% | | | | | Outcomes assessed using a widely used scale?: Yes
| | Group 2 (no ITMS) (mean): 24.67 ± 3.29 (between-group difference NS) | Dropouts: 0 | | Group 2: No increase in EDSS shown | | | | | Outcomes assessed in a blind fashion?: Yes
| | Lumbar puncture to determine presence/ absence of ITMS performed within 6 mo of clinical onset (mean 1.14 ± 0.33 mo) | Age: | | P = 0.01 | | | | | If subgroups with different prognoses identified:
| | | Group 1: 27.91 ± 2.86 | | Mean number of relapses during year 1: | | | | | a) was there adjustment for important prognostic factors? NA
| | | Group 2: 29.00 ± 2.91 | | Group 1: 1.86 ± 0.46 | | | | | b) was there independent validation?: NA
| | | EDSS: | | Group 2: 0.2 ± 0.13
| | | Group 1: 1.05 ± 0.27 | | P = 0.0068
| | | Group 2: 1.17 ± 0.24 | | Probability of remaining without interferon-β treatment:
| | | Mo. since onset: | | Group 1: 0% after 20 months
| | | Group 1: 1.53 ± 0.65 | | Group 2: 45.7% at end of study
| | | Group 2: 0.83 ± 0.25 | | P = 0.0001
| | | Albumin index:
| | | Group 1: 5.42 ± 0.81
| | | Group 2: 4.40 ± 0.49
| | | IgG quotient:
| | | Group 1: 4.23 ± 0.63
| | | Group 2: 4.32 ± 0.64
| | | IgM index:
| | | Group 1: 0.248 ± 0.059
| | | Group 2: 0.063 ± 0.016
| | | P = 0.003
| | | Cells:
| | | Group 1: 6.00 ± 3.48
| | | Group 2: 8.75 ± 3.24

Evidence Table 3a. Disease-modifying therapies and long-term improvement

Study | Selected Inclusion/ Exclusion Criteria | Study Design | Patients | | | Interventions | Outcomes/Results | | | | Comments/Quality Scoring
Achiron, Gabbay, Gilad, et al., 1998 | Inclusion: Clinically definite relapsing remitting MS of > 1 yr duration; average yearly exacerbation rate 0.5–3 in 2 yr preceding study; EDSS score 0–6.0; age 18–60 | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 40 | | | 1) IV immunoglobulin (IV IgG); loading dose of 0.4g/kg/body weight per day for 5 consecutive days, followed by booster doses of 0.4 g/kg/body weight once daily every 2 mo for 2 yr (n = 20) | 1) Physical functioning: | | | | This article demonstrates that a larger proportion of patients demonstrated improvement in EDSS when treated with IV IgG compared with placebo. The definition of improvement was a 1.0-point improvement on EDSS. There are no data delineating how many patients may have improved greater than 1.0 point.
| Exclusion: Secondary progression disease course; serum immunoglobulin deficiency; long-term steroid or cytotoxic treatment 12 mo prior to study; major psychiatric disorder; major cognitive impairment | Duration of study treatment/follow up: 2 yr | Dropouts: 2 | | | 2) Placebo (n = 20) | Definition of “improvement”: 1.0-point change in EDSS compared with baseline | | | | QUALITY ASSESSMENT: Described as “randomized”? Yes
| | Provider specialty: Neurologists | Completed: 38 | | | | Proportion of patients with “improvement”: In the IV IgG group 23.5% of patients improved vs. 10.8% in the placebo group | | | | Method of randomization clearly described? Yes
| | Location: Tel Hashomer, Israel | Age (mean ± SE): | | | | Other (non-improvement) outcomes: No significant change in mean EDSS in treatment arm | | | | Concealment of allocation? Yes
| | | IV IgG: 35.4 ± 2.1 | | | | 2) Relapse frequency: | | | | Described as “double-blind”? Yes
| | | Placebo: 33.8 ± 2.4 | | | | Definition of “relapse”: The rapid appearance, reappearance, or worsening of one or more neurological abnormalities, persisting at least 48 hr, after a relatively stable or improving neurological state of at least 30 days. A relapse was confirmed only when the patient's symptoms were accompanied by objective changes on neurological examination by a blinded neurologist. | | | | Patients blinded? Yes
| | | Baseline EDSS (mean ± SE): | | | | Definition of “improvement”: Not specified on a per patient basis | | | | Investigators blinded? Yes
| | | IV IgG: 2.90 ± 0.43 | | | | Proportion of patients with “improvement”: Not specified | | | | Outcome assessors blinded? Yes
| | | Placebo: 2.82 ± 0.37 | | | | Other (non-improvement) outcomes: | | | | No. of withdrawals in each group stated? No
| | | Baseline relapse rate (mean ± SE per yr in 2 yr preceding study): | | | | a) Yearly exacerbation rates
| | | IV IgG: 1.85 ± 0.26 | | | | | IV IgG | Placebo | P-value
| | | Placebo: 1.55 ± 0.17 | | | | Baseline | 1.85 | 1.55 | 0.34
| | | | | | | Year 1 | 0.75 | 1.8 | 0.0002
| | | | | | | Year 2 | 0.42 | 1.42 | 0.0009
| | | | | | | 2-yr total | 0.59 | 1.61 | 0.0006
| | | | | | | b) Exacerbation-free patients:
| | | | | | | | IV IgG | Placebo | P-value
| | | | | | | Year 1 | 8 | 1 | 0.001
| | | | | | | Year 2 | 12 | 3 | 0.001
| | | | | | | Total study | 6 | 0 | 0.001
| | | | | | | c) Median time to first exacerbation (days):
| | | | | | | | IV IgG | Placebo | P-value
| | | | | | | | 233 | 82 | 0.003
Bastianello, Pozzilli, D'Andrea, et al., 1994 | Inclusion: Definite diagnosis of MS; relapsing-remitting disease course (≥ 2 relapses in 24 mo prior to study entry); disease duration 1–10 yr; EDSS 2.0–5.0; age 18–45; selected to undergo serial MRI scans (subgroup of total study population) | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 25 (subgroup of total study population selected to undergo serial MRI scans) | | | 1) Mitoxantrone (MTX) 8 mg/m^2^ by 30-min IV infusion every month for 1 yr (n = 13) | 1) Physical functioning: | | | | This trial reports initial findings demonstrating a benefit of mitoxantrone in reducing mean exacerbation rates, but does not provide quantitative information regarding absolute improvement of specific patients over baseline status.
| Exclusion: HIV-positive; previous cardiovascular disease; left ventricular ejection fraction < 50% by echocardiography; renal, liver, and/or respiratory dysfunction; diabetes; malignancy; psychiatric illness; pregnancy or no contraception; use of immunosuppressant drugs or steroids in previous 3 mo | Duration of study treatment/follow up: 1 yr (preliminary results from planned 2-yr trial) | Dropouts: 0 | | | 2) Placebo (n = 12) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 25 | | | | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 7 sites in Italy | Age (mean ± SD): | | | | Other (non-improvement) outcomes: | | | | Method of randomization clearly described? Yes
| | | MTX: 29.9 ± 5.2 | | | | No statistical difference was observed in mean EDSS change at 1 yr (p = 0.18) | | | | Concealment of allocation? Yes
| | | Placebo: 28.5 ± 6.5 | | | | 2) Relapse frequency: | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean ± SD): | | | | Definition of “relapse”: The appearance of new symptom or worsening of an old one, attributable to MS and lasting at least 24 hours in the absence of fever | | | | Patients blinded? Yes
| | | MTX: 3.7 ± 0.7 | | | | Definition of “improvement”: Not defined | | | | Investigators blinded? Yes
| | | Placebo: 3.5 ± 1.0 | | | | Proportion of patients with “improvement”: Not delineated | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (mean in previous 2 yr ± SD): | | | | Other (non-improvement) outcomes: | | | | No. of withdrawals in each group stated? Yes
| | | MTX: 2.8 ± 1.2 | | | | | MTX | Placebo | P value
| | | Placebo: 3.3 ± 1.2 | | | | MER | 0.54 | 1.67 | 0.014
| | | | | | | PWE | 5(38%) | 10(83%) | 0.02
| | | | | | | MER = Mean exacerbation rate
| | | | | | | PWE = Number (%) of patients with exacerbations
Bornstein, Miller, Slagle, et al., 1987 | Inclusion: Definite MS; relapsing-remitting form of MS; ≥ 2 well-demarcated and well-documented relapses in previous 2 yr; EDSS ≤ 6; emotionally stable; age 20–35 | RCT (parallel-group, double-blind, single-center, matched-pairs design) | No. of patients randomized: 50 | | | 1) Glatiramer acetate = Copolymer 1 (Cop 1) by SC injection, 20 mg self-injected daily for 2 yr (n = 25) | 1) Physical functioning: | | | | This early study of the efficacy of Copolymer 1 in the treatment of relapsing-remitting MS demonstrated benefits of treatment in the reduction of relapse rates and improved disability status. Data are presented regarding the number of patients demonstrating improvement on EDSS. Although significant efforts were made to maintain blinding, the physician evaluator correctly identified 70% of those taking placebo and 78% of those taking Cop 1.
| Exclusion: None specified | Duration of study treatment/follow up: 2 yr | Dropouts: 7 dropped out before 2 yr, but 5 of these were included in analysis | | | 2) Placebo (n = 25) | Definition of “improvement”: Reduction in EDSS by 1, 2, or 3 points over 2 yr | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 43 completed trial; 48 included in analysis | | | | Proportion of patients with “improvement”: | | | | Described as “randomized”? Yes
| | Location: 1 site in Bronx, NY | Age (mean): | | | | Placebo | Cop 1 | | | Method of randomization clearly described? Yes
| | | Cop 1: 30.0 | | | | 1.0 point | 8.7% | 20.0% | | Concealment of allocation? Yes
| | | Placebo: 31.0 | | | | 2.0 points | 0 | 12.0% | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean): | | | | 3.0 points | 4.4% | 0 | | Patients blinded? Yes
| | | Cop 1: 2.9 | | | | 2) Relapse frequency: | | | | Investigators blinded? Yes
| | | Placebo: 3.2 | | | | Definition of “relapse”: The rapid onset of new symptoms or a worsening of preexisting symptoms that persisted for 48 hours or more, when accompanied by observed objective changes on the neurological examination involving an increase of a atl east one grade in the score for one of the eight functional groups or the Kurtzke Scale | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (mean over 2 yr): | | | | Definition of “improvement”: Decrease in 2-yr relapse rate in comparison with individual baseline relapse rate | | | | No. of withdrawals in each group stated? Yes
| | | Cop 1: 3.8 | | | | Proportion of patients with “improvement”:
| | | Placebo: 3.9 | | | | Placebo - 12 of 23 patients experienced a decrease in relapse rate over the 2yr period
| | | | | | | Cop 1 - 24 of 25 patients experienced a decrease in relapse rate over the 2-yr treatment period
| | | | | | | Other (non-improvement) outcomes:
| | | | | | | Exacerbation-free patients:
| | | | | | | Placebo - 26%
| | | | | | | Cop 1 - 56%
| | | | | | | P = 0.036
Bornstein, Miller, Slagle, et al., 1991 | Inclusion: Definite diagnosis of MS by Poser criteria; evidence of a chronic-progressive course for ≥ 18 mo; ≤ 2 exacerbations in previous 24 mo; EDSS score 2.0–6.5; emotionally stable and able to participate in clinical trial; age 20–60 | RCT (parallel-group, double-blind, two-center) | No. of patients randomized: 106 | | | 1) Copolymer 1 (Cop 1) by SC injection; 15 mg self-injected twice per day for 2 yr (n = 51) | 1) Physical functioning: | | | | This study provides no significant information regarding improvement of patients on this therapy.
| During a 6- to 15-mo pre-trial observation period, patients required to demonstrate progression in one of following ways: worsening of 2 grades in a functional system; worsening of 1 grade in 2 unrelated functional systems; worsening of 2 units on the Ambulation Index; or worsening of 1 grade on the EDSS. Must not have progressed beyond 6.5 on EDSS or have had > 1 exacerbation during pre-trial observation period. | Duration of study treatment/follow up: 2 yr or until confirmed progression (whichever first) | Dropouts: 20 | | | 2) Placebo (n = 55) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Provider specialty: Neurologists | Completed: 86 | | | | Proportion of patients with “improvement”: | | | | Described as “randomized”? Yes
| | Location: Bronx, NY; and Houston, TX | Age (mean): | | | | Cop 1: 19.6% improved | | | | Method of randomization clearly described? Yes
| | | Cop 1: 41.6 | | | | 37.3% remained stable | | | | Concealment of allocation? Yes
| | | Placebo: 42.3 | | | | 41.1% worsened | | | | Described as “double-blind”? Yes
| | | Baseline EDSS: | | | | Placebo: 14.5% improved | | | | Patients blinded? Yes
| | | Mean: | | | | 34.6% remained stable | | | | Investigators blinded? Yes
| | | Cop 1: 5.7 | | | | 50.9% worsened | | | | Outcome assessors blinded? Yes
| | | Placebo: 5.5 | | | | Other (non-improvement) outcomes: The primary endpoint, confirmed progression of 1.0 or 1.5 units (depending on baseline disability) on the Kurtzke Disability Status Scale, was not statistically different in the two groups | | | | No. of withdrawals in each group stated? Yes
| | | | Cop 1 | Plac | | 2) Relapse frequency:
| | | < 5: | 22% | 27% | | Definition of “relapse”: Not defined
| | | 5–5.5: | 8% | 15% | | Definition of “improvement”: Not assessed
| | | 6–6.5: | 71% | 58% | | Proportion of patients with “improvement”: Not delineated
| | | Baseline relapse rate: NR
British and Dutch Multiple Sclerosis Azathioprine Trial Group, 1988 | Inclusion: Clinically definite MS (≥ 2 episodes and 2 clinical lesions or 2 episodes and 1 subclinical lesion [revealed by VEP or CT]); or laboratory confirmed MS (≥ 2 anatomically separate episodes, 1 clinical lesion, and oligoclonal bands or increased IgG in the CSF); or currently progressive MS (2 separate lesions [of which 1 might be subclinical], oligoclonal bands, or increased IgG in the CSF, and progression for at least 6 mo); patients with relapsing-remitting disease had to have been in a remittent phase for ≥ 1 mo and have had ≥ 1 relapses in the previous year; EDSS ≤ 6 (ambulant); age 15–50; not on other immunomodulatory drugs or hyperbaric oxygen treatment | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 354 (199 [56%] clinically definite, 37 [10%] laboratory confirmed; 51 [14%] progressive from onset; 67 [19%] progressive after remission) | | | 1) Azathioprine PO 2.5 mg/kg (to the nearest 25 mg) daily (n = 174) | 1) Physical functioning: | | | | The treatment effect in this study was marginal, and no data are reported that delineate improvement of any patient with respect to baseline status.
| Exclusion: Concomitant systemic disease; mental deficit that precluded understanding and cooperation | Duration of study treatment/follow up: 3 yr | Lost to follow up (cumulative totals): 20 at 1 yr, 24 at 2 yr, 22 at 3 yr, 153 at 4 yr | | | 2) Placebo (n = 180) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Discontinued treatment (cumulative totals): 48 at 1 yr, 64 at 2 yr, 75 at 3 yr | | | | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 20 sites in the UK and The Netherlands | Completed: 279 completed treatment, 332 followed up through 3 yr | | | | Other (non-improvement) outcomes: The only statistically significant result was a reduction in the deterioration of the Ambulation Index in the azathioprine group compared with the placebo group after 3 yr | | | | Method of randomization clearly described? No
| | | Age (mean ± SD): | | | | | | | | Concealment of allocation? Yes
| | | Azathioprine: 39 ± 8.6 | | | | | | | | Described as “double-blind”? Yes
| | | Placebo: 38 ± 8.3 | | | | | | | | Patients blinded? Yes/No/Unclear
| | | Baseline EDSS (mean ± SD): | | | | | | | | Investigators blinded? Yes
| | | Azathioprine: 3.69 ± 1.50 | | | | | | | | Outcome assessors blinded? Yes
| | | Placebo: 3.66 ± 1.62 | | | | | | | | No. of withdrawals in each group stated? Yes
| | | Baseline relapse rate (months since last relapse):
| | | | Az | Plac
| | | 1–6: | 43% | 45%
| | | 7–12: | 20% | 18%
| | | > 12: | 37% | 37%
Canadian Cooperative Multiple Sclerosis Study Group, 1991 | Inclusion: Clinically definite or laboratory-supported definite MS in a progressive phase (deterioration of at least 1 point on EDSS over preceding 12 mo); EDSS 4.0–6.5; age ≥ 15 | RCT (parallel-group, not double-blinded, multicenter) | No. of patients randomized: 168 (81 relapsing-progressive, 86 chronic-progressive, 1 unkown) | | | 1) Cyclophosphamide IV + prednisone PO (n = 55). Cyclophosphamide 1g given intravenously on alternate days until WBC count fell below 4.5 × 10^9^/L or until total dose of 9 g reached. Prednisone 40 mg given orally for 10 days, then reduced by 10 mg on alternate days and discontinued on day 16. | 1) Physical functioning: | | | | This study provides data specifically addressing the number of patients who improved with regard to EDSS, but the results show no statistically significant benefit of the treatments studied.
| Exclusion: Previous treatment with cyclophosphamide, cyclosporin, antilymphocyte globulin, or interferon; treatment with azathioprine or plasma exchange in preceding yr or corticosteroids in preceding mo; illnesses that might be adversely affected by study treatments; substantial cognitive impairment; unwillingness to use contraception during trial and for 2 yr after; weekly venous access difficult | Duration of study treatment/follow up: Duration of treatment variable (see at right, under “Interventions”); patients followed up for at least 12 mo; mean follow up, 30.4 mo | Dropouts: 2 (died) | | | 2) Plasma exchange + cyclophosphamide PO + prednisone PO (n = 57). Plasma exchange of one plasma volume (40 mL/kg) done weekly for 20 wk with either intermittent (5 sites) or continuous (4 sites) flow-type centrifuges. Replacement = 5% serum albumin. Oral cyclophosphamide 1.5–2.0 mg/kg given daily for 22 wk; dose adjusted to achieve target WBC of 4.0–5.0 × 10^9^/L. Oral prednisone 20 mg given every other day and tapered over 22 wk. | Definition of “improvement”: 1.0-point improvement on EDSS sustained for 6 mo | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 166 | | | 3) Placebo (placebo oral cyclophosphamide and prednisone for 22 wk + sham plasma exchange for 20 wk) (n = 56) | Proportion of patients with “improvement”: | | | | Described as “randomized”? Yes
| | Location: 9 sites in Canada | Age (mean at disease onset ± SD): | | | | No statistically significant difference among the treatment arms | | | | Method of randomization clearly described? Yes
| | | Cyclophosphamide IV: 31.9 ± 10.3 | | | | Number of patients improved: | | | | Concealment of allocation? Yes
| | | Plasma exchange: 29.9 ± 7.9 | | | | Cycl | PEX | Placebo | | Described as “double-blind”? Yes
| | | Placebo: 32.1 ± 9.7 | | | | 1 yr | 3 (6%) | 4 (8%) | 1 (2%) | Patients blinded? Yes
| | | Baseline EDSS (mean ± SD): | | | | 2 yr | 2 (6%) | 1 (3%) | 0 | Investigators blinded? No (treating providers)
| | | Cyclophosphamide IV: 5.79 ± 0.61 | | | | 3 yr | 2 (4%) | 1 (2%) | 1 (2%) | Outcome assessors blinded? Yes
| | | Plasma exchange: 5.66 ± 0.72 | | | | Other (non-improvement) outcomes: No statistically significant difference between treatment arms in any outcome measure | | | | No. of withdrawals in each group stated? Yes
| | | Placebo: 5.79 ± 0.64
| | | Baseline relapse rate: NR
Cohen, Cutter, Fischer, et al., 2002 | Inclusion: Clinically definite secondary progressive MS, with or without recent relapses; disease progression over previous 1 yr; cranial MRI demonstrating lesions consistent with MS; EDSS 3.5–6.5; age 18–60 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 436 | | | 1) Interferon β-1a (IFNβ-1a) 60 μg weekly by IM injection for 2 yr (n = 217); half dose (30 μg) given for first four doses to minimize adverse events | 1) Physical functioning: | | | | This study examined the benefit of IFNβ-1a in secondary progressive MS utilizing assessments of EDSS, MSFC, and MSQLI and demonstrated beneficial effects on MSFC and MSQLI. This was the first use of the MSFC in a large-scale MS trial. The beneficial effects of treatment observed on MSFC were primarily driven by improvements in upper extremity function. The report focuses on between-group differences and provides few data on individual patient improvement.
| Exclusion: Primary progressive disease course; inability to complete MS Functional Composite at baseline; prior treatment with interferon-β | Duration of study treatment/follow up: 2 yr | Dropouts: 115; of these, 63 had complete 2-yr follow up | | | 2) Placebo for 2 yr (n = 219) | Definition of “improvement”: Not defined for individual patients | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 321 completed treatment; 384 followed up for 2 yr | | | | Proportion of patients with “improvement”: | | | | Described as “randomized”? Yes
| | Location: 42 sites in US, Europe, and Canada | Age (mean ± SD): | | | | Improvement based on EDSS - baseline to 24 months | | | | Method of randomization clearly described? Yes
| | | IFNβ-1a: 47.2 ± 8.2 | | | | Placebo - 7.3% | | | | Concealment of allocation? Yes
| | | Placebo: 47.9 ± 7.7 | | | | IFNβ-1a - 7.5% | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean ± SD): | | | | No statistically significant difference | | | | Patients blinded? Yes
| | | IFNβ-1a: 5.2 ± 1.1 | | | | Other (non-improvement) outcomes: | | | | Investigators blinded? Yes
| | | Placebo: 5.2 ± 1.1 | | | | 24-month MSFC data-median: | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (mean ± SD, prior 3 yr): | | | | | Placebo | IFNβ-1a | P value | No. of withdrawals in each group stated? Yes
| | | IFNβ-1a: 1.5 ± 2.1 | | | | MSFC | -0.161 | -0.362 | 0.033
| | | Placebo: 1.3 ± 2.1 | | | | 9HPT | -0.290 | -0.202 | 0.024
| | | | | | | Timed 25-ft walk - no statistical difference
| | | | | | | PASAT - no statistical difference
| | | | | | | 2) Relapse frequency:
| | | | | | | Definition of “relapse”: New or recurrent neurological symptoms, not associated with fever or infection, lasting at least 48 hours and accompanied by objective change on the examining neurologist's examination at an unscheduled visit corresponding to the reported symptoms
| | | | | | | Definition of “improvement”: Not delineated on individual patients
| | | | | | | Proportion of patients with “improvement”: Not delineated
| | | | | | | Other (non-improvement) outcomes:
| | | | | | | Annual relapse rate:
| | | | | | | Placebo - 0.30
| | | | | | | IFNβ-1a - 0.20
| | | | | | | P = 0.008
| | | | | | | Relapse-free patients - intention to treat:
| | | | | | | Placebo - 63%
| | | | | | | IFNβ-1a - 74%
| | | | | | | P=0.023
| | | | | | | 3) Quality of life: The MS Quality of Life Inventory (MSQLI) was administered to English-speaking subjects at baseline, 12 months, and 24 months
| | | | | | | Definition of “improvement”: Not defined
| | | | | | | Proportion of patients with “improvement”: NR
| | | | | | | Other (non-improvement) outcomes: Significant benefit favoring IFNβ-1a treatment was observed on 8 of 11 subscales of the MSQLI, with a favorable trend on the remaining three scales. The IFNβ-1a group improved from baseline to month 24 on 10 of 11 subscales (all except Bladder Control Scale). In contrast, the placebo group worsened from baseline to month 24 on 10 of 11 subscales, the Modified Fatigue Impact Scale being the only subscale showing improvement. Data not shown (reference made towww.neurology.org web site).
Currier, Haerer, and Meydrech, 1993 | Inclusion: Definite MS; a worsening in function or an exacerbation in the previous yr; understanding and willingness to cooperate | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 45 (20 “exacerbating remitting” and 24 “chronic” MS [latter includes 18 “exacerbating progressive,” 3 “chronic progressive,” and 3 “spinal patients”]) | | | 1) Methotrexate PO; 2.5 mg every 12 hr for 3 consecutive doses once per wk (7.5 mg/ wk) for 18 mo (n = 22) | 1) Physical functioning: | | | | This study provides no data regarding individual patient improvement on therapy.
| Exclusion: History or evidence of renal or hepatic disease; gross obesity; diabetes | Duration of study treatment/follow up: Initially 1 yr; changed during trial to 18 mo | Dropouts: 9 | | | 2) Placebo (n = 22) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologist | Completed: 36 | | | | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: Jackson, MS | Age (median, reported only by MS type): | | | | Other (non-improvement) outcomes: | | | | Method of randomization clearly described? No
| | | Exacerbating remitting: 39.5 | | | | 2) Relapse frequency: | | | | Concealment of allocation? Yes
| | | Chronic: 46.8 | | | | Definition of “relapse”: 1.0-point EDSS worsening (unsustained) | | | | Described as “double-blind”? Yes
| | | Baseline EDSS: NR | | | | Definition of “improvement”: Not defined | | | | Patients blinded? Yes
| | | Baseline relapse rate (total number of exacerbations in 12 mo preceding trial; reported only for patients with “exacerbating remitting” MS): | | | | Proportion of patients with “improvement”: Not delineated | | | | Investigators blinded? Yes
| | | Methotrexate: 9 in 9 patients | | | | Other (non-improvement) outcomes: No statistically significant difference in treatment groups except for a difference in the mean number of exacerbations p = 0.05 - data presented in graphical form only | | | | Outcome assessors blinded? Yes
| | | Placebo: 12 in 11 patients | | | | | | | | No. of withdrawals in each group stated? Yes
De Castro, Cartoni, Millefiorini, et al., 1995 | Inclusion: Definite diagnosis of MS according to Poser criteria; relapsing-remitting disease course; ≥ 2 relapses in 24 mo prior to study entry; disease duration 1–10 yr; EDSS 2.0–5.0; age 18–45 | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 20 | | | 1) Mitoxantrone (MTX) 8 mg/m^2^ by 30-min IV infusion every month for 1 yr (n = 13) | 1) Physical functioning: | | | | This study demonstrated a statistically significant reduction in mean relapse rate in the treatment arm but did not include data regarding the clinical improvement of individual patients.
| Exclusion: HIV-positive; heart, renal, lung, or liver disease; psychiatric disease; pregnancy or lactation; known allergy to cortico-steroids; other neurological disease; use of corticosteroids during previous 3 mo; use of levamisol, isoprinosin, or plasmapheresis during previous 3 mo; treatment with interferon; immunosuppressive therapy during previous 12 mo | Duration of study treatment/follow up: 1 yr | Dropouts: NR (implied 0) | | | 2) Placebo (n = 12) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (presumably neurologists and cardiologists) | Completed: NR (implied 20) | | | | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 1 site in Italy | Age (mean ± SD): | | | | Other (non-improvement) outcomes: No statistically significant difference between treatment arms with respect to changes in EDSS | | | | Method of randomization clearly described? No
| | | MTX: 31 ± 5 | | | | 2) Relapse frequency: | | | | Concealment of allocation? Yes
| | | Placebo: 30 ± 4 | | | | Definition of “relapse”: Not defined | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean ± SD): | | | | Definition of “improvement”: Not defined | | | | Patients blinded? Yes
| | | MTX: 3.77 ± 0.72 | | | | Proportion of patients with “improvement”: Not delineated | | | | Investigators blinded? Yes
| | | Placebo: 3.33 ± 0.75 | | | | Other (non-improvement) outcomes: | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (mean in previous 2 yr ± SD): | | | | Difference in relapse rate favored treatment with mitoxantrone p = 0.005 | | | | No. of withdrawals in each group stated? No
| | | MTX: 2.82 ± 0.98
| | | Placebo: 3.00 ± 1.94
European Study Group on Interferon beta-1b in Secondary Progressive MS, 1998 | Inclusion: Clinically or laboratory supported definite diagnosis of secondary progressive MS; EDSS 3.0–6.5; ≥ 2 relapses or ≥ 1.0-point increase in EDSS in previous 2 yr; age 18–55 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 718 | | | 1) Interferon β-1b (IFNβ-1b) by SC injection; initial dose 0.5 mL (4 MIU) every other day, increased after 2 wk to 1.0 mL (8 MIU) every other day for up to 3 yr (n = 360) | 1) Physical functioning: Primary endpoint was time to confirmed progression in disability defined as a 1.0-point increase on EDSS sustained for at least 3 months, or a 0.5-point increase if the baseline EDSS was 6.0 or 6.5 | | | | This article demonstrates the efficacy of IFNβ-1b over placebo in reducing the rate of progression and in reducing the relapse rate. It does not provide data regarding improvement of individual patients over their baseline functional status.
| Exclusion: None specified | Mean duration of treatment/follow up: Treatment scheduled to last 36 mo, with 3-mo follow up; article reports results of prospectively planned interim analysis of all patients in study for ≥ 2 yr; mean follow up time 901 days for IFNβ-1b and 892 days for placebo | Lost to follow up: 57 | | | 2) Placebo (n = 358) | Results: Significant difference in time to confirmed progression of disability in favor of IFNβ1-b (p = 0.0008) | | | | See also the entry for Kappos, Polman, Pozzilli, et al., 2001, below.
| | Provider specialty: NR (presumably neurologists) | Withdrew from treatment, but had complete follow up: 130 | | | | On average IFNβ1-b delayed confirmed progression by 9–12 months in this patient population | | | | QUALITY ASSESSMENT:
| | Location: 32 sites in Europe | Completed treatment and follow up: 531 | | | | Confirmed EDSS progression: | | | | Described as “randomized”? Yes
| | | Age (mean ± SD): | | | | Placebo: 46.7% | | | | Method of randomization clearly described? Yes
| | | IFNβ-1b: 41.1 ± 7.2 | | | | IFNβ1-b: 38.9% | | | | Concealment of allocation? Yes
| | | Placebo: 40.9 ± 7.2 | | | | p = 0.0048 | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean ± SD): | | | | 2) Relapse frequency: | | | | Patients blinded? Yes
| | | IFNβ-1b: 5.1 ± 1.1 | | | | Definition of “relapse”: Not defined | | | | Investigators blinded? Yes
| | | Placebo: 5.2 ± 1.1 | | | | Definition of “improvement”: Not defined | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (% of patients without relapse in 2 yr preceding study): | | | | Proportion of patients with “improvement”: Not delineated
| | | IFNβ-1b: 31.9% | | | | Other (non-improvement) outcomes:
| | | Placebo: 28.2% | | | | a) Mean annual relapse rate:
| | | | | | | | Placebo | IFN β-1b | p
| | | | | | | Overall | 0.64 | 0.44 | 0.0002
| | | | | | | Year 1 | 0.82 | 0.57 | 0.0095
| | | | | | | Year 2 | 0.47 | 0.35 | 0.0201
| | | | | | | Year 3 | 0.35 | 0.24 | 0.1624
| | | | | | | b) Proportion of patients with moderate to severe relapse:
| | | | | | | Placebo: n = 190 (53.1%)
| | | | | | | IFNβ1-b: n = 157 (43.6%)
| | | | | | | p = 0.008
Fazekas, Deisenhammer, Strasser-Fuchs, et al., 1997a and Fazekas, Deisenhammer, Strasser-Fuchs, et al., 1997b and Strasser-Fuchs, Fazekas, Deisenhammer, et al., 2000 | Inclusion: Clinically definite diagnosis of relapsing-remitting MS; EDSS score 1.0–6.0; ≥ 2 clearly identified and documented relapses during previous 2 yr; age 15–64; first manifestation of MS at age 10–59 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 150 | | | 1) IV immunoglobulin (IV IgG); 0.15–0.20 g/kg body weight once per month for 2 yr (n = 75) | 1) Physical functioning: | | | | These studies demonstrate benefit from treatment with IV IgG over placebo with regards to progression of EDSS. Moreover, the study documents an increased proportion of patients who demonstrated improvement on EDSS over the 2-yr trial.
| Exclusion: Immuno-suppressive or immunomodulatory therapy in previous 3 mo; corticosteroids in previous 2 wk; primary or secondary progressive MS; benign course of disease as indicated by a deterioration rate (EDSS score divided by duration of disease in years) < 0.25 | Duration of study treatment/follow up: 2 yr | Lost to follow up: 2 (before start of treatment) | | | 2) Placebo (n = 73) | Definition of “improvement”: 1.0-point decrease in EDSS by the end of the study | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Stopped treatment: 28 | | | | Proportion of patients with “improvement”: | | | | Described as “randomized”? Yes
| | Location: 13 sites in Austria | Completed treatment: 120 | | | | IV IgG - 31% of patients improved | | | | Method of randomization clearly described? Yes
| | | Age (mean [95% CI]): | | | | Placebo - 14% of patients improved | | | | Concealment of allocation? Yes
| | | IV IgG: 36.7 (34.3–39.1) | | | | Other (non-improvement) outcomes: Between-group differences in the absolute change on the EDSS score and in the proportion of patients stable or worsened | | | | Described as “double-blind”? Yes
| | | Placebo: 37.3 (35.0–39.6) | | | | 2) Relapse frequency: | | | | Patients blinded? Yes
| | | Baseline EDSS (mean [95% CI]): | | | | Definition of “relapse”: The appearance or reappearance of one or more neurological abnormalities that persisted for at least 24 hours and had been preceded by a stable or improving neurological state of at least 30 days. A relapse was confirmed only if the patient's symptoms were accompanied by objective changes of at least one grade in the scored for one of the eight functional groups on the EDSS. | | | | Investigators blinded? Yes
| | | IV IgG: 3.3 (3.0–3.6) | | | | Definition of “improvement”: Not delineated | | | | Outcome assessors blinded? Yes
| | | Placebo: 3.3 (2.9–3.7) | | | | Proportion of patients with “improvement”: Not delineated | | | | No. of withdrawals in each group stated? Yes
| | | Baseline relapse rate (mean per yr [95% CI]): | | | | Other (non-improvement) outcomes:
| | | IV IgG: 1.3 (1.1–1.5) | | | | | IV IgG | Placebo | P
| | | Placebo: 1.4 (1.2–1.6) | | | | Relapse-free | 53% | 36% | 0.03
| | | | | | | Patients
| | | | | | | Mean Annual
| | | | | | | Relapse Rate
| | | | | | | Year 1 | 0.49 | 1.30 | 0.011
| | | | | | | Year 2 | 0.42 | 0.83 | 0.006
| | | | | | | 3) Quality of life: Incapacity Status Scale and the Environmental Status Scale
| | | | | | | Definition of “improvement”: Not defined prospectively
| | | | | | | Proportion of patients with “improvement”: Not delineated
| | | | | | | Other (non-improvement) outcomes: The mean change of rating scores of 15 of 16 items was more favorable following IV IgG treatment. The total mean change of ratings over all ISS items was significantly in favor of IV IgG-treated patients (P = 0.01) Similarly, IV IgG-treated patients noted improvement in 4 of 7items of the ESS compared to no item rated as improved by placebo patients.
Ghezzi, Di Falco, Locatelli, et al., 1989 | Inclusion: Definite MS | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 185 (74 relapsing, 111 relapsing-progressive) | | | 1) Azathioprine PO 2.5 mg/kg per day for 18 mo (n = 69) | 1) Physical functioning: | | | | This unblended trial of azathioprine in MS did not find statistically significant differences in any outcome measures.
| Exclusion: Disease duration < 1 yr; EDSS > 7; concomitant diseases contraindicating immunosuppression | Duration of study treatment/follow up: 18 mo | Dropouts: 50 | | | 2) No azathioprine (n = 66) | Definition of “improvement”: Not defined | | | | Data are presented that delineate individual patient improvement.
| | Provider specialty: NR (presumably neurologists) | Completed: 135 | | | | Proportion of patients with “improvement”: | | | | QUALITY ASSESSMENT:
| | Location: 1 site in Gallarate, Italy | Age (mean at onset [with range], completers only): | | | | Relapsing patients who improved: | | | | Described as “randomized”? Yes
| | | Relapsing (R)-azathioprine: 26 (15–42) | | | | Azathioprine - 5 of 32 | | | | Method of randomization clearly described? No
| | | R-control: 26 (18–42) | | | | Controls - 0 of 22 | | | | Concealment of allocation? Unclear
| | | Relapsing-progressive (RP)-azathioprine: 29 (12–44) | | | | P > 0.10 | | | | Described as “double-blind”? No
| | | RP-placebo: 31 (16–47) | | | | Relapsing-progressive patients: | | | | Patients blinded? No
| | | Baseline EDSS (mean [with range], completers only): | | | | Azathioprine - 2 of 37 | | | | Investigators blinded? Unclear
| | | R-azathioprine: 2.1 (1–5) | | | | Controls - 3 of 44 | | | | Outcome assessors blinded? Unclear
| | | R-control: 2.2 (1–5) | | | | p > 0.10 | | | | No. of withdrawals in each group stated? Yes
| | | RP-azathioprine: 3.8 1–6.5) | | | | Other (non-improvement) outcomes: No statistical difference between the treatment arms with respect to EDSS
| | | RP-placebo: 3.7 (1–7) | | | | 2) Relapse frequency:
| | | Baseline relapse rate (mean [with range], completers only, time frame not specified): | | | | Definition of “relapse”: Not defined
| | | mean at onset [with range], completers only): | | | | Definition of “improvement”: Not defined
| | | R-azathioprine: 1.2 (0.2–4) | | | | Proportion of patients with “improvement”: Not delineated
| | | R-control: 1.1 (0.2–3) | | | | Other (non-improvement) outcomes: No statistically significant difference in treatment arms
| | | RP-azathioprine: 0.6 (0.1–3.3)
| | | RP-placebo: 0.4 (0.1–2.5)
Goodkin, Bailly, Teetzen, et al., 1991 | Inclusion: Clinically definite or laboratory-supported definite MS; seen at study clinic from 1983 to 1989; relapsing-remitting disease course (≥ 2 exacerbations in previous 18 mo); no exacerbation in previous 1 mo; EDSS 2.0–6.5; AI 1.0–6.0; age 18–65 | RCT (parallel-group, double-blind [patients and examining physician, not treating physician], single-center) | No. of patients randomized: 59 randomized, 54 began treatment | | | 1) Azathioprine PO; initial dose 50 mg 3 times per day, adjusted to target dose of 3 mg/kg, with increases made in increments of 25 mg per day no more than once per month; WBC maintained at 3500–4000/μL (n = 29) | 1) Physical functioning: | | | | This study demonstrates a modest benefit of azathioprine in reducing mean exacerbation rates and provides specific data regarding the proportion of patients who improve on therapy with regard to EDSS and other functional measures. The proportion of patients who improved was, however, not statistically different among the treatment groups.
| Exclusion: Chronic progressive disease (worsening in functional status measurements over 6 mo without exacerbation); use of corticosteroids in previous 1 mo; use of immunosuppressant medication in previous 1 yr; pregnant; unwilling to practice birth control; systemic illness of medical condition that precluded safe administration of study drugs | Duration of study treatment/follow up: 2 yr | No. followed for 2 yr: 52 | | | 2) Placebo (n = 25) | Definitions of “improvement”: Score reflects combined results of change lasting more than 2 mo in any of following: | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | No. treated per protocol for 2 yr: 43 | | | | ≥ 1.0-point on EDSS for patients with baseline EDSS ≤ 5.0, or | | | | Described as “randomized”? Yes
| | Location: 1 site in Fargo, ND | Age (mean ± SD at onset; n = 54 starting treatment): | | | | ≥ 0.5-point on EDSS for patients with baseline EDSS ≥ 5.5, or | | | | Method of randomization clearly described? Yes
| | | Azathioprine: 29.4 ± 8.5 | | | | ≥ 1.0 point on AI, or | | | | Concealment of allocation? Yes
| | | Placebo: 30.0 ± 6.8 | | | | ≥ 20% deterioration from baseline in 9HPT or BBT | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean ± SD; n = 54 starting treatment): | | | | Proportion of patients with “improvement”: | | | | Patients blinded? Yes
| | | Azathioprine: 3.18 ± 1.19 | | | | Placebo = 20% | | | | Investigators blinded? Yes
| | | Placebo: 3.72 ± 1.60 | | | | Azathioprine = 22.2% | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (mean ± SD in previous 18 mo; no = 54 starting treatment): | | | | Other (non-improvement) outcomes: Difference in mean change in EDSS | | | | No. of withdrawals in each group stated? Yes
| | | Azathioprine: 2.34 ± 0.55 | | | | 2) Relapse frequency:
| | | Placebo: 2.32 ± 0.63 | | | | Definition of “relapse”: Objective worsening in the EDSS of ≥ 0.5 points, Ambulation Index (AI) of ≥ 1.0 points, or ≥ 20% deterioration from baseline performance on the nine-hole peg test (9HPT) or box-and-block test (BBT) in patients who were stable or improving within the last month
| | | | | | | Definition of “improvement”: Not defined
| | | | | | | Proportion of patients with “improvement”: Not delineated
| | | | | | | Other (non-improvement) outcomes:
| | | | | | | Mean on-trial exacerbation rates for each group:
| | | | | | | | AZA | Placebo | P
| | | | | | | Year 1 | 0.74 | 1.17 | 0.16
| | | | | | | Year 2 | 0.30 | 0.79 | 0.05
| | | | | | | Total 2 year | 1.04 | 1.88 | 0.08
Goodkin, Rudick, VanderBrug Medendorp, et al., 1995 | Inclusion: Clinically definite chronic progressive MS; progressive neurological impairment during period of ≥ 6 mo prior to start of study; no exacerbation for previous 8 mo; ≤ 1 exacerbation in previous 2 yr; disease duration > 1 yr; EDSS 3.0–6.5; AI 2.0–6.0; no cortico-steroids during previous 1 mo or immunosuppressant medication for previous 1 yr; no prior lymphoid irradiation; willing to use contraception; age 21–60 | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 60 (18 primary progressive, 42 secondary progressive) | | | 1) Methotrexate (METH), one 7.5-mg oral tablet per week for 2 yr (n = 31) | 1) Physical functioning: | | | | This study evaluated therapy with low-dose oral methotrexate (6.5 mg) weekly in patients with chronic progressive MS and found significant benefit on a composite measure of physical functioning. The most prominent benefit observed was in upper extremity function. The study did not evaluate individual patient improvement and provided no data specifically addressing the proportion of patients improved.
| Exclusion: Pregnancy; systemic illness or medical condition that precluded safe administration of study drugs; clinically evident cognitive impairment | Duration of study treatment/follow up: 2 yr | Dropouts: 9 | | | 2) Placebo (n = 29) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 51 | | | | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 1 site in Cleveland, OH | Age (mean ± SD): | | | | Other (non-improvement) outcomes: | | | | Method of randomization clearly described? Yes
| | | METH: 43 ± 9.3 | | | | The primary outcome measure was time to treatment failure on a composite measure of physical functioning that utilized EDSS, Ambulation Index, Box and Block Test and 9-Hole Peg Test for 2 mo or more. Treatment failure was pre-defined on the basis of specific levels of deterioration on any of these scales. | | | | Concealment of allocation? Yes
| | | Placebo: 46 ± 8.8 | | | | There was a significant relationship between sustained progression and treatment group favoring the METH treatment: METH = 51.6%, Placebo = 82.8% (p = 0.011). This treatment effect was strongest for the 9HPT and was seen to a lesser extent (p = NS) for the BBT and EDSS. | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean): | | | | | | | | Patients blinded? Yes
| | | METH: 5.5 | | | | | | | | Investigators blinded? Yes
| | | Placebo: 5.3 | | | | | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate: NR | | | | | | | | No. of withdrawals in each group stated? Yes
Hartung, Gonsette, König, et al., 2002 | Inclusion: Worsening relapsing-remitting MS (stepwise progression of disability between relapses) or secondary progressive MS; EDSS 3.0–6.0; worsening of ≥ 1 point on EDSS in previous 18 mo; no relapse in previous 8 wk; no treatment with glucocorticosteroids in previous 8 wk; no previous treatment with mitoxantrone, interferons, glatiramer acetate, cytotoxic drugs, or total-body lymphoid irradiation; left ventricular ejection fraction > 50%; WBC, neutrophil, and platelet counts in normal ranges; age 18–55 | RCT (parallel-group, double-blind [patients and assessors, not treating physicians], multicenter) | No. of patients randomized: 194 randomized; 188 included in baseline measures (94 worsening relapsing-remitting, 94 secondary progressive) | | | 1) Mitoxantrone (MTX) 12 mg/m^2^ by slow IV infusion every 3 months for 2 yr; dose could be reduced in response to adverse events, infection, or low WBC or platelet count (n = 63) | 1) Physical functioning: EDSS, Ambulation Index, and standard neurological status scores were established at each scheduled and unscheduled visit | | | | This study evaluated therapy with mitoxantrone (12 mg/m^2^) IV every 3 months in the treatment of worsening relapsing-remitting MS and secondary progressive MS. Investigators found statistically significant differences in the treatment groups on the following outcome measures: multivariate analysis of outcome, change in EDSS, change in Ambulation Index, adjusted total number of treated relapses, time to first treated relapse, and change in standardized neurological status. The 5-mg/m^2^dose arm demonstrated less convincing benefits. This study did not provide data regarding improvement in individual patients.
| Exclusion: None specified | Duration of study treatment/follow up: Treatment lasted 2 yr; patients followed for total of 3 yr | Dropouts: 56 | | | 2) Mitoxantrone (MTX) 5 mg/m^2^ by slow IV infusion every 3 months for 2 yr; dose could be reduced in response to adverse events (n = 66) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 138 assessed at 3 yr | | | 3) Placebo (n = 65) | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 17 sites in Belgium, Germany, Hungary, and Poland | Age (mean ± SD): | | | | Other (non-improvement) outcomes: Mean and median EDSS change, Ambulation Index change, SNS change | | | | Method of randomization clearly described? Yes
| | | MTX 12 mg: 39.94 ± 6.85 | | | | 2) Relapse frequency: | | | | Concealment of allocation? Yes
| | | MTX 5 mg: 39.92 ± 8.06 | | | | Definition of “relapse”: Severe relapse defined as the occurrence of new symptoms lasting for longer than 48 hours with a change in functional system score of more than 2 points, or a deterioration of at least 1 point in at least one of the four following systems: pyramidal, brainstem, cerebellar, or visual | | | | Described as “double-blind”? Yes
| | | Placebo: 40.02 ± 7.88 | | | | Definition of “improvement”: Not defined | | | | Patients blinded? Yes
| | | Baseline EDSS (mean ± SD): | | | | Proportion of patients with “improvement”: Not delineated | | | | Investigators blinded? Yes
| | | MTX 12 mg: 4.45 ± 1.05 | | | | Other (non-improvement) outcomes: | | | | Outcome assessors blinded? Yes
| | | MTX 5 mg: 4.64 ± 1.01 | | | | Number of treated relapses per patient (median, with range): | | | | No. of withdrawals in each group stated? Yes
| | | Placebo: 4.69 ± 0.97 | | | | Placebo: 1 (0–5)
| | | Baseline relapse rate (mean ± SD in previous 1 yr): | | | | MTX 12 mg: 0 (0–2)
| | | MTX 12 mg: 1.27 ± 1.12 | | | | p = 0.0002
| | | MTX 5 mg: 1.42 ± 1.26
| | | Placebo: 1.31 ± 1.14
Hauser, Dawson, Lehrich, et al., 1983 | Inclusion: Clinically definite MS; severe progressive disease, with worsening in previous 9 mo (defined as a decrease of ≥ 1 points on functional status or disability scales, either continuous decline or continuous decline with superimposed exacerbations); no corticosteroid therapy in previous month; no immunosuppressive therapy in previous yr | RCT (parallel-group, not double-blinded, two-center) | No. of patients randomized: 58 | | | 1) Adrenocorticotropic hormone (ACTH) (n = 20). Initially given intravenously daily over 8-hr period, with doses as follows: 25 units on days 1–3, 20 units on days 4–6, 15 units on days 7–9, 10 units on days 10–12, and 5 units on days 13–15. IM injections then given on days 16–18 (40 units each) and days 19–21 (20 units each), after which treatment discontinued. | 1) Physical functioning: | | | | This study provides evidence that intensive immunosuppressive therapy, (particularly IV ACTH combined with high-dose IV cyclophosphamide) significantly reduces progressive MS in the population of patients who have severe, progressive MS. The study specifically demonstrates that the proportion of patients who experience clinical improvement on EDSS and Ambulation Index is increased with this therapy.
| Exclusion: Medical illnesses incompatible with safe administration of study medications | Duration of study treatment/follow up: Treatment duration variable (see at right, under “Interventions”; patients followed for total of 1 yr | Dropouts: 0 | | | 2) High-dose cyclophosphamide (CYCLO) + ACTH (n = 20). CYCLO administered intravenously daily for 10–14 days at dosage of 400–500 mg per day in 4 divided doses (total dose 80–100 mg/kg body weight). Discontinued when WBC count fell to approximately 4000/mm^3^. Large volumes of fluids administered orally and by IV to prevent bladder toxicity. ACTH given as above, beginning on same day as CYCLO. | Definition of “improvement”: Decrease of one or more points on either the Ambulation Index or the Disability-Status Scale, as compared with the score at the time of entry | | | | The authors appropriately state that this is not a standard therapy and do not recommend the routine use of this regimen in patients with MS. “Its use should be restricted to experimental treatment programs or to carefully selected patients with rapid or unremitting progressive disease who have not responded to conventional regimens.” This recommendation is based on the recognition that long-term studies have yet to be published and that there exists the potential for significant long-term toxicities.
| | Provider specialty: NR (presumably neurologists) | Completed: 58 | | | 3) Plasma exchange (PEX) + low-dose CYCLO + ACTH (n = 18). PEX performed by means of continuous-glow exchange; approximately 1–1.5 plasma volumes removed per exchange and replaced with 5% serum albumin. 4–5 exchanges given over a 2-wk period. CYCLO given at low dose (2 mg/kg/day) for 8 wk (dose decreased if WBC count fell below 4000/mm^3^). ACTH as above. All 3 treatments started together. | Proportion of patients with “improvement”: | | | | QUALITY ASSESSMENT:
| | Location: 2 sites in Boston, MA | Age (mean ± SE): | | | | ACTH alone - 5% | | | | Described as “randomized”? Yes
| | | ACTH: 35.2 ± 1.5 | | | | ACTH + CYCLO - 40% | | | | Method of randomization clearly described? No
| | | CYCLO + ACTH: 32.9 ± 1.8 | | | | ACTH, PEX and oral CYCLO - 20% | | | | Concealment of allocation? No
| | | PEX + CYCLO + ACTH: 36.3 ± 1.7 | | | | Other (non-improvement) outcomes: Physician's clinical assessment of stabilized neurological status | | | | Described as “double-blind”? No
| | | Baseline EDSS (mean ± SE): | | | | 2) Relapse frequency: | | | | Patients blinded? No
| | | ACTH: 5.6 ± 0.2 | | | | Definition of “relapse”: Not defined | | | | Investigators blinded? No
| | | CYCLO + ACTH: 5.8 ± 0.2 | | | | Definition of “improvement”: Not defined | | | | Outcome assessors blinded? No
| | | PEX + CYCLO + ACTH: 5.6 ± 0.2 | | | | Proportion of patients with “improvement”: Not delineated | | | | No. of withdrawals in each group stated? Yes
| | | Baseline relapse rate: NR
IFNB Multiple Sclerosis Study Group, 1993 and IFNB Study Group and the University of British Columbia MS/MRI Analysis Group, 1995 and IFNB Study Group and the University of British Columbia MS/MRI Analysis Group 1996 and Pliskin, Hamer, Goldstein, et al., 1996 | Inclusion: Clinically definite or laboratory-supported definite MS for > 1 yr; EDSS ≤ 5.5; ≥ 2 acute exacerbations in previous 2 yr; clinically stable for at least 30 days before entry; no ACTH or prednisone during 30 days prior to entry; age 18–50 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 372 | | | 1) Recombinant interferon β-1b (IFNβ-1b), 8 MIU self-administered by SC injection every other day for duration of study (n = 124) | 1) Physical functioning: | | | | These articles demonstrate the efficacy of IFNβ-1b over placebo in reducing exacerbation rates and limiting MRI disease activity, but contain no data to demonstrate the absolute improvement of any patient over baseline status.
| Exclusion: Prior treatment with azathioprine or cyclophosphamide | Duration of study treatment/follow up: Original study period 2 yr; later extended; median time on study was 48.0 mo for the IFNβ-1b 8 MIU group, 45.0 mo for the IFNβ-1b 1.6 MIU group, and 46.0 mo for the placebo group | Dropouts: Sixty-five patients discontinued treatment during the first 2 yr (23 placebo, 18 in the 1.6 MIU, and 24 in the 8 MIU groups) | | | 2) Recombinant IFNβ-1b, 1.6 MIU self-administered by SC injection every other day for duration of study (n = 125) | A secondary endpoint, progression in disability, was defined as a persistent increase of one or more EDSS points confirmed on two consecutive evaluations separated by at least 3 months | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | 154 (over entire study period) | | | 3) Placebo (n = 123) | Results: | | | | Described as “randomized”? Yes
| | Location: 4 sites in Canada and 7 in US | Completed: 307 through 2 yr; 218 through end of study | | | | Median time to progression (yr) | | | | Method of randomization clearly described? Yes
| | | Age (mean ± SE): | | | | Placebo - 4.18 | | | | Concealment of allocation? Yes
| | | IFNβ-1b 8 MIU: 35.2 ± 0.6 | | | | 1.6 MIU - 3.49 | | | | Described as “double-blind”? Yes
| | | IFNβ-1b 1.6 MIU: 35.3 ± 0.7 | | | | 8 MIU - 4.79 | | | | Patients blinded? Yes
| | | Placebo: 36.0 ± 0.6 | | | | Time to progression (placebo vs. 8 MIU) | | | | Investigators blinded? Yes
| | | Baseline EDSS (mean ± SE): | | | | P = 0.096 | | | | Outcome assessors blinded? Yes
| | | IFNβ-1b 8 MIU: 3.0 ± 0.1 | | | | 2) Relapse frequency: | | | | No. of withdrawals in each group stated? Yes
| | | IFNβ-1b 1.6 MIU: 2.9 ± 0.1 | | | | Definition of “relapse”: Appearance of a new symptom or worsening of an old symptom, attributable to MS; accompanied by an appropriate new neurological abnormality; lasting at least 24 hours in the absence of fever; and preceded by stability or improvement for at least 30 days
| | | Placebo: 2.8 ± 0.1 | | | | Annual relapse rate:
| | | Baseline relapse rate (mean in past 2 yr ± SE): | | | | Year 1 | Placebo - 1.44
| | | IFNβ-1b 8 MIU: 3.4 ± 0.2 | | | | | 1.6 MIU - 1.22
| | | IFNβ-1b 1.6 MIU: 3.3 ± 0.1 | | | | | 8 MIU - 0.96
| | | Placebo: 3.6 ± 0.1 | | | | | Placebo vs. 8 MIU: p < 0.001
| | | | | | | Year 2 | Placebo - 1.18
| | | | | | | | 1.6 MIU - 1.04
| | | | | | | | 8 MIU - 0.85
| | | | | | | | Placebo vs. 8 MIU: p ≤ 0.03
| | | | | | | Year 3 | Placebo - 0.92
| | | | | | | | 1.6 MIU - 0.80
| | | | | | | | 8 MIU - 0.66
| | | | | | | | Placebo vs. 8 MIU: p = 0.084
| | | | | | | Year 4 | Placebo - 0.88
| | | | | | | | 1.6 MIU - 0.68
| | | | | | | | 8 MIU - 0.67
| | | | | | | | Placebo vs. 8 MIU: p = 0.166
| | | | | | | Year 5 | Placebo - 0.81
| | | | | | | | 1.6 MIU - 0.66
| | | | | | | | 8 MIU - 0.57
| | | | | | | | Placebo vs. 8 MIU: p = 0.393
| | | | | | | 3) Cognitive functioning: Immediate and delayed recall memory and visual reproduction subtests of the Wechsler Memory Scale, forms 1 and 2, attention/mental speed (Trailmaking Test part B; Stroop Color-Word Test), dominant and nondominant morot function (Purdue Pegboard), and Beck Depression Inventory were administered to patients in all groups during the course of the study. No baseline measurements were made.
| | | | | | | Results: A significant main effect for time
| | | | | | | (F = 15.75 [2, 27], p < 0.001) and an interaction effect between treatment condition and time of testing (F = 4.15 [2, 27], p < 0.03) were found for WMS VR-Delayed Recall. Follow-up pairwise comparisons indicated an improvement in delayed visual reproduction between the second and fourth years of treatment in the high-dose group (WMS VR-Delayed Recall; p < 0.003). The placebo and low-dose groups did not change significantly. No other neuropsychological parameters demonstrated a significant difference between the groups during the study.
Jacobs, Cookfair, Rudick, et al., 1996 and Rudick, Goodkin, Jacobs, et al., 1997 and Fischer, Priore, Jacobs, et al., 2000 and Jacobs, Rudick, and Simon, 2000 and Rudick, Fisher, Lee, et al., 2000 | Inclusion: Definite MS for ≥ 1 yr; EDSS 1.0–3.5; relapsing disease course, with ≥ 2 documented exacerbations in previous 3 yr and no exacerbations for at least past 2 mo; age 18–55 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 301 | | | 1) Interferon β-1a (IFNβ-1a) 6 million units by IM injection weekly for up to 3 yr (n = 158) | 1) Physical functioning: | | | | The study described in these reports demonstrates significant improvement with regard to progression of disability as measured by EDSS, reduction in relapse rates, and improvement in various neuropsychological test parameters in patients treated with IFNβ-1a compared with placebo. Most of the data presented compare treatment groups rather than presenting data on individual patient improvement. Some data are delineated with regard to the number of patients with improved EDSS scores of 0.5 or 1.0 points.
| Exclusion: Prior immunosuppressant or interferon therapy; adrenocorticotropic hormone or corticosteroid treatment in previous 2 mo; pregnancy or nursing; unwilling to practice contraception; chronic progressive MS; any disease other than MS compromising organ function | Duration of study treatment/follow up: Variable (enrollment date varied, but end-of-study date same for all patients) | Dropouts: Not completely clear; 23 early withdrawals, variable treatment durations | | | 2) Placebo for up to 3 yr (n = 143) | Definition of “improvement”: ≥ 0.5- or 1.0-point improvement on EDSS | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 287 followed up through 1 yr; 172 through 2 yr; 31 through 3 yr | | | | Proportion of patients with “improvement”: | | | | Described as “randomized”? Yes
| | Location: 4 sites in US | Age (mean ± SE): | | | | Placebo | | | | Method of randomization clearly described? Yes
| | | IFNβ-1a: 36.7 ± 0.57 | | | | IFNβ-1a | Improved | Unsustained | | Concealment of allocation? Yes
| | | Placebo: 36.9 ± 0.64 | | | | ≥ 1.0 | 10 (11.5%) | 16 (19.3%) | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean ± SE): | | | | 0.5 | 10 (11.5%) | 13 (15.7%) | | Patients blinded? Yes
| | | IFNβ-1a: 2.4 ± 0.06 | | | | | Improved | Sustained | | Investigators blinded? Yes
| | | Placebo: 2.3 ± 0.07 | | | | ≥ 1.0 | 5 (8.9%) | 10 (18.2%) | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (mean ± SE, time frame not specified): | | | | 0.5 | 9 (16.1%) | 14 (25.5%) | | No. of withdrawals in each group stated? Yes
| | | IFNβ-1a: 1.2 ± 0.05 | | | | Other (non-improvement) outcomes:
| | | Placebo: 1.2 ±0.05 | | | | Time to sustained progression of disability, the primary outcome measure, was significantly greater in IFNβ-la-treated patients than in placebo-treated patients (p = 0.02)
| | | | | | | 2) Relapse frequency:
| | | | | | | Definition of “relapse”: Appearance of new neurological symptoms or worsening of preexisting neurological symptoms lasting at least 48 hours in a patient who had been neurologically stable or improving for the previous 30 days accompanied by objective change on neurological examination (worsening of 0.5 point on the EDSS or a worsening by ≥ 1.0 point on the pyramidal, cerebellar, brainstem, or visual functional system scores)
| | | | | | | Definition of “improvement”: Not defined
| | | | | | | Proportion of patients with “improvement”:
| | | | | | | Not delineated
| | | | | | | Other (non-improvement) outcomes:
| | | | | | | Annual relapse rates:
| | | | | | | | Placebo | IFNβ-la | P value
| | | | | | | All patients | 0.82 | 0.67 | 0.04
| | | | | | | 104 week
| | | | | | | patient subset | 0.90 | 0.61 | 0.002
| | | | | | | 3) Cognitive functioning: The Comprehensive NP Battery is a broad-spectrum battery comprising measures from the core battery recommended by the National MS Society Cognitive Function Study Group as well as additional measures covering cognitive domains of theoretical interest
| | | | | | | Definition of “improvement”: Not defined for individual patients.
| | | | | | | Proportion of patients with “improvement”:Not delineated
| | | | | | | Other (non-improvement) outcomes:
| | | | | | | Relapsing MS patients treated with IFNβ-1a for 2 yr performed significantly better than placebo patients on a composite of information processing and learning/recent memory measures (set A from the Comprehensive NP Battery). A similar trend was observed on a composite measure of visuospatial abilities and executive functions (set B) but not on the set C composite (verbal abilities and attention span).
Johnson, Brooks, Cohen, et al., 1995 and Weinstein, Schwid, Schiffer, et al., 1999 and Liu, Blumhardt, and the Copolymer 1 Multiple Sclerosis Study Group, 2000 and Johnson, Brooks, Cohen, et al., 1998 | Inclusion: Clinically definite or laboratory-supported MS; relapsing-remitting course; ambulatory, with EDSS 0–5.0; ≥ 2 clearly documented relapses in 2 yr prior to entry; onset of first relapse ≥ 1 yr before randomization; neurological stability and freedom from corticosteroid therapy for ≥ 30 days prior to entry; age 18–45 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 251 | | | 1) Glatiramer acetate = Copolymer 1 (Cop 1) by SC injection; 20 mg self-injected daily for 2 yr (n = 125) | 1) Physical functioning: | | | | This study demonstrated the benefit of Copolymer 1 therapy in reduction of relapse rates and in proportion of patients who improved by ≥ 1.0 points on EDSS.
| Exclusion: Previous Copolymer 1 therapy; previous immuno-suppressive therapy with cyctotoxic chemotherapy or lymphoid irradiation; need for aspirin or chronic NSAIDs during trial; [other generic exclusions] | Duration of study treatment/follow up: 2 yr | Dropouts: 36 | | | 2) Placebo (n = 126) | Definition of “improvement”: ≥ 1.0-point EDSS reduction | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 215 | | | | Proportion of patients with “improvement”: | | | | Described as “randomized”? Yes
| | Location: 11 sites in the US | Age (mean ± SD): | | | | Original 2-yr trial: | | | | Method of randomization clearly described? No
| | | Cop 1: 34.6 ± 6.0 | | | | Cop 1 - 24.8% | | | | Concealment of allocation? Yes
| | | Placebo: 34.3 ± 6.5 | | | | Placebo - 15.2% | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean ± SD): | | | | Extension study: | | | | Patients blinded? Yes
| | | Cop 1: 2.8 ± 1.2 | | | | Cop 1 - 27.2% | | | | Investigators blinded? Yes
| | | Placebo: 2.4 ± 1.3 | | | | Placebo - 12.0% | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (mean ± SD for prior 2 yr): | | | | Other (non-improvement) outcomes: | | | | No. of withdrawals in each group stated? Yes
| | | Cop 1: 2.9 ± 1.3 | | | | Mean change in EDSS, Ambulation Index, proportion of progression-free patients, area under curve analyses of EDSS progression
| | | Placebo: 2.9 ± 1.1 | | | | 2) Relapse frequency:
| | | | | | | Definition of “relapse”: Appearance or reappearance of one or more neurological abnormalities persisting for at least 48 hours and immediately preceded by a relatively stable or improving neurological state of at least 30 days. A relapse was confirmed only when a patient's symptoms were accompanied by objective changes on the neurological examination consistent with an increase of at least a half a step on the EDSS, two points on one of the seven functional systems, or one point on two or more of the functional systems.
| | | | | | | Definition of “improvement”: Not defined
| | | | | | | Proportion of patients with “improvement”: Not delineated
| | | | | | | Other (non-improvement) outcomes:
| | | | | | | Relapse rate:
| | | | | | | | Cop 1 | Placebo | P-value
| | | | | | | Relapse rate
| | | | | | | 24 months | 1.19 | 1.68 | 0.007
| | | | | | | Annual relapse rate
| | | | | | | | 0.59 | 0.84
| | | | | | | Relapse free | 33.6% | 27.0% | 0.098
| | | | | | | Extension
| | | | | | | Relapse rate | 1.34 | 1.98 | 0.002
| | | | | | | Extension
| | | | | | | Annual relapse rate
| | | | | | | | 0.58 | 0.81
| | | | | | | 3) Cognitive functioning: Brief Repeatable Battery of Neuropsychological Tests - consisting of 5 tests including measures of sustained attention and concentration (Paced Auditory Serial Addition Test and Symbol Digit Modalities Test), verbal learning and delayed recall (Buschke Selective Reminder Test), visuospatial learning and delayed recall (10/36 Spatial Recall Test), and semantic retrieval (Word List Generation Test)
| | | | | | | Definition of “improvement”: Not defined
| | | | | | | Proportion of patients with “improvement”: Mean neuropsychologic test scores were improved at 12 and 24 months compared with baseline for placebo and glatiramer groups. No differences were detected between the treatment groups for any of the neuropsychologic test results.
| | | | | | | Other (non-improvement) outcomes:
Kappos, Polman, Pozzilli, et al., 2001 and Freeman, Thompson, Fitzpatrick, et al., 2001 | Inclusion: Clinically or laboratory supported definite diagnosis of secondary progressive MS; EDSS 3.0–6.5; ≥ 2 relapses or ≥ 1.0-point increase in EDSS in previous 2 yr; age 18–55 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 718 | | | 1) Interferon β-1b (IFNβ-1b) by SC injection; initial dose 0.5 mL (4 MIU) every other day, increased after 2 wk to 1.0 mL (8 MIU) every other day for up to 3 yr (n = 360) | 1) Physical functioning: | | | | These studies examined further analyses and quality-of-life parameters from the previously published trial conducted by the European Study Group in Interferon-β1b in Secondary-Progressive MS, 1998 , above. Significant improvements in EDSS, relapse rate, and quality-of-life parameters were demonstrated. This study provides data on individual patient improvement only with regard to relapse rates.
| Exclusion: None specified | Mean duration of treatment/follow up: Treatment lasted up to 36 mo; article reports results at study termination; mean follow-up time 1068 ± 176 days for IFNβ-1b and 1054 ± 199 days for placebo | Lost to follow up: 88 | | | 2) Placebo (n = 358) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (presumably neurologists) | Withdrew from treatment: 132 | | | | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 32 sites in Europe | Completed treatment and follow up: 498 | | | | Other (non-improvement) outcomes: | | | | Method of randomization clearly described? Yes
| | | Age (mean ± SD): | | | | Time to confirmed progression in EDSS favored IFNβ-1b, p = 0.007 | | | | Concealment of allocation? Yes
| | | IFNβ-1b: 41.1 ± 7.2 | | | | Percent of patients progression-free | | | | Described as “double-blind”? Yes
| | | Placebo: 40.9 ± 7.2 | | | | Placebo - 46.1% | | | | Patients blinded? Yes
| | | Baseline EDSS (mean ± SD): | | | | IFNβ-1b - 54.7% | | | | Investigators blinded? Yes
| | | IFNβ-1b: 5.1 ± 1.1 | | | | P = 0.031 | | | | Outcome assessors blinded? Yes
| | | Placebo: 5.2 ± 1.1 | | | | 2) Relapse frequency: | | | | No. of withdrawals in each group stated? Yes
| | | Baseline relapse rate (% of patients without relapse in 2 yr preceding study): | | | | Definition of “relapse”: Previously defined
| | | IFNβ-1b: 31.9% | | | | Definition of “improvement”: Not defined
| | | Placebo: 28.2% | | | | Proportion of patients with “improvement”: Not assessed
| | | | | | | Other (non-improvement) outcomes:
| | | | | | | Percent of patients relapse-free:
| | | | | | | Placebo - 36.3%
| | | | | | | IFNβ-1b - 42.5%
| | | | | | | P = 0.083
| | | | | | | Percent of patients relapse-free or decrease in relapse rate:
| | | | | | | Placebo - 45.0%
| | | | | | | IFNβ-1b - 53.1%
| | | | | | | P = 0.031
| | | | | | | 3) Quality of life:
| | | | | | | The SIP is a generic self-report questionnaire of health-related quality of life, which examines the individual's perception of the impact of the disease process on behavior in everyday life. The total score ranges from 0 (best) to 100 (worst).
| | | | | | | The GEMS scale was developed specifically for this study and provides a global evaluation of the neurologist's perception of change in terms of disease status and disability. The scale provides 7 points ranging from “very much better” to “very much worse.” No published information is available determining its measurement properties.
| | | | | | | Definition of “improvement”: Not defined
| | | | | | | Proportion of patients with “improvement”:
| | | | | | | Not delineated
| | | | | | | Other (non-improvement) outcomes:
| | | | | | | The difference in total SIP score for the two groups shows a non-statistically significant trend in favor of IFNβ-1b.
| | | | | | | The SIP physical dimension score demonstrates a statistically significant benefit in favor of IFNβ-1b therapy at 6 and 12 months.
| | | | | | | A significant treatment effect of IFNβ-1b was demonstrated in the psychosocial dimension scores at 18 months but not at the end of the study.
Khatri, McQuillen, Harrington, et al., 1985 | Inclusion: Clinically definite MS; chronic progressive disease course (continuous worsening on serial neurological exams during previous 12 mo); patient insured, and insurance company would pay for plasma exchange | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 59 | | | 1) Plasma exchange (n = 30); during each exchange, plasma volume equivalent to 5% of patient's body weight exchanged for 5% albumin solution and normal saline in equal ratios; exchanges performed once per week for 20 wk | 1) Physical functioning: | | | | This study evaluated plasmapheresis in the treatment of chronic progressive MS.
| Exclusion: None specified | Duration of study treatment/follow up: 18 mo | Dropouts: 4 | | | 2) Sham plasma exchange (patient's plasma returned after it had been separated) (n = 29); exchanges performed once per week for 20 wk | Two scoring scales were used in measuring clinical change, the Kurtzke DSS and the Canter Scale, which measures changes in activities of daily living | | | | The results suggest a benefit to plasmapheresis with regard to EDSS measured at 5 and 11 months. Observations suggest some improvement in cognitive function, although the details are not delineated.
| | Provider specialty: Neurologists | Completed: 55 | | | Patients in both groups also received: | Definition of “improvement”: > 1-point improvement on DSS | | | | QUALITY ASSESSMENT:
| | Location: 1 site in Milwaukee, WI | Age (mean, completers): Genuine: 37.8 | | | a) Oral cyclophospha-mide (1.5 mg/kg per day, rounded to nearest 50 mg); | Proportion of patients with “improvement”: | | | | Described as “randomized”? Yes
| | | Sham 42.2 | | | b) prednisone (1 mg/kg every other day, gradually decreasing doses after 15^th^ wk); and c) pooled human immune serum globulin (40 ml in 4 divided IM injections over 2 days after each exchange) | At 5 mo, 14 plasmapheresis patients improved and 8 sham pheresis patients improved with details as follows: | | | | Method of randomization clearly described? Yes
| | | Baseline EDSS (mean, completers): Genuine 6.6 | | | | 5-mo evaluation: | | | | Concealment of allocation? Yes
| | | Sham: 6.3 | | | | | PP | Sham | | Described as “double-blind”? Yes
| | | Baseline relapse rate NR | | | | 3 or more points | 5 | 0 | | Patients blinded? Yes
| | | | | | | 2 points | 5 | 4 | | Investigators blinded? Yes
| | | | | | | 1 points | 4 | 4 | | Outcome assessors blinded? Yes
| | | | | | | 11-mo evaluation: | | | | No. of withdrawals in each group stated? Yes
| | | | | | | | PP | Sham
| | | | | | | 3 or more points | 3 | 0
| | | | | | | 2 point | 4 | 1
| | | | | | | 1 point | 4 | 4
| | | | | | | Other (non-improvement) outcomes: Not delineated
| | | | | | | 2) Relapse frequency:
| | | | | | | Definition of “relapse”: Not defined
| | | | | | | Definition of “improvement”: Not defined
| | | | | | | Proportion of patients with “improvement”: Not delineated
| | | | | | | Other (non-improvement) outcomes:
| | | | | | | Not delineated
| | | | | | | 3) Cognitive functioning: Standard neurological examination
| | | | | | | Definition of “improvement”: Not defined
| | | | | | | Proportion of patients with “improvement”: 4 patients with cognitive deficits improved in these functions at the 15^th^ PP treatment, but this did not occur in similar patients in the sham group
Leary, Miller, Stevenson, et al., 2003 | Inclusion: Primary progressive MS (progressive history without relapse or remission, ≥ 2 typical lesions on MRI brain or spinal cod, and oligoclonal bands in the CSF not present in parallel serum or abnormal visual evoked potentials); disease duration ≥ 2 yr; EDSS 2.0–7.0; age 18–60 | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 50 | | | 1) Interferon β-1a (IFNβ-1a) 60 μg weekly by IM injection for 2 yr (n = 15) | 1) Physical functioning: | | | | This study examined the efficacy of IFNβ-1a in the treatment of primary progressive MS with a primary endpoint of time to sustained progression and found no statistically significant treatment effect. No data are reported regarding individual patient improvement.
| Exclusion: Interferon, immunosuppressant, or chronic steroid therapy in previous 3 mo; pregnancy or lactation; seizure in previous 3 mo; history of severe depression | Duration of study treatment/follow up: 2 yr | Dropouts: 7 withdrew from treatment; all but 1 of these followed up for 2 yr | | | 2) IFNβ-1a 30 μg weekly by IM injection for 2 yr (n = 15) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (presumably neurologists) | Completed: 43 completed treatment; 49 followed up for 2 yr | | | 3) Placebo for 2 yr (n = 20) | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 1 site in London, UK | Age (mean [with range]): | | | | Other (non-improvement) outcomes: | | | | Method of randomization clearly described? Yes
| | | IFNβ-1a 60: 47 (25–59) | | | | Primary endpoint was time to sustained progression in disability, and there was no statistically significant difference among the treatment arms | | | | Concealment of allocation? Yes
| | | IFNβ-1a 30: 46.5 (29–58) | | | | | | | | Described as “double-blind”? Yes
| | | Placebo: 43 (30–59) | | | | | | | | Patients blinded? Yes
| | | Baseline EDSS (median [with range]): | | | | | | | | Investigators blinded? Yes
| | | IFNβ-1a 60: 5.5 (2.0–6.5) | | | | | | | | Outcome assessors blinded? Yes
| | | IFNβ-1a 30: 5.5 (3.5–7.0) | | | | | | | | No. of withdrawals in each group stated? Yes
| | | Placebo: 4.5 (2.0–7.0)
| | | Baseline relapse rate: NA
Milanese, La Mantia, Salmaggi, et al., 1988 | Inclusion: Clinically definite MS by Schumacher's criteria; relapsing-remitting (with ≥ 2 relapses in previous 3 yr) or progressive (with continuous worsening of neurological status over previous 1 yr) disease course | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 23 included in 1-yr analysis reported here (13 relapsing-remitting, 10 progressive) | | | 1) Azathioprine (AZA) PO 2–2.5 mg/kg per day for 1 yr (n = 9) | 1) Physical functioning: | | | | This study evaluated the efficacy of azathioprine in patients with relapsing-remitting and progressive MS. No statistically significant differences were detected in the first year of this 3-year trial. At the time of publication 17 of 38 patients had withdrawn from the study resulting in significant questions regarding the utility of 3-year data. No information is provided regarding individual patient improvement.
| Exclusion: Conditions which did not permit regular examination or which hampered patient's reliability (e.g., DSS > 7 or psychic disturbances); contraindications to immunosuppressive treatment; previous use of immunosuppressive therapy; pregnancy | Duration of study treatment/follow up: 1 yr (see “Comments”) | Dropouts: 0 (though 2 dropped out after 1 yr; see “Comments”) | | | 2) Placebo for 1 yr (n = 14) | Definition of “improvement”: Not delineated | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 23 | | | | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 1 site in Milan, Italy | Age (mean): | | | | Other (non-improvement) outcomes: No statistically significant difference at 1 yr | | | | Method of randomization clearly described? Yes
| | | AZA-relapsing: 33.1 | | | | 2) Relapse frequency: | | | | Concealment of allocation? Yes
| | | Placebo-relapsing: 34.1 | | | | Definition of “relapse”: Schumacher criteria | | | | Described as “double-blind”? Yes
| | | AZA-progressive: 38.1 | | | | Definition of “improvement”: Not defined | | | | Patients blinded? Yes
| | | Placebo-progressive: 42.4 | | | | Proportion of patients with “improvement”: Not delineated | | | | Investigators blinded? Yes
| | | Baseline EDSS (mean): | | | | Other (non-improvement) outcomes: | | | | Outcome assessors blinded? Yes
| | | AZA-relapsing: 2.17 | | | | Relapse rate - Progressive MS: | | | | No. of withdrawals in each group stated? Yes
| | | Placebo-relapsing: 2.43 | | | | | [underlined: Pre-] | [underlined: Final]
| | | AZA-progressive: 5.00 | | | | AZA | 0.5 | 0.42
| | | Placebo-progressive: 3.86 | | | | Placebo | 0.32 | 0.42
| | | Baseline relapse rate (mean per yr): | | | | Relapse rate - Relapsing-remitting MS:
| | | AZA-relapsing: 1.144 | | | | | [underlined: Pre-] | [underlined: Final]
| | | Placebo-relapsing: 0.890 | | | | Aza | 1.14 | 0.98
| | | AZA-progressive: 0.500 | | | | Placebo | 0.89 | 0.92
| | | Placebo-progressive: 0.318 | | | | No statistically significant differences in relapse rates
Millefiorini, Gasperini, Pozzilli, et al., 1997 | Inclusion: Clinically definite or laboratory-supported relapsing-remitting MS; disease duration 1–10 yr; EDSS 2–5; at least 2 exacerbations in previous 2 yr; age 18–45 | RCT (parallel-group, double-blind [patients and assessors, not treating physicians], multicenter) | No. of patients randomized: 51 (all relapsing-remitting) | | | 1) Mitoxantrone (MTX), 30-min IV infusion (8 mg/m^2^) ever month for 1 yr (n =27) | 1) Physical functioning: | | | | This study examined the efficacy of mitoxantrone in patients with relapsing-remitting MS and found statistically significant benefit of mitoxantrone with regard to EDSS progression and relapse rate reduction. No data are presented with regard to individual patient improvement.
| Exclusion: HIV-positive; previous cardiovascular disease; left ventricular ejection fraction < 50%; renal, liver, and/or respiratory dysfunction; diabetes; malignancy; psychiatric illness; pregnancy; women not using contraception; use of steroids in previous 3 mo; previous immunosuppressant therapy | Duration of study treatment/follow up: Treatment lasted 1 yr; patients followed for total of 2 yr | Dropouts: 9 | | | 2) Placebo (n = 24) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 42 completed all assessments (including MRIs) | | | | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 8 sites in Italy | Age (mean ± SD): | | | | Other (non-improvement) outcomes: | | | | Method of randomization clearly described? Yes
| | | MTX: 30.9 ± 6.0 | | | | % of patients who progressed by 1.0 point on EDSS - found statistically significant benefit of mitoxantrone at 2 yr | | | | Concealment of allocation? Yes
| | | Placebo: 28.7 ± 6.5 | | | | 2) Relapse frequency: | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean ± SD): | | | | Definition of “relapse”: Appearance of a new symptom or worsening of an old symptom, attributable to MS, accompanied by a documented new neurological abnormality, lasting more than 48 hours and preceded by stability or improvement for at least 30 days | | | | Patients blinded? Yes
| | | MTX: 3.6 ± 0.9 | | | | Definition of “improvement”: Not defined | | | | Investigators blinded? Yes
| | | Placebo: 3.5 ± 1.2 | | | | Proportion of patients with “improvement”: Not delineated | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (mean ± SD in previous 2 yr): | | | | Other (non-improvement) outcomes: | | | | No. of withdrawals in each group stated? No - appears that there were none
| | | MTX: 2.8 ± 1.2 | | | | Number of exacerbation (mean ± SD):
| | | Placebo: 2.8 ± 1.1 | | | | MTX: 0.89 ± 2.1
| | | | | | | Placebo: 2.62 ± 1.9
| | | | | | | p = 0.0002
| | | | | | | Exacerbation-free patients:
| | | | | | | MTX: 17 (63%)
| | | | | | | Placebo: 5 (21%)
| | | | | | | p = 0.006
Multiple Sclerosis Study Group, 1990 | Inclusion: Clinically definite MS for ≥ 1 yr; EDSS 3.0–7.0; age 18–55; chronic and progressive clinical deterioration of ≥ 1 grade, but not > 3 grades, on EDSS in previous 12 mo, with some decline in last 6 mo; no acute relapse in previous 3 mo; no immunosuppressive drugs in previous 3 mo; no unproven therapies for MS (e.g., hyperbaric oxygen, gangliosides, snake venom [!]) in previous 1 mo; no prior treatment with cyclophosphamide or radiation; no uncontrolled hypertension (SBP > 170 mmHg or DBP > 110 mmHg), malignancy, recent myocardial infarction, chronic pulmonary disease, active infection, hepatic or renal dysfunction, or other neurological disorders; not using medications known to interfere with study drugs | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 547 | | | 1) Cyclosporine PO (liquid suspension); initial dose of 6 mg/kg diluted in milk or orange juice and taken each morning with breakfast; dose adjusted to achieve whole-blood cyclosporine trough level of 400–600 ng/mL, later reduced to 300–500 ng/mL; maximum dose permitted was 10 mg/kg/day (n = 273) | 1) Physical functioning: Extensive evaluations performed including EDSS, incapacity status scales, functional system scores of the Multiple Sclerosis Minimal Record of Disability, standardized neurological examination, quantitative examination of neurological functional, Ambulation Index, physical examination, and clinical evaluation | | | | This study evaluated cyclosporine therapy in chronic progressive MS patients. The study is complicated by a high dropout rate, but appears to demonstrate statistically significant benefit as measured by a reduction in progression in EDSS. This study does not present data on individual patient improvement.
| Exclusion: Known sensitivity or adverse reactions to immunosuppressive drug; severe dementia; paraplegia or gait ataxia sufficient to prevent walking; severe upper extremity ataxia preventing independent feeding or dressing | Duration of study treatment/follow up: 2 yr | Dropouts: 120 (cyclosporine) + 87 (placebo) = 207 | | | 2) Placebo (n = 274) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 340 | | | | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 12 sites in US | Age (mean ± SD): | | | | Other (non-improvement) outcomes: | | | | Method of randomization clearly described? Yes
| | | Cyclosporine: 40.5 ± 7.7 | | | | Mean change in EDSS - found benefit of cyclosporine therapy with p = 0.006 in patients completing study, and p = 0.002 in all patients. | | | | Concealment of allocation? Yes
| | | Placebo: 40.6 ± 8.2 | | | | 2) Relapse frequency: | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean ± SD): | | | | Definition of “relapse”: Not defined | | | | Patients blinded? Yes
| | | Cyclosporine: 5.4 ± 1.2 | | | | Definition of “improvement”: Not defined | | | | Investigators blinded? Yes
| | | Placebo: 5.4 ± 1.2 | | | | Proportion of patients with “improvement”: Not delineated | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate: NR | | | | Other (non-improvement) outcomes: | | | | No. of withdrawals in each group stated? Yes - a total of 37.3% of all patients withdrew by the end of the study, necessitating some modifications to the primary outcome assessments. These modifications were made prior to data analysis.
| | | | | | | | | | | 56% of patients randomized to receive cyclosporine completed 24 months of continuous therapy, whereas 68% of those randomized to placebo successfully completed the trial (p=0.003)
Noseworthy, O'Brien, Petterson, et al., 2001 | Inclusion: One or more episodes of demyelinating optic neuritis occurring in the setting of clinically definite or laboratory-supported definite MS or in the presence of cranial MRI changes consistent with MS; first episode of optic neuritis between ages of 18 and 45; age < 50 at enrollment; fixed, apparently irreversible loss of visual acuity in at least one eye that met following criteria: a) visual acuity worse than 20/40 for a period of at least 6 mo and unchanged on at least 2 exams separated by at least 1 mo; b) optic disc pallor as detected by study neuro-ophthalmologist; c) abnormal visual field measured on Humphrey Field Analyzer with a mean deviation ≤ -4.00 and a pattern of defect consistent with optic neuritis; no adrenocorticotropic hormone or corticosteroids in previous 2 mo | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 55 (42 relapsing-remitting, 13 secondary progressive) | | | 1) IV immunoglobulin (IV IgG) 0.4 g/kg daily for 5 days, then once per month for 3 months (total of 8 infusions) (n = 27) | 1) Physical functioning: | | | | This study evaluated the efficacy of IV IgG in the treatment of optic neuritis in patients with MS. The study was terminated early due to negative results.
| Exclusion: Primary progressive MS; nondemyelinating cause for visual loss; preexisting ocular abnormalities; serious intercurrent medical illness; concomitant use of experimental drug for MS or other disease; serum creatinine > 1.5 times normal; pregnancy or unwillingness to use contraception; known antibody deficiency syndrome; need for IV IgG administration | Duration of study treatment/follow up: Treatment lasted 12 wk + 5 days; patients followed for total of 12 mo | Dropouts: 2 (both between 6 and 12 mo) | | | 2) Placebo (n = 28) | Definition of “improvement”: Not defined | | | | No data are presented that demonstrate individual patient improvement.
| | Provider specialty: Ophthalmologists and neurologists | Completed: 53 | | | | Proportion of patients with “improvement”: Not delineated | | | | QUALITY ASSESSMENT:
| | Location: 1 site in Rochester, MN | Age (mean ± SD): | | | | Other (non-improvement) outcomes: | | | | Described as “randomized”? Yes
| | | IV IgG: 38.0 ± 7.2 | | | | Several measures of visual function were assessed, as well as EDSS. No measures demonstrated statistically significant benefit from therapy. | | | | Method of randomization clearly described? Yes
| | | Placebo: 39.2 ± 6.7 | | | | 2) Relapse frequency: | | | | Concealment of allocation? Yes
| | | Baseline EDSS (mean ± SD, excluding visual functional status scores): | | | | Definition of “relapse”: Not defined | | | | Described as “double-blind”? Yes
| | | IV IgG: 3.6 ± 2.5 | | | | Definition of “improvement”: Not assessed | | | | Patients blinded? Yes
| | | Placebo: 3.0 ± 2.5 | | | | Proportion of patients with “improvement”: Not assessed | | | | Investigators blinded? Yes
| | | Baseline relapse rate: NR | | | | Other (non-improvement) outcomes: | | | | Outcome assessors blinded? Yes
| | | | | | | | | | | No. of withdrawals in each group stated? Yes
Patti, L'Episcopo, Cataldi, et al., 1999 | Inclusion: Definite MS; disease course relapsing-remitting (with ≥ 2 documented relapses in previous 2 yr and EDSS ≤ 3.5) or secondary progressive (with deterioration of ≥ 1.0 point on the EDSS over previous 2 yr and EDSS ≤ 7.0); emotionally stable; negative for HIV, HbsAg, and Borreliosis; free of other immune or neurological diseases; clinically stable for ≥ 30 days; no ACTH or corticosteroids in previous 30 days; age 18–45 | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 98 (58 relapsing-remitting, 40 secondary progressive) | | | 1) Natural interferon-β (nIFNβ) 6 MIU by IM injection three times per wk for 2 yr (n = 49) | 1) Physical functioning: | | | | This study examined treatment effect of nIFNβ in relapsing-remitting and secondary-progressive MS. Statistically significant differences were found in the treatment group with regard to proportion of patients improving by 0.5 or 1.0 points on EDSS and in the proportion of patients relapse-free.
| Exclusion: Pregnancy; prior treatment with azathioprine or cyclophosphamide (in previous 1 yr) | Duration of study treatment/follow up: 2 yr | Dropouts: 0 | | | 2) Placebo for 2 yr (n = 49) | Definition of “improvement”: Decrease of 0.5 or 1.0 in EDSS | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 98 | | | | Proportion of patients with “improvement”: | | | | Described as “randomized”? Yes
| | Location: 1 site in Catania, Italy | Age (mean): | | | | Relapsing-remitting patients: | | | | Method of randomization clearly described? Yes
| | | Relapsing-remitting (RR) patients: 36.6 | | | | Placebo - 1 of 29 patients (3.4%) improved | | | | Concealment of allocation? Yes
| | | Secondary progressive (SP) patients: 36.9 | | | | nIFNβ - 15 of 29 patients (52%) improved | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean): | | | | P = 0.002 | | | | Patients blinded? Yes
| | | RR-nIFNβ: 3.06 | | | | Secondary progressive patients: | | | | Investigators blinded? Yes
| | | RR-placebo: 3.1 | | | | Placebo - 1 of 20 patients (5%) improved | | | | Outcome assessors blinded? Yes
| | | SP-nIFNβ: 5.8 | | | | nIFNβ - 8 of 20 patients (40%) improved | | | | No. of withdrawals in each group stated? Yes
| | | SP-placebo: 6.0 | | | | P = 0.006
| | | Baseline relapse rate (mean over previous 2 yr): | | | | 2) Relapse frequency:
| | | RR-nIFNβ: 1.8 | | | | Definition of “relapse”: Rapid onset of new symptoms or a worsening of preexisting symptoms persisting for 48 hours or more and were accompanied by objective changes on the neurologic examination - an increase of at least one grade in the score for at least one of the functional groups of EDSS
| | | RR-placebo: 1.9 | | | | Definition of “improvement”: Not defined
| | | SP-nIFNβ: 0.4 | | | | Proportion of patients with “improvement”: Not delineated
| | | SP-placebo: 0.6 | | | | Other (non-improvement) outcomes:
| | | | | | | The probability of remaining exacerbation-free was significantly higher in the nIFNβ-treated group (presented in graphical form; p < 0.001)
Patzold, Hecker, and Pocklington, 1982 | Inclusion: Confirmed MS; resident in district of study site | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 142 | | | 1) Azathioprine PO, daily dose of 2 mg/kg for 2 yr (n = 74) | 1) Physical functioning (EDSS not assessed): | | | | This study examined the efficacy of azathioprine in the treatment of MS. This trial suffers from two major design issues - lack of blinding, and lack of validated treatment outcome measures. The significance of the findings is unclear. This study does not provide data regarding individual patient improvement.
| Exclusion: None specified | Duration of study treatment/follow up: 2 yr | Dropouts: 27 before completing 1 yr; 17 more before completing 2 yr | | | 2) No azathioprine (n = 68) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 115 completed 1 yr (53 intermittent, 52 intermittent-progressive, 10 progressive); 98 completed 2 yr (47 intermittent, 43 intermittent-progressive, 8 progressive) | | | | Proportion of patients with “improvement”: Not assessed | | | | Described as “randomized”? Yes
| | Location: 1 site in Hanover, Germany | Age: NR | | | | Other (non-improvement) outcomes: Patients were evaluated clinically and the severity of disease was calculated by means of an objective weighting scale corresponding to the data recorded by the examiner. | | | | Method of randomization clearly described? Yes
| | | Baseline EDSS: NR | | | | In the untreated group on average MS deteriorated three times as rapidly as in the treated group. | | | | Concealment of allocation? No
| | | Baseline relapse rate: NR | | | | 2) Relapse frequency: | | | | Described as “double-blind”? No
| | | | | | | Definition of “relapse”: Definite worsening of condition lasting for 24 hr or more, or the occurrence or recurrence of symptoms and signs after a period of 4 wk in which these had either disappeared or improved | | | | Patients blinded? No
| | | | | | | Definition of “improvement”: Not defined | | | | Investigators blinded? No
| | | | | | | Proportion of patients with “improvement”: Not delineated | | | | Outcome assessors blinded? No
| | | | | | | Other (non-improvement) outcomes: | | | | No of withdrawals in each group stated? Yes
| | | | | | | No. of relapses:
| | | | | | | Azathioprine: 2.4 ± 2.0
| | | | | | | Control: 1.9 ± 1.3
PRISMS Study Group and the University of British Columbia MS/MRI Analysis Group, 1998 and Liu and Blumhardt, 1999 and Liu and Blumhardt, 2002 and Patten and Metz, 2001 | Inclusion: Clinically definite or laboratory-supported definite MS of at least 1 yr duration; relapsing-remitting MS with ≥ 2 relapses in preceding 2 yr and EDSS score 0–5.0; adult | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 560 | | | 1) Interferon β-1a (IFNβ-1a) by SC injection, 44 μg (12 MIU), 3 times weekly (n = 184) | 1) Physical functioning: | | | | This study provides significant data regarding the benefit of treatment over placebo with regard to relapse rate and EDSS outcome measures. These data are reported as group improvement and no data are provided on individual patient improvement from baseline status.
| Exclusion: Any previous systemic treatment with interferons, lymphoid irradiation, or cyclophosphamide; other immunomodulatory or immunosuppressive treatment in previous 12 mo | Duration of study treatment/follow up: 2 yr | Lost to follow up: 27 | | | 2) IFNβ-1a by SC injection, 22 μg (6 MIU), 3 times weekly (n = 189) | Definition of “improvement”: In the categorical disability trend analysis sustained improvement was defined as a decrease of at least 1.0 EDSS point confirmed at 3 months and sustained until the end of the study | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Withdrew from treatment: 31 | | | 3) Placebo (n = 187) | Proportion of patients with “improvement”: Not stated - in the categorical disability trend analysis data were not reported on the number of patients with sustained improvement. 31% of treated patients and 20% of placebo patients attained stable course. | | | | Described as “randomized”? Yes
| | Location: 22 sites in Canada, Australia, and 7 European countries | Followed up to 2 yr: 533 | | | | Other (non-improvement) outcomes: 22-mcg dose and 44-mcg dose patients both had mean reduction in EDSS compared with placebo of 0.25 | | | | Method of randomization clearly described? Yes
| | | Completed treatment to 2 yr: 502 | | | | 2-yr change in EDSS: | | | | Concealment of allocation? Yes
| | | Age (median with IQR): | | | | | Mean | AUC | | Described as “double-blind”? Yes
| | | IFNβ-1a 44 μg: 35.6 (28.4–41.0) | | | | Placebo | +0.48 | +0.48 | | Patients blinded? Yes
| | | IFNβ-1a 22 μg: 34.8 (29.3–39.8) | | | | 22-mcg dose | +0.23 | +0.05 | | Investigators blinded? Yes
| | | Placebo: 34.6 (28.8–40.4) | | | | 44-mcg dose | +0.24 | +0.06 | | Outcome assessors blinded? Yes
| | | Baseline EDSS (mean ± SD): | | | | 2) Relapse frequency (primary outcome measure): | | | | No. of withdrawals in each group stated? Yes
| | | IFNβ-1a 44 μg: 2.5 ± 1.3 | | | | Definition of “relapse”: As defined by Schumacher criteria, required the appearance of a new symptom or worsening of an old symptom over at least 24 hr that could be attributed to MS activity and was preceded by stability or improvement for at least 30 days
| | | IFNβ-1a 22 μg: 2.5 ± 1.2 | | | | Definition of “improvement”: Proportion of patients with “improvement”: - Not stated
| | | Placebo: 2.4 ± 1.2 | | | | Other (non-improvement) outcomes:
| | | Baseline relapse rate (mean relapses in previous 2 yr [± SD]: | | | | Relapses per patient:
| | | IFNβ-1a 44 μg: 3.0 ± 1.1 | | | | Placebo - 2.56
| | | IFNβ-1a 22 μg: 3.0 ± 1.1 | | | | 22 mcg dose - 1.82
| | | Placebo: 3.0 ± 1.3 | | | | 44 mcg dose - 1.73
| | | | | | | % reduction in relapses vs. placebo:
| | | | | | | 22 mcg dose - 29
| | | | | | | 44 mcg dose - 32
| | | | | | | % relapse free over 1 year:
| | | | | | | Placebo - 22
| | | | | | | 22 mcg dose - 37
| | | | | | | 44 mcg dose - 45
| | | | | | | % relapse free over 2 years:
| | | | | | | Placebo - 16
| | | | | | | 22 mcg dose - 27
| | | | | | | 44 mcg dose - 32
| | | | | | | Moderate or severe relapses - % with no relapses:
| | | | | | | Placebo - 42
| | | | | | | 22 mcg dose - 61
| | | | | | | 44 mcg dose - 62
| | | | | | | % with no admissions for MS:
| | | | | | | Placebo - 75
| | | | | | | 22 mcg dose - 77
| | | | | | | 44 mcg dose - 82
| | | | | | | 3) Cognitive functioning [describe scale/ instrument used]:
| | | | | | | Definition of “improvement”: Not assessed
| | | | | | | Proportion of patients with “improvement”: Not assessed
| | | | | | | 5) Quality of life: Center for Epidemiological Studies Depression Rating Scale was used to assess whether treatment with IFNβ-1a was associated with depression
| | | | | | | Other (non-improvement) outcomes: Proportion of patients exceeding cut-point did not vary significantly across treatment groups
Rice, Filippi, and Comi, 2000 | Inclusion: Clinically definite or laboratory-supported MS according to Schumacher or Poser criteria; chronic progressive disease course (slow progression of signs and symptoms over preceding 12 mo); EDSS 3.0–6.5; serum creatinine < 1.5 mg/dL and creatinine clearance ≥ 80% of age-adjusted normal; aspartate and alanine transaminase and alkaline phosphatase levels < twice the normal upper limit; neutrophil count > 1600/μL; platelet count > 130,000/μL; clinically normal ECG and chest X-ray; age 21–60 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 159 (111 secondary progressive, 48 primary progressive) | | | 1) Cladribine by SC injection, 6 monthly courses of 0.07 mg/kg/day for 5 consecutive days (total dose 2.1 mg/kg), followed by 2 monthly courses of placebo (n = 52) | 1) Physical functioning: | | | | This study evaluated two different doses of cladribine and found no statistically significant difference in clinical outcomes. No data are provided regarding individual patient improvement.
| Exclusion: Significant history of medical disease in previous 2 yr; use of corticosteroids or other immunosuppressants in previous 3 mo; total lymphoid irradiation; persistent leukopenia or thrombocytopenia after treatment with immunosuppressive agents; alcohol or drug abuse or attempted suicide in previous 1 yr; malignancy in previous 5 yr; pregnancy or nursing; HIV+; use of experimental drug or device in last 60 days; previous participation in cladribine trial | Duration of study treatment/follow up: 12 mo | Dropouts: 4 | | | 2) Cladribine by SC injection, 2 monthly courses of 0.07 mg/kg/day for 5 consecutive days (total dose 0.7 mg/kg), followed by 6 monthly courses of placebo (n = 53) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (presumably neurologists) | Completed: 155 | | | 3) Placebo, 8 monthly courses (n = 54) | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 6 sites in Canada and the US | Age (mean): | | | | Other (non-improvement) outcomes: Primary outcome measure was mean change in EDSS - no statistical difference in treatment groups observed | | | | Method of randomization clearly described? Yes
| | | High-dose: 43.8 | | | | 2) Relapse frequency: | | | | Concealment of allocation? Yes
| | | Low-dose: 44.6 | | | | Definition of “relapse”: Not assessed | | | | Described as “double-blind”? Yes
| | | Placebo: 44.2 | | | | Definition of “improvement”: Not delineated | | | | Patients blinded? Yes
| | | Baseline EDSS (mean): | | | | Proportion of patients with “improvement”: Not assessed | | | | Investigators blinded? Yes
| | | High-dose: 5.6 | | | | | | | | Outcome assessors blinded? Yes
| | | Low-dose: 5.6 | | | | | | | | No. of withdrawals in each group stated? No - 97% of all patients completed the study
| | | Placebo: 5.6
| | | Baseline relapse rate: NR
Romine, Sipe, Koziol, et al., 1999 | Inclusion: Clinically definite relapsing-remitting MS for at least 1 yr; ≥ 2 relapses in previous 2 yr; EDSS ≤ 6.5 | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 52 | | | 1) Cladribine by SC injection; 5 consecutive daily injections of 0.07 mg/kg/day given monthly for 6 mo for total cumulative dose of 2.1 mg/kg; during remaining 2 mo of 8-mo treatment period, placebo given unless investigators had had to substitute placebo for a monthly dose earlier due to blood count inadequacy, in which case active drug could be given during mo 7 or 8 (n = 27) | 1) Physical functioning: | | | | This study evaluated the efficacy of cladribine compared with placebo in patients with relapsing-remitting MS. No statistical difference was found with regard to EDSS scores. A modest benefit was found in favor of cladribine with regard to relapse rate and severity. The data were not evaluated with regard to clinical improvement of individual patients.
| Exclusion: Treatment with immunosuppressive drugs in previous 3 mo; serum creatinine > 1.5 mg/dL; serum glutamic-oxaloacetic transaminase/serum glutamic-pyruvic transaminase or alkaline phosphatase elevated to twice the upper limit of normal; neutrophil counts of < 1600/μL or platelet counts < 130,000/μL; previous total lymphoid irradiation or extensive myelosuppressive chemotherapy | Duration of study treatment/follow up: Treatment lasted 8 mo; patients followed for total of 18 mo | Dropouts: 2 before 12 mo, plus 6 more before 18 mo | | | 2) Placebo (n = 25) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 50 to 12 mo, 44 to 18 mo | | | | Proportion of patients with “improvement”: Not assessed | | | | Described as “randomized”? Yes
| | Location: 1 site in La Jolla, CA | Age (mean, with range): | | | | Other (non-improvement) outcomes: | | | | Method of randomization clearly described? Yes
| | | Cladribine: 43.4 (30–52) | | | | No significant differences between the two groups with regard to EDSS or SNRS scores over the 18-mo period | | | | Concealment of allocation? Yes
| | | Placebo: 39.8 (31–52) | | | | 2) Relapse frequency: | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean, with range): | | | | Definition of “relapse”: Appearance of new symptoms or worsening of an existing symptom, attributable to MS and accompanied by objective worsening of neurological findings and must have been preceded by disease stability or improvement lasting for at least 30 days, and the worsening must have lasted at least 24 hours and occur in the absence of fever | | | | Patients blinded? Yes
| | | Cladribine: 3.9 (2.0–6.5) | | | | Definition of “improvement”: Not defined | | | | Investigators blinded? Yes
| | | Placebo: 3.8 (2.0–6.5) | | | | Proportion of patients with “improvement”: Not delineated | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (number in previous 1 yr): | | | | Other (non-improvement) outcomes: | | | | No. of withdrawals in each group stated? Yes
| | | Cladribine: | | | | Relapse rate:
| | | 1: 5 (19%) | | | | Cladribine - 0.77 (95% CI, 0.37 to 1.41)
| | | 2: 16 (59%) | | | | Placebo - 1.67 (95% CI, 1.02 to 2.57)
| | | 3–4: 6 (22%)
| | | Placebo:
| | | 1: 13 (52%)
| | | 2: 5 (20%)
| | | 3–4: 7 (28%)
Schwartz, Coulthard-Morris, Cole, et al., 1997 | Inclusion: Relapsing-remitting MS | RCT (see under “Comments”) | No. of patients randomized: NR | | | 1) Recombinant interferon β-1b (IFNβ-1b); dose, route of administration, and treatment regimen not described (n = 34) | 1) Physical functioning: Not assessed | | | | As recognized by the authors, the small sample size may have precluded the finding of statistical significance on some of the other measures of cognitive function
| Exclusion: None specified | Duration of study treatment/follow up: 1 yr | Dropouts: NR | | | 2) Usual care (n = 45) | 2) Relapse frequency: Not assessed | | | | Study design was retrospective, taking advantage of random allocation of IFNβ-1b in a treatment lottery; however, control condition was not standardized, and follow-up data were collected by survey and thus were subject to respondent bias
| | Provider specialty: NR | Completed: 79 | | | | 3) Cognitive functioning: Multiple scales used as below | | | | QUALITY ASSESSMENT:
| | Location: NR; patients had applied to lottery to gain access to experimental drug | Age (mean): | | | | Definition of “improvement”: Improvement was defined as population mean change | | | | Described as “randomized”? No
| | | IFNβ-1b: 43.9 | | | | Proportion of patients with “improvement”: Not assessed | | | | Method of randomization clearly described? No
| | | Control: 43.3 | | | | Other (non-improvement) outcomes: | | | | Concealment of allocation? No
| | | Baseline EDSS: NR | | | | Wechsler Memory Scale delayed visual recall demonstrated improvement in the high-dose group compared with placebo (p < 0.003). Other measures failed to reach statistical significance. Individual patient data and percentage of patients improving not reported. | | | | Described as “double-blind”? No
| | | Baseline relapse rate: NR | | | | | | | | Patients blinded? No
| | | | | | | | | | | Investigators blinded? No
| | | | | | | | | | | Outcome assessors blinded? No
| | | | | | | | | | | No. of withdrawals in each group stated? Yes
Sipe, Romine, Koziol, et al., 1994 | Inclusion: Clinically definite or laboratory-supported definite chronic progressive MS for more than 2 yr | RCT (designed as 2-yr crossover trial, but analyzed as parallel-group trial after 1 yr; double-blind [examining physicians and patients, not treating physicians], single-center, matched-pair design) | No. of patients randomized: 51 (49 initially entered + 2 replacements for dropouts) | | | Central venous access device surgically implanted in all patients for study drug administration | 1) Physical functioning: | | | | This study examined the effect of cladribine therapy in patients with progressive MS and found a statistically significant benefit to cladribine therapy with regard to group differences in progression as measured by EDSS and SNRS. No data are presented with regard to improvement of individual patients.
| Exclusion: Serum creatinine ≥ 132 μmol/L or creatinine clearance < 80% of age-adjusted normal; serum transaminases or hepatic alkaline phosphatase more than twice the upper limit of normal; neutrophil count < 1600 μL or platelet count < 130,000/μL; inadequate birth control; plans to father a child during study; treatment with corticosteroids or other immunosuppressive medications in previous 6 mo; decreased marrow reserve as manifested by leukopenia or thrombocytopenia for > 6 wk after conclusion of immunosuppressive treatment | Duration of study treatment/follow up: 1 yr | Dropouts: 3 cladribine patients (2 of whom were replaced), 1 placebo patient (included in analyses) | | | 1) Cladribine administered by continuous 7-day IV infusion at the rate of 0.1 mg/kg daily; total of 4 monthly courses given (n = 24) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 47 (48 analyzed) | | | 2) Placebo infusion (n = 24) | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 1 site in La Jolla, CA | Age (mean, with range): | | | | Other (non-improvement) outcomes: | | | | Method of randomization clearly described? Yes
| | | Cladribine: 43.0 (28–53) | | | | Paired differences in the two groups were significant in favor of cladribine: | | | | Concealment of allocation? Yes
| | | Placebo: 42.7 (21–54) | | | | | EDSS | SNRS | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean ± SE): | | | | Cladribine | 4.4 ± 2.0 | 74.8 ± 10.3 | | Patients blinded? Yes
| | | Cladribine: 4.7 ± 0.3 | | | | Placebo | 5.6 ± 1.5 | 62.6 ± 11.3 | | Investigators blinded? Yes
| | | Placebo: 4.6 ± 0.3 | | | | P-value | p < 0.01 | p < 0.001 | | Outcome assessors blinded? Yes
| | | Baseline relapse rate: NRs | | | | 2) Relapse frequency: | | | | No. of withdrawals in each group stated? Yes
| | | | | | | Definition of “relapse”: Not defined
| | | | | | | Definition of “improvement”: Not defined
| | | | | | | Proportion of patients with “improvement”: Not assessed
| | | | | | | Other (non-improvement) outcomes: None
SPECTRIMS Study Group, 2001 | Inclusion: Clinically definite secondary progressive MS (defined as progressive deterioration of disability for ≥ 6 mo, with increase of ≥ 1 EDSS point over the last 2 yr [or 0.5 point between EDSS 6.0 and 6.5], with or without superimposed exacerbations, following an initial relapsing-remitting course); EDSS 3.0–6.5; pyramidal functional score ≥ 2; age 18–55 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 618 | | | 1) Interferon β-1a (IFNβ-1a) 44 µg by SC injection three times weekly for 3 yr (n = 204) | 1) Physical functioning: | | | | This study examined the benefit of IFNβ-1a in the treatment of secondary progressive MS. There was no significant treatment effect on the primary outcome measure of time to confirmed progression. Significant benefits were demonstrated with regard to relapse rates. No data on improvement with regard to individual patients.
| Exclusion: Immunosuppressive or immunomodulatory treatments during previous 3–12 mo (depending on drug); corticosteroid use or disease exacerbation in previous 8 wk; severe concurrent illness; pregnancy or lactation; unwillingness to use contraception | Duration of study treatment/follow up: 3 yr | Dropouts: 112 withdrew from treatment; 65 of these were followed up for 3 yr | | | 2) IFNβ-1a 22 µg by SC injection three times weekly for 3 yr (n = 209) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 506 completed treatment; 571 were followed up for 3 yr | | | 3) Placebo (n = 205) | Proportion of patients with “improvement”: Not delineated | | | | Described as “randomized”? Yes
| | Location: 22 sites in Europe, Canada, and Australia | Age (mean ± SD): | | | | Other (non-improvement) outcomes: | | | | Method of randomization clearly described? Yes
| | | IFNβ-1a 44: 42.6 ± 7.3 | | | | The primary outcome, time to sustained progression, revealed no statistically significant difference among treatment arms. | | | | Concealment of allocation? Yes
| | | IFNβ-1a 22: 43.1 ± 7.2 | | | | 2) Relapse frequency: | | | | Described as “double-blind”? Yes
| | | Placebo: 42.7 ± 6.8 | | | | Definition of “relapse”: Appearance of a new symptom or worsening of an old symptom attributable to MS, accompanied by an appropriate new neurologic abnormality or focal neurologic dysfunction lasting at least 24 hours in the absence of fever and preceded by stability or improvement for at least 30 days | | | | Patients blinded? Yes
| | | Baseline EDSS (mean ± SD): IFNβ-la 44: 5.3 ± 1.1 | | | | Definition of “improvement”: Not defined | | | | Investigators blinded? Yes
| | | IFNβ-1a 22: 5.5 ± 1.1 | | | | Proportion of patients with “improvement”: Not delineated | | | | Outcome assessors blinded? Yes
| | | Placebo: 5.4 ± 1.1 | | | | Other (non-improvement) outcomes: | | | | No. of withdrawals in each group stated? Yes
| | | Baseline relapse rate (mean ± SD in previous 2 yr): | | | | Mean annual relapse rate:
| | | IFNβ-la 44 0.9 ± 1.3 | | | | IFN 22 mcg | Placebo | IFN 44 mcg
| | | IFNβ-la 22 0.9± 1.3 | | | | 0.50 | 0.71 | 0.50
| | | Placebo: 0.9± 1.2 | | | | | p < 0.001 | p < 0.001
van de Wyngaert, Beguin, D'Hooghe, et al., 2001 | Inclusion: Definite clinical diagnosis of MS by Poser criteria; relapsing, secondary progressive disease course; at least partial recovery from last relapse at least 1 mo before study entry; EDSS 3.0–6.0; worsening of EDSS by 1 point in previous 12 mo; effective birth control; normal isotopic cardiac ventriculography and routine blood analysis at entry; age 18–50 | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 49 | | | 1) Mitoxantrone (MTX) 12 mg/m^2^ initially given intravenously over one hour once per month for 3 mo; then given once every 3 mo, 10 times, until month 32; each treatment preceded by IV administration of 3 vials of alizapride (anti-emetic) (n = 28) | 1) Physical functioning: | | | | This study examined the effectiveness of cladribine in relapsing, secondary progressive MS. The study demonstrated a non-significant trend in favor of cladribine with regard to the number of patients who improved. The precise definition of improvement was not given. The small sample size may have contributed to the lack of statistical significance.
| Exclusion: Remittent disease course, primary progressive disease, or secondary progressive disease without relapses; major illness other than MS or immunosuppressive drugs other than corticosteroids in previous 3 yr | Duration of study treatment/follow up: Treatment lasted 32 mo; patients followed up for an additional 4 mo | Dropouts: 25 | | | 2) Methylprednisolone (MP) 1 g initially given intravenously over one hour between 8 and 10 a.m. once per month for 3 mo; then given once every 3 mo, 10 times, until month 32 (n = 21) | Definition of “improvement”: Not defined | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 24 | | | | Proportion of patients with “improvement”: | | | | Described as “randomized”? Yes
| | Location: 1 site in Belgium | Age (mean ± SD): | | | | 35% of patients receiving MTX improved clinically compared with 22% receiving placebo - difference not statistically significant | | | | Method of randomization clearly described? No
| | | MTX: 38.3 ± 6.9 | | | | Other (non-improvement) outcomes: | | | | Concealment of allocation? Unclear
| | | MP: 39.2 ± 7.8 | | | | 2) Relapse frequency: | | | | Described as “double-blind”? Yes
| | | Baseline EDSS (mean, with range): | | | | Definition of “relapse”: Not defined | | | | Patients blinded? Unclear
| | | MTX: 5.1 (3.0–6.0) | | | | Definition of “improvement”: Not defined | | | | Investigators blinded? Yes
| | | MP: 5.0 (3.0–6.0) | | | | Proportion of patients with “improvement”: Not delineated | | | | Outcome assessors blinded? Yes
| | | Baseline relapse rate (mean in previous 12 mo ± SD): | | | | Other (non-improvement) outcomes: | | | | No. of withdrawals in each group stated? Yes
| | | MTX: 2.3 ± 1.0 | | | | Mean number of relapses/patient/year was significantly lower in the MTX group after 2 and 3 years of treatment (p = 0.016 and 0.029, respectively)
| | | MP: 2.2 ± 1.2

Evidence Table 3b. Symptom management and improvement

Study | Selected Inclusion/ Exclusion Criteria | Study Design | Patients | Interventions | Outcomes/Results | | | | | | Comments/Quality Scoring
Bass, Wein-shenker, Rice, et al., 1988 and Rice, 1989 | Inclusion: Clinically definite MS; spasticity interfered with activities of daily living; spasticity stable for ≥ 2 mo | RCT (crossover, double-blind, single-center) | No. of patients randomized: 66 | 1) Tizanidine PO initiated at dose of 2 mg on the first day and 6 mg daily for the next three days; then increased by 6 mg every four days to a maximum of 32 mg/day (increased until spasticity controlled, AEs intolerable, or maximum dose reached); maintenance dose taken for 5 wk; tapered withdrawal during wk 9 of treatment | 1) Symptom-specific functional status/ quality-of-life outcomes: Muscle strength (7-point ordinal scale); muscle tone (6-point ordinal scale) | | | | | | Non-standard instruments used for assessing spasticity; much of data not shown
| Exclusion: None specified | Duration of study treatment/follow up: 9 wk with each treatment, 22 wk total (2-wk run-in, two 9-wk treatment periods, 2-wk washout) | Dropouts: 4 excluded for protocol violations/ non-compliance; 14 more failed to complete both treatment periods | 2) Baclofen PO initiated at dose of 5 mg on the first day and 15 mg daily for the next three days; then increased by 15 mg every four days to a maximum of 80 mg/day (increased until spasticity controlled, AEs intolerable, or maximum dose reached); maintenance dose taken for 5 wk; tapered withdrawal during wk 9 of treatment | Definition of “improvement”: ≥ 1-point change from baseline in right or left side | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists and physiotherapists | Completed: 48 completed both treatment periods and were analyzed (MS diagnoses NR; of 62 not excluded for protocol violations/ non-compliance, 1 was “remitting” at entry, 19 were “progressive,” and 42 were “stable”) | 2-wk washout period between treatments (in addition to 1-wk tapered withdrawal) | Proportion of patients with “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 1 site in London, Ontario, Canada | Age (mean, with range; n = 62 not excluded for protocol violations/ non-compliance): 51.1 (30–74) | | Similar percentages of patients improved, remained the same, and worsened on tizanidine compared to baclofen (p = NS) | | | | | | Method of randomization clearly described? No
| | | Baseline | | Other (non-improvement) outcomes: NR | | | | | | Concealment of allocation? Unclear
| | | EDSS: NR | | 2) Physical functioning (EDSS): | | | | | | Described as “double-blind”? Yes
| | | | | Definition of “improvement”: Decrease of ≥ 1 point from baseline | | | | | | Patients blinded? Yes
| | | | | Proportion of patients with “improvement”: | | | | | | Investigators blinded? Yes
| | | | | Tizanidine | 9/48 (18%) | | | | | Outcome assessors blinded? Yes
| | | | | Baclofen | 6/48 (12%) (P = NS) | | | | | No. of withdrawals in each group stated? Yes
| | | | | Other (non-improvement) outcomes: NR | | | | | | Crossover trials only:
| | | | | 3) Cognitive functioning: NR | | | | | | Period or carry-over effects? Not discussed
| | | | | 4) Work or employment outcomes: NR | | | | | | Washout period? Yes (2 weeks)
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | No. of patients in each sequence clearly described? No
| | | | | 6) Adverse events: | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | Tizanidine (daytime somnolence, insomnia, xerostomia) 46% required dosage reduction; 4 withdrew (weakness)
| | | | | Baclofen (muscle weakness) 61% required dosage reduction; 7 withdrew (weakness)
Brar, Smith, Nelson, et al., 1991 | Inclusion: Clinically definite MS; EDSS ≤ 5.5; clinically stable for past 3 mo; mild to moderate spasticity in one or both lower extremities; age 24–54 | RCT (crossover, partially double-blind, single-center) | No. of patients randomized: 38 | 1) Baclofen alone; titrated according to a predetermined schedule of 5-mg increments or decrements every day for 5 days to maximum of 20 mg/day; maximum dose then maintained for seven days | 1) Symptom-specific functional status/ quality-of-life outcomes: Quadriceps hypertonicity; muscle tone (Ashworth scale); self-rated questionnaire of functional abilities | | | | | | QUALITY ASSESSMENT:
| Exclusion: Systemic disorders; impaired mentation; previous intolerance to baclofen | Duration of study treatment/follow up: 10 wk total: 2 wk each with baclofen, stretching, and combination; 4 wk with placebo (after each period involving baclo-fen; included tapering of baclofen) | Dropouts: 8 | 2) Stretching exercises + placebo; exercise instruction given by physical therapist; program included stretches for hamstrings, quadri-ceps, adductor, and plantarflexor muscles | Definition of “improvement”: Not given | | | | | | Described as “randomized”? Yes
| | Provider specialty: Neurologists and physical therapists | Completed: 30 | 3) Stretching exercises (as above) + baclofen (as above) | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Denver, CO | Age: NR | 4) Placebo alone | Ashworth | Improved | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS: NR | Placebo periods followed each period in which baclofen was used and included a period for tapering off baclofen | Baclofen | 9 (30%) | | | | | Described as “double-blind”? Yes
| | | | | Stretch | 5 (17%) | | | | | Patients blinded? No (only to baclofen vs. placebo)
| | | | | Comb | 12 (40%); p=0.10 v placebo | | | | | Investigators blinded? No (only to baclofen vs. placebo)
| | | | | Placebo | 6 (20%) | | | | | Outcome assessors blinded? Unclear
| | | | | | 100-yd Walk | Stair climb | Household activities | | | No. of withdrawals in each group stated? No
| | | | | Baclofen | 10% | 20% | 17% | | | Crossover trials only:
| | | | | Stretch | 30% | 7% | 23% | | | Period or carry-over effects? Not discussed
| | | | | Comb | 10% | 23% | 23% | | | Washout period? No
| | | | | Placebo | 17% | 13% | 20% | | | No. of patients in each sequence clearly described? No
| | | | | Other (non-improvement) outcomes: | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | Quadriceps spasticity was significantly improved after both baclofen and combination treatment when compared to placebo (p < 0.05)
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: None reported
Canadian MS Research Group, 1987 | Inclusion: At least 6-mo history of definite MS according to Schumacher criteria; ≥ 3-mo history of chronic, persistent, moderate to severe, daily fatigue (confirmed during 2-wk run-in) | RCT (crossover, double-blind, multicenter) | No. of patients randomized: 115 (57 relapsing-remitting, 33 relapsing-progressing, 22 chronic progressing, 3 benign) | 1) Amantadine PO 100 mg twice per day for 3 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: VAS fatigue score | | | | | | QUALITY ASSESSMENT:
| Exclusion: Pregnancy; hypersensitivity to amantadine; CHF or peripheral edema; hepatic or renal impairment; epilepsy; history of depression or other psychiatric disorders; acute anemia; thyroid disorders; diabetes; gastric or duodenal ulcers; alcohol or drug abuse | Duration of study treatment/follow up: 3 wk with each treatment, 10 wk total (2-wk placebo run-in, two 3-wk treatment periods, 2-wk placebo washout) | Dropouts: 6 | 2) Placebo for 3 wk | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (presumably neurologists) | Completed: 109 | 2-wk placebo washout period between treatments | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? Yes
| | Location: 11 sites in Canada | Excluded from all analyses: 2 (protocol violations) | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Excluded from some analyses: 21 (discovered post-randomization to have had insufficient baseline fatigue) | | Change in VAS fatigue score baseline to end: | | | | | | Described as “double-blind”? Yes
| | | “Efficacy-analyzable” population: 86 (41 relapsing-remitting, 28 relapsing-progressing, 15 chronic progressing, 2 benign) | | Amantadine: 29 to 25 (23 to 26), -4.3 mm Placebo: 30 to 27 (25 to 29), -2.6 mm | | | | | | Patients blinded? Yes
| | | Age (mean ± SE; n = 86): 40.1 ± 1.0 | | p = NS | | | | | | Investigators blinded? Unclear
| | | Baseline EDSS (mean ± SE; n = 86): 4.3 ± 0.2 | | 2) Physical functioning: most affected activity VAS; effect on activities of daily living total score | | | | | | Outcome assessors blinded? Unclear
| | | | | Definition of “improvement”: None | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Proportion of patients with “improvement”: NA | | | | | | Crossover trials only:
| | | | | Other (non-improvement) outcomes: | | | | | | Period or carry-over effects? Yes
| | | | | Most affected activity VAS favored amantadine p < 0.05 | | | | | | Washout period? Yes (2 wk)
| | | | | ADL total score amantadine 27 (SE 1.13) baseline to 24 (SE 1.06) end, change of -2.5 compared to placebo 26 (SE 0.74) baseline to 26 (SE 0.74) end; change of -0.3 (p = 0.09) | | | | | | No. of patients in each sequence clearly described? No
| | | | | 3) Cognitive functioning: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Unclear
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | 66/115 (57%) reported AEs on amantadine; 62/115 (54%) reported AEs on placebo; 1 dropout for acute confusional state on amantadine
Cartlidge, Hudgson, and Weightman, 1974 | Inclusion: Spasticity; Ashworth score of 3–4 in at least one lower limb | RCT (crossover, double-blind, single-center) | No. of patients randomized: 40 (34 MS “in remission but with severe residual neurological deficits,” 2 hereditary spastic paraplegia, 1 spondylotic myelopathy, 1 traumatic paraplegia) | 1) Baclofen PO 30 mg per day for 2 wk, then 60 mg per day for 2 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: Spasticity score (Ashworth scale) | | | | | | Adverse events at high dose levels resulted in high dropout rate
| Exclusion: None specified | Duration of study treatment/follow up: 4 wk with each treatment, 9 wk total (two 4-wk treatment periods, 1-wk washout) | Dropouts: 3 | 2) Diazepam PO 15 mg per day for 2 wk, then 30 mg per day for 2 wk | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 37 | 1-wk washout between treatment periods | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | Location: Newcastle, UK | Age (range): 22–61 | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR | | Low-dose | Baclofen | Diazepam | | | | Concealment of allocation? No
| | | | | N | 37 | 37 | | | | Described as “double-blind”? Yes
| | | | | Before/after | 2.87/2.38 | 2.87/2.16 | | | | Patients blinded? Yes
| | | | | Change (SE) | 0.49 (0.163) | 0.71 (0.159) | | | | Investigators blinded? Yes
| | | | | p-value | < 0.01 | < 0.001 | | | | Outcome assessors blinded? Yes
| | | | | High-dose | | | | | | No. of withdrawals in each group stated? Yes
| | | | | N | 26 | 23 | | | | Crossover trials only:
| | | | | Change (SE) | 1.31 (0.227) | 1.13 (0.202) | | | | Period or carry-over effects? No
| | | | | p-value | < 0.001 | < 0.001 | | | | Washout period? Yes (1 wk)
| | | | | No differences between baclofen and diazepam. No period effect or treatment-period interaction | | | | | | No. of patients in each sequence clearly described? Yes
| | | | | 2) Physical functioning: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? No
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | Daytime sedation, weakness, gustatory disturbances (loss of taste and smell)
| | | | | 11 withdrew on high-dose baclofen
| | | | | 14 withdrew on high-dose diazepam
Cohen and Fisher, 1989 | Inclusion: Definite or probable MS according to Poser criteria; diagnosis established at least 6 mo prior to study entry; daily symptomatic fatigue for ≥ 3 mo | RCT (crossover, double-blind, single-center) | No. of patients randomized: 29 (16 benign or relapsing-remitting, 13 chronic-deteriorating or relapsing-deteriorating) | 1) Amantadine PO 100 mg twice per day for 4 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: Fatigue (daily ratings; point scale 1–5) | | | | | | QUALITY ASSESSMENT:
| Exclusion: EDSS > 6; moderate or major depression on Beck Depression Inventory; pregnancy; CHF; renal or hepatic impairment; epilepsy; anemia; thyroid disorders; diabetes; active gastric or duodenal ulcer; psychiatric disorder; alcohol or drug abuse; current use of stimulants, sedative-hypnotics, anti-depressants, major tranquilizers, beta-blockers, immuno-suppressants, or steroids | Duration of study treatment/follow up: 4 wk with each treatment, 10 wk total (two 4-wk treatment periods, 2-wk washout) | Dropouts: 7 | 2) Placebo for 4 wk | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR | Completed: 22 | 2-wk washout between treatment periods | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Worcester, MA | Age (mean ± SD): 44.5 ± 9.3 | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS (mean ± SD, n = 22 completers): 4.0 ± 1.4 | | Amantadine mean fatigue score 3.2 ± 0.04 SE versus placebo 3.0 ± 0.03 SE (p = 0.58) | | | | | | Described as “double-blind”? Yes
| | | | | 2) Physical functioning: NR | | | | | | Patients blinded? Unclear
| | | | | 3) Cognitive functioning: NR | | | | | | Investigators blinded? Unclear
| | | | | 4) Work or employment outcomes: NR | | | | | | Outcome assessors blinded? Unclear
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | No. of withdrawals in each group stated? Yes
| | | | | 6) Adverse events: | | | | | | Crossover trials only:
| | | | | 4 amantadine and 4 placebo patients reported AEs. At least 1 amantadine-treated patient withdrew due to nausea and anxiety; 1 placebo patient with constipation may have withdrawn. | | | | | | Period or carry-over effects? No
| | | | | | | | | | | Washout period? Yes (2 wk)
| | | | | | | | | | | No. of patients in each sequence clearly described? No
| | | | | | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
Crawford and McIvor, 1985 | Inclusion: Primary diagnosis of MS; mental status optimal or only mildly to moderately deficient | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 32 | 1) Traditional, insight-oriented group psychotherapy (IOT; n = NR); two 1-hr sessions per wk for approximately 6 mo (50 sessions total) | 1) Symptom-specific functional status/ quality-of-life outcomes: | | | | | | Little assessment of the clinical importance of changes observed in psychological scales
| Exclusion: None specified | Duration of study treatment/follow up: 6 mo | Dropouts: NR | 2) Current events discussion group (CE, active control; n = NR); two 1-hr sessions per wk for approximately 6 mo (50 sessions total) | 2) Physical functioning: NR | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (presumably psychologists) | Completed: NR | 3) No treatment (n = NR) | 3) Cognitive functioning: MMPI Depression-30 Scale (D-30); Anxiety Scale Questionnaire (ASQ); Internal-External Control Scale (IECS); Rosenberg Self-Esteem Scale (SES) | | | | | | Described as “randomized”? Yes
| | Location: 1 site in New York, NY | Age: Mean, 47.25; range, 20–63 | | Definition of “improvement”: None | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR; patients described as “moderately to severely disabled physically” | | Proportion of patients with “improvement”: NA | | | | | | Concealment of allocation? Unclear
| | | | | Other (non-improvement) outcomes: | | | | | | Described as “double-blind”? No
| | | | | | IOT | CE | Control | p-value | | Patients blinded? No
| | | | | D-30 | 19.3 | 23.5 | 23.5 | 0.025 | | Investigators blinded? No
| | | | | IECS | 28.3 | 30.7 | 37 | 0.005 | | Outcome assessors blinded? No
| | | | | ASQ | NR | NR | NR | NS | | No. of withdrawals in each group stated? No
| | | | | SES | NR | NR | NR | NS
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Cutter, Scott, Johnson, et al., 2000 | Inclusion: Laboratory-supported diagnosis of chronic progressive MS (MRI and/or CSF); clinical evidence of spasticity; veteran eligible for care at study site (Denver VAMC); age 18–85 | RCT (crossover, double-blind, single-center) | No. of patients randomized: 22 | 1) Gabapentin PO; 300 mg three times per day for 2 days, then 600 mg three times per day for 2 days, finally 900 mg three times per day for 2 days (n = 22) | 1) Symptom-specific functional status/ quality-of-life outcomes: Spasm frequency scale; spasm severity scale, interference with function scale, painful spasm scale, global assessment scale | | | | | | Some impact on spasticity measures, but none on EDSS
| Exclusion: Lack of clinically significant spasticity; inability to travel to study site for evaluations; potential to become pregnant during study; significant renal dysfunction | Duration of study treatment/follow up: 26 days (6 days treatment with each intervention + 14-day washout period) | Dropouts: 1 | 2) Placebo (n = 22) | Definition of “improvement”: | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR | Completed: 21 | 14-day washout between treatment periods | Spasm frequency - no spasms | | | | | | Described as “randomized”? Yes
| | Location: Denver, CO (1 site) | Age: Range, 34–67 | | Interference with function - not defined | | | | | | Method of randomization clearly described? No
| | | Baseline | | Global assessment - not defined | | | | | | Concealment of allocation? Unclear
| | | EDSS: Range, 6.0–9.0 | | Proportion of patients with “improvement”: | | | | | | Described as “double-blind”? Yes
| | | | | Spasm frequency (p = 0.0001) | | | | | | Patients blinded? Yes
| | | | | | Gabapentin | | Placebo | | | Investigators blinded? Yes
| | | | | | ≤B/l | Post | B/l | Post | | Outcome assessors blinded? Yes
| | | | | None | 0 (0%) | 6 (28%) | 0 (0%) | 0 (0%) | | No. of withdrawals in each group stated? Yes
| | | | | Mild | 5 (24%) | 12 (57%) | 5 (24%) | 7 (33%) | | Crossover trials only:
| | | | | Mod | 11 (52%) | 2 (9%) | 11 (52%) | 12 (57%) | | Period or carry-over effects? No
| | | | | Sev | 5 (24%) | 1 (5%) | 5 (24%) | 2 (9%) | | Washout period? Yes (14 days)
| | | | | Interference with function (p = 0.02) | | | | | | No. of patients in each sequence clearly described? Yes
| | | | | | Gabapentin | | Placebo | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | | B/l | Post | B/l | Post
| | | | | None | 2 (9%) | 10 (48%) | 4 (19%) | 4 (19%)
| | | | | Difficult | 13 (62%) | 10 (48%) | 11 (52%) | 12 (57%)
| | | | | Imposs | 6 (29%) | 1(5%) | 6 (29%) | 5 (24%)
| | | | | Global assessment (p = 0.003)
| | | | | | Gabapentin | Placebo
| | | | | | Post | Post
| | | | | Lot better | 11 (52%) | 1 (5%)
| | | | | Little better | 4 (19%) | 4 (19%)
| | | | | Unchanged | 6 (27%) | 12 (57%)
| | | | | Worse | 0 (0%) | 4 (19%)
| | | | | Other (non-improvement) outcomes:
| | | | | Modified Ashworth Scale (p = 0.0005)
| | | | | 2) Physical functioning (EDSS):
| | | | | Definition of “improvement”:
| | | | | Proportion of patients with “improvement”:
| | | | | “No significant change in…EDSS with either gabapentin or placebo?
| | | | | Other (non-improvement) outcomes:
| | | | | 3) Cognitive functioning:
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | Digit Span, Digit Symbol, adjective generation technique
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: Falls in 2 patients, 1 gabapentin, 1 placebo
Eyssette, Rohmer, Serratrice, et al., 1988 | Inclusion: Chronic spasticity due to MS; age 18–70 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 100 | 1) Tizanidine (n = 50); initiated at 2 mg three times per day; daily dose then increased, if tolerated, by 2 mg every 2 days for first 2 wk, up to maximum dose of 24 mg/day; maximum dose then taken for 6 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: Muscle tone (5-point scale); flexor spasms, clonus, strength, locomotor function | | | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Duration of study treatment/follow up: Treatment lasted 8 wk; preceded by 3-day run-in | Dropouts: 14 | 2) Baclofen (n = 50); initiated at 5 mg three times per day; daily dose then increased, if tolerated, by 5 mg every 2 days for first 2 wk, up to maximum dose of 60 mg/day; maximum dose then taken for 6 wk | Definition of “improvement”: Flexor spasms & muscle tone - none described; clonus - no longer detectable | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (presumably neurologists) | Completed: 86 | | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? No
| | Location: 6 sites in France | Age (mean ± SE): | | Flexor spasms | 2 wk | 8 wk | | | | Concealment of allocation? Unclear
| | | Tizanidine: 46.8 ± 1.6 | | Tizanidine (n = 36) | 47% | 55% | | | | Described as “double-blind”? Yes
| | | Baclofen: 47.5 ± 1.7 | | Baclofen (n = 33) | 48% | 43% | | | | Patients blinded? Yes
| | | Baseline EDSS: NR | | P = NS | | | | | | Investigators blinded? Yes
| | | (60/100 patients were bedridden at entry) | | Muscle tone by muscle group improved in between 40% to 67% of patients; no statistically significant difference between tizanidine and baclofen for any muscle group or time point | | | | | | Outcome assessors blinded? Yes
| | | | | Clonus | 2 wk | 8 wk | | | | No. of withdrawals in each group stated? Yes
| | | | | Tizanidine | 8/35 (23%) | 8/28 (29%)
| | | | | Baclofen | 8/30 (27%) | 6/28 21%)
| | | | | Other (non-improvement) outcomes:
| | | | | In ambulatory patients (40/100) there was no significant change in walking distance for tizanidine or baclofen
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | Tizanidine: daytime drowsiness (n = 15), dry mouth (n = 14), fatigue (n = 8), orthostatic hypotension (n = 6), and insomnia (n = 7).
| | | | | Discontinued in 6: daytime drowsiness (n = 2); weakness and drowsiness (n = 2), syncope (n = 1) and bradycardia (n = 1).
| | | | | Baclofen (daytime drowsiness (n = 10), fatigue (n = 12), muscular weakness (n = 10), disturbances of affect (n = 9), and vomiting (n = 8). Discontinued in 4: rash (n = 1), vomiting (n = 1), disturbed affect (n = 1), and muscular weakness and syncope (n = 1).
Feldman, Kelly-Hayes, Conomy, et al., 1978 | Inclusion: Adults with an established diagnosis of MS; spontaneous flexor contractions or spasticity for ≥ 3 mo; free of infections, peripheral vascular disease, contrac-tures, advanced arthritis, or other conditions that might hinder evaluation of joint movement | RCT (crossover, double-blind, single-center) | No. of patients randomized: 33 | 1) Baclofen; initiated at 5 mg three times per day for 3 days; increases then made at intervals not less than 3 days up to a maximum dose of 80 mg/day (or less if AEs occurred or maximum benefit achieved at lower dose) | 1) Symptom-specific functional status/ quality-of-life outcomes (spasm frequency, clonus [knee], resistance to passive movement, functional assessment): | | | | | | QUALITY ASSESSMENT:
| Exclusion: Women of childbearing age; patients with bleeding tendencies, GI disease, or liver and renal impairment | Duration of study treatment/follow up: 4 wk with each treatment; 10 wk total (1-wk placebo run-in, two 4-wk treatment periods, 1-wk placebo washout) | Dropouts: 10 | 2) Placebo (with dose adjustments as above) | Definition of “improvement”: Not defined | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR | Completed: 23 | 1-wk placebo washout between treatment periods | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? No
| | Location: Boston, MA | Age: Mean, 43; range, 38–53 | | | ROM exercies | Spasm frequency | | | | Concealment of allocation? Unclear
| | | Baseline EDSS: NR; disability said to have varied “from being ambulatory with a spastic gait to functional quadriplegia” | | Baclofen | 15/23 (65%) | 9/16 (56%) | | | | Described as “double-blind”? Yes
| | | | | Placebo | 4/23 (17%) | 1/16 (6%) | | | | Patients blinded? Yes
| | | | | | P < 0.05 | p < 0.05 | | | | Investigators blinded? Yes
| | | | | | Clonus | Barthel | | | | Outcome assessors blinded? Yes
| | | | | Baclofen | 12/15 (80%) | 8/16 (50%) | | | | No. of withdrawals in each group stated? No
| | | | | Placebo | 1/15 (7%) | 7/16 (46%) | | | | Crossover trials only:
| | | | | | P < 0.01 | p = NS | | | | Period or carry-over effects? Not discussed
| | | | | Other (non-improvement) outcomes: | | | | | | Washout period? Yes (1 wk)
| | | | | 2) Physical functioning: NR | | | | | | No. of patients in each sequence clearly described? No
| | | | | 3) Cognitive functioning: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Unclear
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | Dry mouth (baclofen n = 5; placebo n = 1). Also observed: drowsiness, dizziness, anorexia, nocturia and constipation.
Foley, Bedell, LaRocca, et al., 1987 | Inclusion: Confirmed diagnosis of MS; DSS ≥ 8; no major cognitive deficits | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 41 (type of MS not specified; 60% of patients were experiencing a relapse at start of trial, 58% at end) | 1) Stress inoculation therapy (SIT) (n = NR); combination of cognitive-behavioral therapy (focused on relieving affective distress and preventing maladaptive psycho-logical responses to stress) and rogress-sive muscle relaxation (shortened version); total of 6 sessions over 5 wk (length of individual session NR) | 1) Symptom-specific functional status/ quality-of-life outcomes (BDI; STAI-S; STAI-T; Hassles scale; PFC): | | | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Duration of study treatment/follow up: 5 wk (6-mo follow up included only 10 patients and only patients in experimental group) | Dropouts: 5 (missing data) | 2) Current available care (CAC) (n = NR); patients received a variety of psycho-therapeutic and medical interventions (including minimum of 2 hr of supportive psychotherapy) for 5 wk | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: Experimental group: Advanced clinical psychology graduate student, supervised by 2 licensed clinical psychologists | Completed: 36 | | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Control group: “Hospital staff who utilized standard methods in treating patients” | Age: Mean, 38.8 | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | Location: 1 site in Bronx, NY | Baseline DSS: Mean, 6; range, 1–8 | | MANOVA showed significant treatment effect for composite of all outcome measures (p < 0.002): | | | | | | Described as “double-blind”? No
| | | | | | SIT | CAC | p-value | | | Patients blinded? No
| | | | | BDI | 13.2 ± 10.5 | 21.6 ± 14.2 | < 0.05 | | | Investigators blinded? No
| | | | | STAI-S | 37.2 ± 13.8 | 50.5 ± 13.0 | < 0.05 | | | Outcome assessors blinded? No
| | | | | STAI-T | 46.2 ± 13.1 | 51.9 ± 13.4 | NS | | | No. of withdrawals in each group stated? No
| | | | | Hassles | 57.5 ± 37.6 | 89.2 ± 67.1 | < 0.05
| | | | | WCC | 16.2 ± 4.8 | 11.8 ± 4.6 | < 0.05
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Franca-bandera, Holland, Wiesel-Levison, et al., 1988 | Inclusion: Definite MS; followed at study site; EDSS 6.0–9.0; evidence of ability to benefit from rehabilitation (at least 3 specific rehabilitation goals); not institutionalized and able to return home after inpatient treatment; insurance or other resources to pay for inpatient or outpatient treatment | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 84 | 1) Inpatient rehabilitation (n = 42); daily physical (two 45-min sessions per day) and occupational therapy (1 session per day); bladder management, speech therapy, and social services provided as needed; equipment needs assessed and addressed; individual care plan for each patient; coordinated, multidisciplinary approach | 1) Symptom-specific functional status/ quality-of-life outcomes: Incapacity Status Scale (ISS) (part of Minimal Record of disability [16-item self-report inventory reflecting ambulation status and level of independence in self-care); need for home assistance (number of hours of assistance in ADLs) | | | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Duration of study treatment/follow up: 3 mo | Dropouts: 11 did not enter treatment or were lost to follow up | 2) Outpatient rehabilitation (n = 42); physical and occupational therapy; bladder management, speech therapy, and social services as needed; equipment needs assessed and addressed; treatment administered through community-based visiting nurse services or public health nurse services | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: Neurologists, physical therapists, occupational therapists, nurses | Completed: 73 | Treatment of both groups supervised by neurologist at study site | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Bronx, NY | Age: NR | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS: NR | | | Entry adjusted | 3-mo | 3-mo | p-value | | Described as “double-blind”? No
| | | | | ISS | | | | | | Patients blinded? No
| | | | | Inpt | 28± 9 | 26± 9.4 | 24.3 | < 0.05 | | Investigators blinded? No
| | | | | Opt | 24± 7.2 | 26± 8.5 | 27.2 | | | Outcome assessors blinded? No
| | | | | Assistance | | | | | | No. of withdrawals in each group stated? No
| | | | | Inpt | 62± 52 | 73± 62 | 76.9 | 0.17
| | | | | Opt | 71± 56 | 77± 56 | 73.1
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Fredrikson, 1996 | Inclusion: Clinically definite MS; increased daytime frequency of voiding/ incontinence episodes; had previously tested anticholinergic drugs with unsatisfactory effect on bladder symptoms | RCT (crossover, double-blind, single-center) | No. of patients randomized: 27 | 1) Desmopressin nasal spray 20 μg daily | 1) Symptom-specific functional status/ quality-of-life outcomes: Number of voidings and incontinence episodes (a) during 6 hr after drug intake, (b) during 24 hr | | | | | | QUALITY ASSESSMENT:
| Exclusion: Hyper-tension, coronary artery disease; diabetes; hepatic disease | Duration of study treatment/follow up: 2 wk with each treatment; 6 wk total (2-wk run-in, two 2-wk treatment periods, no washout) | Dropouts: 0 premature withdrawals; 1 patient excluded from analyses (appendectomy); 4 provided incomplete data for main outcome | 2) Placebo nasal spray | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (presumably neurologists) | Completed: 22 included in analysis of main outcome | No washout between treatment periods | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Huddinge, Sweden | Age: Mean, 51; range, 24–69 | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS: NR | | Voidings | Mean ± SD | | | | | Described as “double-blind”? Yes
| | | | | | 6 hr | 24 hr | | | | Patients blinded? Yes
| | | | | Baseline | 3.1± 1.0 | 10.7± 2.5 | | | | Investigators blinded? Yes
| | | | | Placebo | 3.1± 1.0 | 8.6± 2.3 | | | | Outcome assessors blinded? Yes
| | | | | Desmopressin | 2.6± 1.0 | 8.4± 2.6 | | | | No. of withdrawals in each group stated? Yes
| | | | | p-value | < 0.05 | NS | | | | Crossover trials only:
| | | | | 2) Physical functioning: NR | | | | | | Period or carry-over effects? Not discussed
| | | | | 3) Cognitive functioning: NR | | | | | | Washout period? No
| | | | | 4) Work or employment outcomes: NR | | | | | | No. of patients in each sequence clearly described? No
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | 6) Adverse events: NR
Freeman, Langdon, Hobart, et al., 1997 | Inclusion: Clinically or laboratory-supported definite MS; in progressive phase of the disease as established by neurologist; considered appropriate for inpatient rehabilitation | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 70 | 1) Comprehensive, short-term (mean, 20 days; range, 17–31), inpatient rehabilitation program; not described in detail, but said to involve multi-disciplinary team approach, interventions tailored to individual's needs, and patient-centered functional goal-setting approach (n = 32) | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | No difference was shown between treatment and control groups for those who were walking (p = 0.38), but there was a significant difference among wheelchair users (p = 0.03)
| Exclusion: Current or recent (within 1 mo) relapse; use of steroids in previous mo; required urgent admission on clinical grounds; other diseases; cognitive impairment such that unable to give informed consent | Duration of study treatment/follow up: Active treatment lasted average of 20 days; patients followed for total of 6 wk | Dropouts: 4 | 2) Wait-list control (n = 34) | 2) Physical functioning (EDSS): | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Multi-disciplinary team | Completed: 66 (60 secondary progressive, 6 primary progressive) | | Definition of “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 1 site in London, UK | Age (mean ± SD; n = 66 completers): | | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? Yes
| | | Rehab: 43.2 ± 10.8 | | EDSS - No statistically significant difference between the two groups in … EDSS change scores (p = 0.42)…“with change scores clustering closely around zero” | | | | | | Concealment of allocation? No
| | | Wait-list: 44.6 ± 9.7 | | FIM motor scores - 72% of people in the treatment group improved their overall level of disability, 3% stayed the same, and 25% deteriorated. In contrast, 29% of people in the control group improved their overall level of disability, 9% stayed the same, and 62% deteriorated (p < 0.001) | | | | | | Described as “double-blind”? No
| | | Baseline EDSS (median, with range): | | Other (non-improvement) outcomes: | | | | | | Patients blinded? No
| | | Rehab: 6.5 (5.0–9.0) | | LHS - 53% of the treatment group improved their total handicap score, 3% remained the same, and 44% deteriorated. In contrast 23% of the control group improved, 12% stayed the same, and 65% deteriorated (p = 0.01) | | | | | | Investigators blinded? No
| | | Wait-list: 6.5 (6.0–8.5) | | 3) Cognitive functioning: NR | | | | | | Outcome assessors blinded? No
| | | | | 4) Work or employment outcomes: NR | | | | | | No. of withdrawals in each group stated? Yes
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
From and Heltberg, 1975 | Inclusion: Spasticity due to MS; inpatients | RCT (crossover, double-blind, single-center) | No. of patients randomized: 17 | 1) Baclofen PO 10-mg tablets; dose titrated to optimal level during first 2 wk, then continued for 2 wk; mean optimal dose, 61.2 mg (range, 30–120 mg) | 1) Symptom-specific functional status/ quality-of-life outcomes (flexor spasm, clonus): | | | | | | No significant differences between baclofen and diazepam
| Exclusion: None specified | Duration of study treatment/follow up: 4 wk with each treatment, 10 wk total (two 4-wk treatment periods, 1-wk washout, 1-wk follow up) | Dropouts: 1 | 2) Diazepam PO 5-mg tablets; dose titrated to optimal level during first 2 wk, then continued for 2 wk; mean optimal dose, 26.8 mg (range, 10–40 mg) | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 16 | 1-wk washout between treatment periods | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Copenhagen, Denmark | Age: Mean, 51; range, 38–68 | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR; only 2 patients had significant walking ability | | | Baclofen | Diazepam | | | | Concealment of allocation? Unclear
| | | | | Flexor spasm | 10/12 (83%) 12/14 (86%) | | | | | Described as “double-blind”? Yes
| | | | | Clonus | 16/26 (62%) 18/28 (64%) | | | | | Patients blinded? Yes
| | | | | 2) Physical functioning: NR | | | | | | Investigators blinded? Yes
| | | | | 3) Cognitive functioning: NR | | | | | | Outcome assessors blinded? Yes
| | | | | 4) Work or employment outcomes: NR | | | | | | No. of withdrawals in each group stated? Yes
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Crossover trials only:
| | | | | 6) Adverse events: | | | | | | Period or carry-over effects? Not discussed
| | | | | Baclofen 8 (sedation [n = 5], weakness, depression, nausea) | | | | | | Washout period? Yes (1 wk)
| | | | | Diazepam 12 (sedation [n = 11], weakness) | | | | | | No. of patients in each sequence clearly described? Yes
| | | | | One patient discontinued treatment with baclofen due to AE (sedation). | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Unclear
Gambi, Rossini, Calenda, et al., 1983 | Inclusion: Spinal spasticity | RCT (crossover, double-blind, single-center) | No. of patients randomized: 24 (12 MS, 12 degenerative myelopathies) | 1) Dantrolene sodium PO; initiated at 25 mg twice per day and increased by slow weekly increments until therapeutic goal achieved (maximum dose permitted = 350 mg per day); treatment lasted 5 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | Few data shown
| Exclusion: None specified | Duration of study treatment/follow up: 5 wk with each treatment, 13 wk total (2-wk run-in, two 5-wk treatment periods, 1-wk washout) | Dropouts: 2 (both MS) | 2) Placebo, with dose adjustments as above, for 5 wk | 2) Physical functioning: | | | | | | Small study, especially when MS subgroup considered separately
| | Provider specialty: NR (presumably neurologists) | Completed: 22 (10 MS, 12 degenerative myelopathies) | 1-wk washout between treatment period | Hip flexor movement (degrees); degree of spasticity (6-point scale); muscular strength (6-point scale); clonus (6-point scale); knee and ankle tendon reflexes (6-point scale) | | | | | | QUALITY ASSESSMENT:
| | Location: 1 site in Milan, Italy | Age (mean ± SE, MS patients only): 38.2 ± 2 | | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | | Baseline EDSS: NR | | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? No
| | | | | Change in hip flexor movement (degrees) | | | | | | Described as “double-blind”? Yes
| | | | | | Dantrolene | Placebo | p-value | | | Patients blinded? Yes
| | | | | Left hip | 8.5± 3.7 | 1.5± 3.9 | NS | | | Investigators blinded? Yes
| | | | | Right hip | 9.5± 2.7 | -1± 2.9 | NS | | | Outcome assessors blinded? Yes
| | | | | No influence on knee joint movements | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Dantrolene reduced spasticity of both lower limbs (p < 0.05; data not shown) | | | | | | Crossover trials only:
| | | | | No significant difference for muscular strength, clonus and tendon reflexes (data not shown) | | | | | | Period or carry-over effects? Not discussed
| | | | | 3) Cognitive functioning: NR | | | | | | Washout period? Yes (1 wk)
| | | | | 4) Work or employment outcomes: NR | | | | | | No. of patients in each sequence clearly described? No
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Unclear
| | | | | 6) Adverse events:
| | | | | 13/24 (59%) reported AEs (headache drowsiness, nausea, vomiting, gastric pain, malaise, muscular weakness).
| | | | | 2/24 (9%) on dantrolene and 3/24 (14%) on placebo withdrew due to AEs.
Geisler, Sliwinski, Coyle, et al., 1996 | Inclusion: Clinically or laboratory-supported definite MS according to Poser criteria; severe fatigue (Fatigue Severity Scale score ≥ 4.0); ambulatory; EDSS ≤ 6.5; age 18–50 | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 45 (38 relapsing-remitting, 7 chronic progressive) | 1) Amantadine PO 100 mg twice daily for 6 wk (n = 16) | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | Study patients were subgroup of the patients examined in Krupp, Coyle, Doscher, et al., 1995, below
| Exclusion: EDSS > 6.5; severe depression (score > 35 on Center for Epidemiologic Studies Depression Scale); severe dementia (score < 15 on Mini-Mental State Examination); current or recent (within 2 mo) MS relapse; current or recent (within 2 mo) use of fatigue-producing medication (e.g., tricyclic anti-depressants, benzodiazepines) | Duration of study treatment/follow up: 6 wk treatment, 10 wk total (2-wk run-in, 6 wk treatment, 2 wk follow up) | Dropouts: NR (implied 0) | 2) Pemoline PO 18.75 mg, once daily for 1st wk, twice daily for 2nd wk, then three times per day during weeks 3–6 (n = 13) | 2) Physical functioning: NR | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: NR (implied 45) | 3) Placebo (double-dummy technique used) (n = 16) | 3) Cognitive functioning: Attention (Digit Span, Trail Making Test, Symbol Digit Modalities Test); verbal memory (Selective Reminding Test); nonverbal memory (Benton Visual Retention Test), and motor speed (Finger Tapping Test) | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Stony Brook, NY | Age (mean ± SD): | | Definition of “improvement”: None | | | | | | Method of randomization clearly described? No
| | | Amantadine: 40 ± 6.4 | | Proportion of patients with “improvement”: NA | | | | | | Concealment of allocation? Unclear
| | | Pemoline: 41 ± 6.2 | | Other (non-improvement) outcomes: | | | | | | Described as “double-blind”? Yes
| | | Placebo: 40 ± 5.6 | | All three treatment groups showed significant improvement on cognitive measures; however, only written SDMT (a measure of attention and visual search) showed a significant difference between treatment groups, with amantadine-treated group showing the greatest improvement. For other measures, the change scores were nearly identical between groups with no significant differences between the active drug groups and the placebo group. | | | | | | Patients blinded? Yes
| | | Baseline EDSS (mean ± SD): | | 4) Work or employment outcomes: NR | | | | | | Investigators blinded? Yes
| | | Amantadine: 3.1 ± 2.1 | | 5) Generic quality-of-life outcomes: NR | | | | | | Outcome assessors blinded? Yes
| | | Pemoline: 2.6 ± 0.9 | | 6) Adverse events: NR | | | | | | No. of withdrawals in each group stated? Yes
| | | Placebo: 2.2 ± 1.7
Gillson, Richards, Smith, et al., 2002 | Inclusion: Diagnosis of MS confirmed by neurologist exam and the presence of CNS sclerotic lesions on MRI; EDSS 5.0–6.5; Modified Fatigue Impact Scale (MFIS) score > 40; no relapse in previous 3 mo; age ≥ 18 | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 29 (10 relapsing-remitting, 16 secondary progressive, 3 primary progressive; significant difference between treatment groups at baseline) | 1) Transdermal cream containing histamine diphosphate 1.65 mg + caffeine citrate 100 mg per 0.2 mL (Prokarin^™^); applied twice per day using a skin patch (n = 22) | 1) Symptom-specific functional status/ quality-of-life outcomes: Modified Fatigue Impact Scale (MFIS); timed walk test (25-foot); 9-hole peg test | | | | | | Authors point out that baseline differences showed more relapsing-remitting patients in the Prokarin^™^ group
| Exclusion: Current or previous use of study drug; current use of antispasmodic agents, cortico-steroids, chemo-therapeutic agents, MAOIs, or histamine blockers; started antidepressants, interferons, or glatiramer acetate in past 3 mo; serious renal, hepatic, endocrine, cardiac, or pulmonary disease | Duration of study treatment/follow up: 12 wk | Dropouts: 3 | 2) Placebo cream | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR | Completed: 26 | (n = 7) | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Seattle, WA | Age: Mean, 47.4 | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR | | MFIS Week | 0 | 4 | 8 | 12 | p-value within group | Concealment of allocation? Unclear
| | | | | PK | 58±8.9 | 38± 18 | 38± 16 | 37± 15 | < 0.001 | Patients blinded? Yes
| | | | | Pl | 61±7.5 | NR | NR | 53± 11 | NS | Investigators blinded? Yes
| | | | | p-value (between-group) | < 0.02 | | | | | Outcome assessors blinded? Yes
| | | | | No significant differences between the Prokarin^™^ group and the placebo group for secondary endpoints (25-foot timed walk, 9-hole peg test) | | | | | | No. of withdrawals in each group stated? Yes
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: Paced Auditory Serial Additions Test (PASAT)
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes: No significant differences between the Prokarin^™^ group and the placebo group for PASAT
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: All AEs observed were mild - specific AEs included skin irritation, itching, and headache
Hauser, Doolittle, Lopez-Bresnahan, et al., 1992 | Inclusion: Clinically definite MS of either inactive (relapsing-remitting MS that had been clinically stable for > 2 yr) or very slowly progressive (chronic MS without change for ≥ 1 yr as assessed by Ambulation Index and EDSS) form; spasticity or spontaneous flexor spasms sufficient in degree to interfere with functional activities for ≥ 3 mo; ambulatory, with EDSS ≥ 6 and Ambulation Index ≤ 5; reasonable functional use of arms; good general health; age 18–55 | RCT (crossover, double-blind, single-center) | No. of patients randomized: 26 | 1) Threonine (naturally occurring amino acid), 5 capsules three times per day for a total daily dose of 7.5 mg for 8 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: Ashworth Scale; Clinician Spasticity Scale (upper extremity muscle tone, lower extremity muscle tone, reflexes and spontaneous flexor spasms each graded improved [+1]/same[0]/worse [-1] then summed); Patient Spasticity Scale | | | | | | QUALITY ASSESSMENT:
| Exclusion: Cancer or serious underlying medical illness; advanced arthritis, contractures, or other conditions hindering evaluation of joint movement; use of psychoactive drugs; antispasticity treatment within previous 1 mo; use of chemotherapeutic agents within previous 6 mo | Duration of study treatment/follow up: 8 wk each treatment, 18 wk total (two 8-wk treatment periods, 2-wk washout) | Dropouts: 5 | 2) Placebo for 8 wk | Definition of “improvement”: Not described | | | | | | Described as “randomized”? Yes
| | Provider specialty: Neurologists | Completed: 21 | 2-wk washout between treatment periods | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? Yes
| | Location: 1 site in Boston, MA | Age (mean ± SE): 41 ± 6.5 | Patients also instructed to consume “a standard 75-g protein diet” during the study | Spasticity | Clinician Scale | Patient Scale | | | | Concealment of allocation? Yes
| | | Baseline EDSS (mean ± SE): | | Threonine | 11/21 (52%) | 8/21 (38%) | | | | Described as “double-blind”? Yes
| | | 4.7 ± 1.5 | | Placebo | 5/21 (24%) | 4/21 (19%) | | | | Patients blinded? Yes
| | | | | p-value | 0.04 | 0.18 | | | | Investigators blinded? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | Outcome assessors blinded? Yes
| | | | | 2) Physical functioning: EDSS; Ambulation Index | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Definition of “improvement”: | | | | | | Crossover trials only:
| | | | | Proportion of patients with “improvement”: | | | | | | Period or carry-over effects? No
| | | | | Other (non-improvement) outcomes: | | | | | | Washout period? Yes (2 wk)
| | | | | 3) Cognitive functioning: NR | | | | | | No. of patients in each sequence clearly described? No
| | | | | 4) Work or employment outcomes: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? No
| | | | | 5) Generic quality-of-life utcomes: NR
| | | | | 6) Adverse events: None reported
Hilton, Hertogs, and Stanton, 1983 | Inclusion: Women with MS who complained of nocturia (waking to void on two or more occasions each night) | RCT (crossover, double-blind, single-center) | No. of patients randomized: 16 | 1) Desmopressin nasal spray 20 μg daily at bedtime | 1) Symptom-specific functional status/ quality-of-life outcomes: Subjective benefit in nocturia | | | | | | Treatment duration not described; apparently no washout period and no analysis reported for period or carry-over effects
| Exclusion: History of impaired renal function, ischemic heart disease, hypertension, or urinary infection | Duration of study treatment/follow up: NR (1-wk run-in, but length of treatment not specified) | Dropouts: 0 | 2) Placebo nasal spray at bedtime | Definition of “improvement”: Not described | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: OB/GYNs | Completed: 16 | No washout period described | Proportion of patients with “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 1 site in London, UK | Age: NR | | Desmopressin | 9/16 (56%) | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR | | Placebo | 1/16 (6%) | | | | | Concealment of allocation? Unclear
| | | | | P = 0.008 | | | | | | Described as “double-blind”? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | Patients blinded? Yes
| | | | | | | | | | | Investigators blinded? Yes
| | | | | Urinary freq | Desmopressin | Placebo | p-value | | | Outcome assessors blinded? Yes
| | | | | Daytime | 8.7± 3.4 | 8.6± 2.5 | ns | | | No. of withdrawals in each group stated? Yes
| | | | | Nighttime | 1.3± 1.0 | 2.0± 0.9 | < 0.001 | | | Crossover trials only:
| | | | | 2) Physical functioning: NR | | | | | | Period or carry-over effects? Not discussed
| | | | | 3) Cognitive functioning: NR | | | | | | Washout period? No
| | | | | 4) Work or employment outcomes: NR | | | | | | No. of patients in each sequence clearly described? Yes
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? No (no dropouts)
| | | | | 6) Adverse events:
| | | | | Headache (n = 3), nasal congestion (n = 1)
| | | | | No patients stopped treatment due to AEs
Hoog-straten, van der Ploeg, Burg, et al., 1988 | Inclusion: Spasticity due to MS; spasticity stable for ≥ 2 mo; EDSS 4–7 | RCT (crossover, open label [only assessors of selected outcomes were blinded], single-center) | No. of patients randomized: 16 | 1) Tizanidine PO; dose titrated to optimal level (range, 12–24 mg daily) over first 2–3 wk, then continued for 4 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | Small study
| Exclusion: Severe cardiac insufficiency; marked hypertension (DBP > 110 mmHg); severe hypotension; chronic alcoholism; history of mental illness; pretreatment with diazepam or dantrolene | Duration of study treatment/follow up: 6–7 wk with each treatment, 13.5–15.5 wk+ total (two 6- to 7-wk treatment periods, 1.5-wk+ washout period) | Dropouts: 5 | 2) Baclofen PO; dose titrated to optimal level (range, 15–60 mg daily) over first 2–3 wk, then continued for 4 wk | 2) Physical functioning: Spasticity (7-point scale); spasms (7-point scale); mobility (7-point scale) | | | | | | Unclear relationship between primary measures (spasticity, spasms, mobility) and variable analyzed (overall efficacy)
| | Provider specialty: NR (presumably neurologists) | Completed: 11 | Washout between treatment periods: taper off of study meds over 1–2 wk, followed by drug-free period of at least 3 days | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Location: 1 site in Groningen, The Netherlands | Age (mean ± SD): 54.9 ± 8.3 | | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | | Baseline EDSS (mean ± SD): 6.1 ± 0.8 | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | | | Data not provided for spasticity. | | | | | | Concealment of allocation? Unclear
| | | | | Overall efficacy variable showed no significant difference whether completers of both periods analyzed as cross-over (n = 11) or first-period only data (n = 14) analyzed. | | | | | | Described as “double-blind”? No
| | | | | 3) Cognitive functioning: NR | | | | | | Patients blinded? No
| | | | | 4) Work or employment outcomes: NR | | | | | | Investigators blinded? No
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Outcome assessors blinded? Yes
| | | | | 6) Adverse events: | | | | | | No. of withdrawals in each group stated? Yes
| | | | | AEs reported on baclofen (muscle weakness (n = 11), somnolence (n = 4), dry mouth, nausea (n = 3), urine incontinence (n = 3), dizziness) and on tizanidine (muscle weakness (n = 4), somnolence (n = 8), dry mouth (n = 5); flushed (n = 3); | | | | | | Crossover trials only:
| | | | | Severe AEs on baclofen (muscle weakness (n = 6); nausea (n = 1)) and tizanidine (somnolence (n = 1), depression (n = 1)) | | | | | | Period or carry-over effects? No
| | | | | 3 patients discontinued treatment due to AEs on baclofen | | | | | | Washout period? Yes (1–2 wk+)
| | | | | | | | | | | No. of patients in each sequence clearly described? Yes
| | | | | | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
Hoverd and Fowler, 1998 | Inclusion: MS and neurogenic bladder dysfunction (≥ 8 episodes of voiding per day); sufficient lower limb power to stand; cognitively unimpaired | RCT (crossover, double-blind, single-center) | No. of patients randomized: 28 | 1) Desmopressin nasal spray 20 μg at same time each day (between 8:00 AM and 2:00 PM) | 1) Symptom-specific functional status/ quality-of-life outcomes [describe scale/instrument used]: | | | | | | No washout period; no discussion of carry-over or period effects
| Exclusion: Diabetes; heart disease; hypertension; renal disease; use of diuretic therapy | Duration of study treatment/follow up: 2 wk with each treatment; 6 wk total (2-wk run-in, two 2-wk treatment periods, no washout) | Dropouts: 4 (3 before treatment started) | 2) Placebo nasal spray | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR | Completed: 24 | No washout between treatment periods | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | Location: 1 site in London, UK | Age: Mean, 43; range 18–65 | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR | | Urinary freq | Desmo pressin | Placebo | p-value | | | Concealment of allocation? Unclear
| | | | | Day (6 hr) | 2.4± 0.9 | 3.1± 1.4 | 0.008 | | | Described as “double-blind”? Yes
| | | | | Nighttime | 1.5± 1.2 | 1.4± 1.1 | 0.26 | | | Patients blinded? Yes
| | | | | Vol (6 hr) | 246± 99 | 342± 166 | 0.006 | | | Investigators blinded? Yes
| | | | | Vol (24 hr) | 1218± 455 | 1272 ± 482 | 0.052 | | | Outcome assessors blinded? Yes
| | | | | 2) Physical functioning: NR | | | | | | No. of withdrawals in each group stated? Yes
| | | | | 3) Cognitive functioning: NR | | | | | | Crossover trials only:
| | | | | 4) Work or employment outcomes: NR | | | | | | Period or carry-over effects? Not discussed
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Washout period? No
| | | | | 6) Adverse events: | | | | | | No. of patients in each sequence clearly described? No
| | | | | Hyponatremia, malaise, headache nausea (required withdrawal from desmopressin) | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
Hyman, Barnes, Bhakta, et al., 2000 | Inclusion: Definite or probable MS; disabling spasticity affecting the hip adductor muscles of both legs (EDSS ≥ 7), which had been stable for ≥ 6 mo and which caused moderate pain or difficulty in nursing (hygiene score ≥ 2); age ≥ 18 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 74 | 1) Botulinum toxin (Dysport®) IM 1500 units, one injection to hip adductor muscles of both legs (n = 17) | 1) Symptom-specific functional status/ quality-of-life outcomes: Hygeine assessment | | | | | | QUALITY ASSESSMENT:
| Exclusion: Acute exacerbation of MS; contracture of the hip; hypersensitivity to botulinum toxin; myasthenia gravis; other neuromuscular junction diseases; pregnant; pre-menopausal and unwilling to use contraception; recent treatment with botulinum toxin (4 mo), phenol injection (4 mo), intrathecal baclofen (14 days), or any investigational drug (3 mo) | Duration of study treatment/follow up: Single treatment; patients followed up for 12 wk | Dropouts: 14 | 2) Botulinum toxin IM 1000 units, one injection, as above (n = 20) | Definition of “improvement”: Overall investigator and patient opinion at end of study - excellent, good or fair on 5-point scale where lowest categories are poor, no benefit | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR | Completed: 60 | 3) Botulinum toxin IM 500 units, one injection, as above (n = 21) | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? No
| | Location: 8 sites in Europe (6 UK, 1 Germany, 1 Austria) | Age (mean ± SD): | 4) Placebo, one injection, as above (n = 16) | [underlined: Overall opinion] | | | | | | Concealment of allocation? Unclear
| | | BTX 1500: 46.8 ± 10.3 | | Outcome | Invest | Patient | | | | Described as “double-blind”? Yes
| | | BTX 1000: 54.0 ± 9.9 | | Placebo | 7(44%) | 7 (44%) | | | | Patients blinded? Yes
| | | BTX 500: 47.0 ± 12.2 | | BTX 500 | 14 (67%) | 13 (62%) | | | | Investigators blinded? Yes
| | | Placebo: 50.7 ± 10.9 | | BTX 1000 | 9 (48%) | 10 (53%) | | | | Outcome assessors blinded? Yes
| | | Baseline EDSS (median): | | BTX 1500 | 6 (36%) | 8 (47%) | | | | No. of withdrawals in each group stated? No
| | | BTX 1500: 7.50 | | Other (non-improvement) outcomes:
| | | BTX 1000: 7.50 | | Outcome | Hygiene assessment (median)
| | | BTX 500: 8.00 | | Placebo | 2.0
| | | Placebo: 7.75 | | BTX 500 | 2.0
| | | | | BTX 1000 | 1.0
| | | | | BTX 1500 | 1.0
| | | | | 2) Physical functioning: Passive hip abduction; active hip abduction; modified Ashworth score; spasm frequency
| | | | | Definition of “improvement”:
| | | | | Hip abduction - Not described
| | | | | Proportion of patients with “improvement”:
| | | | | Active
| | | | | Outcome | Hip abd
| | | | | Placebo | 2 (13%)
| | | | | BTX 500 | 1 (5%)
| | | | | BTX 1000 | 1 (6%)
| | | | | BTX 1500 | 2 (12%)
| | | | | Other (non-improvement) outcomes:
| | | | | [underlined: Hip abduction]
| | | | | | Passive Deg (SD) | Active possible (%)
| | | | | Placebo | 54 (20) | 4 (27)
| | | | | BTX 500 | 56 (25) | 5 (26)
| | | | | BX 1000 | 63 (24) | 5 (31)
| | | | | BTX 1500 | 61 (25) | 7 (41)
| | | | | p-value | NS | NS
| | | | | | Ashworth | Muscle | Spasm
| | | | | | Score Max | Tone Max | Frequency
| | | | | | (median) | n (%) | n (%)
| | | | | Placebo | 8.0 | 13 (87) | 3 (20)
| | | | | BTX 500 | 4.0 | 13 (68) | 3 (16)
| | | | | BTX 1000 | 12.0 | 13 (76) | 7 (41)
| | | | | BTX 1500 | 8.0 | 10 (59) | 4 (24)
| | | | | p-value | NS | NS | NS
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | AEs reported by 32/58 (55%) BTX; 10/16 (62%) placebo
| | | | | Hypertonia (22%), weakness of non-injected muscles (14%), fatigue (7%), UTI (5%), headache (5%), micturition frequency (5%). Back pain (5%), diarrhea (5%).
| | | | | Twice as many AEs reported by 1500 Unit group (mean 2.7/pt) compared with the 500 Unit group (mean 1.2/pt)
| | | | | Six patients had serious AEs;2 on BTX, 4 on placebo; none was believed to be drug related.
Killestein, Hooger-vorst, Reif, et al., 2002 | Inclusion: Progressive MS; disease duration > 1 yr; severe spasticity (mean Ashworth spasticity score ≥ 2 in at least one limb); EDSS 4–7.5 | RCT (crossover, double-blind, single-center) | No. of patients randomized: 16 (10 secondary progressive, 6 primary progressive) | 1) Synthetic delta-9-tetrahydrocannabinol (THC) PO; initiated at 2.5 mg twice daily for 2 wk; if well tolerated, then increased to 5 mg twice daily for 2 more wk | 1) Symptom-specific functional status/ quality-of-life outcomes: Multiple Sclerosis Functional Composite (MSFC) score; 9-hole Peg Test | | | | | | QUALITY ASSESSMENT:
| Exclusion: Other disease of clinical importance; use of other investigational drug; MS exacerbation; steroid treatment or use of cannabinoids in previous 2 mo; history of alcohol or drug abuse, depression, psychosis, or schizophrenia | Duration of study treatment/follow up: 4 wk with each treatment; 20 wk total (three 4-wk treatment periods and two 4-wk washouts) | Dropouts: 0 | 2) Cannabis sativa plant extract with delta-9-THC and cannabidiol PO; initiated at 2.5 mg twice daily for 2 wk; if well tolerated, then increased to 5 mg twice daily for 2 more wk | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (presumably neurologists) | Completed: 16 | 3) Placebo (with dose escalation after 2 wk, as above) | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Amsterdam, The Netherlands | Age (mean ± SD): 46 ± 7.9 | 4-wk washout between treatment periods | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS (mean ± SD): 6.2 ± 1.2 | | Compared to placebo, MSFC (p = 0.09) and 9-hole peg test (p = 0.02) scores were worse on delta-9-THC treatment | | | | | | Described as “double-blind”? Yes
| | | | | 2) Physical functioning: EDSS, muscle tone (Ashworth score) | | | | | | Patients blinded? Yes
| | | | | Definition of “improvement”: None | | | | | | Investigators blinded? Yes
| | | | | Proportion of patients with “improvement”: NA | | | | | | Outcome assessors blinded? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Compared with placebo, active treatment did not result in significant differences of muscle tone or EDSS score | | | | | | Crossover trials only:
| | | | | 3) Cognitive functioning: Fatigue Severity Scale (FSS) | | | | | | Period or carry-over effects? Not discussed
| | | | | Definition of “improvement”: None | | | | | | Washout period? Yes (4 wk)
| | | | | Proportion of patients with “improvement”: NA | | | | | | No. of patients in each sequence clearly described? No
| | | | | Other (non-improvement) outcomes: | | | | | | Were patients who did not complete all of the periods excluded from the analysis? No (no dropouts)
| | | | | No significant changes in FSS scores
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: SF-36
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | Mental Health subscale (p = 0.02) and Psychological status domain (p = 0.02) improved during delta-9-THC treatment.
| | | | | Other SF-36 data not given.
| | | | | 6) Adverse events:
| | | | | AEs more common during plant-extract treatment than placebo (p = 0.01). Increased spasticity (n = 5). One serious AE (brief acute psychosis).
Kinn and Larson, 1990 | Inclusion: MS for > 5 yr; advanced urgency and urinary leakage due to detrusor hyperreflexia; normal liver and renal function tests | RCT (crossover, double-blind, single-center) | No. of patients randomized: 13 | 1) Desmopressin PO at optimal daily dose (established during dose-titration phase) for 3 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: Micturition frequency within 6 hr | | | | | | QUALITY ASSESSMENT:
| Exclusion: Diabetes; heart disease; hypertension | Duration of study treatment/follow up: 3 wk with each treatment, no washout period; trial preceded by a 7-day run-in period and a 12-day desmopressin dose-titration phase (doses increased every 3 days from 0.1 mg to 0.2, 0.4, and 0.8 mg per day) | Dropouts: 1 | 2) Placebo for 3 wk | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: Urologists | Completed: 12 | No washout period described | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Malmö, Sweden | Age: Mean, 48; range, 28–68 | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS: NR | | Micturition frequency decreased significantly for desmopressin compared to run-in and placebo (p < 0.05) | | | | | | Described as “double-blind”? Yes
| | | | | No. of voidings in 24 hr did not show difference (p = NS) | | | | | | Patients blinded? Yes
| | | | | Urine volume in 6 hr lower for desmopressin than run-in and placebo (325 mL vs 440 mL; p < 0.05) | | | | | | Investigators blinded? Yes
| | | | | 2) Physical functioning: NR | | | | | | Outcome assessors blinded? Yes
| | | | | 3) Cognitive functioning: NR | | | | | | No. of withdrawals in each group stated? No
| | | | | 4) Work or employment outcomes: NR | | | | | | Crossover trials only:
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Period or carry-over effects? Not discussed
| | | | | 6) Adverse events: | | | | | | Washout period? No
| | | | | 1 withdrawal during run-in (on desmopressin) - tachycardia and pruritis | | | | | | No. of patients in each sequence clearly described? No
| | | | | | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Unclear
Krupp, Coyle, Doscher, et al., 1995 | Inclusion: Clinically or laboratory-supported definite MS; severe fatigue (Fatigue Severity Scale score ≥ 4.0), persisting as a problem after a 2-wk pre-trial monitoring phase; ambulatory; EDSS ≤ 6.0; age 18–52 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 119 | 1) Amantadine PO 100 mg twice daily for 6 wk (n = 31) | 1) Symptom-specific functional status/ quality-of-life outcomes: MS-FS; FSS | | | | | | QUALITY ASSESSMENT:
| Exclusion: Current or recent (within 2 mo) use of benzodiazepines, antidepressants, azathioprine, or cyclophosphamide; severe depression (score of ≥ 36 on the Center for Epidemiologic Studies Depression scale) | Duration of study treatment/follow up: 6 wk treatment, 10 wk total (2-wk run-in, 6 wk treatment, 2 wk follow up) | Dropouts: 26 | 2) Pemoline PO 18.75 mg, once daily for 1^st^ wk, twice daily for 2^nd^ wk, then three times per day during weeks 3–6 (n = 27) | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: Neurologists | Completed: 93 (83 relapsing-remitting) | 3) Placebo (double-dummy technique used) (n = 35) | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Location: 3 sites in metropolitan New York City area | Age (mean ± SD, n = 93 completers): | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Amantadine: 40.7 ± 7.1 | | MS-FS | Baseline | End | Change | | | Described as “double-blind”? Yes
| | | Pemoline: 40.2 ± 8.2 | | Aman | 4.9 ± 0.24 | 4.4 ± 0.29 | -0.5 | | | Patients blinded? Yes
| | | Placebo: 41.4 ± 5.9 | | Pemoline | 4.7 ± 0.20 | 4.7 ± 0.18 | -0.03 | | | Investigators blinded? Yes
| | | Baseline EDSS (mean ± SD; n = 93 completers): | | Placebo | 4.7 ± 0.14 | 4.7 ± 0.20 | 0.1 | | | Outcome assessors blinded? Unclear
| | | Amantadine: 2.7 ± 1.8 | | Aman vs. placebo; p = 0.04 | | | | | | No. of withdrawals in each group stated? Yes
| | | Pemoline: 3.1 ± 1.7 | | Pemoline vs. placebo; p = 0.394
| | | Placebo: 2.1 ± 1.2 | | FSS | Baseline | End | Change
| | | | | Aman | 5.6 ± 0.17 | 5.2 ± 0.22 | -0.45
| | | | | Pemoline | 5.7 ± 0.18 | 5.4 ± 0.27 | 0.3
| | | | | Placebo | 5.6 ± 0.15 | 5.4 ± 0.20 | -0.22
| | | | | Aman vs. placebo; p = NS
| | | | | Pemoline vs. placebo; p = 0.845
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | 5 AEs reported on amantadine (2 withdrawals for rash, anxiety); 6 AEs reported on pemoline (2 withdrawals for irritability, anxiety); 3 AEs reported on placebo (1 withdrawal due to sleep disturbance)
Larcombe and Wilson, 1984 | Inclusion: Diagnosis of MS by a neurologist; self-reported duration of depression ≥ 3 mo; no current or prior treatment with major tranquilizers or lithium; score of ≥ 20 on Beck Depression Inventory; definite or probable depression according to Feighner criteria; no other major psychological disorders; low suicide risk, as assessed by Beck criteria; score within normal range on revised version of the Paired Associate Learning sub-test of the Wechsler Memory Scale and on the Simpson Memory Pictures Test; age 20–65 | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 20 | 1) Cognitive-behavioral therapy (n = 9); weekly group sessions lasting 1.5 hr each for 6 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: BDI; HRSD; Significant-Other Rating; Best Mood; Worst Mood; Average Mood | | | | | | Differences between CBT and wait-list were not only statistically significant, but also clinically important at 1 mo. Longer follow up in CBT group only suggested benefits were maintained at least 2 mo, although these data were not controlled.
| Exclusion: None specified | Duration of study treatment/follow up: 6 wk treatment; 1-wk run-in and 1-wk post-treatment follow up | Dropouts: 1 | 2) Wait-list control (n = 10) | Definition of “improvement”: | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Psychologists | Completed: 19 | | Proportion of patients with “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Australia | Age (mean, with range, overall only): 42.5 (26–61) | | Subjects in the cognitive-behavioral therapy condition improved significantly more than subjects in the waiting list control condition on each of: | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR; 8 patients required wheelchair for mobility | | BDI p < 0.01 | | | | | | Concealment of allocation? Unclear
| | | | | 27± 5.6 to 8.1 ± 5 vs. 29 ± 8.7 to 33 ± 9.7 | | | | | | Described as “double-blind”? No
| | | | | Hamilton Rating Scale p < 0.01 | | | | | | Patients blinded? No
| | | | | 16± 5 to 2± 1.5 vs. 16.9± 6.4 to 17.4± 8.3 | | | | | | Investigators blinded? No
| | | | | Significant-Other Rating Scale p < 0.01 | | | | | | Outcome assessors blinded? Unclear
| | | | | 10.7 ± 4.4 to 5.9 ± 2.8 vs. 12 ± 2.7 to 11.7± 2.8 | | | | | | No. of withdrawals in each group stated? No
| | | | | Worst Mood Rating p < 0.05
| | | | | 25 ± 5.7 to 37 ± 6.5 vs. 20.9 ± 7.2 to 19.6 ± 5.4
| | | | | No significant effect for:
| | | | | Best Mood
| | | | | 39.8 ±7 to 44.4 ± 6.0 vs. 30.8 ± 8.0 to 30 ± 6.8
| | | | | Average Mood
| | | | | 34.7± 6.2 to 42.2 ± 5 vs. 27.3 ± 8.3 to 26.1± 5.8
| | | | | Other (non-improvement) outcomes:
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Lee and Patterson, 1993 | Inclusion: Spasticity and a clinical picture of predominant spinal cord involvement; increased lower extremity tone associated with upper motor neuron signs such as weakness, hyperreflexia, or extensor plantar responses; spasticity score (Ashworth Scale) ≥ 15 and stable over 4-wk run-in period | RCT (crossover, double-blind, single-center) | No. of patients randomized: 41? | 1) L-threonine PO 6 g per day (four 500-mg capsules 3 times per day on an empty stomach) for 2 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: Spasticity Score - sum of 6 highest scoring lower extremity muscle groups according to Ashworth Scale; Spasm score (not described); Barthel Index | | | | | | QUALITY ASSESSMENT:
| Exclusion: Suspicion of an extra-pyramidal contribution to their increased tone | Duration of study treatment/follow up: 2 wk with each treatment; 10 wk total (4-wk run-in, two 2-wk treatment periods, 2-wk washout) | Dropouts: 8 (4 during 4-wk run-in, 4 during treatment) | 2) Placebo for 2 wk | Definition of “improvement”: 10% reduction in Spasticity score | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (presumably neurologists) | Completed: 33 (26 MS, 5 spinal cord injury, 1 syringomyelia, and 1 spinal tumor) | 2-wk washout between treatment periods | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Belfast, Northern Ireland | Age (range; n = 33 completers): 17–70 | | Only a few patients reported a symptomatic benefit. 16/33 “responded” to L-threonine; 3/33 to placebo; 8 had no response to either treatment; 2 responded to both treatments; 4 dropped out. | | | | | | Concealment of allocation? Unclear
| | | Baseline DSS (mean, with range; n = 33 completers): 7.4 (2–9) | | Spasticity score 21.5 baseline; 18.9 post threonine; 20.6 post placebo (p = NR) | | | | | | Described as “double-blind”? Yes
| | | | | Spasm score 3.8 to 2.6 on L-threonine and 3.4 to 3.0 on placebo (p = NR) | | | | | | Patients blinded? Yes
| | | | | No change in Barthel Index …was seen with either treatment. | | | | | | Investigators blinded? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | Outcome assessors blinded? Yes
| | | | | 2) Physical functioning: Kurtzke DSS | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Definition of “improvement”: | | | | | | Crossover trials only:
| | | | | Proportion of patients with “improvement”: | | | | | | Period or carry-over effects? Not discussed
| | | | | No change in … Kurtzke DSS in either treatment | | | | | | Washout period? Yes (2 wk)
| | | | | Other (non-improvement) outcomes: | | | | | | No. of patients in each sequence clearly described? No
| | | | | 3) Cognitive functioning: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | 4 patients dropped out; 2 for medical reasons (urosepsis, chest infection) believed to be unrelated to treatment. 2 dropped out for non-medical reasons. Two other patients reported minor side-effects on L-threonine (indigestion and diarrhea); 1 reported headache on placebo.
Levine, Jossmann, and DeAngelis, 1977 | Inclusion: Spasticity caused by MS or spinal cord injury; severely disabled (confined to bed or bed and wheelchair) | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 19 | 1) Baclofen (Lioresal) PO given in evenly divided daily doses for 5 wk as follows: wk 1, 15 mg; wk 2, 30 mg; wk 3, 45 mg; wk 4, 60 mg; wk 5, 80 mg (n = NR) | 1) Symptom-specific functional status/ quality-of-life outcomes: Ashworth scale | | | | | | Results of MS and SCI patients were not presented separately; however, baclofen “was 10% more effective in MS than in SCI; on the other hand placebo reaction was 36% greater in SCI than in MS.”
| Exclusion: None specified | Duration of study treatment/follow up: 5 wk treatment; 11 wk total (3-wk run-in, 5 wk treatment, 3 wk post-treatment follow up) | Dropouts: 1 | 2) Placebo for 5 wk (n = NR) | Definition of “improvement”: 10% drop in spasticity score | | | | | | “Clinical grading of spasticity was found lacking in sensitivity to changes in skeletal muscle hypertonia appreciated by more objective bio-electric monitoring of integrated EMG.”
| | Provider specialty: NR (presumably neurologists) | Completed: 18 (12 MS, 6 spinal cord injury) | | Proportion of tests with “improvement”: | | | | | | QUALITY ASSESSMENT:
| | Location: 1 site in Boston, MA | Age (mean overall, n = 18 completers): 42.5 | | Dose | Baclofen | Placebo | | | | Described as “randomized”? Yes
| | | Baseline EDSS: NR | | 15 mg | 1/17 (6%) | 1/15 (7%) | | | | Method of randomization clearly described? No
| | | “The patients being reported were severely disabled and were either bed or bed and wheelchair confined” | | 30 mg | 4/16 (25%) | 2/16 (13%) | | | | Concealment of allocation? Unclear
| | | | | 45 mg | 4/15 (25%) | 4/17 (25%) | | | | Described as “double-blind”? Yes
| | | | | 60 mg | 8/15 (50%) | 8/15 (50%) | | | | Patients blinded? Yes
| | | | | 80 mg | 8/15 (50%) | 6/15 (40%) | | | | Investigators blinded? Yes
| | | | | p-value NR at any dose | | | | | | Outcome assessors blinded? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Avg change in spasticity scores
| | | | | Dose | Baclofen | Placebo
| | | | | 15 mg | -2 | -5
| | | | | 30 mg | -7 | -3
| | | | | 45 mg | -11 | -6
| | | | | 60 mg | -13 | -9
| | | | | 80 mg | -12 | -10
| | | | | p-value NR at any dose
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | Baclofen “ was for the most part tolerated quite well. Side effects included occasional mild drowsiness and infrequent complaints of vertigo, weakness and fatigue.”
Lincoln, Dent, Harding, et al., 2002 | Inclusion: Clinically definite, laboratory-supported, or clinically probable MS; resident within 20-mile radius of study site; able to undergo 30-min assessments | RCT (parallel-group, single-blind [assessors only], single-center) | No. of patients randomized: 240 (107 relapsing-remitting, 94 secondary progressive, 19 primary progressive, 20 unknown) | 1) Detailed cognitive assessment + cognitive rehabilitation program (n = 79); 3-hr assessment session using multiple instruments selected according to nature of patient's problems; results communicated to GP, hospital staff, patients, and families; cognitive rehabilitation program designed and implemented for any deficits identified | 1) Symptom-specific functional status/ quality-of-life outcomes: Extended Activities of Daily Living Scale (EADL) | | | | | | Although 28% did not report cognitive problems on the GNDS, only 5% reported no cognitive problems and had no significant impairment on cognitive testing. Intervention was not intensive, carried out at home.
| Exclusion: None specified | Duration of study treatment/follow up: Only extended intervention (cognitive rehabilitation program) lasted 6 wk; all patients followed up for 8 mo | Dropouts: 17 | 2) Detailed cognitive assessment, as above, but no subsequent intervention (n = 79); results of assessment communicated to GP, hospital staff, patients, and families | Definition of “improvement”: None | | | | | | Heterogeneous patient group, which leads to increased variance on outcome measures, more difficult to detect treatment effect
| | Provider specialty: Psychologists | Completed: 223 | 3) No psychological/ cognitive assessment beyond screening tests; results of screening tests not communicated to medical or rehabilitation staff, patients, or families (n = 82) | Proportion of patients with “improvement”: NA | | | | | | QUALITY ASSESSMENT:
| | Location: 1 site in Nottingham, UK | Age (mean ± SD): 43 ± 10 | | Other (non-improvement) outcomes: | | | | | | Described as “randomized”? Yes
| | | Baseline EDSS: NR; baseline Ambulation Index (median): | | EADL | Control | Assess | Intervention | p-value | | Method of randomization clearly described? Yes
| | | Rehab: 4 | | 4-month | 48.0 | 43.0 | 45.0 | 0.23 | | Concealment of allocation? Yes
| | | Assessment: 4 | | 8-month | 47.5 | 44.5 | 42.0 | 0.21 | | Described as “double-blind”? No
| | | Control: 3 | | 2) Physical functioning: NR | | | | | | Patients blinded? No
| | | | | 3) Cognitive functioning: General Health Questionnaire-28 (GHQ-28); Dysexecutive Syndrome Questionnaire (DEX); Everyday Memory Questionnaire (EMQ); Memory Aids Questionnaire (MAQ) | | | | | | Investigators blinded? No
| | | | | Definition of “improvement”: None | | | | | | Outcome assessors blinded? Yes
| | | | | Proportion of patients with “improvement”: NA | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Other (non-improvement) outcomes:
| | | | | GHQ-28 | Control | Assess | Intervention | p-value
| | | | | 4-month | 21.0 | 21.0 | 22.0 | 0.73
| | | | | 8-month | 18.0 | 18.5 | 21.0 | 0.59
| | | | | DEX
| | | | | 4-month | 17.0 | 16.0 | 20.0 | 0.77
| | | | | 8-month | 16.5 | 18.0 | 18.0 | 0.98
| | | | | EMQ
| | | | | 4-month | 16.5 | 18.5 | 17.0 | 0.69
| | | | | 8-month | 14.0 | 15.0 | 15.0 | 0.76
| | | | | MAQ
| | | | | 4-month | 10.0 | 11.0 | 10.0 | 0.92
| | | | | 8-month | 10.0 | 9.0 | 10.0 | 0.80
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: SF-36 physical and mental composite scores
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | SF-36 | Control | Assess | Intervention | p-value
| | | | | 4-month
| | | | | Physical | 25.6 | 27.1 | 31.4 | 0.45
| | | | | Mental | 44.7 | 44.7 | 46.9 | 0.55
| | | | | 8-month
| | | | | Physical | 30.0 | 32.1 | 30.7 | 0.55
| | | | | Mental | 47.3 | 49.3 | 46.9 | 0.76
| | | | | 6) Adverse events: NR
Livesley, 1992 | Inclusion: Spasticity as a component of a chronic neurological disease (stable for ≥ 6 mo); high level of cognitive awareness; inpatient or outpatient | RCT (parallel-group, single-blind [patients only], single-center) | No. of patients randomized: 40 (37 MS, 2 spinal injuries, 1 stroke) | 1) Electrical neuromuscular stimulation (ENS); quadriceps and hamstrings treated for 12 min every working day for 6 wk; frequency gradually increased from 3 Hz (2 min) to 10 Hz (5 min) to 35 Hz (5 min) during each treatment session (n = 20) | 1) Symptom-specific functional status/ quality-of-life outcomes: Functional ambulation classification appendix; Spasticity self-rating | | | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Duration of study treatment/follow up: 6 wk | Dropouts: 1 | 2) Sham ENS; as above, but stimulator deactivated (n = 20) | Definition of “improvement”: Rated better on scale of worse, same, or better | | | | | | Described as “randomized”? Yes
| | Provider specialty: Physiotherapist | Completed: 39 | | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Nottingham, UK | Age (mean ± SD): | | Treatment | 9/20 (45%) | | | | | Concealment of allocation? Unclear
| | | ENS: 48 ± 8.8 | | Sham | 4/19 (21%) | | | | | Described as “double-blind”? No
| | | Sham ENS: 47 ± 11.2 | | Other (non-improvement) outcomes: | | | | | | Patients blinded? Unclear
| | | Baseline EDSS: NR | | Functional ambulation (median) | | | | | | Investigators blinded? No
| | | | | Treatment | | Sham | | | | Outcome assessors blinded? No
| | | | | Entry | Exit | Entry | Exit | p-value | | No. of withdrawals in each group stated? Yes
| | | | | 4 | 4 | 5 | 5 | NS
| | | | | 2) Physical functioning: Rivermead motor assessment; Range of movement at hip, knee and ankle (degrees)
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | Rivermead motor assessment (median)
| | | | | | Treatment | | Sham
| | | | | | Entry | Exit | Entry | Exit | p
| | | | | Gross | 8 | 9 | 11 | 11 | NS
| | | | | Leg | 8 | 8 | 7 | 9 | NS
| | | | | Joint ROM (degrees)
| | | | | | Treatment | | Sham
| | | | | | Entry | Exit | Entry | Exit | p
| | | | | Hip flex | 98±19 | 102±21 | 100±17 | 100±18 | NS
| | | | | Hip ext | 8.5±6 | 8.5±6 | 7±6 | 7.5±7 | NS
| | | | | Hip abd | 33±11 | 35±10 | 29±13 | 34±13 | NS
| | | | | Knee fl | 121±25 | 126±19 | 122±18 | 120±24 | NS
| | | | | Knee ex | 1±3 | 2.5±5.5 | 0.5±2 | 0.5±2 | NS
| | | | | Ank dor | 18±6.5 | 26±6 | 21±12 | 18±4 | NS
| | | | | Ank pla | 21±17 | 14±5 | 12.5±7 | 19±8 | NS
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Mendoza, Pittenger, and Weinstein, 2001 | Inclusion: Advanced MS; resident in a skilled nursing facility specializing in the treatment of patients with advanced MS | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 20 | 1) Active treatment (n = 10); extended battery of cognitive tests, plus specific problem-solving strategy: Individual CAN assigned to each patient, provided with special training, and charged with keeping a notebook, attached to patient's chair, in which information was recorded on patient's comments or concerns, special assistance required, etc. | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | QUALITY ASSESSMENT:
| Exclusion: Primary admitting diagnosis not MS; unable to read test stimuli; co-morbid major mental disorder; unable to answer test questions at a sufficiently high verbal level; performance on Kaufman Short Neuropsychological Assessment Procedure Mental Status Subtest in the impaired range | Duration of study treatment/follow up: 2 mo | Dropouts: 0 (though post-study data not collected from 1 patient because of a medical complication) | 2) Control (n = 10); no change to previous treatment routine | 2) Physical functioning: NR | | | | | | Described as “randomized”? Yes
| | Provider specialty: Certified nursing assistants (CNAs), social workers, and psychologists | Completed: 20 | | 3) Cognitive functioning: Beck Depression Inventory | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Dorchester, MA | Age (mean): | | Definition of “improvement”: Change score greater than 2 SD | | | | | | Concealment of allocation? Unclear
| | | Active: 54.6 | | Proportion of patients with “improvement”: | | | | | | Described as “double-blind”? No
| | | Control: 64.7 | | Treatment | 6/10 (60%) | | | | | Patients blinded? No
| | | Baseline EDSS: NR; 2 groups “equivalent in terms of general physical status” | | Control | 1/9 (11%) | | | | | Investigators blinded? No
| | | | | Other (non-improvement) outcomes: | | | | | | Outcome assessors blinded? No
| | | | | BDI | Pre | Post | | | | No. of withdrawals in each group stated? Yes
| | | | | Treatment | 11.3 | 5.5
| | | | | Control | 9.3 | 8.6
| | | | | p-value | NS
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Mohr, Boudewyn, Goodkin, et al., 2001 | Inclusion: Confirmed diagnosis of MS (Poser criteria); relapsing-remitting or secondary progressive disease course confirmed by a neurologist; diagnosis of major depressive disorder based on Structured Clinical Interview for the DSM-IV; score ≥ 16 on 17-item Hamilton Rating Scale for Depression; score ≥ 16 on Beck Depression Inventory; willingness to abstain from psychological or pharmacological treatment for depression other than that provided as part of study | (Pseudorandomized, parallel-group, open-label, single-center) | No. of patients randomized: 63 | 1) Cognitive-behavioral therapy focused on improving coping skills (in relation to both depression and MS); individual sessions (50 min each) once weekly for 16 wk (n = 20 at start, 19 at end) | 1) Symptom-specific functional status/ quality-of-life outcomes: BDI, HRSD (Hamilton) | | | | | | QUALITY ASSESSMENT:
| Exclusion: Other serious psychological disorders; dementia (below 5^th^ percentile in 3 or 6 areas of neuropsychological functioning); severe suicidality; treatment with corticosteroids in previous 14 days; initiation of treatment with interferon in previous 2 mo; current MS exacerbation; other disorders of CNS; current or planned pregnancy; current psychological or pharmacological treatment for depression | Patients allocated to group therapy based on threshold number during 4-week period; if fewer than 6 pts enrolled, then they were randomized to CBT or sertraline. | Dropouts: 11 | 2) Supportive-expressive group therapy, focused on facilitating expression and providing social support; sessions involved 5–9 patients and 2 therapists; weekly 90-min sessions for 16 wk (n = 22 at start, 18 at end) | Definition of “improvement”: 50% decrease in symptoms and symptoms severity on HRSD | | | | | | Described as “randomized”? No
| | Duration of study treatment/follow up: 16 wk; 43 patients also followed up at 6 mo | Completed: 52 | 3) Sertraline PO, initiated at 50 mg per day, increased by 50 mg every 4 wk until dosage of 200 mg was reached or until full remission achieved as judged by treating clinicians; patient visits lasting 10–15 min every 4 wk; treatment lasted 16 wk (n = 21 at start, 15 at end) | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? Yes
| | Provider specialty: Neurologists and psychologists | Age (mean ± SD, overall only): 43.9 ± 10.0 | | CBT | 10 (50%) | | | | | Concealment of allocation? No
| | Location: 1 site in San Francisco, CA | Baseline EDSS (mean, with range, overall only): 2.4 (0 to 8.0) | | SEG | 3 (14%) | | | | | Described as “double-blind”? No
| | | | | Sertraline | 5 (24%) | | | | | Patients blinded? No
| | | | | Other (non-improvement) outcomes: | | | | | | Investigators blinded? No
| | | | | ITT | | | | | | Outcome assessors blinded? No
| | | | | BDI - SEG significantly less effective than CBT (P = 0.003) and sertraline (p = 0.047) | | | | | | No. of withdrawals in each group stated? Yes
| | | | | BDI-18 - SEG less effective than CBT (p = 0.0007) and marginally less effective than sertraline (p = 0.84)
| | | | | HRSD - CBT more effective than SEG (p = 002); no significant differences between SEG and sertraline (p = 0.45) or between CBT and sertraline (p = 0.13)
| | | | | 2) Physical functioning: EDSS
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”:
| | | | | NR
| | | | | Other (non-improvement) outcomes:
| | | | | 3) Cognitive functioning: Symbol Digit Modalities Test, Digit Span; Ret Auditory Verbal Learning Test, 7/24, Controlled Oral Word Association, California Card Sort Test
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”:
| | | | | NR
| | | | | Other (non-improvement) outcomes: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Mohr, Likosky, Bertagnolli, et al., 2000 | Inclusion: Diagnosis of a relapsing form of MS; score of ≥ 15 on the Depression-Dejection scale of the Profile of Mood States; treatment for depression (if any) initiated at least 3 mo before start of study with continuation intended | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 32 (all relapsing) | 1) Telephone-administered cognitive-behavioral therapy (n = 16); eight weekly 50-min sessions; included training in thought monitoring, increasing pleasant events, and managing fatigue, as needed for individual patients | 1) Symptom-specific functional status/ quality-of-life outcomes: Profile of Modd States Depression-Dejection scale | | | | | | No change in control condition over 6 wk, but statistically significant change in treatment condition. Post-treatment scores in treatment groups approached upper end of population sample norms.
| Exclusion: Dementia (score < 5^th^ percentile on the Short Word List); other neurological disorder | Duration of study treatment/follow up: 8 wk | Dropouts: 9 | 2) Usual care (n = 16) | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists and psychologists | Completed: 23 | | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | Location: 1 managed care program in northern California | Age: Mean, 42.4 | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR; 56% walked without aids, 34% walked with aids, and 9% used a wheelchair | | Completers | Pre | Post | | | | Concealment of allocation? Unclear
| | | | | CBT | 34.8±13.5 | 13.8±12.8 | | | | Described as “double-blind”? No
| | | | | Usual | 26.0±8.1 | 24.3±10.7 | | | | Patients blinded? No
| | | | | P = 0.003 | | | | | | Investigators blinded? No
| | | | | ITT | Pre | Post | | | | Outcome assessors blinded? No
| | | | | CBT | 33.1±12.4 | 18.7±13.8 | | | | No. of withdrawals in each group stated? Yes
| | | | | Usual | 27.9±12.1 | 26.7±13.7
| | | | | P = 0.01
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Mondrup and Pedersen, 1984a and Mondrup and Pedersen, 1984b | Inclusion: Spastic paresis in a stable phase for ≥ 2 mo | RCT (crossover, double-blind, single-center) | No. of patients randomized: 17 | 1) Progabide PO administered three times per day; maximum dose reached after 3–5 days; treatment lasted 2 wk; median daily dose 24.3 mg/kg (range, 14.3–32.7 mg/kg) | 1) Symptom-specific functional status/ quality-of-life outcomes: Overall therapeutic effect (includes evaluation of gait and other ADLs; 4-point scale) | | | | | | No washout period was described, and no test for treatment-period interaction was described - there is potential for carry-over effect
| Exclusion: Markedly impaired liver or renal function; severe hypertension (DBP > 110 mmHg); orthostatic hypotension; chronic alcoholism; diabetes; cardiac disease; overt psycho-pathology; epilepsy; disease with dominating cerebellar symptoms; pregnancy | Duration of study treatment/follow up: 2 wk with each treatment, 4 wk total (no washout described) | Dropouts: 1 | 2) Placebo, with dose adjustments as above, for 2 wk | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 16 (14 MS, 2 hereditary spastic paraplegia) | No washout described | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Aarhus, Denmark | Age (completers): Median, 45.5; range, 30–62 | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR | | Overall therapeutic effect | | | | | | Concealment of allocation? Unclear
| | | | | Investigator | p < 0.01 | | | | | Described as “double-blind”? Yes
| | | | | Patient | p < 0.01 | | | | | Patients blinded? Yes
| | | | | 2) Physical functioning: Spastic hypertonia (angle at which stretch reflex appears by mobilization of limb at gravity speed in steps of 15 degrees); tendon reflexes-patellar (4-point scale) Achilles (3-point scale); flexor spasms frequency (5-point scale) and discomfort (4-point scale); flexor reflex (4-point scale); muscle strength (6-point scale); | | | | | | Investigators blinded? Yes
| | | | | Definition of “improvement”: None | | | | | | Outcome assessors blinded? Yes
| | | | | Proportion of patients with “improvement”: NA | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | Crossover trials only:
| | | | | | p-value | | | | | Period or carry-over effects? Not discussed
| | | | | Spastic hypertonia | < 0.01 | | | | | Washout period? No
| | | | | Tendon reflexes | | | | | | No. of patients in each sequence clearly described? No
| | | | | Patellar | < 0.01 | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | Achilles | NS
| | | | | Clonus
| | | | | Patellar | NS
| | | | | Foot | NS
| | | | | Flexor reflex | NS
| | | | | Flexor spasms
| | | | | Frequency | < 0.05
| | | | | Discomfort | NS
| | | | | Muscle strength
| | | | | Upper | NS
| | | | | Lower | NS
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: “No side-effects were registered”
Mueller, Gruenthal, Olson, et al., 1997 | Inclusion: Laboratory-supported definite MS, including characteristic MRI findings; spasticity and leg cramps severe enough to interfere with daily activities, including sleep; age 18–50 | RCT (crossover, double-blind, single-center) | No. of patients randomized: 15 | 1) Gabapentin PO 400 mg three times per day for 2 days | 1) Symptom-specific functional status/ quality-of-life outcomes: Visual Faces Scale, Ashworth Scale; clonus; reflexes; Response to Noxious Stimuli | | | | | | Improvements on objective scales were statistically significant, but not as dramatic as patients self-evaluations
| Exclusion: Pregnancy; significant renal disease | Duration of study treatment/follow up: 2 days with each treatment; 15 days total (two 2-hr run-ins [on 1^st^ day of treatment during each period], two 2-day treatment periods, 11-day washout) | Dropouts: 0 | 2) Placebo three times per day for 2 days | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (neurologists and others?) | Completed: 15 | 11-day washout between treatment periods | Proportion of patients with “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Louisville, KY | Age (mean, with range): 42.2 (31–59) | | NR | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS (median): | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Yes
| | | Prior to gabapentin: 12 | | | VFS | Ashworth | Clonus | | | Described as “double-blind”? Yes
| | | Prior to placebo: 13 | | Placebo b/l | 2 | 22 | 1 | | | Patients blinded? Yes
| | | | | Gabapentin b/l | 2 | 23 | 1 | | | Investigators blinded? Yes
| | | | | Placebo | 2 | 23 | 1 | | | Outcome assessors blinded? Yes
| | | | | Gabapentin | 1 | 22 | 1 | | | No. of withdrawals in each group stated? Yes
| | | | | p-value | 0.008 | 0.007 | 0.1 | | | Crossover trials only:
| | | | | | Reflexes | Noxious | | | | Period or carry-over effects? Yes
| | | | | Placebo b/l | 14 | 2 | | | | Washout period? Yes (11 days)
| | | | | Gabapentin b/l | 14 | 2 | | | | No. of patients in each sequence clearly described? No
| | | | | Placebo | 14 | 2 | | | | Were patients who did not complete all of the periods excluded from the analysis? No (no dropouts)
| | | | | Gabapentin | 13 | 2
| | | | | p-value | 0.28 | 0.25
| | | | | 2) Physical functioning: EDSS
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”:
| | | | | NR
| | | | | Other (non-improvement) outcomes:
| | | | | | EDSS
| | | | | Placebo b/l | 13
| | | | | Gabapentin b/l | 12
| | | | | Placebo | 12.5
| | | | | Gabapentin | 10
| | | | | p-value | 0.03
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Newman, Nogues, Newman, et al., 1982 | Inclusion: Disabled by spasticity; neurologically stable | RCT (crossover, double-blind, single-center) | No. of patients randomized: 36 (32 MS, 4 syringomyelia) | 1) Tizanidine PO in 2-mg capsules; dose increased over 2 wk to 8 capsules daily (16 mg), then maintained at this level for a further 1 mo (dose could be lowered if not tolerated) | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Duration of study treatment/follow up: 6 wk with each treatment, 13 wk total (two 6-wk treatment periods, 1-wk washout) | Dropouts: 10 | 2) Baclofen PO in 5- mg capsules; dose increased over 2 wk to 8 capsules daily (40 mg), then maintained at this level for a further 1 mo (dose could be lowered if not tolerated) | 2) Physical functioning: Muscle tone (Ashworth); EDSS; Pedersen score | | | | | | Described as “randomized”? Yes
| | Provider specialty: Neurologists | Completed: 26 | 1-wk washout between treatment periods | Definition of “improvement”: None | | | | | | Method of randomization clearly described? Yes
| | Location: 1 site in Newcastle, UK | Age (mean ± SD, completers): 45.9 ± 9.4 | | Proportion of patients with “improvement”: NA | | | | | | Concealment of allocation? Yes
| | | Baseline EDSS: NR | | Other (non-improvement) outcomes: | | | | | | Described as “double-blind”? Yes
| | | | | Overall score of lower limb muscle tone: | | | | | | Patients blinded? Yes
| | | | | Tizanidine | 9/26 (35%) | p < 0.02 | | | | Investigators blinded? Yes
| | | | | Baclofen | 8/26 (31%) | p > 0.05 | | | | Outcome assessors blinded? Yes
| | | | | Difference between treatments p = NS | | | | | | No. of withdrawals in each group stated? No
| | | | | No significant difference in muscle power | | | | | | Crossover trials only:
| | | | | Flexor, extensor, and adductor spasms in the lower limbs were improved more in baclofen group (p = NS) | | | | | | Period or carry-over effects? No
| | | | | No significant change in Kurtzke scores or Pedersen scores | | | | | | Washout period? Yes (1 wk)
| | | | | 3) Cognitive functioning: NR | | | | | | No. of patients in each sequence clearly described? No
| | | | | 4) Work or employment outcomes: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | AEs experienced by 17/26 (65%) on tizanidine and 17/26 (65%) on baclofen.
| | | | | Drowsiness, muscle pains, dizziness, weakness, abdominal pain, bowel or bladder disturbance, sleeplessness, depression. Similar AE profiles for both drugs.
Nielsen, Sinkjaer, and Jakobsen, 1996 | Inclusion: Clinically definite or laboratory-supported definite MS by Poser criteria; EDSS < 7.0; stable neurological condition for ≥ 6 mo; lower limb spasticity ≥ 2 on Ashworth score for at least one joint; preserved walking performance for 10 m | RCT (parallel-group, double-blind [patients and assessors, not treating clinicians], single-center/ multicenter) | No. of patients randomized: 38 | 1) Repetitive magnetic stimulation twice daily for 7 consecutive days (n = 21); magnetic coil place in midline of back at mid-thoracic level; subjects stimulated in supine position for 25 min with repeated periods of stimulation for 8 sec at 25 Hz, followed by 22 sec of repose; magnetic field strength gradually increased to 0.7 Tesla within a few minutes | 1) Symptom-specific functional status/ quality-of-life outcomes: Clinical score = muscle tone (Ashworth score) + reflex activity; self-score | | | | | | Treating clinicians were not blinded to treatment group
| Exclusion: Epilepsy; other neurological disorders; pregnancy; implanted spinal metal, drug infusion pump, or pacemaker; previous exposure to magnetic stimulation | Duration of study treatment/follow up: 7 days treatment; follow-up evaluations 1, 8, and 16 days after last treatment | Dropouts: 3 | 2) Sham stimulation twice daily for 7 consecutive days (n = 17) | Definition of “improvement”: None | | | | | | No definition of threshold for defining “improvement”
| | Provider specialty: NR (neurologists?) | Completed: 35 | | Proportion of patients with “improvement”: | | | | | | QUALITY ASSESSMENT:
| | Location: 1 site in Aarhus, Denmark | Age (median, with range): | | | Mag stim | Sham | | | | Described as “randomized”? Yes
| | | Active: 44 (34–67) | | Self-score | 9/18 (50%) | 10/17 (59%) | | | | Method of randomization clearly described? No
| | | Sham: 44 (26–66) | | Clin score | 14/18 (78%) | 10/17 (59%) | | | | Concealment of allocation? Unclear
| | | Baseline EDSS: NR | | p-values NR | | | | | | Described as “double-blind”? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | Patients blinded? Yes
| | | | | | Mag stim | Sham | p-value | | | Investigators blinded? No
| | | | | Self-score | 1.1 ± 1.6 | 1.5 ± 1.8 | NS | | | Outcome assessors blinded? Yes
| | | | | Clinical 1d | -3.3 ± 4.7 | 0.7 ± 2.5 | 0.003 | | | No. of withdrawals in each group stated? Yes
| | | | | Improvements in clinical score extinguished at 8 and 16 days after treatment
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
O'Hara, Cadbury, De Souza, et al., 2002 | Inclusion: Diagnosis of MS confirmed by GP | RCT (parallel-group, single blinded [assessors only, not treating clinicians or patients], multicenter) | No. of patients randomized: 183 | 1) Professionally guided self-care program (n = 73); two 1- to 2-hr group or individual discussions of self-care strategies during 1^st^ mo; supported by an information booklet developed for the study in line with consumer priorities; information covered physical, social, and psychological domains of life | 1) Symptom-specific functional status/ quality-of-life outcomes: Standard Day Dependency Record (SDDR) subscales SDDRO & SDDRE | | | | | | QUALITY ASSESSMENT:
| Exclusion: None | Duration of study treatment/follow up: 6 mo | Dropouts: 14 | 2) No-treatment control (n = 96) | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR | Completed: 169 (80 relapsing-remitting, 82 chronic progressive, 7 unknown) | | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? No
| | Location: Multiple local sites in London, UK | Age (mean ± SD): | | NA | | | | | | Concealment of allocation? Unclear
| | | Active: 52.5 ± 11.2 | | Other (non-improvement) outcomes: | | | | | | Described as “double-blind”? No
| | | Control: 50.4 ± 10.4 | | Change from baseline to follow up: | | | | | | Patients blinded? No
| | | Baseline EDSS: NR | | | Intervention | Control | p-value | | | Investigators blinded? No
| | | | | SDDRO | 0.5 | 0.8 | 0.6 | | | Outcome assessors blinded? Yes
| | | | | SDDRE | -0.3 | 0.6 | 0.04 | | | No. of withdrawals in each group stated? Yes
| | | | | 2) Physical functioning: Barthel Index
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | | Intervention | Control
| | | | | Barthel | 0 (0,0) | 0 (-1,0)
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: SF-36
| | | | | Change from baseline to follow up:
| | | | | | Intervention | Control | p-value
| | | | | Mental hlth | 3.7 | -1.2 | 0.04
| | | | | Pain | 2.4 | -1.1 | 0.32
| | | | | Phys role | -6.4 | -6.2 | 0.31
| | | | | Phys fn | 0.6 | -1.4 | 0.5
| | | | | Role emo | -4.2 | -3.1 | 0.9
| | | | | Social fn | 0.8 | -3.3 | 0.33
| | | | | Vitality | 1.5 | -4.2 | 0.05
| | | | | Gen hlth | 7.4 | 4.8 | 0.32
| | | | | 6) Adverse events: NR
Ørsnes, Sørensen, Larsen, et al., 2000 | Inclusion: clinically definite MS; stable disease for ≥ 1 mo; increased stretch reflexes and hyperreflexia; moderate functional deficits; able to walk unaided and without support for at least 1 min | RCT (crossover, double-blind, single-center) | No. of patients randomized: 14 (5 relapsing-remitting, 4 primary progressive, 5 secondary progressive) | 1) Baclofen PO; dose initiated at 5 mg three times per day and increased by 5 mg every 3 days to maximum of 15 mg three times per day or maximum tolerated dose; after 11 days at this dose, treatment tapered over “about 1 wk” | 1) Symptom-specific functional status/ quality-of-life outcomes: Ashworth index | | | | | | QUALITY ASSESSMENT:
| Exclusion: Use of drugs that could affect spasticity | Duration of study treatment/follow up: Approximate-ly 24 days with each treatment; approximately 62 days total (no run-in described, two 24-day treatment periods, 2-wk washout) | Dropouts: 0 | 2) Placebo, dosing schedule as above, for approximately 24 days | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (presumably neurologists) | Completed: 14 | 2-wk washout between treatment periods | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Copenhagen, Denmark | Age (median, with age): 42 (24–57) | | NA | | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS (median, with range): 5 (3.5–6.0) | | Other (non-improvement) outcomes: | | | | | | Described as “double-blind”? Yes
| | | | | | Tendon Reflexes | Muscle tone Ashworth | | | | Patients blinded? Yes
| | | | | Baclofen | | | | | | Investigators blinded? Yes
| | | | | Before | 13.6 (2.8) | 1.9 (1.5) | | | | Outcome assessors blinded? Yes
| | | | | During | 11.7 (4.1) | 2.8 (2.4) | | | | No. of withdrawals in each group stated? Yes
| | | | | Placebo | | | | | | Crossover trials only:
| | | | | Before | 13.7 (3.5) | 3.1 (2.1) | | | | Period or carry-over effects? No
| | | | | During | 13.1 (3.1) | 3.2 (2.3) | | | | Washout period? Yes (2 wk)
| | | | | p-value | 0.14 | 0.33 | | | | No. of patients in each sequence clearly described? Yes
| | | | | 2) Physical functioning: EDSS, Ambulation Index (AI), Neurologic Rating Scale (NRS), MS-impairment scale (MSIS) | | | | | | Were patients who did not complete all of the periods excluded from the analysis? No (no dropouts)
| | | | | Definition of “improvement”: Not defined
| | | | | Proportion of patients with “improvement”:
| | | | | EDSS & AI:
| | | | | Baclofen | 1/14 (7%)
| | | | | Placebo | 3/14 (21%)
| | | | | Other (non-improvement) outcomes:
| | | | | No significant differences between baclofen and placebo in EDSS, AI, NRS or MSIS
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Patti, Ciancio, Reggio, et al., 2002 | Inclusion: Clinically definite or laboratory-supported MS; primary or secondary progressive form of MS; EDSS 4.0–8.0; age 18–65 | RCT (parallel-group, single-blind [assessors only], single-center) | No. of patients randomized: 111 | 1) Comprehensive outpatient rehabilitation program for 6 wk + self-exercise treatment for 6 wk (n = 58); rehabilitation program included physiotherapy, occupational therapy, speech therapy (if needed), and complementary and alternative therapies | 1) Symptom-specific functional status/ quality-of-life outcomes: Fatigue Impact Scale (FIS) | | | | | | QUALITY ASSESSMENT:
| Exclusion: One or more exacerbations in previous 3 mo; cognitive impairment (Mini-Mental State Examination score ≤ 24); history of cardiovascular, respiratory, ortho-pedic, psychiatric, or other medical condition precluding participation; pregnancy; treatment with immunosup-pressives, inter-ferons, copolymer, 4-amminopyridine, or experimental drugs in preceding 6 mo; rehabilitation therapy in previous 3 mo | Duration of study treatment/follow up: 12 wk | Dropouts: 5 | 2) Control = 12-wk self-exercise treatment (n = 53) | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (presumably neurologists) | Completed: 106 | | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? Yes
| | Location: 1 site in Catania, Italy | Age: Mean, 45.6; range, 25–60 | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Yes
| | | Baseline EDSS: Mean, 6.2; range, 4–8 | | | Change from T0 to T1 | | | | | Described as “double-blind”? No
| | | | | | Treatment | Control | p-value | | | Patients blinded? No
| | | | | FIS | -18.8 ± 14.3 | 0.6 ± 0.9 | < 0.001 | | | Investigators blinded? No
| | | | | 2) Physical functioning: EDSS | | | | | | Outcome assessors blinded? Yes
| | | | | Definition of “improvement”: None | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | “Changes in EDSS scores clustered nearly around 0 in both groups at weeks 6 and 12.”
| | | | | 3) Cognitive functioning: Tempelaar Social Experience Checklist (SET); Beck Depression Inventory (BDI)
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | | Change from T0 to T1
| | | | | | Treatment | Control | p-value
| | | | | SET | -2.6 ± 6.0 | -0.3 ± 0.8 | < 0.001
| | | | | BDI | -2.2 ± 3.4 | 0.1 ± 1.0 | < 0.001
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: SF-36
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | SF-36 Change from T0 to T1
| | | | | | Treatment | Control | p-value
| | | | | PF | 6.9 ± 18 | -0.1 ± 0.3 | < 0.001
| | | | | RP | 14 ± 24 | -0.2 ± 0.5 | < 0.001
| | | | | BP | 15 ± 20 | -0.1 ± 0.6 | < 0.001
| | | | | GH | 5.8 ± 10 | -0.2 ± 0.5 | < 0.001
| | | | | VT | 7.4 ± 12 | -0.1 ± 0.5 | < 0.05
| | | | | SF | 12 ± 15 | -0.1 ± 0.3 | < 0.001
| | | | | RE | 6.2 ± 24 | -0.1 ± 0.3 | < 0.05
| | | | | MH | 7.7 ± 16 | -0.1 ± 0.5 | < 0.05
| | | | | 6) Adverse events: NR
Penn, Savoy, Corcos, et al., 1989 | Inclusion: Severe, disabling spasms caused by MS or spinal-cord injury; not responsive to oral doses of anti-spastic medication; agreed to implantation of drug pump after pre-trial test dose of intrathecal baclofen | RCT (crossover, double-blind, single-center) | No. of patients randomized: 20 (10 MS, 10 spinal-cord injury) | 1) Baclofen by intrathecal infusion via surgically implanted pump; daily dose 1.5–2 times the effective bolus intrathecal dose (typically 100–150 μg per day) given by continuous infusion over 3 days | 1) Symptom-specific functional status/ quality-of-life outcomes: Ashworth score; Spasm score | | | | | | Study was effectively unblinded due to the effect of the drug. Most results not given separately for SCI and MS patients.
| Exclusion: None specified | Duration of study treatment/follow up: 3 days with each treatment; pre-trial test with bolus intrathecal dose; no washout | Dropouts: 0 | 2) Placebo by same route for 3 days | Definition of “improvement”: Not defined | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Physiatrists, motor physiologists, and neurosurgeons | Completed: 20 | No washout between treatment periods | Proportion of patients with “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Chicago, IL | Age (mean, with range): 41.5 (23–62) | | 9/10 patients had clinically important improvement - 1 had no improvement during dbl blind trial, but did show improvement at higher dosage during open trial | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR; 9/10 MS patients wheelchair-bound; all 10 “functionally dependent” | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | | | Ashworth | | | | | | Described as “double-blind”? Yes
| | | | | Placebo | 4.0 ± 1.0 | | | | | Patients blinded? Yes
| | | | | Baclofen | 1.2 ± 0.4 | | | | | Investigators blinded? Yes
| | | | | Change | 2.8 (p < 0.0001) | | | | | Outcome assessors blinded? Yes
| | | | | Spasm score | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Placebo | 3.3 ± 1.2 | | | | | Crossover trials only:
| | | | | Baclofen | 0.4 ± 0.8 | | | | | Period or carry-over effects? Not discussed
| | | | | Change | 2.9 (p < 0.0005) | | | | | Washout period? No
| | | | | 2) Physical functioning: NR | | | | | | No. of patients in each sequence clearly described? No
| | | | | 3) Cognitive functioning: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Unclear
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | During 26 mo follow up, 2 catheters dislodged, 1 pump failed at 4 mo, pain at implantation site
Petajan, Gappmaier, White, et al., 1996 | Inclusion: Confirmed diagnosis of clinically definite MS; EDSS ≤ 6.0; not involved in any form of regular physical activity for previous 6 mo; no history of cardio-vascular, respiratory, orthopedic, metabolic, or other medical condition that would preclude participation in exercise program | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 54 | 1) Exercise program (n = 21); 3 supervised training session per week for 15 wk; each session consisted of 5-min warm-up at 30% VO_2_max, 30 min at 60% VO_2_max, 5-min cool-down, and 5–10 min stretching focusing on posterior muscles of lower leg, thigh, and back | 1) Symptom-specific functional status/ quality-of-life outcomes: Fatigue Severity Scale (FSS); Sickness Impact Profile (SIP) | | | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Duration of study treatment/follow up: 15 wk | Dropouts: 8 | 2) No treatment (patients agreed not to alter their level of physical exercise) (n = 25) | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: Neurologists (and physical therapists/ exercise physiologists) | Completed: 46 | | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Salt Lake City, UT | Age (mean ± SE): | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Exercise: 41.1 ± 2.0 | | “No changes were observed for exercise or non-exercise groups on the FSS” | | | | | | Described as “double-blind”? No
| | | Control: 39.0 ± 1.7 | | Significant improvement in exercise group compared to non-exercise group for physical dimension subscale of the SIP. | | | | | | Patients blinded? No
| | | Baseline EDSS (mean ± SE): | | In other dimensions (ambulation, mobility, and body care and movement) exercise patients improved compared to baseline, but not significantly compared to non-exercise group. | | | | | | Investigators blinded? No
| | | Exercise: 3.8 ± 0.3 | | No changes for psychosocial dimension subscale. | | | | | | Outcome assessors blinded? No
| | | Control: 2.9 ± 0.3 | | 2) Physical functioning: EDSS; ISS; VO2max | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | EDSS | Exercise | Non-exercise
| | | | | Baseline | 3.8 ± 0.3 | 2.9 ± 0.3
| | | | | 15-week | 3.7 ± 0.3 | 2.8 ± 0.3
| | | | | p = NS
| | | | | ISS | Exercise | Non-exercise
| | | | | Baseline | 9.0 ± 0.9 | 8.1 ± 0.9
| | | | | 15-week | 6.8 ± 1.1 | 8.3 ± 0.9
| | | | | p = NS
| | | | | VO2max | Exercise | Non-exercise
| | | | | Baseline | 24.2 ± 1.4 | 26.0 ± 1.3
| | | | | 15-week | 29.4 ± 1.3 | 26.4 ± 1.4
| | | | | p < 0.01
| | | | | 3) Cognitive functioning: Profile of Mood States (POMS)
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | POMS - Lower scores for depression (5,10 wk), anger (5,10 wk), and fatigue (10 wk) subscales from baseline to post-treatment in exercise group; no between-group differences
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Pozzilli, Brunetti, Amicosante, et al., 2002 | Inclusion: Clinically definite MS; resident in Rome service area of Italian National Health Service | RCT (parallel-group, open-label, multicenter) | No. of patients randomized: 201 (40 relapsing-remitting, 41 primary progressive, 120 secondary progressive) | 1) Home-based management (n = 133); patients managed through home visits and telephone calls; multidisciplinary care team designed individualized clinical care plan and coordinated home services; care included observation, administration of IV drugs, nursing care, rehabilitation, education, psychological support, and social services; treatment continued for 1 yr | 1) Symptom-specific functional status/ quality-of-life outcomes: SF-36, Fatigue Severity Scale (FSS); Functional Independence Measure (FIM) | | | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Duration of study treatment/follow up: 1 yr | Dropouts: 13 | 2) Traditional hospital care (n = 68); patients followed as usual in their MS referral centers for 1 yr | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: Multidisciplinary care teams for home-care patients; neurologists for hospital patients | Completed: 188 | | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? Yes
| | Location: Care provided in patients' homes and at various MS clinics in Rome, Italy | Age (mean ± SD): | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Home: 47.0 ± 10.3 | | SF-36 | Diff | CI | p-value | | | Described as “double-blind”? No
| | | Hospital: 46.7 ± 13.3 | | Phys fn | 0.27 | -0.53 to 1.06 | 0.55 | | | Patients blinded? No
| | | Baseline EDSS (mean ± SD): | | Role phys | 3.67 | -1.19 to 8.53 | 0.09 | | | Investigators blinded? No
| | | Home: 6.0 ± 2.0 | | Bodily pain | 3.46 | 2.4 to 4.5 | 0.0001 | | | Outcome assessors blinded? No
| | | Hospital: 5.8 ± 2.2 | | Gen Health | 5.01 | 4.5 to 5.5 | 0.0001 | | | No. of withdrawals in each group stated? Yes
| | | | | Vitality | 0.28 | -0.38 to 0.94 | 0.41
| | | | | Social fn | 1.09 | 0.51 to 1.67 | 0.001
| | | | | Role, emo | 12.4 | 9.8 to 14.9 | 0.0001
| | | | | Mental hlth | -0.10 | -0.25 to 0.05 | 0.19
| | | | | Phys component score
| | | | | | 1.19 | 1.04 to 1.34 | 0.0001
| | | | | Mental comp score
| | | | | | 0.75 | 0.58 to 0.91 | 0.0001
| | | | | No significant differences between intervention and control groups for FSS or FIM
| | | | | 2) Physical functioning: EDSS
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | No significant differences between intervention and control groups for EDSS
| | | | | 3) Cognitive functioning: MMSE, State-trait Anger Expression Inventory (STAXI); State-Trait Anxiety Inventory (STAI); Clinical Depression Questionnaire (CDQ)
| | | | | Definition of “improvement”:
| | | | | Proportion of patients with “improvement”:
| | | | | No significant differences between intervention and control groups for MMSE, STAXI, STAI
| | | | | Trend in favor of intervention group for changes in depression as measured by the CDQ score; intervention (-7.8%); control (+0.7%) (p = 0.11)
| | | | | Other (non-improvement) outcomes:
| | | | | No significant differences between intervention and control groups for MMSE
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Prasad, Smith, and Wright, 2003 | Inclusion: MS; voiding dysfunction, (such as frequency or urgency) associated with elevated residual volume of > 100 mL and < 500 mL; attending a continence advisory clinic or a neuro-rehabilitation clinic; reasonable hand dexterity; intact abdominal sensation; able to walk short distances indoors without aids | RCT (crossover, open-label, two-center) | No. of patients randomized: 30 | 1) Abdominal vibration; provided by low-cost, commercially available body massager (Queen Square Bladder Stimulator); used against supra-pubic region (2.5 cm above public symphysis) during and for 1 min after voiding; treatment continued for 2 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: Frequency of micturition (per 72 hr); incontinence; frequency of incontinence; post-void residual urine volume (ml) | | | | | | QUALITY ASSESSMENT:
| Exclusion: Urinary symptoms caused by infection | Duration of study treatment/follow up: 2 wk with each treatment; 8 wk total (no run-in described, three 2-wk treatment periods, two 1-wk washouts) | Dropouts: 2 (post-randomization, but pre-treatment) | 2) Abdominal pressure; applied using same massager as above, but without batteries, for 2 wk | Definition of “improvement”: No incontinence/72 hr | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (rehabilitation medicine) | Completed: 28 | 3) No treatment for 2 wk | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? No
| | Location: 2 sites in Edinburgh, Scotland | Age (mean ± SD): 49 ± 9.2 | 1-wk washout between treatment periods | Vibration | 20/28 (71%) | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS: NR | | Abd pressure | 12/28 (43%) | | | | | Described as “double-blind”? No
| | | | | No treatment | 16/28 (57%) | | | | | Patients blinded? No
| | | | | Other (non-improvement) outcomes: | | | | | | Investigators blinded? No
| | | | | | Frequency per 72 hr ± SD | | | | | Outcome assessors blinded? No
| | | | | Vibration | 25 ± 8.9 | | | | | No. of withdrawals in each group stated? Yes
| | | | | Abd pressure | 26 ± 9 | | | | | Crossover trials only:
| | | | | No treatment | 27 ± 10.3 | | | | | Period or carry-over effects? Not discussed
| | | | | | Mean episodes of incontinence | | | | | Washout period? Yes (1 wk)
| | | | | Vibration | 1.3 (0–3) | | | | | No. of patients in each sequence clearly described? No
| | | | | Abd pressure | 1.6 (0–20) | | | | | Were patients who did not complete all of the periods excluded from the analysis? No (no dropouts)
| | | | | No treatment | 1.9 (0–20)
| | | | | | Post-void residuals (ml) (± SD)
| | | | | Vibration | 126 ± 121 (p = 0.002 vs NT)
| | | | | Abd pressure | 191 ± 132 (p = 0.059 vs Vib)
| | | | | No treatment | 231 ± 119
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Rinne, 1980 | Inclusion: Stable spasticity (≥ 1 yr) due to MS or myelopathy | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 30 (all MS) | 1) Tizanidine PO 2-mg capsules (n = 15); dose gradually increased (at 2-wk intervals) to maximum of nine capsules (18 mg) daily, taken in three divided doses; treatment lasted 6 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | Article describes three separate trials. Trials 1 and 3 included patients with MS and chronic myelopathy; neither reported results separately for patients with MS. Results summarized here are for Trial 2, which included only patients with MS.
| Exclusion: None specified | Duration of study treatment/follow up: 6 wk | Dropouts: 4 | 2) Diazepam PO 2.5-mg capsules (n = 15); dose gradually increased (at 2-wk intervals) to maximum of nine capsules (22.5 mg) daily, taken in three divided doses; treatment lasted 6 wk | 2) Physical functioning: Muscle tone (Ashworth scale) | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (presumably neurologist) | Completed: 26 | | Definition of “improvement”: Marked, moderate or slight improvement on scale including no change and deterioration, based on muscle tone | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Turku, Finland | Age (mean ± SD): | | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? No
| | | Tizanidine: 42 ± 3 | | Tizanidine | 10/16 (63%) | | | | | Concealment of allocation? Unclear
| | | Diazepam: 40 ± 2 | | Diazapam | 9/15 (60%) | | | | | Described as “double-blind”? Yes
| | | Baseline EDSS: NR | | Other (non-improvement) outcomes: | | | | | | Patients blinded? Yes
| | | | | 3) Cognitive functioning: NR | | | | | | Investigators blinded? Yes
| | | | | 4) Work or employment outcomes: NR | | | | | | Outcome assessors blinded? Yes
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | No. of withdrawals in each group stated? Yes
| | | | | 6) Adverse events:
| | | | | AEs reported by 10/15 (67%) on tizanidine and 12/15 (80%) on diazepam
| | | | | Muscle weakness, drowsiness required withdrawal in 4 patients (diazepam)
| | | | | Overall tolerance was significantly better on tizanidine than diazepam (p < 0.05)
Rossini, Pasqualetti, Pozzilli, et al., 2001 | Inclusion: Primary and secondary clinically definite MS; stable neurological deficits for ≥ 2 mo | RCT (crossover, double-blind, single-center) | No. of patients randomized: 54 | 1) 4-aminopyridine (4-AP) 8 mg taken orally 4 times per day for 6 mo (dose gradually raised to this level over 1^st^ mo) | 1) Symptom-specific functional status/ quality-of-life outcomes: Fatigue Severity Scale (FSS) | | | | | | QUALITY ASSESSMENT:
| Exclusion: History of previous epileptic seizures; EEG epileptiform activity; treatment with corticosteroids or immunosuppressants in previous 60 days | Duration of study treatment/follow up: 6 mo with each treatment, 12 mo total (no run-in described, no washout between treatments) | Dropouts: 5 | 2) Placebo for 6 mo | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (presumably neurologists) | Completed: 49 (43 secondary progressive, 6 primary progressive) | No washout between treatment periods | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Rome, Italy | Age (mean ± SD; n = 49 completers): 43.9 ± 8.9 | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS (mean ± SD; n = 49 completers): 6.2 ± 0.8 | | No significant difference in FSS improvements between 4-AP and placebo (p = 0.19) | | | | | | Described as “double-blind”? Yes
| | | | | 2) Physical functioning: EDSS | | | | | | Patients blinded? Yes
| | | | | Definition of “improvement”: None | | | | | | Investigators blinded? Yes
| | | | | Proportion of patients with “improvement”: NA | | | | | | Outcome assessors blinded? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | No. of withdrawals in each group stated? Yes
| | | | | EDSS | Mean Difference ± SD | | | | | Crossover trials only:
| | | | | Placebo | -0.05± 0.37 | | | | | Period or carry-over effects? No
| | | | | 4-AP | -0.05± 0.50 | | | | | Washout period? No
| | | | | p = NS | | | | | | No. of patients in each sequence clearly described? Yes
| | | | | Similarly no significant difference for any of the EDSS Functional Systems (FS) | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: None observed
Rudick, Breton, and Krall, 1987 | Inclusion: Definite MS by Schumacher criteria; at least grade-3 spasticity (Ashworth Scale) or spasms associated with significant discomfort or functional impairment | RCT (crossover, double-blind, single-center/ multicenter) | No. of patients randomized: 32 | 1) Progabide, dose increased to 30 mg/kg/day over 10 days, then to 45 mg/kg/day over 10 days of weeks 3–4; treatment lasted total of 4 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: Ashworth | | | | | | QUALITY ASSESSMENT:
| Exclusion: Epilepsy; significant medical illnesses | Duration of study treatment/follow up: 4 wk with each treatment; 12 wk total (two 4-wk treatment periods, 2-wk run-in, 2-wk washout) | Dropouts: 7 | 2) Placebo for 4 wk | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (presumably neurologists) | Completed: 25 | 2-wk washout between treatment periods | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Location: 1 site in Rochester, NY | Age (mean, with range): 45.3 (24–67) | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS (mean ± SD): 6.3 ± 1.7 | | Ashworth | | | | | | Described as “double-blind”? Yes
| | | | | Baseline | 10.3 | | | | | Patients blinded? Yes
| | | | | Progabide | 8.0 | | | | | Investigators blinded? Yes
| | | | | Placebo | 9.6 | | | | | Outcome assessors blinded? Yes
| | | | | P < 0.01 progabide vs placebo | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Measure | p-value | | | | | Crossover trials only:
| | | | | Timed 8-meter walk | 0.62 | | | | | Period or carry-over effects? No
| | | | | Zip-a-garment test | 0.45 | | | | | Washout period? Yes (2 wk)
| | | | | Dial-a-phone test | 0.74 | | | | | No. of patients in each sequence clearly described? Yes
| | | | | Pick-up-coins test | 0.25 | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | Spasm count | 0.28
| | | | | Reflex scores | 0.20
| | | | | Arm+leg power | 0.77
| | | | | 2) Physical functioning: EDSS
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | No significant change
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | 8 serious AEs included fever and weakness or transaminase elevation (associated with rash, hepatomegaly or fever)
Sachais, Logue, and Carey, 1977 | Inclusion: Spasticity secondary to MS; inpatients or outpatients; age ≥ 18; no muscle relaxant, anti-hypertensive, or psychoactive drugs for at least 7 days prior to start of trial | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 166 | 1) Baclofen PO (n = 85). Dosing for inpatients: | 1) Symptom-specific functional status/ quality-of-life outcomes: impairment of sexual performance (4-point scale); interference with daily activities (4-point scale); overall disability (6-point scale) | | | | | | Large numbers of patients were excluded from analysis due to use of “disallowed” medications, presumably to treat spasticity symptoms
| Exclusion: Evidence or history of renal, hepatic, or active GI disease; clinically evident joint contractures; psychiatric illness unrelated to MS; seizure disorders; drug or alcohol abuse; clinically significant lab abnormalities; pregnant and nursing women and those likely to become pregnant | Duration of study treatment/follow up: 5 wk | Dropouts: 60 | Wk 1: 10 mg three times per day for 3 days, 15 mg three times per day for 4 days | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 106 | Wk 2: 20 mg three times per day | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | Location: 16 sites in US | Age (mean [with range], completers): | Wk 3–5: 1–2 10-mg tablets could be added to daily dose as needed; total daily dose not to exceed 80 mg | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | Baclofen: 43 (20–64) | Dosing for outpatients: | | Baclofen | Placebo | p-value | | | Concealment of allocation? Unclear
| | | Placebo: 43 (21–65) | Wk 1: 5 mg three times per day for 3 days, 10 mg three times per day for 4 days | Sex perf | -0.13 | +0.09 | NS | | | Described as “double-blind”? Yes
| | | Baseline EDSS: NR | Wk 2: 15 mg three times per day for 3 days, 20 mg three times per day for 4 days | ADLs | -0.16 | -0.16 | NS | | | Patients blinded? Yes
| | | | Wk 3–5: One or two 10-mg tablets could be added to daily dose as needed; total daily dose not to exceed 80 mg | Overall disability | -0.36 | -0.25 | NS | | | Investigators blinded? Yes
| | | | 2) Placebo (n = 81) | 2) Physical functioning: MD rated flexor spasm pain, frequency (5-point scale); muscle tone (5-point scale) during flexion and extension at ankle, knee and hip; patellar reflexes, right and left (5-point scale); global severity (6-point scale) | | | | | | Outcome assessors blinded? Yes
| | | | | Definition of “improvement”: MS assessment | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Proportion of patients with “improvement”:
| | | | | | Baclofen | Placebo | p
| | | | | Flexor spasms | 17 (42%) | 6 (16%) | < 0.02
| | | | | Ankle clonus | 12 (27%) | 5 (11%) | NS
| | | | | Other (non-improvement) outcomes:
| | | | | | Baclofen | Placebo | p-value
| | | | | Flex spasm
| | | | | Pain | -1.1 | -0.08 | < 0.001
| | | | | Freq | -0.63 | -0.14 | < 0.05
| | | | | Musc tone
| | | | | Ank flex | -0.39 | -0.04 | < 0.005
| | | | | Ank ext | -0.45 | -0.21 | NS
| | | | | Knee f | -0.46 | -0.11 | < 0.01
| | | | | Knee e | -0.50 | +0.02 | < 0.001
| | | | | Hip abd | -0.34 | -0.21 | NS
| | | | | Hip ext | -0.33 | -0.12 | NS
| | | | | Reflexes
| | | | | L knee | -0.60 | +0.04 | < 0.005
| | | | | R knee | -0.70 | -0.02 | < 0.001
| | | | | Global | -0.26 | -0.19 | NS
| | | | | 3) Cognitive functioning: Depression; euphoria, irritability (4-point scale)
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | Mental state | Baclofen | Placebo | p-value
| | | | | Depression | -0.23 | -0.21 | NS
| | | | | Euphoria | -0.13 | -0.37 | NS
| | | | | Irritability | -0.26 | -0.68 | NS
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | Somnolence occurred in 75% of baclofen-treated and 36% of placebo-treated patients.
| | | | | Vertigo, weakness, urinary frequency, nausea, vomiting and constipation were other frequent AEs that were more common in baclofen- than placebo-treated patients.
Sawa and Paty, 1979 | Inclusion: Clinically definite MS or chronic myelopathy (presumed MS); otherwise well | RCT (crossover, double-blind, single-center) | No. of patients randomized: 21 | 1) Baclofen 10 mg tablets; dose gradually increased from 15 mg per day (three 5-mg doses) to 60 mg per day, or until intolerable side effects resulted; treatment continued for 3 wk | 1) Symptom-specific functional status/ quality-of-life outcomes [describe scale/instrument used]: | | | | | | No quantitative data presented and no statistical comparison between groups
| Exclusion: Use of drugs that could affect muscle tone (e.g., diazepam or steroids) in previous 7 days | Duration of study treatment/follow up: 3 wk with each treatment, 7 wk total (no run-in described, two 3-wk treatment periods, 1-wk washout) | Dropouts: 3 | 2) Placebo for 3 wk | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (presumably neurologists) | Completed: 18 | 1-wk washout between treatment periods | Proportion of patients with “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 1 site in London, Ontario, Canada | Age (mean, reported only by sex): | | 13/18 exhibited an objective improvement in spasticity on baclofen; none on placebo | | | | | | Method of randomization clearly described? No
| | | Men (n = 15): 49 | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Women (n = 6): 36 | | 2) Physical functioning: NR | | | | | | Described as “double-blind”? Yes
| | | Baseline EDSS: NR | | 3) Cognitive functioning: NR | | | | | | Patients blinded? Yes
| | | | | 4) Work or employment outcomes: NR | | | | | | Investigators blinded? Yes
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Outcome assessors blinded? Yes
| | | | | 6) Adverse events: | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Withdrawals 1 due to weakness (baclofen) | | | | | | Crossover trials only:
| | | | | Reported AEs | | | | | | Period or carry-over effects? Not discussed
| | | | | Sedation | 6 (29%) | | | | | Washout period? Yes (1 wk)
| | | | | Headache | 3 (14%) | | | | | No. of patients in each sequence clearly described? No
| | | | | Mood changes | 4 (19%) | | | | | Were patients who did not complete all of the periods excluded from the analysis? Unclear
| | | | | Dizziness | 2 (10%)
| | | | | Weakness | 3 (14%)
| | | | | Nausea | 5 (24%)
| | | | | Vomiting | 2 (10%)
| | | | | Abdominal pain | 2 (10%)
| | | | | Malaise | 2 (10%)
Schiffer, Herndon, and Rudick, 1985 | Inclusion: Confirmed MS according to Poser criteria; episodes of involuntary laughing or weeping | RCT (crossover, double-blind, single-center) | No. of patients randomized: 17 | 1) Amitriptyline; initial dose 25 mg per day, increased to 75 mg per day over first 5 days; mean dose, 57.8 mg per day, with no patient exceeding 75 mg per day; treatment continued for 30 days | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | One-tailed statistical tests for effectiveness of drug
| Exclusion: None specified | Duration of study treatment/follow up: 30 days with each treatment; total approxi-mately 6 wk (two 30-day treatment periods, 1-wk run-in; 1-wk washout) | Dropouts: 5 | 2) Placebo for 30 days | 2) Physical functioning: NR | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (neurologists and psychiatrists) | Completed: 12 (5 relapsing, 7 progressive) | 1-wk washout between treatment periods | 3) Cognitive functioning: No. episodes of pathological laughing or crying; Beck Depression Inventory; Hamilton Rating Scale for Depression | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Rochester, NY | Age (mean, with range; n = 12 completers): 44.3 (22–67) | | Definition of “improvement”: Not reported | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR; 5/12 completers not ambulatory | | Proportion of patients with “improvement”: | | | | | | Concealment of allocation? Unclear
| | | | | 8/12 (67%) on amitriptyline | | | | | | Described as “double-blind”? Yes
| | | | | 1/12 (8%) on placebo | | | | | | Patients blinded? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | Investigators blinded? Yes
| | | | | No significant change in BDI or HRSD | | | | | | Outcome assessors blinded? Yes
| | | | | 4) Work or employment outcomes: NR | | | | | | No. of withdrawals in each group stated? No
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Crossover trials only:
| | | | | 6) Adverse events: | | | | | | Period or carry-over effects? No
| | | | | Drowsiness and dry mouth requiring reduction of dosage in 4/8 responders | | | | | | Washout period? Yes (1 wk)
| | | | | | | | | | | No. of patients in each sequence clearly described? No
| | | | | | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
Schiffer and Wineman, 1990 | Inclusion: Definite MS according to Poser criteria; definite major depressive disorder (diagnosis made in accordance with the Research Diagnostic Criteria and the Schedule for Affective Disorders and Schizophrenia) | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 32 | 1) Desipramine + psychotherapy (n = 14); desipramine PO 25 mg; dose raised at 2-day intervals over first 7 days to 6 capsules per day (3 twice per day) or to maximum dose permitted by side effects; serum levels checked and dose adjustments made during 2^nd^ week; psychotherapy administered in weekly 45-min sessions; treatment continued for total of 30 days | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | QUALITY ASSESSMENT:
| Exclusion: Depressive episode occurred during period of acute corticosteroid administration; current use of psychotropic drugs | Duration of study treatment/follow up: 30 days | Dropouts: 4 | 2) Placebo + psychotherapy (as above) for 30 days (n = 14) | 2) Physical functioning: NR | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR | Completed: 28 (completed at least 2 wk of 30-day protocol; mean study duration over 29 days in both groups) | | 3) Cognitive functioning (BDI, HRSD): | | | | | | Method of randomization clearly described? Yes
| | Location: 1 site in Rochester, NY | Age (mean, with range): | | Definition of “improvement”: Blind clinical judgment of “sufficient improvement in depressive features so as to permit a definite improvement in psychosocial function” | | | | | | Concealment of allocation? No
| | | Desipramine: 37.8 (22–55) | | Proportion of patients with “improvement”: | | | | | | Described as “double-blind”? Yes
| | | Placebo: 39.1 (22–75) | | 11/13 desipramine | | | | | | Patients blinded? Yes
| | | Baseline EDSS (mean ± SD): | | 6/14 placebo | | | | | | Investigators blinded? Yes
| | | Desipramine: 4.4 ± 2.1 | | p = 0.05, Fisher's exact test | | | | | | Outcome assessors blinded? Yes
| | | Placebo: 4.8 ± 2.4 | | Other (non-improvement) outcomes: | | | | | | No. of withdrawals in each group stated? No
| | | | | BDI | Baseline | End
| | | | | Desipramine | 18.4± 5.9 | 11.4± 8.0
| | | | | Placebo | 18.6± 8.6 | 15.5± 11.3
| | | | | p = 0.16
| | | | | HRSD | Baseline | End
| | | | | Desipramine | 28.3± 5.8 | 12.7± 5.8
| | | | | Placebo | 24.9± 8.6 | 20.1± 13.6
| | | | | p = 0.02
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | 12/14 desipramine patients reported AEs; commonly postural hypotension, dry mouth (n = 5), constipation
| | | | | 7/14 placebo patients reported AEs; dry mouth (n = 5)
Schmidt, Lee, and Spehlmann, 1975 and Schmidt, Lee, and Spehlmann, 1976 | Inclusion: MS; moderate or severe spasticity clearly interfering with physical function, but relatively less ataxia or weakness; condition stable for ≥ 6 mo; no ACTH or corticosteroids in previous 6 mo; no muscle relaxants or sedatives in previous 2 wk | RCT (crossover, double-blind, single-center) | No. of patients randomized: 46 | 1) Dantrolene sodium PO; dose gradually increased according to a fixed schedule in three increments over a 2-wk period (low dose); this process then continued over another 2-wk period (high dose); usual doses at end of low- and high-dose titrations were 25 mg and 75 mg four times per day, respectively (reductions permitted for side effects) | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | Multiple comparisons without statistical correction increases likelihood of finding significant associations by chance
| Exclusion: Severe dementia, ataxia, or tremor | Duration of study treatment/follow up: 4 wk with each treatment, 12 wk total (2-wk run-in, two 4-wk treatment periods, 2-wk washout) | Dropouts: 4 | 2) Diazepam PO; gradually increased over two 2-wk periods, as above; usual doses at end of low- and high-dose titrations were 2 mg and 5 mg four times per day, respectively (reductions permitted for side effects) | 2) Physical functioning: Spasticity, deltoid strength, hip flexor strength, station stability, hand coordination, hand speed, foot speed, stretch reflexes, clonus, and walking speed. Score calculations for each function by summing individual values from R and L sides and multiple trials. | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 42 | 2-wk washout between treatment periods | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Evanston, IL | Age: NR | | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | | Baseline DSS: Mean, 5.5 | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | | | | Lo DS | Hi DS | Lo DZ | Hi DZ | | Described as “double-blind”? Yes
| | | | | Spasticity | 10.0 | 9.54 | 9.40 | 9.14 | | Patients blinded? Yes
| | | | | Deltoid str | 48.5* | 47.4# | 49.6 | 50.2 | | Investigators blinded? Yes
| | | | | Hip flex | 120* | 122 | 156 | 127 | | Outcome assessors blinded? Yes
| | | | | Hand coord | 145 | 147 | 141 | 134* | | No. of withdrawals in each group stated? No
| | | | | Stability | 43.2 | 45.9* | 39.1 | 34.1 | | Crossover trials only:
| | | | | Hand speed | 238 | 250 | 239 | 227 | | Period or carry-over effects? Not discussed
| | | | | Foot speed | 242 | 240 | 233 | 226 | | Washout period? Yes (2 wk)
| | | | | Reflexes | 20.5* | 19.4* | 22.5 | 22.1 | | No. of patients in each sequence clearly described? No
| | | | | Clonus | 3.77 | 3.15 | 3.50 | 3.41 | | Were patients who did not complete all of the periods excluded from the analysis? Unclear
| | | | | Walk speed | 11.3 | 10.6 | 13.8 | 17.1
| | | | | *P < 0.05 compared to corresponding dose of comparator drug
| | | | | #p < 0.10
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | | Dantrolene | Diazepam | p
| | | | | Impaired gait | 52% | 75% | NS
| | | | | Drowsiness | 31% | 67% | NS
| | | | | Imbalance | 17% | 36% | NS
| | | | | Incoordination | 10% | 29% | NS
| | | | | At least 1 of 4 withdrawals was due to AEs
Smith, Birnbaum, Carter, et al., 1994 | Inclusion: Stable spasticity secondary to MS; spasticity severe enough to cause significant discomfort of functional impairment and to produce score ≥ 2 on Ashworth Scale for muscle tone or ≥ 2 for muscle spasm type and frequency in most severely affected muscle group; age 18–70 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 257 | 1) Tizanidine PO, dose titrated over 3 wk from 2 mg/day to maximum of 36 mg/day (12 mg three times daily); optimal dose continued through plateau phase (9 wk); dose then tapered over 1 wk and discontinued (n = 111) | 1) Symptom-specific functional status/ quality-of-life outcomes: Ashworth | | | | | | 36 patients disqualified because of inadvertent contamination - placebo patients accidentally given active drug
| Exclusion: Use of any other muscle relaxant or drugs with muscle-relaxant properties; current or recent (within 3 mo) acute MS relapse; fibrous contractures | Duration of study treatment/follow up: 16 wk total (2-wk run-in, 3-wk dose titration, 9 wk at plateau dose, 1-wk dose tapering, followed by post-treatment evaluation) | Dropouts: 98 | 2) Placebo (n = 109) | Definition of “improvement”: Decrease in total Ashworth Score | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 159 (220 analyzable) | | Proportion of patients with “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 14 sites in US | Age (mean ± SD; n = 220 analyzable): | | Tizanidine | /111 (58%) | | | | | Method of randomization clearly described? No
| | | Tizanidine: 44.5 ± 9.4 | | Placebo | /109 (60%) | | | | | Concealment of allocation? Unclear
| | | Placebo: 46.1 ± 9.6 | | P = 0.83 | | | | | | Described as “double-blind”? Yes
| | | Baseline EDSS: NR | | Other (non-improvement) outcomes: | | | | | | Patients blinded? Yes
| | | | | Ashworth | adj. mean change (± SD) | | | | | Investigators blinded? Yes
| | | | | Tizanidine | -2.03 ± 7.22 | | | | | Outcome assessors blinded? Yes
| | | | | Placebo | -2.73 ± 7.17 | | | | | No. of withdrawals in each group stated? Yes
| | | | | P = 0.46
| | | | | Spasms & clonus response ratio (% change):
| | | | | Tizanidine | -0.44± 0.45 | -61.1± 118
| | | | | Placebo | -0.26± 0.44 | -41.0± 102
| | | | | | P = 0.028 | p = NS
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | 101 (91%) tizanidine
| | | | | 66 (61%) placebo
| | | | | Dry mouth, asthenia, somnolence, dizziness, increased SGOT/AST
| | | | | Serious AE - hepatitis (n = 1), hallucinations (n = 1)
| | | | | Discontinuations:
| | | | | 14/111 (13%) tizanidine
| | | | | 6/109 (6%) placebo
Smolenski, Muff, and Smolenski-Kautz, 1981 | Inclusion: MS; hospitalized; stable spasticity for ≥ 2 mo | RCT (parallel-group, double-blind, single-center) | No. of patients randomized: 21 | 1) Tizanidine PO 4 mg capsules; dose initiated at 2 capsules per day and gradually increased during first few weeks to optimal level (usually between 3 and 6 capsules per day in 3 divided doses); treatment continued for 6 wk (n = 11) | 1) Symptom-specific functional status/ quality-of-life outcomes: Muscle strength, Ashworth, spasms | | | | | | Multiple measures
| Exclusion: History or evidence of cardiac, renal, or hepatic disease; severe hypertension; epilepsy; chronic alcoholism; diabetes; overt psycho-pathology | Duration of study treatment/follow up: 6 wk | Dropouts: 0 | 2) Baclofen PO 10 mg capsules; dose initiated at 2 capsules per day and gradually increased during first few weeks to optimal level (usually between 3 and 6 capsules per day in 3 divided doses); treatment continued for 6 wk (n = 10) | Definition of “improvement”: Not described | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (presumably neurologists) | Completed: 21 | | Proportion of patients with “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Bern, Switzerland | Age (mean ± SD): | | Ashworth (muscle tone) | | | | | | Method of randomization clearly described? No
| | | Tizanidine: 53 ± 11 | | Reported by muscle group | | | | | | Concealment of allocation? Unclear
| | | Baclofen: 55 ± 10 | | | Tizanidine | Baclofen | | | | Described as “double-blind”? Yes
| | | Baseline EDSS: NR | | Left leg | 8/11 | 9/10 | | | | Patients blinded? Yes
| | | | | Right leg | 6/11 | 8/10 | | | | Investigators blinded? Yes
| | | | | Left foot | 8/11 | 8/10 | | | | Outcome assessors blinded? Yes
| | | | | Right foot | 8/10 | 8/10 | | | | No. of withdrawals in each group stated? Yes
| | | | | Spasms (reported by muscle group):
| | | | | | Tizanidine | Baclofen
| | | | | Flex left leg | 6/8 | 4/7
| | | | | Flex right leg | 5/8 | 6/8
| | | | | Ext left leg | 7/9 | 6/8
| | | | | Ext right leg | 7/9 | 8/9
| | | | | Abd left leg | 4/7 | 5/8
| | | | | Abd right leg | 4/7 | 7/9
| | | | | Other (non-improvement) outcomes:
| | | | | Overall spastic state, spasms and clonus were similarly improved with both medications
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | Tizanidine (tiredness, weakness, dry mouth, ataxia)
| | | | | Baclofen (weakness, dry mouth, nausea, pyrosis)
| | | | | No withdrawals due to AEs
Snow, Tsui, Bhatt, et al., 1990 | Inclusion: Stable, chronic MS; chair- or bed-bound (EDSS 8.0–9.5); resident at one of two long-stay institutions; spastic contraction of adductor muscles that interfered with sitting, positioning in bed, cleaning, or urethral catheterization; not currently taking anti-spastic medication (most unresponsive in past) | RCT (crossover, double-blind, two-center) | No. of patients randomized: 10 | 1) Botulinum-A toxin, single IM injection of 400 mouse units (160 ng) | 1) Symptom-specific functional status/ quality-of-life outcomes: Spasticity score = Ashworth (muscle tone)+spasm frequency; Hygiene score. | | | | | | Small preliminary study; severely spastic patients with very high EDSS scores
| Exclusion: None specified | Duration of study treatment/follow up: Single injections given for each treatment, with follow up at 2 and 6 wk; 3 mo between two treatment periods/injections | Dropouts: 1 | 2) Placebo injection | Definition of “improvement”: None defined | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (presumably neurologists) | Completed: 9 | 3 mo between injections | Proportion of patients with “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 2 sites in Vancouver, British Columbia, Canada | Age (mean, with range): 40.2 (23–61) | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? Yes
| | | Baseline EDSS: 8.0 to 9.5 | | Spasticity score @ 6 wk | | | | | | Concealment of allocation? No
| | | | | Botulinum | 7.9± 4.9 | 4.7± 4.3 | | | | Described as “double-blind”? Yes
| | | | | Placebo | 6.8± 5.3 | 7.1 ± 4.8 | | | | Patients blinded? Yes
| | | | | p-value | 0.009 | | | | | Investigators blinded? Yes
| | | | | Hygiene score @ 6 wk better for botulinum than placebo (p = 0.02) | | | | | | Outcome assessors blinded? Yes
| | | | | 2) Physical functioning: NR | | | | | | No. of withdrawals in each group stated? Yes
| | | | | 3) Cognitive functioning: NR | | | | | | Crossover trials only:
| | | | | 4) Work or employment outcomes: NR | | | | | | Period or carry-over effects? No
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Washout period? Yes (3 mo)
| | | | | 6) Adverse events: NR | | | | | | No. of patients in each sequence clearly described? Yes
| | | | | | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
Solari, Filippini, Gasco, et al., 1999 | Inclusion: Clinically definite or laboratory-supported MS; EDSS 3.0–6.5; age 18–65 | RCT (parallel-group, single-blind [evaluating physician only], single-center) | No. of patients randomized: 50 (11 relapsing-remitting, 8 primary progressive, 31 secondary progressive) | 1) Inpatient physical rehabilitation program (n = 27); twice daily exercise periods of 45 min each for 3 consecutive wk; for patients with EDSS ≤ 4.5, main goals were normalization of postural control, facilitation of normal gait pattern, increasing range of movement, and maximizing muscle power and endurance; for those with EDSS > 4.5, program also included instruction in use of mobility aids and orthoses and refinement of compensatory strategies. Patients given home exercise program at conclusion of inpatient program. | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | QUALITY ASSESSMENT:
| Exclusion: 1 or more exacerbations in preceding 3 mo; cognitive impairment likely to interfere with study adherence (Mini-Mental State Examination score ≤ 23.8, after adjustment for age and education); history of cardio-vascular, respiratory, orthopedic, psychiatric, or other medical conditions precluding participa-tion; pregnancy; treatment with immunosuppres-sants, interferons, copolymers, 4-aminopyridine, or experimental drugs in previous 6 mo; rehabilitation therapy in previous 3 mo | Duration of study treatment/follow up: Inpatient program lasted 3 wk; patients followed for total of 15 wk | Dropouts: 5 | 2) Home exercise program (control) (n = 23) | 2) Physical functioning: EDSS; Functional Independence Measure (FIM) motor domain | | | | | | Described as “randomized”? Yes
| | Provider specialty: Neurologists and physiotherapists | Completed: 45 | | Definition of “improvement”: | | | | | | Method of randomization clearly described? Yes
| | Location: 1 site in Milan, Italy | Age (mean ± SD): | | EDSS - 1-step improvement | | | | | | Concealment of allocation? Yes
| | | Rehab: 44.6 ± 10.2 | | FIM motor - 2- or more step improvement | | | | | | Described as “double-blind”? No
| | | Control: 44.9 ± 10.6 | | Proportion of patients with “improvement”: | | | | | | Patients blinded? No
| | | Baseline EDSS (median, with range): | | EDSS 1/27 study group; 0/23 control group | | | | | | Investigators blinded? No
| | | Rehab: 5.5 (3.0–6.5) | | FIM motor | Intervention | Control | | | | Outcome assessors blinded? Yes
| | | Control: 5.5 (3.5–7.0) | | 3 weeks | 13/27 (48%) | 2/23 (9) (p = 0.001) | | | | No. of withdrawals in each group stated? Yes
| | | | | 9 weeks | 12/27 (44%) | 1/23 (4%) (p = 0.001)
| | | | | Other (non-improvement) outcomes:
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: SF-36
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | SF-36
| | | | | component | Intervention | Control | p
| | | | | 3wk
| | | | | Physical | 3.8 ±6.7 | 3.3 ±8.4 | 0.7
| | | | | Mental | 5.2 ±7.0 | -0.77 ±7.3 | 0.008
| | | | | 9 wk
| | | | | Physical | 3.7±10 | 1.6±12
| | | | | Mental | 4.8±9.9 | -5.3±15
| | | | | 15 wk
| | | | | Physical | 3.2±6.5 | 0.26±7.9
| | | | | Mental | 2.1±9.7 | 0.26±7.9
| | | | | 6) Adverse events: NR
Stien, Nordal, Oftedal, et al., 1987 | Inclusion: Definite MS (McAlpine 1972); resident at one of several nursing homes for neurological patients; in stable phase of the disease for ≥ 3 mo | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 40 | 1) Tizanidine 4 mg capsules (n = 19); dose gradually increased over first 2 wk to maximum of 5 capsules per day (20 mg, given in 3 divided doses); during last 4 wk, daily dose carefully adjusted for each patient, weighing anti-spastic effect vs. side effects; mean daily dose, 23 mg; range, 4–36 mg | 1) Symptom-specific functional status/ quality-of-life outcomes: Functional disability (Pedersen) | | | | | | Study power too low to detect differences between these drugs
| Exclusion: Mental diseases; overt signs of dementia | Duration of study treatment/follow up: 6 wk | Dropouts: 2 | 2) Baclofen 10 mg capsules (n = 21); dose gradually increased over first 2 wk to maximum of 5 capsules per day (50 mg, given in 3 divided doses); during last 4 wk, daily dose carefully adjusted for each patient, weighing anti-spastic effect vs. side effects; mean daily dose, 59 mg; range, 20–90 mg | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Neurologists | Completed: 38 | | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | Location: Multiple sites (number NR) in Oslo, Norway | Age (median, with range; n = 38 completers): | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | Tizanidine: 50 (29–70) | | Neither tizanidine nor baclofen induced significant changes in functional disability (Pedersen) [data not shown] | | | | | | Concealment of allocation? Unclear
| | | Baclofen: 45 (26–66) | | 2) Physical functioning: Tendon reflexes; muscle tone (Ashworth scale); provoked or spontaneous spasm activity; muscle strength in extremities; Kurtzke's scale | | | | | | Described as “double-blind”? Yes
| | | Baseline EDSS: NR | | Definition of “improvement”: Not described | | | | | | Patients blinded? Yes
| | | | | Proportion of patients with “improvement”: | | | | | | Investigators blinded? Yes
| | | | | | Tizanidine | Baclofen | p-value | | | Outcome assessors blinded? Yes
| | | | | Clonus | 7/18(39%) | 9/20 (45%) | NS | | | No. of withdrawals in each group stated? Yes
| | | | | Musc tone | 13/18 (72%) | 13/20 (65%) | NS
| | | | | Spasms | 12/18 (76%) | 13/20 (65%) | NS
| | | | | Strength | 2/18 (11%) | 2/20 (10%) | NS
| | | | | Other (non-improvement) outcomes:
| | | | | Neither tizanidine nor baclofen induced significant changes in neurological disability (Kurtzke's scale) [data not shown].
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | AEs were “mild” and dose-dependent
| | | | | Tizanidine n = 6 (tiredness, weakness, sleepiness, dry mouth)
| | | | | Baclofen n = 5 (weakness, tiredness)
| | | | | Withdrawals due to AE: tizanidine (n = 1) subjective stiffness; baclofen (n = 1) gastroenteritis
Stuifbergen, Becker, Blozis, et al., 2003 | Inclusion: Physician-diagnosed MS for at least 6 mo; female sex; age 20–70 | RCT (parallel-group, open-label, multicenter) | No. of patients randomized: 142 | 1) Wellness intervention (n = 56); two phases - a) an educational and skill-building lifestyle change program (8 sessions over 8 wk that presented information, guided participants in self-assessment of behaviors, resources, and barriers, and supported specific strategies aimed at building self-efficacy for health behaviors; b) supportive telephone follow-up (biweekly calls for 3 mo) | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | Authors acknowledge that population was a convenience sample and may reflect selection bias; may not be representative of MS population at large because of recruitment through MS Society. Such women may be more interested in health behaviors than other women with MS.
| Exclusion: Pregnancy; concurrent medical conditions for which changes in exercise and diet would be contraindicated | Duration of study treatment/follow up: Active treatment lasted 5 mo; patients followed up for total of 8 mo | Dropouts: 29 failed to provide minimal data needed to be included in analysis | 2) Usual care (n = 57) | 2) Physical functioning: NR | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Clinical nurse specialist and woman with MS (intervention facilitators), dietician, fitness instructor, nurse practitioner associated with a woman's wellness center, and a counselor | Completed: 113 | | 3) Cognitive functioning [describe scale/ instrument used]: | | | | | | Described as “randomized”? Yes
| | Location: Outpatients recruited from two large metropolitan areas | Age: Mean ± SD, 45.8 ± 10.1; range, 21–70 | | Definition of “improvement”: | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR | | Proportion of patients with “improvement”: | | | | | | Concealment of allocation? Unclear
| | | | | Other (non-improvement) outcomes: | | | | | | Described as “double-blind”? No
| | | | | Self-rate [results?] | | | | | | Patients blinded? No
| | | | | 4) Work or employment outcomes: Proportion employed | | | | | | Investigators blinded? No
| | | | | Definition of “improvement”: None | | | | | | Outcome assessors blinded? No
| | | | | Proportion of patients with “improvement”: NA | | | | | | No. of withdrawals in each group stated? No
| | | | | Other (non-improvement) outcomes:
| | | | | By month 8, women in the intervention group were more likely to be employed than women in the control group (p < 0.05)
| | | | | 5) Generic quality-of-life outcomes: Self-Rated Abilities Scale (measure of self-efficacy); Barriers Scale; Personal Resources Questionnaire (measure of social support); Health Promoting Lifestyle Profile-II (HPLP-II); SF-36
| | | | | Definition of “improvement”:
| | | | | Proportion of patients with “improvement”:
| | | | | Other (non-improvement) outcomes:
| | | | | | Control | Interv | p-value
| | | | | Self-efficacy | 84± 19 | 94±14 | <0.01
| | | | | Barriers | 32±8.4 | 31±7.5 | NS
| | | | | PRQ | 143±22 | 145±22 | NS
| | | | | HPLP-II
| | | | | Total | 147±23 | 158±22 | <0.01
| | | | | SF-36 scales
| | | | | PF | 40±31 | 51±29 | NS
| | | | | RP | 41±42 | 47±44 | NS
| | | | | BP | 64±28 | 67±25 | <0.05
| | | | | GH | 60±24 | 57±25 | NS
| | | | | VT | 41±22 | 44±22 | NS
| | | | | SF | 70±24 | 70±26 | NS
| | | | | RE | 66±42 | 76±36 | NS
| | | | | MH | 71±20 | 75±15 | <0.05
| | | | | 6) Adverse events: NR
United Kingdom Tizanidine Trial Group, 1994 | Inclusion: Spasticity secondary to clinically definite, laboratory-supported, or probable MS; stable disease during previous 1 mo; no concomitant neurological illness likely to alter muscle tone; age 18–75 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 187 (102 clinically definite MS, 58 laboratory-supported, 27 probable) | 1) Tizanidine PO (n = 94), titrated over a 3-wk period between 2 and 36 mg daily to the maximum tolerated dose; this dose then maintained for 9 more weeks; dose then tapered over 1-wk period | 1) Symptom-specific functional status/ quality-of-life outcomes: Intermediate motor skills (turning, lying, and transfer); upper extremity functions; ADL (items from Kurtzke Incapacity Status Scale); impact of spasticity on quality of life (5-point scale) | | | | | | Used intention-to-treat analysis
| Exclusion: Use of immunosuppressant drugs during previous 1 mo or cortico-steroids during previous 3 mo; uncontrolled hypertension (SBP > 180 mmHg, DBP > 120 mmHg) or hypotension (SBP < 90 mmHg, DBP < 60 mmHg); systemic disease; abnormalities on routine clinical lab tests; active bedsores, infection, or contractures | Duration of study treatment/follow up: 12 wk treatment (3 wk dose titration, followed by 9 wk at maximum tolerated dose), plus 1-wk tapering period; last follow up visit at 14 wk | Dropouts: 32 excluded from completers' analysis for more than minor protocol violations; 51 withdrew prematurely | 2) Placebo (n = 93) (with dose titration, as above) | Definition of “improvement”: Not described | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR | Completed: 155 included in completers' analysis; 136 completed entire study | | Proportion of patients with “improvement”: | | | | | | Described as “randomized”? Yes
| | Location: 16 sites throughout the UK | Age (mean ± SD): 47 ± 9 | | | Tizan | Pbo | p-value | | | Method of randomization clearly described? No
| | | Baseline EDSS: NR | | Intermed fn | 20% | 10% | NS | | | Concealment of allocation? Unclear
| | | | | Upper limb fn | 6% | 5% | NS | | | Described as “double-blind”? Yes
| | | | | Impact on PT | 40% | 21% | NS | | | Patients blinded? Yes
| | | | | Nursing care | 22% | 4% | 0.09 | | | Investigators blinded? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | Outcome assessors blinded? Yes
| | | | | 2) Physical functioning: Muscle tone (Ashworth scale) | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Definition of “improvement”: Decrease by at least 1 point on Ashworth
| | | | | Proportion of patients with “improvement”:
| | | | | Tizanidine | 67/94 (71%)
| | | | | Placebo | 46/93 (50%)
| | | | | Other (non-improvement) outcomes:
| | | | | ITT analysis Muscle tone | EDSS
| | | | | | Baseline | Week 12 | change
| | | | | Tizanidine | 1.85±9.4 | 14.6±10.1 | 0.1
| | | | | Placebo | 16.8±11.1 | 15.3±10 | 0
| | | | | P-value | ≤0.004 | NS
| | | | | Strength | Baseline | Week 12 | change
| | | | | Tizanidine | 71±16 | 73±16 | +4
| | | | | Placebo | 72±14 | 74±13 | +3
| | | | | P-value | NS
| | | | | Spasms | Baseline | Week 12 | change
| | | | | (freq)
| | | | | Tizanidine | 6.3±6.6 | 5.5±7.0 | -13
| | | | | Placebo | 5.2±5.8 | 4.4±6.0 | -15
| | | | | P-value | NS
| | | | | DTRs | Baseline | Week 12 | change
| | | | | Tizanidine | 18±7.1 | 16±7.1 | -9
| | | | | Placebo | 17±6.5 | 17±6.8 | -4
| | | | | P-value | NS
| | | | | Timed walk | Baseline | Week 12 | change
| | | | | (sec for 8m)
| | | | | Tizanidine | 20±20 | 21±34 | +4
| | | | | Placebo | 28±31 | 25±26 | -10
| | | | | P-value | NS
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events:
| | | | | | Tizanidine | Placebo
| | | | | Total no. AEs | 669 | 261
| | | | | No. pts with AEs | 82 (87%) | 57 (61%)
| | | | | Dropouts due to AEs | 12 (13%) | 5 (5%)
| | | | | Dry mouth; drowsiness, tiredness
Vahtera, Haaranen, Viramo-Koskela, et al., 1997 | Inclusion: Clinically definite MS by Poser criteria; in stable phase of disease; EDSS ≤ 6.5; current symptoms of lower urinary tract disorder; post-void residual volume ≤ 100 mL on ultrasound | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 80 | 1) Pelvic floor rehabilitation (n = 40); consciousness of action of pelvic floor muscles stimulated using electrical stimulation at 6 sessions over 2 wk; at final session, patients taught by biofeedback to exercise pelvic floor muscles and advised to continue these exercises 3–5 times per week for at least 6 mo | 1) Symptom-specific functional status/ quality-of-life outcomes [describe scale/instrument used]: | | | | | | Uncertain validity of symptom measures; multiple assessments and statistical tests; potential for type I error
| Exclusion: Pregnancy; cardiac pacemaker or any metallic implant near the treated area; history of pelvic malignancy; dementia; any nervous system disorder other than MS | Duration of study treatment/follow up: 6.5 mo | Dropouts: 0 lost to follow up; in active group, 25/40 exercising regularly at 6 mo, 12/40 exercising irregularly, and 3/40 not exercising at all | 2) No-treatment control (n = 40) | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR | Completed: 80 (see immediately above on compliance) | | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Masku, Finland | Age (mean, with range): | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | Active: 43.4 (25–57) | | Incontinence and nocturia at week 3 and months 2 and 6 were significantly less frequent in treatment than control group (p < 0.05) | | | | | | Concealment of allocation? Unclear
| | | Control: 44.2 (26–68) | | No differences in frequency of acute UTIs | | | | | | Described as “double-blind”? No
| | | Baseline EDSS (mean, with range): | | Urinary symptom related handicap at month 6 lower for treatment than control (traveling, social shame, need of diapers) (p < 0.05) | | | | | | Patients blinded? No
| | | Active: 4.4 (1.0–6.5) | | 2) Physical functioning: NR | | | | | | Investigators blinded? No
| | | Control: 4.3 (1–6.5) | | 3) Cognitive functioning: NR | | | | | | Outcome assessors blinded? No
| | | | | 4) Work or employment outcomes: NR | | | | | | No. of withdrawals in each group stated? Yes
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: None reported
Valiquette, Herbert, and Meade-D'Alisera, 1996 | Inclusion: Clinically definite or laboratory-supported definite MS by Poser criteria; relapsing-remitting or progressive forms of disease; MS in remission for at least 3 mo; 2 or more episodes of nocturia in typical night or (for patients with limited mobility) any number of micturitions or episodes of incontinence per night; age 18–70 | RCT (crossover, double-blind, single-center) | No. of patients randomized: 17 (5 relapsing-remitting, 4 relapsing-progressive, 8 chronic progressive) | 1) Desmopressin administered as a nasal spray, one 10-μg dose per day at bedtime for 2 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: Proportion of nights with nocturia; proportion of nights with incontinence; number of episodes of nocturia per night; maximum uninterrupted sleep hours | | | | | | QUALITY ASSESSMENT:
| Exclusion: Evidence or history of hypertension, thrombotic events, or cardiovascular, thyroid, or renal disease; use of pulsed steroid therapy or short course of immuno-suppressive therapy in previous 3 mo | Duration of study treatment/follow up: 2 wk with each treatment; 6 wk total (2-wk run-in, two 2-wk treatment periods, no washout) | Dropouts: 6 | 2) Placebo nasal spray for 2 wk | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR (neurologists?) | Completed: 11 | No washout between treatment periods | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? No
| | Location: 1 site in West Haverstraw, NY | Age (mean, with range): 48.9 (26–70) | | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS (mean, with range): 6.7 (2.5–8.5) | | | Mean diff | p-value | | | | Described as “double-blind”? Yes
| | | | | Nocturia, mean* | -0.74 | <0.01 | | | | Patients blinded? Yes
| | | | | Incontinence | -0.36 | 0.08 | | | | Investigators blinded? Yes
| | | | | Nocturia, freq | -2.2 | <0.01 | | | | Outcome assessors blinded? Yes
| | | | | Max uninterrupted | 4.28 | <0.01 | | | | No. of withdrawals in each group stated? No
| | | | | Sleep (hrs)* | | | | | | Crossover trials only:
| | | | | *Carry-over effect observed, only period 1 data analyzed. | | | | | | Period or carry-over effects? Yes
| | | | | 2) Physical functioning: NR | | | | | | Washout period? No
| | | | | 3) Cognitive functioning: NR | | | | | | No. of patients in each sequence clearly described? Yes
| | | | | 4) Work or employment outcomes: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: Hyponatremia requiring discontinuation (n = 4)
Wassem and Dudley, 2003 | Inclusion: MS | RCT (parallel-group, open-label, single-center) | No. of patients randomized: 27 | 1) Intensive outpatient intervention (n = NR); four weekly 2-hr group sessions; included education about MS, instruction in relaxation techniques, and discussion of dietary concerns, symptom management, psychosocial issues, memory and cognitive problems, etc. | 1) Symptom-specific functional status/ quality-of-life outcomes: Fatigue, sleep and pain severity (VAS) | | | | | | Study used alpha = 0.10 rather than conventional level of 0.05 for hypothesis testing
| Exclusion: None specified | Duration of study treatment/follow up: Active treatment lasted 4 wk; patients followed up for total of 4 yr | Dropouts: 11 | 2) Usual care (n = NR) | Definition of “improvement”: None | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: Advance practice nurses | Completed: 16 | | Proportion of patients with “improvement”: NA | | | | | | Described as “randomized”? Yes
| | Location: 1 site in Utah | Age: Mean, 44; range, 18–54 | | Other (non-improvement) outcomes: | | | | | | Method of randomization clearly described? No
| | | Baseline EDSS: Mean, 3.36; range, 0–9 | | Fatigue levels were lower for intervention than control at most data collection points (p = 0.09) | | | | | | Concealment of allocation? Unclear
| | | | | Sleep disturbance scores were significantly better for intervention compared to control (p = 0.07) | | | | | | Described as “double-blind”? No
| | | | | Pain levels were not significantly different for intervention compared to control (P = NS) | | | | | | Patients blinded? No
| | | | | Sum of symptom severity scores improved for intervention compared to control (p = 0.03) | | | | | | Investigators blinded? No
| | | | | 2) Physical functioning: | | | | | | Outcome assessors blinded? No
| | | | | Modified DSS | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Definition of “improvement”:
| | | | | Proportion of patients with “improvement”:
| | | | | Other (non-improvement) outcomes:
| | | | | 3) Cognitive functioning: Self-Efficacy for Adjustment Behaviors (SEAB) scale (26 behaviors × 4-point responses ranging from 0 [no confidence in being able to perform the behavior] to 4 [total confidence ]); Psychosocial Adjustment to Illness Scale-Self-Report (PAIS-SR);
| | | | | Definition of “improvement”: None
| | | | | Proportion of patients with “improvement”: NA
| | | | | Other (non-improvement) outcomes:
| | | | | SEAB scores were not significantly different for intervention compared to control (p = 0.55)
| | | | | PAIS-SR scores were not significantly different for intervention compared to control (p = 0.72)
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Wein-shenker, Penman, Bass, et al., 1992 | Inclusion: Clinically definite MS; severe fatigue for ≥ 3 mo; age 18–65 | RCT (crossover, double-blind, two-center) | No. of patients randomized: 46 | 1) Pemoline PO in 18.75-mg capsules; dose gradually increased during first week from 1 capsule (18.75 mg) to maximum of 4 capsules (75 mg) per day; maintenance dose then continued for additional 4 wk | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | QUALITY ASSESSMENT:
| Exclusion: Pregnant or not practicing birth control; epilepsy; psychiatric disease; drug abuse; major medical illness | Duration of study treatment/follow up: 5 wk with each treatment, 12 wk total (two 5-wk treatment periods, 2-wk washout) | Dropouts: 5 | 2) Placebo, with dose adjustments as above, for total of 5 wk | 2) Physical functioning: EDSS; fatigue (50-mm VAS); relief of fatigue (4-point scale) | | | | | | Described as “randomized”? Yes
| | Provider specialty: NR | Completed: 41 | 2-wk washout between treatment periods | Definition of “improvement”: Excellent/good versus fair/poor rating on relief of fatigue | | | | | | Method of randomization clearly described? No
| | Location: 2 sites in Ontario, Canada | Age (mean ± SD): 42.6 ± 10.6 | | Proportion of patients with “improvement”: | | | | | | Concealment of allocation? Unclear
| | | Baseline EDSS (mean ± SD): 3.6 ± 2.0 | | Trend toward better relief of fatigue on pemoline than placebo (p = 0.06) | | | | | | Described as “double-blind”? Yes
| | | | | Other (non-improvement) outcomes: | | | | | | Patients blinded? Yes
| | | | | All patients remained within 1.0 point on the EDSS score during the course of the study (except for patients who were withdrawn due to exacerbations. | | | | | | Investigators blinded? Yes
| | | | | No significant difference in fatigue (VAS) between pemoline and placebo. | | | | | | Outcome assessors blinded? Yes
| | | | | 3) Cognitive functioning: Modified Beck self-rating depression inventory | | | | | | No. of withdrawals in each group stated? Yes
| | | | | Definition of “improvement”: | | | | | | Crossover trials only:
| | | | | Proportion of patients with “improvement”: | | | | | | Period or carry-over effects? No
| | | | | Other (non-improvement) outcomes: | | | | | | Washout period? Yes (2 wk)
| | | | | 4) Work or employment outcomes: NR | | | | | | No. of patients in each sequence clearly described? Yes
| | | | | 5) Generic quality-of-life outcomes: NR | | | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | 6) Adverse events:
| | | | | AEs experienced by > 25% while receiving pemoline:
| | | | | Irritability (n = 15); insomnia (12), anorexia (17), and nausea (13).
Wiles, Newcombe, Fuller, et al., 2001 | Inclusion: Definite or probable MS; difficulty walking, but able to walk 5 meters with or without a mechanical aid; not in a current relapse; free of other major general medical or surgical disorders and pregnancy; age ≥ 18 | RCT (crossover, single-blind [assessors only], single-center) | No. of patients randomized: 42 | 1) Home physio-therapy; two 45-min sessions per wk for 8 wk; individualized problem-solving approach, focusing on specific functional activities | 1) Symptom-specific functional status/ quality-of-life outcomes: Rivermead mobility index; balance time; Walk A; 9-hole peg | | | | | | QUALITY ASSESSMENT:
| Exclusion: None specified | Duration of study treatment/follow up: 8 wk with each treatment, 48 wk total (three 8-wk treatment periods, two 8-wk washouts, one 8-wk follow-up period) | Dropouts: 2 | 2) Hospital outpatient physiotherapy, as above, but focusing on specific facilitation techniques | Definition of “improvement”: None | | | | | | Described as “randomized”? Yes
| | Provider specialty: Neurophysio-therapists | Completed: 40 | 3) No physiotherapy for 8 wk | Proportion of patients with “improvement”: NA | | | | | | Method of randomization clearly described? Yes
| | Location: 1 site in Cardiff, UK | Age: Mean, 47.2; range, 28.2–68.8 | 8-wk washout period between treatment periods | Other (non-improvement) outcomes: | | | | | | Concealment of allocation? Yes
| | | Baseline EDSS: Mean, 6.0 | | | Treatment | | | | | Described as “double-blind”? No
| | | | | | None | Hosp | Home | | | Patients blinded? No
| | | | | Mobil | 9.1 ± 3.9 | 10.5 ± 3.5 | 10.6 ± 2.9 | | | Investigators blinded? No
| | | | | Index | p < 0.001 | p < 0.001 | | | | Outcome assessors blinded? Yes
| | | | | Bal | 15.0 ± 13.8 | 19.9 ± 13.2 | 19.7 ± 13.2 | | | No. of withdrawals in each group stated? No
| | | | | time | p = 0.004 | p = 0.001 | | | | Crossover trials only:
| | | | | Walk | 148 ± 129 | 148 ± 129 | 138 ± 108 | 138 ± 110 | | Period or carry-over effects? No
| | | | | A | p = 0.003 | p = 0.002 | | | | Washout period? Yes (8 wk)
| | | | | 9-hole | 207 ± 85 | 190 ± 69 | 194 ± 70 | | | No. of patients in each sequence clearly described? No
| | | | | peg | p = 0.014 | p = 0.076 | | | | Were patients who did not complete all of the periods excluded from the analysis? Yes
| | | | | Global | 46 ± 11 | 44 ± 11 | 44 ± 14
| | | | | Mobility | p < 0.001 | p < 0.001
| | | | | 2) Physical functioning: NR
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR
Zajicek, Fox, Sanders, et al., 2003 | Inclusion: Clinically definite or laboratory-supported MS; stable disease for previous 6 mo (in the opinion of the treating physician); problematic spasticity (Ashworth score ≥ 2 in two or more lower limb muscle groups); age 18–64 | RCT (parallel-group, double-blind, multicenter) | No. of patients randomized: 657 | 1) Cannabis extract containing delta-9- tetrahydrocannabinol (THC) and cannabidiol PO (n = 211); each capsule contained 2.5 mg of delta-9-THC equivalent, 1.25 mg of cannabidiol, and < 5% other cannabinoids; initiated at one capsule (2.5 mg delta-9-THC equivalent) twice daily, then increased by one capsule twice daily every wk, as tolerated, during 5-wk dose titration period; maximum daily dose 25 mg (10 capsules) | 1) Symptom-specific functional status/ quality-of-life outcomes: NR | | | | | | “There was a degree of unmasking among patients in the active treatment groups” which should have been expected to bias the study toward showing a benefit; may be responsible for a statistically significant subjective effect, but no significant objective effect on spasticity.
| Exclusion: Ischemic heart disease; active sources of infection; use of medication that could affect spasticity; not able to avoid driving while on study; fixed-tendon contractures; severe cognitive impairment; history of psychotic illness; other major illness; pregnancy; any previous use of delta-9-tetrahydro-cannabinol; use of cannabis in previous 30 days | Duration of study treatment/follow up: Treatment lasted 14 wk; patients followed for an additional (15^th^) wk | No. treated and included in ITT analysis: 630 (452 secondary progressive, 145 primary progressive, 33 relapsing-remitting) | 2) Synthetic delta-9- tetrahydrocannabinol (THC) PO (n = 206); initiated at one capsule (2.5 mg) twice daily, then increased by one capsule twice daily every wk, as tolerated, during 5-wk dose titration period; maximum daily dose 25 mg (10 capsules) | 2) Physical functioning: Ashworth scale - overall (upper and lower extremity); subjective spasticity (improved, same, deteriorated); mobility (10-m walk time) | | | | | | QUALITY ASSESSMENT:
| | Provider specialty: NR (presumably neurologists) | Dropouts (from ITT population): 19 | 3) Placebo, with dose titration as above (n = 213) | Definition of “improvement”: None provided | | | | | | Described as “randomized”? Yes
| | Location: 33 neurology and rehabilitation centers in the UK | Completed: 611 | | Proportion of patients with “improvement”: | | | | | | Method of randomization clearly described? Yes
| | | Age (mean ± SD): | | Cannabis extract | 61% | | | | | Concealment of allocation? Yes
| | | Cannabis: 50.5 ± 7.6 | | Delta-9-THC | 60% | | | | | Described as “double-blind”? Yes
| | | Delta-9-THC: 50.2 ± 8.2 | | Placebo | 46% p = 0.003 | | | | | Patients blinded? Unclear
| | | Placebo: 50.9 ± 7.6 | | Other (non-improvement) outcomes: | | | | | | Investigators blinded? Yes
| | | Baseline EDSS: | | Ashworth score: No treatment effect overall (p = 0.4); estimated difference in mean reduction in total Ashworth score: | | | | | | Outcome assessors blinded? Yes
| | | 0-3.5: 3 | | Cannabis extract | 0.32 (-1.04 to 1.67) | | | | | No. of withdrawals in each group stated? Yes
| | | 4-5.5: 23 | | Delta-9-THC | 0.94 (-0.44 to 2.31)
| | | 6–6.5: 299 | | Reduction in 10-m walk time from baseline to visit 7
| | | 7–9: 299 | | Cannabis extract | 4% (0 to 10%)
| | | NR: 6 | | Delta-9-THC | 12% (6 to 21%)
| | | | | Placebo | 4% (-2 to 7%)
| | | | | P = 0.015
| | | | | 3) Cognitive functioning: NR
| | | | | 4) Work or employment outcomes: NR
| | | | | 5) Generic quality-of-life outcomes: NR
| | | | | 6) Adverse events: NR

Evidence Table 4. Association of clinical findings with work ability

Study | Selected Inclusion/Exclusion Criteria | Study Design | Patients | Findings Considered | Results | Comments/Quality Scoring
Beatty, Blanco, Wilbanks, et al., 1995 | Inclusion: | Cross-sectional study | N = 102 | 1) Physical: | No direct measure of work capacity or ability | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| Clinically definite MS by Poser criteria; adequate vision to read a newspaper; judged able to complete a 2.5- to 3-hr battery of neuro-psychological tests; age < 65 | Location/recruitment: Patients recruited from practices of collaborating neurologists (n = 50) and from support groups (n = 52) in the areas of Tulsa and Oklahoma City, OK | Age (mean ± SD): | Ambulation Index | Work status measured through self-report | Duration of “retirement” at time of study was not considered;
| Exclusion: History of alcohol or drug abuse; serious head injury; learning disability; recent or complicated heart attack; uncontrolled hypertension; metabolic disease; CNS disease other than MS; major psychiatric illness; history of depression (if major episode preceded onset of MS-like symptoms); MS relapse in previous 1 mo | Data collection: Work status self-reported by study participants; not clear how clinical data (medication use, time since diagnosis, etc.) collected; testing described below performed in a single 2.5- to 3-hr session, usually (94% of the time) conducted in patient's home; following tests administered: | Overall: 44.2 ± 7.8 (range, 29–62) | Visual Acuity | 49% of the variance in employment status was explained by walking ability, age, two measures of memory, and one test of verbal fluency. | All participants had been previously employed; however, employment status at time of diagnosis was not considered;
| | 1) Beck Depression Inventory | Employed subjects: 39.9 ± 6.1 | 2) Mental: | Partial R^2^: | Sample size may be too small to detect true differences between groups.
| | 2) Brief test of visual acuity | Retired subjects: 46.8 ± 7.8 | Beck Depression Inventory | Ambulation Index: 0.25 | Authors note study limitation regarding absence of a measure of upper limb dexterity. Functional losses of fine motor control of the hands, which might not be reflected in scores on the Ambulation Index, may have contributed to premature retirement of clerical and skilled trade workers.
| | 3) Ambulation Index | Baseline measures of physical and mental functioning: | Cognitive testing in 7 domains (see under “Study Design” for details; investigators also calculated a global measure of the severity of cognitive impairment = number of cognitive domains in which patient “impaired”) | Short Term Memory-Correct: 0.13 | Authors note that patients with global cognitive deficits can continue to work at intellectually demanding jobs.
| | 4) Handedness inventory | Ambulation Index (mean ± SD): | 3) Laboratory: None | Selective Reminding Test-Delay Recall: 0.04 | QUALITY ASSESSMENT:
| | 5) Neuropsychological testing in 7 domains: | Overall: 3.4 ± 2.6 | 4) Radiographic: None | Age (29–62 years): 0.03 | Study described as “population-based”?: Yes
| | -Verbal ability (Shipley Institute of Living Scale Vocabulary Test) | Employed: 1.8 ± 1.8 | 5) Other: | Letter fluency: 0.03 | Follow up > 80%?: No
| | -Attention/ concentration (Digit Span from the Wechsler Adult Intelligence Scale-Revised) | Retired: 4.3 ± 2.6 | Age | | Work outcomes assessed using a widely used scale?: Work status
| | -Information processing speed (letter fluency, category fluency, and Symbol Digit Modalities Test | Beck Depression Inventory (mean ± SD): | Years of education | | Work outcomes assessed in a blind fashion?: No
| | -Naming (15-item version of Boston Naming Test) | Overall: NR | Age at diagnosis | | If subgroups with different work ability identified:
| | -Visuospatial perception (Benton Line Orientation Test) | Employed: 10.4 ± 7.5 | Time since diagnosis | | a) was there adjustment for important prognostic factors? Yes
| | -Memory (Brown Peterson Short Term Memory Test, New Map Test, Selective Reminding Test) | Retired: 13.4 ± 8.8 | Sex | | b) was there independent validation?: NA
| | -Problem solving/ abstraction (Wisconsin Card Sorting Test, Shipley Institute of Living Scale Abstraction Test, and Conceptual Quotient) | Baseline work status: | Use of symptomatic medication
| | | Employed: 38 (33 full-time, 3 part-time, 2 at least half-time college students; homemakers not considered to be employed)
| | | Retired: 64 (all had once worked at full-time jobs and retired prematurely)
Beukelman, Kraft, and Freal, 1985 | Inclusion: MS diagnosis from at least one physician; follow-up services from either the University of Washington MS Clinic, the Puget Sound Chapter of the National MS Society, or the Neurological Disease Epidemiologic Study; moderate to severe symptoms | Cross-sectional study | N = 656 returned questionnaires (90% response rate) | 1) Physical: None | No direct measure of work capacity or ability | Comparison groups were not mutually exclusive (communication-disordered patients vs. all study subjects);
| Exclusion: None specified | Location/recruitment: Survey mailed to “persons diagnosed as having multiple sclerosis and residing in Western Washington [state]” | Age: | 2) Mental: Self-reported expressive communication disorder | Work status measured through self-report | Measurement of “communication disorder” was self-reported;
| | Data collection: | 1% ≤ 25 | 3) Laboratory: None | Those with communication disorder (n = 149, 23% of total sample) were asked whether their communication disorder interfered with employment; 3% responded positively. | Employment status prior to disease onset not considered;
| | 8-page questionnaire requesting information on symptom characteristics and patterns, employment, daily living activities, rehabilitation needs, presence and severity of an expressive communication disorder, and use of communication augmentation equipment | 23% 25–39 | 4) Radiographic: None | Employment patterns of communication-disordered group vs. total sample: | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| | | 39% 40–54 | 5) Other: None | 1) Full-time employment: Communication-disordered: 7% | No discussion section provided by authors where points about study bias and limitations discussed.
| | | 37% ≥ 55 | | Total sample: 17% | As pointed out by the authors, study subjects may be less critical of their communication limitations than a third-party pathologist, who may be more objective.
| | | Baseline measures of physical and mental functioning: NR | | Chi-square p < 0.001 | No data were provided about overall employment patterns among the population, so interpretation of study findings is limited.
| | | Baseline work status: NR | | 2) “Disabled employment”: | QUALITY ASSESSMENT:
| | | | | Communication-disordered: 56% (“larger percentage … as compared to the total sample”) | Study described as “population-based”?: No
| | | | | Total sample: NR | Follow up > 80%?: NA
| | | | | 3) Part-time employment: | Work outcomes assessed using a widely used scale?: Work status
| | | | | Communication-disordered: 3% | Work outcomes assessed in a blind fashion?: No
| | | | | Total sample: 4% | If subgroups with different work ability identified:
| | | | | | a) was there adjustment for important prognostic factors? No
| | | | | | b) was there independent validation?: NA
Canadian Burden of Illness Study Group, 1998a and Canadian Burden of Illness Study Group, 1998b | Inclusion: Clinically or laboratory-supported definite MS according to Poser criteria; age ≥ 18 | Cross-sectional study (cost analysis designed to estimate annual and lifetime costs of MS from the Canadian societal perspective); some data collected retrospectively for previous 3 mo | N = 198 (62 “mild” MS [EDSS ≤ 2.5], 68 “moderate” [EDSS 3.0–6.0], 68 “severe” [EDSS ≥ 6.5]) | 1) Physical: EDSS scores | No direct measure of work capacity or ability | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| Exclusion: Treatment with interferon-β; pregnancy or delivery in last 3 mo; any major acute or chronic disorder in last 3 mo; other neurological illness; recent participation in a drug trial | Location/recruitment: Patients recruited from 14 MS outpatient clinics across Canada | Types of MS (incomplete data): | 2) Mental: None | Work status measured through self-report | Sample size too small to examine changes between groups;
| | Data collection: Patients assessed using EDSS and SF-36; other data collected from patients and their families, clinic charts, hospital charts, and summaries of medical history from other institutions; cost data from various sources | Mild: 79% relapsing-remitting | 3) Laboratory: None | 1) Current employment status by EDSS category : | Employment status prior to disease onset not considered.
| | | Moderate: 43% relapsing-remitting, 43% secondary progressive | 4) Radiographic: None | EDSS ≤ 2.5: | Authors consider changes in employment status due to MS; however, study participants who may have been “unemployed” prior to disease onset were included in the analysis for EDSS vs. employment status.
| | | Severe: 57% secondary progressive, 41% primary progressive | 5) Other: None | 23 (37%) Full-time | QUALITY ASSESSMENT:
| | | Age (mean ± SD): | | 13 (21%) Part-time | Study described as “population-based”?: Yes
| | | Mild MS: 39.8 ± 9.5 | | 18 (29%) Unemployed | Follow up > 80%?: NA
| | | Moderate: 45.2 ± 10.7 | | 8 (13%) Other | Work outcomes assessed using a widely used scale?: Work status
| | | Severe: 49.6 ± 12.2 | | EDSS 3–6: | Work outcomes assessed in a blind fashion?: No
| | | Baseline measures of physical and mental functioning: See above for breakdown into EDSS categories; median EDSS scores within each category were: | | 19 (28%) Full-time | If subgroups with different work ability identified: NA
| | | Mild: 2.0 | | 7 (10%) Part-time | a) was there adjustment for important prognostic factors? No
| | | Moderate: 4.5 | | 30 (44%) Unemployed | b) was there independent validation?: NA
| | | Severe: 7.5 | | 12 (18%) Other
| | | Baseline work status: | | EDSS ≥ 6.5:
| | | Full-time: 23% | | 3 (4%) Full-time
| | | Part-time: 12% | | 4 (6%) Part-time
| | | Unemployed: 44% | | 39 (57%) Unemployed
| | | Other: 21% | | 22 (32%) Other
| | | | | 2) Employment change because of MS (self-report):
| | | | | 37% of those with EDSS ≤ 2.5
| | | | | 62% of those with EDSS 3.0–6.0
| | | | | 82% of those with ≥ 6.5
| | | | | 3) Employment status compared to general population:
| | | | | 37% with mild MS were employed full-time versus 85% in age-matched comparator Canadian population
| | | | | 4) Lost workdays in a 1-yr period (dependent on number of people working - not very informative):
| | | | | EDSS ≤ 2.5: 49
| | | | | EDSS 3–6: 109
| | | | | EDSS ≥ 6.5: 40
Dyck and Jongbloed, 2000 and Jongbloed, 1996 | Inclusion: | Cross-sectional study | N = 534 eligible respondents (66% response rate) | 1) Physical: | No direct measure of work capacity or ability | Sample size is sufficient for comparing work ability between groups;
| Women with definitive diagnosis of MS; working age (age 19–60) | Location/recruitment: Questionnaire survey of all women with MS, age 19–60, who had attended MS clinic British Columbia, Canada | Age (mean): | Use of mobility aids | Work status measured through self-report | Employment status prior to onset of MS was considered;
| Exclusion: None specified | Data collection: All data collected by postal questionnaire; three different questionnaires used: | Currently employed: 39.6 | Visibility of MS | Work status (self-report): | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| | 1) Women currently in paid employment (n = 252) completed Questionnaire A; | Now unemployed: 43.3 | 2) Mental: None (except self-reported barriers/helps to employment) | 47% currently employed | Qualitative aspects of the study helped guide the quantitative analyses;
| | 2) Those who had been employed at time of diagnosis, but were no longer employed (n = 163), completed Questionnaire B; | Unemployed at diagnosis: NR | 3) Laboratory: None | 31% no longer employed | Discussion section focused on work issues specific to women.
| | 3) Those who were not employed at time of diagnosis (n = 119) completed Questionnaire C. | Baseline measures of physical and mental functioning: | 4) Radiographic: None | 22% never employed | Vague measurement of physical function
| | Questionnaires A and B included questions on age, education, marital status, income, housing, transportation, use of adaptive aids, visibility of MS, employment history since diagnosis, and difficulties experienced at work. Questionnaire A asked women (in open-ended way?) to identify work-related and social/ family factors that allowed them to continue working; Questionnaire B asked women (in open-ended way?) to identify factors that contributed to their leaving employment; content of Questionnaire C not described. | Use of scooter: | 5) Other: | “Statistically significant differences in highest level of education”: | Authors note that a study limitation included the absence of cognitive function measurements in the study
| | Study questionnaires developed on basis of in-depth interviews with 54 women with MS in first (qualitative) phase of study | Currently employed: 5.8% | Age | Attended university (yes/no): | QUALITY ASSESSMENT:
| | | Currently unemployed: 30.5% | Age at diagnosis | 25.3% - currently employed | Study described as “population-based”?: Yes
| | | Unemployed at diagnosis: NR | Level of education | 14.8% - no longer employed | Follow up > 80%?: NA
| | | Use of wheelchair: | Household income | (statistical test and level not provided) | Work outcomes assessed using a widely used scale?: Work status
| | | Currently employed: 8% | Job title at time of diagnosis | Comparing currently employed with no longer employed in a regression model: | Work outcomes assessed in a blind fashion?: Unclear
| | | Currently unemployed: 36.6% | Marital status | Mobility aids used and employment status controlling for education and age in model: R^2^ = 0.20 | If subgroups with different work ability identified:
| | | Unemployed at diagnosis: NR | Household composition | Factors contributing to maintaining employment - 44% of currently employed women were limited in the kind and amount of work they could do because of MS including: | a) was there adjustment for important prognostic factors? Yes
| | | Baseline work status (self-reported): | Size of city of residence | NR - fatigue “most common” | b) was there independent validation?: NA
| | | Currently employed: 47% | Home ownership | 16% - difficulty with standing and stairs
| | | Currently unemployed: 31% | Type of employment (self-employed, permanent, temporary, etc.) | 15% - walking
| | | Unemployed at diagnosis: 22% | Place of employment | 12% - writing
| | | | Questionnaires also asked subjects (in open-ended way?) to identify factors contributing to their maintaining or leaving employment | 11% - memory/ concentration
| | | | | 17% no longer working indicated “inability to negotiate reduced work hours” with their manager as reason for quitting work
Edgley, Sullivan, and Dehoux, 1991 | Inclusion: Respondent to survey in MS Canada; currently or previously employed; age 18–55 | Cross-sectional study | N = 602 eligible respondents; 562 included in multivariate analysis of covariance | 1) Physical: | No direct measure of work capacity or ability | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| Exclusion: None specified | Location/ recruitment: Survey printed in summer 1989 issue of MS Canada, a newsletter distributed to approximately 25,000 individuals across Canada (of whom approximately 20,000 have MS) | Age: Mean, 43 | Mobility status (1–5 = no problems, some unsteadiness, assistive device required, wheelchair required for long distances, unable to walk) | Work status measured through self-report | Evaluation of cognitive abilities “self-perceived”;
| | Data collection: All data collected by questionnaire survey; items included were sex, age, occupation, level of education, duration of illness, mobility status, self-perceived cognitive problems (Perceived Deficits Questionnaire), and self-perceived primary reason for unemployment (open-ended question) | Baseline measures of physical and mental functioning: | 2) Mental: | 1) Determinants of employment status: | All participants had been previously employed; however, employment status at time of diagnosis was not considered;
| | | 1) Mobility status: | Self-perceived cognitive problems (0–4 = never, rarely, sometimes, often, almost always; composite score obtained by summing 4 subscales of the Perceived Deficits Questionnaire) | Mobility (mean [SD]): | Sample size information is inconsistent throughout text, especially Table 1.0;
| | | No problems with ambulation: 13% | 3) Laboratory: None | Unemployed: 3.1 (1.2) | Occupation was coded according the Blishen Socioeconomic Index for Occupations, but interpretation of scale not provided.
| | | Some unsteadiness: 35% | 4) Radiographic: None | Employed: 2.2 (1.0) | QUALITY ASSESSMENT:
| | | Assistive device required: 15% | 5) Other: | p < 0.001 | Study described as “population-based”?: Yes
| | | Wheelchair required for long distances: 27% | Sex | Results on Perceived Deficit | Follow up > 80%?: NA
| | | Unable to walk: 10% | Age | Questionnaire (mean [SD]): | Work outcomes assessed using a widely used scale?: Work status
| | | 2) Perceived cognitive problems: | Years of education | Unemployed: 1.6 (0.7) | Work outcomes assessed in a blind fashion?: No
| | | Never: 0 | Number of people living at home | Employed: 1.4 (0.7) | If subgroups with different work ability identified:
| | | Rarely: 23% | Type of occupation (coded according to Blishen Socio-economic Index for Occupations) | p < 0.001 | a) was there adjustment for important prognostic factors? Yes
| | | Sometimes: 48% | Duration of illness | 2) Study participants who indicated that they had quit working because of MS symptoms were asked an open-ended question about types of symptoms (n = 313; 78%): | b) was there independent validation?: Yes/No/Unclear/NA
| | | Often: 27% | Self-perceived primary reason for unemployment (open-ended question) | Ambulation difficulties (41%)
| | | Almost always: 2% | | Fatigue (39%)
| | | Baseline work status: | | Memory problems (12%)
| | | Employed: 200 or 201 | | Emotional problems (10%)
| | | Unemployed: 402 or 401 | | Visual difficulties (12%)
| | | (discrepancy between text and Table 1) | | Problems with coordination (6%)
| | | Only subjects employed at diagnosis or employed at time of study were included | | Pain (2%)
| | | | | Incontinence (1%)
| | | | | 22% left employment for reasons unrelated to MS. Women (26%) were significantly more likely than men (11%) to cite reasons unrelated to MS as the primary cause of unemployment (chi-square = 9.3, P < 0.01).
Freal, Kraft, and Coryell, 1984 | Inclusion: Physician diagnosis of MS | Cross-sectional study | N = 656 completed initial questionnaire; 309 completed follow-up questionnaire on fatigue (60% response rate on follow-up questionnaire) | 1) Physical: Fatigue | No direct measure of work capacity or ability | The main purpose of this study was to examine how individuals with MS deal with fatigue; the occupational component was secondary;
| Exclusion: None specified | Location/recruitment: | Age: NR | 2) Mental: None | Work status measured through self-report | Missing information about baseline work status hinders interpretation;
| | Subjects recruited by third parties, including hospitals, National MS Society chapters, a local MS association, and an epidemiological MS research study group (all in western Washington state) | Baseline measures of physical and mental functioning: In follow-up population (n = 309): | 3) Laboratory: None | Responses to open-ended question about how study participants (n = 309 responding to fatigue questionnaire) had changed work or lifestyle to cope with fatigue (only work-related factors reported here): | Employment status prior to disease onset not considered.
| | Data collection: All data collected by survey questionnaires; initial questionnaire gathered data on MS symptoms experienced and whether or not these symptoms interfered with activities of daily living; follow-up questionnaire on fatigue sent to all subjects identifying fatigue as a symptom; this questionnaire asked about characteristics of fatigue, its frequency, environmental variables affecting fatigue, relationship of other MS disease variables to fatigue, and affect of fatigue on subjects' lives | 35% could walk without aids | 4) Radiographic: None | 30 (10%) quit work | QUALITY ASSESSMENT:
| | | 32% used canes, walkers, or furniture when walking | 5) Other: None | 10 (3%) changes in work | Study described as “population-based”?: Yes
| | | 33% used wheelchairs or were bedridden | | 9 (3%) rest and work changes | Follow up > 80%?: NA
| | | Baseline work status: NR | | 6 (2%) quit work and social activities | Work outcomes assessed using a widely used scale?: Work status
| | | | | | Work outcomes assessed in a blind fashion?: No
| | | | | | If subgroups with different work ability identified:
| | | | | | a) was there adjustment for important prognostic factors? No
| | | | | | b) was there independent validation?: NA
Genevie, Kallos, and Struening, 1987 | Inclusion: | Cross-sectional study | N = 333 eligible respondents | The following variables were examined for their relationship to job retention in correlation and stepwise multiple regression analyses. Symptom severity (16 items) was graded on a scale of 0 (“not at all severe”) to 5 (“very severe”). Functional impairment (8 items) was measured on a scale of 1 (“can do without difficulty”) to 5 (“cannot do at all”). | No direct measure of work capacity or ability | SSDI was included as a predictor of “no” work. Authors infer that income from other sources, such as SSDI, is a disincentive to work. However, SSDI may be a result of one's inability to work and not a disincentive. It would be difficult to disentangle the relationship between SSDI and work incentive, especially in a cross-sectional study design.
| Member of New York City Chapter of the National MS Society; employed at time of MS diagnosis and not yet retired | Location/recruitment: | Age: Median, 44 | 1) Physical: | Work status measured through self-report | All study participants were employed at time of diagnosis of MS.
| Exclusion: Incomplete data | Survey questionnaires mailed to all members of the New York City Chapter of the National MS Society | Baseline measures of physical and mental functioning: NR | Numbness/tingling | 1) 31% of the variance in job retention was accounted for by demographic characteristics, symptom severity, and functional impairment. | QUALITY ASSESSMENT:
| | Data collection: All data collected by survey questionnaire; 10-page instrument captured data on demographic characteristics, symptom severity (at time of diagnosis and present), functional impairment, vocational improvement, job change, sources of income, and medical, psychological, and vocational needs of patient | Baseline work status: | Speech | 2) 32% of the variance in job retention was accounted for by demographic characteristics, symptom severity, functional impairment, and vocational activity. | Study described as “population-based”?: Yes
| | | Employed: 41% (21% at job they held when diagnosed, 20% had changed jobs) | Vision | 3) 49% of the variance in job retention was accounted for by demographic characteristics, symptom severity, functional impairment, vocational activity, and various sources of income (12% of this [49% of] variance was explained by SSI or SSDI being an income source). | Follow up > 80%?: NA
| | | Unemployed (but not retired): 48% (36% voluntarily, 12% dismissed because of MS) | Pain | | Work outcomes assessed using a widely used scale?: Work status
| | | Subjects required to have been employed at time of MS diagnosis and not yet retired | Fatigue | | Work outcomes assessed in a blind fashion?: No
| | | | Functional impairment | | If subgroups with different work ability identified:
| | | | Incontinence | | a) was there adjustment for important prognostic factors? Yes (see note above)
| | | | Ambulation | | b) was there independent validation?: NA
| | | | 2) Mental:
| | | | Affective lability
| | | | Cognition
| | | | Motor disturbance
| | | | 3) Laboratory: None
| | | | 4) Radiographic: None
| | | | 5) Other:
| | | | Sex
| | | | Age
| | | | Family income
| | | | Education
| | | | Time since diagnosis
| | | | Vocational improvement
| | | | Job change
| | | | Sources of income (savings/investments, SSDI, SSI, spouse)
Grima, Torrance, Francis, et al., 2000 | Inclusion: History of relapsing-remitting MS (including some patients who had entered a secondary progressive phase within past 2 yr); EDSS < 7 (ambulatory); not in a clinical trial; age ≥ 18 | Cross-sectional study (estimating costs of relapsing-remitting MS to Canadian health care system and society, measuring health utilities of patients, and examining influence of EDSS scores on these outcomes); some data collected retrospectively for previous 12 mo | N = 195 (153 in remission at time of study visit [44 of whom could recall a relapse in the previous 6 mo] and 42 in relapse at time of visit) | 1) Physical: EDSS scores (assessed by neurologist at time of study visit) | No direct measure of work capacity or ability | No information about employment status prior to disease onset;
| Exclusion: None specified | Location/recruitment: Patients recruited during regular visits to MS clinics at two sites in Ontario, Canada | Age (mean ± SD): | 2) Mental: None | Work status measured through self-report | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| | Data collection: | Remission patients: 41 ± 15 | 3) Laboratory: None | 1) EDSS 1 (n = 37): | Details of subject selection criteria and process are limited;
| | Patient survey (patient information, resource use, and health utilities), chart review (resource use, medications, lab tests, procedures), and EDSS status assessment. Note: resource use data not collected on patients in relapse at time of study visit. | Relapse patients: 36 ± 14 | 4) Radiographic: None | 51% - work full-time | Details of how information about employment was collected are sparse;
| | | Baseline measures of physical and mental functioning (EDSS): | 5) Other: None | 3% - work part-time, unable to work full-time due to MS | Multivariate analysis considering known and suspected risk factors for high EDSS and employment status was not conducted.
| | | Remission patients: | | 8% - work part-time for other reasons | The primary purpose of this study was to examine cost and quality of life among individuals with MS. Details about employment are limited.
| | | 1 - 24% | | 16% - not working due to MS | QUALITY ASSESSMENT:
| | | 2 - 27% | | 22% - not working for other reasons | Study described as “population-based”?:-Yes
| | | 3 - 22% | | EDSS 2 (n = 41): | Follow up > 80%?: NA
| | | 4 - 10% | | 37% - work full-time | Work outcomes assessed using a widely used scale?: Work status
| | | 5 - 5% | | 7% - work part-time, unable to work full-time due to MS | Work outcomes assessed in a blind fashion?: Unclear
| | | 6 - 12% | | 10% - work part-time for other reasons | If subgroups with different work ability identified:
| | | Relapse patients: NR | | 15% - not working due to MS | a) was there adjustment for important prognostic factors? No
| | | Baseline work status: | | 32% - not working for other reasons | b) was there independent validation?: NA
| | | Remission patients: | | EDSS 3 (n = 33):
| | | Full-time: 29% | | 15% - work full-time
| | | Part-time due to MS: 4% | | 0% - work part-time, unable to work full-time due to MS
| | | Part-time not due to MS: 7% | | 9% - work part-time for other reasons
| | | Unemployed due to MS: 37% | | 52% - not working due to MS
| | | Unemployed not due to MS: 20% | | 18% - not working for other reasons
| | | No response: 2% | | 6% - NR
| | | Relapse patients: NR | | EDSS 4 (n = 16):
| | | | | 31% - work full-time
| | | | | 0% - work part-time, unable to work full-time due to MS
| | | | | 6% - work part-time for other reasons
| | | | | 50% - not working due to MS
| | | | | 13% - not working for other reasons
| | | | | EDSS 5 (n = 7):
| | | | | 0% - work full-time
| | | | | 0% - work part-time, unable to work full-time due to MS
| | | | | 0% - work part-time for other reasons
| | | | | 86% - not working due to MS
| | | | | 14% - not working for other reasons
| | | | | EDSS 6 (n = 19):
| | | | | 5% - work full-time
| | | | | 11% - work part-time, unable to work full-time due to MS
| | | | | 0% - work part-time for other reasons
| | | | | 75% - not working due to MS
| | | | | 5% - not working for other reasons
| | | | | 5% - NR
Grønning, Hannisdal, and Mellgren, 1990 | Inclusion: Diagnosed with clinically definite, probable, or possible MS; resident of one of two counties in Norway | Retrospective cohort study | N = 79 (49 remittent, 12 remittent-progressive, 18 progressive) | Possible predictors all assessed at time of onset of MS (time of first symptoms) | No direct measure of work capacity or ability | Possible misclassification of work exertion. Nurses were categorized as “light work,” but nursing ranks as one of the highest for musculoskeletal injuries in the US; similarly, working as a housewife was categorized as “light work,” though this may require significant physical exertion;
| Exclusion: No occupational data on file | Univariate and multivariate survival (time-to-response) analyses used to study variables at onset of MS as possible predictors of time to unemployment | Age at MS onset: Mean, 30; range, 13–55 | 1) Physical: | Work status measured through self-report. Work status determined by receipt of disability pension. | Researchers relied on statistical testing to indicate differences between groups without calculating risk estimates, limiting ability to interpret findings;
| | Location/recruitment: Included MS patients seen in neurological departments and clinics in two counties in Norway | Measures of physical and mental functioning at MS onset: NR | Diagnostic category (definite MS vs. probable/possible MS); | 1) Employed at last follow up, by disease subtype: | Sample size may be too small to detect true differences between groups in multivariate analyses.
| | Data collection: All data taken from patient files recorded from 1974-82; observation time from onset of MS to last follow up varied from 1–33 yr, with mean of 10 yr | Work status at MS onset: | Clinical course (remittent vs. non-remittent) | 18/49 (37%) - Remittent MS | QUALITY ASSESSMENT:
| | | Housewives: 20% | Brain stem symptoms (no vs. yes) | 28/30 (93%) - Non-remittent MS | Study described as “population-based”?: Yes
| | | Light work (secretaries, nurses, teachers, engineers, drivers, students): 43% | Paresis (no vs. yes) | 2) Employed at last follow up, by job type: | Follow up > 80%?: Yes
| | | Heavy work (sailors, industrial workers, fishermen, craftsmen): 37% | Sensory disturbances (no vs. yes) | 25/29 (86%) - Heavy work | Work outcomes assessed using a widely used scale?: Work status
| | | | 2) Mental: None | 21/50 (42%) - Light work | Work outcomes assessed in a blind fashion?: Unclear
| | | | 3) Laboratory: None | 3) Employed at last follow up, by age: | If subgroups with different work ability identified:
| | | | 4) Radiographic: None | 26/50 (52%) ≤ age 30 | a) was there adjustment for important prognostic factors?
| | | | 5) Other: | 20/29 (69%) > age 30 | Yes
| | | | Occupation (light work/housewives vs. heavy work) | 4) Univariate analyses of time to unemployment: | b) was there independent validation?: Yes
| | | | Age (≤ 30 vs. > 30) | Non-remittent MS vs. remittent
| | | | Sex (female vs. male) | (p < 0.001)
| | | | County of residence (Troms vs. Finnmark) | Heavy vs. light work (p < 0.01)
| | | | | Male vs. female (p < 0.05)
| | | | | Age > 30 vs. ≤ 30 at onset (p < 0.01)
| | | | | 5) In multivariate analyses, only disease subtype was predictive of early unemployment (p < 0.01).
| | | | | 6) In multivariate analyses, when disease subtype was not considered, light work vs. heavy (p < 0.01) and age > 30 years (p < 0.05) were predictive of early unemployment.
Gulick, Yam, and Touw, 1989 | Inclusion: | Cross-sectional study | N = 508 eligible respondents (response rate “approximately 90%”) | 1) Physical: | No direct measure of work capacity or ability | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| Previous diagnosis of MS; not a resident of a nursing home or long-term care facility; age ≤ 65; self-reported employment status one of following: “employed outside the home,” “home-maker,” “unemployed,” or “retired” (of 8 possible responses) | Location/recruitment: | Age (mean ± SD): | Walking ability (subscale of ADL Self-Care MS Scale) | Work status measured through self-report | No statistical comparison of responses across groups;
| Exclusion: None specified | Subjects selected randomly from two local chapters of the National MS Society (n = 412) and recruited from a university-affiliated MS comprehensive care clinic (all in New Jersey) | Employed outside home: 41.9 ± 8.9 | 2) Mental: None | 1) 1-way ANOVA comparing work groups on selected characteristics (f Ratio): | Employment status at time of diagnosis was not considered; however, authors acknowledge that their method of categorizing study participants did not distinguish between “home makers who used to work” and “never employed workers who may be retired”;
| | Data collection: All data collected by survey questionnaires, which included a personal data inventory, the ADL Self-Care MS Scale, and two open-ended questions about what conditions/situations make work or chores more difficult or easier to perform | Homemaker: 48.0 ± 9.2 | 3) Laboratory: None | 39.5 (p < 0.001) - Present age | No information provided about how “unemployed” study participants were to answer this question. Not sure if their answers are based on prior employment experiences.
| | | Unemployed: 48.8 ± 9.9 | 4) Radiographic: None | 18.8 (p < 0.001) - MS duration | QUALITY ASSESSMENT:
| | | Retired: 56.3 ± 7.0 | 5) Other: | 14.1 (p < 0.001) - Education | Study described as “population-based”?: Yes
| | | Baseline measures of physical and mental functioning: | Age | 4.8 (p < 0.001) - Walking | Follow up > 80%?: NA
| | | Walking ability (subscale of ADL Self-Care MS Scale; mean ± SD): | Sex | 2) Ranked comparison of conditions/situations that impede work performance (selected physical functions among those employed outside the home [n = 104] and unemployed [n = 92]; data on homemakers and retired participants not described here): | Work outcomes assessed using a widely used scale?: Work status
| | | Employed outside home: 20.5 ± 6.9 | Marital status | Fatigue: | Work outcomes assessed in a blind fashion?: No
| | | Homemaker: 12.7 ± 9.0 | MS duration (since diagnosis) | Employed: 50% | If subgroups with different work ability identified:
| | | Unemployed: 5.8 ± 7.5 | Education | Unemployed: 25% | a) was there adjustment for important prognostic factors? Yes
| | | Retired: 8.9 ± 8.4 | Investigators also reported responses to two open-ended questions about conditions/situations that make work or chores more difficult or easier to perform (responses to “easier to perform” questions not included in this table) | Walking: | b) was there independent validation?: NA
| | | Baseline work status: | | Employed: 12%
| | | Employed outside home: 110 | | Unemployed: 0
| | | Homemaker: 209 | | Standing:
| | | Unemployed: 110 | | Employed: 8%
| | | Retired: 79 | | Unemployed: 12%
| | | | | Numbness:
| | | | | Employed: 8%
| | | | | Unemployed: 5%
| | | | | Tremors:
| | | | | Employed: o
| | | | | Unemployed: 10%
| | | | | Use of wheelchair:
| | | | | Employed: 0
| | | | | Unemployed: 10%
| | | | | Restricted mobility:
| | | | | Employed: 0
| | | | | Unemployed: 9%
| | | | | Stiffness:
| | | | | Employed: 5%
| | | | | Unemployed: 0
Hammond, McLeod, Macaskill, et al., 1996 | Inclusion: Clinically definite, probable, or possible MS | Cross-sectional study | N = 2307, of which 2099 were of working age (15–64) and reported both DSS and employment data | 1) Physical: Level of disability: | No direct measure of work capacity or ability | Employment status prior to disease onset not considered;
| Exclusion: None specified | Location/recruitment: Patients identified as part of epidemiological study of MS in New South Wales, Queensland, South Australia, Western Australia, and Tasmania | Age: NR | Low (DSS 0–3) | Work status measured through self-report | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| | Data collection: Survey/interview conducted by neurologists; included questions on age, sex, date of birth, occupation, marital status, and education; DSS score assessed for prevalence day (30 June 1981) | Baseline measures of physical and mental functioning: NR | Moderate (DSS 4–6) | 1) Reported being “employed”: | Sample size is a study strength, able to control for some possible confounders using multivariate analyses.
| | | Baseline work status: | Severe (DSS 7–9) | Men: | QUALITY ASSESSMENT:
| | | Men: 50% employed, 45% retired or receiving a pension | 2) Mental: None | 78% = DSS-low | Study described as “population-based”?: Yes
| | | Women: 27% employed, 30% retired or receiving a pension | 3) Laboratory: None | 27% = DSS-moderate | Follow up > 80%?: NA
| | | | 4) Radiographic: None | 4% = DSS-severe | Work outcomes assessed using a widely used scale?: Work status
| | | | 5) Other: Type of work (trade/farm vs. professional/clerical) | Women: | Work outcomes assessed in a blind fashion?: No
| | | | | 40% = DSS-low | If subgroups with different work ability identified:
| | | | | 8% = DSS-moderate | a) was there adjustment for important prognostic factors? Yes
| | | | | 1% = DSS-severe | b) was there independent validation?: NA
| | | | | 2) Adjusting for age and sex, the relationship between DSS level and employment status was noted separately for men and women:
| | | | | Men - prevalence ratio (95% CI):
| | | | | Moderate vs. low DSS = 2.7 (2.1–3.6)
| | | | | Severe vs. low DSS = 17.6 (7.5–41.4)
| | | | | Women - prevalence ratio (95% CI):
| | | | | Moderate vs. low DSS = 4.0 (2.7–5.8)
| | | | | Severe vs. low DSS = 24.6 (8.0–76.1)
| | | | | Job type: Authors noted that trade and farm workers were less likely to be in paid employment than professional or clerical workers as their level of disability increased; however, no data were provided to support this statement.
Jacobs, Wende, Brownscheidle, et al., 1999 | Inclusion: Definite MS in the judgment of clinical site neurologists; entered into New York State MS Consortium registry | Cross-sectional study | N = 3019 (55% relapsing-remitting, 31% secondary progressive, 9% primary progressive, 5% progressive relapsing) | 1) Physical: MS disease course (relapsing-remitting vs. progressive) | No direct measure of work capacity or ability | EDSS scores ascertained but not examined in conjunction with work status;
| Exclusion: None specified | Location/recruitment: | Age: Mean ± SD, 45.2 ± 11.2; median, 45.0 | 2) Mental: None | Work status measured through self-report | Employment status prior to disease onset not considered;
| | Patients attended one of 12 MS centers comprising the New York State MS Consortium | Baseline measures of physical and mental functioning: NR | 3) Laboratory: None | 1) Employment status by disease course: | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| | Data collection: Consortium registry/study data collected using a 5-page form consisting of 2 sections: (a) 3 pages of demographic data and self-report assessments completed by patient (some mailed, some completed during office visit), and (b) 2 pages of clinical data completed by examining neurologist and/or study nurse (included physical exam findings, exacerbation history, MS type, EDSS score, and lab findings) | Baseline work status: NR | 4) Radiographic: None | Relapse-remitting: 55% employed | Multivariate analyses considering important known and suspected risk factors for both poor physical function and employment status were not conducted.
| | | | 5) Other: None | Primary progressive: 21% employed | QUALITY ASSESSMENT:
| | | | | 2) Disabled and under age 60: | Study described as “population-based”?: Yes
| | | | | 44% with primary progressive | Follow up > 80%?: NA
| | | | | 17% with relapsing-remitting | Work outcomes assessed using a widely used scale?: Work status
| | | | | 3) There were no group differences in patients who were homemakers, unemployed, or retired after 60 years of age (2–12%) in relapsing-remitting or progressive MS. | Work outcomes assessed in a blind fashion?: No
| | | | | 4) Interesting summary of type of insurance coverage by stage of disease, which may be directly related to employment status. Participants with relapsing-remitting MS were more likely to be insured by HMOs and commercial carriers, and those with progressive MS were more likely to be covered by Medicare and Medicaid. | If subgroups with different work ability identified:
| | | | | | a) was there adjustment for important prognostic factors? No
| | | | | | b) was there independent validation?: No
Kornblith, La Rocca, and Baum, 1986 | Inclusion: Interviewed as part of US National MS Survey | Cross-sectional study; path analysis used to construct a causal model explaining variation in employment status | N = 987 met inclusion/ exclusion criteria; 949 provided complete data for multivariate analysis | 1) Physical: | No direct measure of work capacity or ability | Measurement of mobility is crude. The 3-point scale may not be sensitive enough to changes in physical function that are associated with inability to work;
| Exclusion: Never worked; did not admit to having MS | Location/recruitment: | Age: Mean, 48.3 | Duration of illness | Work status measured through self-report | Stratified linear regression (by sex):
| | Subjects were subset of patients interviewed for US National MS Survey; sampling and recruitment of this population not described in the current paper | Baseline measures of physical and mental functioning: | Functional disability (Mobility Dysfunction Index) | Proxy of physical function was assessed using the Mobility Dysfunction Index: | Men: adjustment for age, education, and duration of illness;
| | Data collection: Patient interviews designed to obtain disease history, employment history, and data on functional disability, utilization of medical services, costs incurred, and disruptions in the lives of patients and their families due to MS | Mobility dysfunction: | ADL and leisure disability (study-specific measure) | a. No assistance needed indoor and outdoors | Women: adjustment for age, duration of illness, ADL, leisure activity, marital status;
| | | No assistance needed: 31% | 2) Mental: None | b. Any combination of cane, walker, crutches, leg brace, use of person, for any amount of chair and wheel chair once in awhile | Authors indicate (p. 160) that occupational history over the life span was ascertained; however, these data are not included in the paper or considered in the analyses;
| | | Assistance needed half-time: 28% | 3) Laboratory: None | c. Use of wheel chair more than half of the time indoors or outdoors. | Employment status prior to disease onset not considered.
| | | Assistance needed all the time: 41% | 4) Radiographic: None | Data analyzed separately for males vs. females since sociocultural differences between sexes might affect employment in response to MS | QUALITY ASSESSMENT:
| | | Baseline work status: | 5) Other: | 1) Author's comment: Mobility was a major determinant of employment status in both males and females, while age and duration were minor. | Study described as “population-based”?: Yes
| | | Employed: 20% | Sex | 2) Men: Each 1-point increase in the Mobility Dysfunction Index decreased the probability of males working by 24.3%. | Follow up > 80%?: NA
| | | Unemployed: 80% | Age | 3) Women: Each 1-point increase in the Mobility Dysfunction Index decreased the likelihood of females working by 15.4%. | Work outcomes assessed using a widely used scale?: Work status
| | | | Marital status | | Work outcomes assessed in a blind fashion?: No
| | | | Education level | | If subgroups with different work ability identified:
| | | | Number of other adults in the home | | a) was there adjustment for important prognostic factors? Yes
| | | | Number of children younger than 14 | | b) was there independent validation?: No
LaRocca, Kalb, Kendall, et al., 1982 | Inclusion: MS | Cross-sectional study | N = 312 | 1) Physical: | No direct measure of work capacity or ability | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| Exclusion: None specified | Location/recruitment: Patients recruited from an MS clinic in the Bronx, NY, and 3 (unspecified) voluntary agencies | Age: Mean, 43; range, 18–72 | Duration of illness | Work status measured through self-report | Reasons for leaving job not provided;
| | Data collection: | Baseline measures of physical and mental functioning: | Symptoms | 1) 76% of study sample were unemployed at assessment and out of work an average of 9 years; however, 96% had been employed at some time. | No discussion section provided by authors where points about study bias and limitations were discussed;
| | Highly structured clinical interview, plus standard neurological exam with DSS assessment | Mean DSS, 4.6 | Disability (measured by DSS scores) | 2) 1-point increase in DSS was associated with a 7% decrease in the likelihood of being employed | No tests of statistical significance.
| | | Baseline work status: | 2) Mental: None | 3) Being male increased the probability of being employed by 11%. | QUALITY ASSESSMENT:
| | | 77% unemployed; out of work for an average of 9 yr | 3) Laboratory: None | 4) 86% of variability in employment status unexplained by: | Study described as “population-based”?: Yes
| | | 96% employed at some time in the past | 4) Radiographic: None | Age | Follow up > 80%?: NA
| | | | 5) Other: | Sex | Work outcomes assessed using a widely used scale?: Work status
| | | | Age | Education | Work outcomes assessed in a blind fashion?: Unclear
| | | | Sex | Marital status | If subgroups with different work ability identified:
| | | | Education | Occupation | a) was there adjustment for important prognostic factors? Yes
| | | | Marital status | Parenthood | b) was there independent validation?: NA
| | | | Occupation | However, variability in employment status was explained by factors such as premorbid personality, coping style, characteristics of the workplace, and social support systems. Authors suggest that these findings contribute to the probability of a patient with MS staying at work.
| | | | Parenthood
Miller, Rudick, Cutter, et al., 2000 | Inclusion: | Cross-sectional study (validation of Multiple Sclerosis Functional Composite [MSFC], consisting of timed 25-ft walk, 9-Hole Peg Test [9-HPT], and Paced Auditory Serial Addition Test 3-min version [PASAT-3]) | N = 300 | 1) Physical: | No direct measure of work capacity or ability | The purpose of this study was to validate MSFC, and the authors state that employment status was included as a surrogate measure of health status impact. Researchers expected employment status to be moderately correlated with the MSFC.
| Clinically definite MS | Location/recruitment: | Age (mean ± SD): 44.7 ± 9.3 | EDSS scores | Work status measured through self-report | Authors cite low relative participant numbers in high EDSS severity subgroup (56/300) as explanation for lack of demonstrated statistical significance with respect to work status, although article also states selection process was designed to “provide an even representation” of EDSS severity
| Exclusion: None specified | Patients with clinically definite MS recruited from 4 clinical sites in the US and Canada; stratified sampling plan by disease severity and sex; subjects selected to provide an even representation of mild (EDSS 0–3.0), moderate (EDSS 3.5–6.5), and severe (EDSS 7.0–8.5) neurological impairment | Baseline measures of physical and mental functioning: | MSFC scores | 1) Employment status by EDSS score: | QUALITY ASSESSMENT:
| | Data collection: Following data collected (during clinic visits?): | EDSS severity: | 2) Mental: None | EDSS (0–3.0): | Study described as “population-based”?: Yes
| | 1) MSFC | Low (0–3.0): 38% | 3) Laboratory: None | None - 37.5% | Follow up > 80%?: NA
| | 2) EDSS | Moderate (3.5–6.5): 44% | 4) Radiographic: None | Part-time - 20.5% | Work outcomes assessed using a widely used scale?: Work status
| | 3) Sickness Impact Profile (SIP) | High (7.0–8.5): 17% | 5) Other: None | Full-time - 42.0% | Work outcomes assessed in a blind fashion?: Unclear
| | 4) SF-36 | Baseline work status: | | EDSS (3.5–6.5): | If subgroups with different work ability identified:
| | 5) Fatigue Impact Scale (FIS) | Full-time: 24.2% | | None - 74.6% | Was there adjustment for important prognostic factors? No (except that overall sex ratio in study was said to reflect that of usual MS population)
| | 6) Self-reported employment status | Part-time: 13.1% | | Part-time - 10.0% | b) was there independent validation?: NA
| | 7) Social Support Survey-Tangible Support subscale | Unemployed: 62.8% | | Full-time - 15.4%
| | | | | EDSS (7.0–8.5):
| | | | | None - 85.7%
| | | | | Part-time - 5.4%
| | | | | Full-time - 8.9%
| | | | | 2) Employment status (0 = none; 1= part-time; 2 = full-time) correlated significantly with MSFC (Spearman coefficient = 0.43 [p < 0.001]), and correlation remained significant when EDSS controlled for (Spearman coefficient = 0.13 [p < 0.05]). No MSFC score is provided with regard to employment status.
| | | | | 3) When stratified by disease severity, Spearman correlations between MSFC and work status for:
| | | | | EDSS 0–3.0: 0.21 (p = NS)
| | | | | EDSS 3.5–5.5: 0.32 (p < 0.001)
| | | | | EDSS 7.0–8.5: 0.18 (p = NS)
Rao, Leo, Ellington, et al., 1991 | Inclusion: MS | Cross-sectional study | N = 100 MS patients (38 relapsing-remitting, 19 chronic-progressive, 43 chronic-stable); 100 non-MS controls used to determine cognitive impairment levels only | 1) Physical: None | No direct measure of work capacity or ability | Non-MS controls apparently used only in Katz Adjustment Scale determination;
| Exclusion: None specified | Location/recruitment: | Age: Mean, 45.9 | 2) Mental: | Work status measured through self-report | Cross sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| | Sample described as coming from a “large community-based sample of MS patients”; sampling/ recruitment not described in detail in this publication | Baseline measures of physical and mental functioning: | Cognitive status (intact vs. impaired) | Mean score on the Environmental Status Scale (range 0–4) for the “actual work status” item (1 of 7 items) was lower (approximately 1.8) for cognitively impaired versus cognitively intact (approximately 2.8) subjects (p < 0.01 [Figure 1.0]) | Employment status prior to disease onset not considered.
| | Data collection: Cognitive status (intact vs. impaired) determined on basis of performance on 31 cognitive test scores; patients then assessed using Minimal Record of Disability (includes EDSS, Kurtzke Functional Systems, Incapacity Status Scale, and Environmental Status Scale), a 2-hr occupational therapy evaluation, various self-report measures (Zung Depression Scale, State-Trait Anxiety Inventory, SIP), and relative/ friend ratings (Katz Adjustment Scale) | EDSS (mean): 4.1 | 3) Laboratory: None | | QUALITY ASSESSMENT:
| | | Baseline work status: NR (“Actual Work Status” scores reported only graphically [Figure 1]) | 4) Radiographic: None | | Study described as “population-based”?: Yes
| | | | 5) Other: None | | Follow up > 80%?: Yes
| | | | | | Work outcomes assessed using a widely used scale?: Work status
| | | | | | Work outcomes assessed in a blind fashion?: No
| | | | | | If subgroups with different work ability identified:
| | | | | | a) was there adjustment for important prognostic factors? No
| | | | | | b) was there independent validation?: NA
Rozin, Schiff, Cooper, et al., 1982 | Inclusion: | Cross-sectional study | N = 117 eligible; 101 interviewed and classified according to functional group | 1) Physical: Neurological exam, content unspecified | Direct measure of work capacity or ability was conducted | Evaluation of mental/cognitive function is unclear;
| Possible or probable MS by modified Allison and Miller criteria (diagnosis verified by research team); age 17–50; diagnosed during 1970-72 | Location/recruitment: | Age: Mean, 36 | 2) Mental: None | Work status measured through self-report | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| Exclusion: None specified | Study described below | Baseline measures of physical and mental functioning: | 3) Laboratory: None | Study participants initially grouped as follows (Series I and II combined; n = 299) | Not clear whether process of classifying groups was independent of Hyllested scale grade (in terms of blinding), but probably was not.
| | (Rozin, Schiff, Kahana, et al., 1975) updated with new series of patients contacted during 1974-78 | Disability: | 4) Radiographic: None | n = 71 - Group A: Completely handicapped with no rehabilitation potential | QUALITY ASSESSMENT:
| | Data collection: Interviews conducted by social workers in patients' homes; included questions on demographic data, family history, educational and occupational history, present economic status, usual daily schedule, and desire to work or be trained; neurological exam also performed and disability assessed using Hyllested scale. All patients classified according to functional groups as follows: A = completely handicapped, no rehabilitation potential; B = potential for vocational rehabilitation (including those who were working, but needed vocational rehabilitation services); and C = working, holding on to their previous jobs, or changed jobs without the intervention of rehabilitation services | Mild (0–2): 57% | 5) Other: | n = 53 - Group B: Potential for vocational rehabilitation, but unemployed or currently employed, but needs rehabilitation services for continuation of employment | Study described as “population-based”?: Yes
| | | Moderate (3–4): 36% | Disability assessed using Hyllested scale, graded 0–6 | n = 175 - Group C: Currently working, holding previous jobs or changed jobs without intervention of rehabilitation services | Follow up > 80%?: NA
| | | Severe (5–6): 6% | Years of education | 1) Type of MS disability by Group | Work outcomes assessed using a widely used scale?: Work status, work ability
| | | Functional groups (see under “Study Design” at left): | | (Series I and II combined): | Work outcomes assessed in a blind fashion?: No
| | | A: 16% | | No disability: | If subgroups with different work ability identified:
| | | B: 24% | | NR - Group A | a) was there adjustment for important prognostic factors? No
| | | C: 60% | | 3% - Group B | b) was there independent validation?: NA
| | | Baseline work status: | | 29% - Group C
| | | Working: 60% (functional group C) | | Physical MS:
| | | | | 59% - Group A
| | | | | 75% - Group B
| | | | | 61% - Group C
| | | | | Physical and mental MS:
| | | | | 30% - Group A
| | | | | 11% - Group B
| | | | | 6% - Group C
| | | | | Mental MS:
| | | | | 1% - Group A
| | | | | 2% - Group B
| | | | | 1% - Group C
| | | | | Other causes:
| | | | | 7% - Group A
| | | | | 2% - Group B
| | | | | 1% - Group C
| | | | | MS and other:
| | | | | 3% - Group A
| | | | | 7% - Group B
| | | | | 2% - Group C
| | | | | “Comparison of Group A with Group C with mental disability due to MS (with or without physical disability) is higher in Group A than C - 31% vs. 7%, respectively - p < 0.001.”
| | | | | “Group A and Group C had similar percentages of subjects with physical disability due to MS.”
| | | | | 2) Hyllested Criteria of Disability (Series I and II combined):
| | | | | Group A (n = 71):
| | | | | 15% - Mild (0–2)
| | | | | 38% - Moderate (3–4)
| | | | | 46% - Severe (5–6)
| | | | | Group B (n = 53):
| | | | | 36% - Mild (0–2)
| | | | | 51% - Moderate (3–4)
| | | | | 13% - Severe (5–6)
| | | | | Group C (n = 175):
| | | | | 74% - Mild (0–2)
| | | | | 25% - Moderate (3–4)
| | | | | 0.6% - Severe (5–6)
Rozin, Schiff, Kahana, et al., 1975 | Inclusion: | Cross-sectional study | N = 222 eligible; 159 interviewed; 172 classified according to functional group | 1) Physical: Neurological exam, content unspecified | Direct measure of work capacity or ability was conducted | Evaluation of mental/cognitive function is unclear;
| MS; age 20–50 in 1971 | Location/recruitment: | Age: 53% older than 40 | 2) Mental: None | Work status measured through self-report | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| Exclusion: None specified | Patient population derived from a survey of MS patients in Israel, updated in 1968 and including all MS patient living in Israel at the time (n = 490); those age 20–50 in 1971 included in present study | Baseline measures of physical and mental functioning: | 3) Laboratory: None | Study participants (n = 172) were initially grouped as follows: | Examines changes in work status across time period of disease.
| | Data collection: Interviews conducted by social workers in patients' homes; included questions on demographic data, family history, educational and occupational history, present economic status, usual daily schedule, and desire to work or be trained; neurological exam also performed and disability assessed using Hyllested scale; all patients classified according to functional groups as follows: A = completely handicapped, no rehabilitation potential; B = potential for vocational rehabilitation (including those who were working, but needed vocational rehabilitation services); and C = working, holding on to their previous jobs, or changed jobs without the intervention of rehabilitation services | Disability: | 4) Radiographic: None | n = 41 - Group A: Completely handicapped with no rehabilitation potential | QUALITY ASSESSMENT:
| | | Mild (0–2): 38% | 5) Other: Disability assessed using Hyllested scale, graded 0–6 | n = 37 - Group B: Potential for vocational rehabilitation, but unemployed or currently employed, but needs rehabilitation services for continuation of employment | Study described as “population-based”?: Yes
| | | Moderate (3–4): 29% | | n = 94 - Group C: Currently working, holding previous jobs or changed jobs without intervention of rehabilitation services | Follow up > 80%?: Yes
| | | Severe (5–6): 33% | | 1) Type of MS disability by group: | Work outcomes assessed using a widely used scale?: Work status, work ability
| | | Functional groups (see under “Study Design” at left): | | No disability: | Work outcomes assessed in a blind fashion?: No
| | | A: 24% | | NR - Group A | If subgroups with different work ability identified:
| | | B: 21% | | NR - Group B | a) was there adjustment for important prognostic factors? No
| | | C: 55% | | 50% - Group C | b) was there independent validation?: NA
| | | Baseline work status: | | Physical disability due to MS:
| | | Not working: 76% | | 39% - Group A
| | | | | 81% - Group B
| | | | | 41% - Group C
| | | | | Physical and mental disability due to MS:
| | | | | 56% - Group A
| | | | | 19% - Group B
| | | | | 3% - Group C
| | | | | Mental disability due to MS:
| | | | | NR - Group A
| | | | | NR - Group B
| | | | | 1% - Group C
| | | | | Other causes of disability not connected with MS:
| | | | | 5% - Group A
| | | | | NR - Group B
| | | | | 5% - Group C
| | | | | 3) Hyllested Criteria of Disability:
| | | | | Group A (n = 41):
| | | | | 0% - Mild (0–2)
| | | | | 0% - Moderate (3–4)
| | | | | 100% - Severe (5–6)
| | | | | Group B (n = 37):
| | | | | 0% - Mild (0–2)
| | | | | 57% - Moderate (3–4)
| | | | | 43% - Severe (5–6)
| | | | | Group C (n = 94):
| | | | | 70% - Mild (0–2)
| | | | | 30% - Moderate (3–4)
| | | | | 0% - Severe (5–6)
| | | | | 4) Changes in work status from onset of MS to time study in 1971. Work type by work groups:
| | | | | Group A (n = 41):
| | | | | Unskilled labor:
| | | | | 18% - onset of MS
| | | | | 0% - at time of study
| | | | | Skilled, semiskilled, service:
| | | | | 27% - onset of MS
| | | | | 0% - at time of study
| | | | | Clerical, profession, student:
| | | | | 37% - onset of MS
| | | | | 0% - at time of study
| | | | | Housewives:
| | | | | 2% - onset of MS
| | | | | 0% - at time of study
| | | | | Not working:
| | | | | 6% - onset of MS
| | | | | 100% - at time of study
| | | | | Group B (n = 37):
| | | | | Unskilled labor:
| | | | | 28% - onset of MS
| | | | | 3% - at time of study
| | | | | Skilled, semiskilled, service:
| | | | | 31% - onset of MS
| | | | | 3% - at time of study
| | | | | Clerical, profession, student:
| | | | | 31% - onset of MS
| | | | | 21% - at time of study
| | | | | Housewives:
| | | | | 5% - onset of MS
| | | | | 8% - at time of study
| | | | | Not working:
| | | | | 5% - onset of MS
| | | | | 65% - at time of study
| | | | | Group C (n = 94):
| | | | | Unskilled labor:
| | | | | 22% - onset of MS
| | | | | 8% - at time of study
| | | | | Skilled, semiskilled, service:
| | | | | 18% - onset of MS
| | | | | 17% - at time of study
| | | | | Clerical, profession, student:
| | | | | 40% - onset of MS
| | | | | 37% - at time of study
| | | | | Housewives:
| | | | | 12% - onset of MS
| | | | | 38% - at time of study
| | | | | Not working:
| | | | | 8% - onset of MS
| | | | | 0% - at time of study
| | | | | 4) Authors note that “of the 131 clients with working potential, only 18% stopped working because of MS” -supporting data not provided.
Scheinberg, Holland, Larocca, et al., 1980 | Inclusion: MS; patient at study clinic | Cross-sectional study | N = 401 selected; 257 (64%) completed interviews | 1) Physical: Self-report of physical limitations | No direct measure of work capacity or ability | Self-report of physical limitations without clinical measurement;
| Exclusion: None specified | Location/recruitment: | Age: 37% ≤ 39; 53% 40–59; 9% ≥ 60 | 2) Mental: None | Work status measured through self-report | Employment status prior to disease onset not considered;
| | Sample of patients from a multidisciplinary MS clinic assembled by selecting alternate names from an alphabetic file | Baseline measures of physical and mental functioning: NR | 3) Laboratory: None | Among those having left employment, the most common reason for leaving among multiple reasons given by 182 subjects (categories not mutually exclusive): | Cross-sectional design - temporal relationship between exposure and outcome of employment status not assessed;
| | Data collection: Structured interview containing 20 questions administered either by phone or in person; areas assessed included employment, education, household activities, and medical care | Baseline work status: | 4) Radiographic: None | 52.7% - Physical difficulty | Sample size is too small todetect true differences between groups or to consider possible confounders in multivariate analysis;
| | | Employed: 19.5% | 5) Other: Job category | 15.9% - Visual difficulty | Descriptive study only.
| | | Independent homemaker: 21.4% | | 12.1% - Transportation difficulty | Authors' note indicates possible selection bias since sample was self-selected to come to the center where recruitment occurred. Sample may be more handicapped, more affluent, and better informed about availability of services than the general population with MS.
| | | Semi-independent homemaker: 12.8% | | 9.3% - Fatigue | Authors infer from findings that high unemployment rate among individuals with MS is partly due to current shortcomings of vocational rehabilitation agencies (note: study published in 1980, so rehabilitation services may have changed considerably since that time).
| | | Employed in sheltered workshop: 1.2% | | 1.3% - Emotional difficulty | QUALITY ASSESSMENT:
| | | Retired: 3.9% | | 37.4% - Other (mainly marriage and/or pregnancy) | Study described as “population-based”?: Yes (clinic)
| | | Student: 2.3% | | Job category of currently employed subjects (n = 51): | Follow up > 80%?: No
| | | Unemployed: 38.5% | | 35.3% - Clerical | Work outcomes assessed using a widely used scale?: Work status
| | | Other: 0.4% | | 23.5% - Professional | Work outcomes assessed in a blind fashion?: Unclear
| | | | | 13.7% - Semi-Professional | If subgroups with different work ability identified:
| | | | | 13.7% - Skilled Labor | a) was there adjustment for important prognostic factors? No
| | | | | 7.8% - Managerial | b) was there independent validation?: NA
| | | | | 2.0% - Unskilled Labor
| | | | | 3.9% - Other
| | | | | Among the unemployed, 18.3% were seeking employment, training, or education, and 21.4% were able to care for their own home with little or no assistance.
Verdier-Taillefer, Sazdovitch, Borgel, et al., 1995 | Inclusion: | Case-control study | N = 171 total = 77 cases (unemployed for < 5 yr at time of study) and 94 controls (still employed) | 1) Physical: | No direct measure of work capacity or ability | Retrospective design - EDSS not known at time cases ceased employment, but at time of study;
| Clinically or laboratory definite MS by Poser criteria; EDSS 3–7; age 20–50 | Location/recruitment: | Type of MS: | EDSS | Work status measured through self-report | Authors only indicate that cases were unemployed for less than 5 years at the time of the study, but do not indicate if they were employed at time of MS diagnosis. Since a high percentage indicated leaving work because of MS, it is assumed they were all employed at time of diagnosis;
| Exclusion: None specified | Subjects were consecutive patients at 4 neurology clinics in France between Jan and Dec 1991 | Cases: 31% relapsing-remitting, 53% relapsing-progressive, 16% primary progressive | See further under “Specific job characteristics,” below | Work status (Yes/No) | Cognitive function required for jobs (Table 3.0) may be biased by self-report by study subjects.
| | Data collection: Study neurologist examined patients to determine type of MS, age at onset, and EDSS score. Neurologist then administered questionnaire asking about demographic characteristics and 14 specific items relating to the occupational environment of current (or past) job; subjects also asked (in open-ended way?) why they stopped working | Controls: 48% relapsing-remitting, 36% relapsing-progressive, 16% primary progressive | 2) Mental: See under “Specific job characteristics,” below | Cases = unemployed | QUALITY ASSESSMENT:
| | | Age (mean ± SD): | 3) Laboratory: None | Controls = employed | Study described as “population-based”?: Yes
| | | Cases (unemployed): 39.0 ± 0.9 | 4) Radiographic: None | 1) Disease stage and work status | Follow up > 80%?: NA
| | | Controls (employed): 40.5 ± 0.7 | 5) Other: | (p = 0.01): | Work outcomes assessed using a widely used scale?: Work status
| | | Baseline measures of physical and mental functioning: | Age | Relapsing-remitting: | Work outcomes assessed in a blind fashion?: No
| | | EDSS (mean ± SD): | Sex | Cases = 31% | If subgroups with different work ability identified:
| | | Cases: 5.4 ± 0.1 | Marital status | Controls = 48% | a) was there adjustment for important prognostic factors? Yes
| | | Controls: 4.5 ± 0.1 | Job grade (high, medium, low) | Relapsing-progressive: | b) was there independent validation?: NA
| | | Baseline work status: | High school education (yes/no) | Cases = 53%
| | | Cases (45% of total study population) unemployed | Age at onset | Controls = 36%
| | | Controls (55% of total study population) employed | Type of MS | Primary progressive:
| | | | Specific job characteristics: | Cases = 16%
| | | | a) Public sector | Controls = 16%
| | | | b) Desk job | 2) EDSS (mean ± SD) and work status:
| | | | c) Sitting position | Cases = 5.4 ± 0.1
| | | | d) Possibility of obtaining specific arrangements | Controls = 4.5 ± 0.1
| | | | e) Travel time > 30 min/day | p = 0.01
| | | | f) Daily working time > 8 hr | 3) Work requirements and odds of unemployment (odds ratio [95% CI]):
| | | | g) Accessibility problems | 0.9 (0.4–1.8) - close attention
| | | | h) Work requiring: | 0.7 (0.3–1.5) - good memory
| | | | - Close attention | 7.6 (3.2–18.2) - physical strength
| | | | - Good memory | 3.1 (1.6 – 6.3) - manual precision
| | | | - Physical strength | 2.2 (1.1 – 4.6) - rigid work schedule
| | | | - Manual precision | 1.7 (0.7 – 3.4) - decision making
| | | | - Rigid work schedule | 2.5 (1.3 – 4.9) - frequent moves
| | | | - Decision-making | 4) Job characteristics and odds of unemployment (odds ratio [95% CI]):
| | | | - Frequent moves | 0.3 (0.1 – 0.5) - desk job
| | | | | 0.3 (0.1 – 0.7) - sitting position
| | | | | 0.4 (0.2, 0.8) - possibility of obtaining specific arrangements
| | | | | 1.7 (0.9–3.2) - travel time > 30 min
| | | | | 2.6 (1.2–5.7) - daily work hrs > 8 h
| | | | | 1.9 (0.9–4.0) - accessibility problems
| | | | | 5) Logistic regression of job characteristics significantly related to unemployment (odds ratio [p-value]):
| | | | | 0.4 (p < 0.05) - work in public sector
| | | | | 4.5 (p < 0.01) - work needing physical strength

Evidence Table 5. Environmental factors and work ability

Study | Selected Inclusion/ Exclusion Criteria | Study Design | Patients | Environmental Factors Considered | Results | Comments/Quality Scoring
Gulick, Yam, and Touw, 1989 | Inclusion: Previous diagnosis of MS; not a resident of a nursing home or long-term care facility; age ≤ 65; self-reported employment status one of following: “employed outside the home,” “home-maker,” “unemployed,” or “retired” (8 work status categories possible, but results were reported only for respondents in the above four categories because “too few subjects fit into categories of homebound employment, sheltered workshop, student, and volunteer for meaningful analysis”) | Cross-sectional study | N = 508 eligible respondents (response rate “approximately 90%”) | Rater-assigned responses to work-impeding categories of “heat/temperature intolerance” and work-enhancing category of cool temperature | Work ability was not directly assessed. The only relevant work capacity variable was self-reported work status. | Authors acknowledge that methods would not distinguish between lifelong homemakers versus homemakers who previously worked outside the home, and that some respondents who were never employed might never consider themselves to be retired.
| Exclusion: None specified | Location/recruitment: | Age (mean ± SD): | (Subject responses were to open-ended questions about conditions/situations that make it difficult [impeders] or easier [enhancers] to perform work or chores) | Responses to open-ended questions regarding impediments to and enhancers of work performance were grouped into condition/situation categories by two independent raters. Inter-rater agreement coefficients ranged from 0.84 to 0.98 for four work-impeding categories and from 0.82 to 1.0 for five work-enhancing categories (particular categories tested for inter-rater agreement were not specified). | Authors suggest that intergroup differences in unassessed factors such as activity level or absence of air conditioners may have contributed to apparent differences in reports of “heat/temperature intolerance” as a work impediment among work status groups.
| | Subjects selected randomly from two local chapters of the National MS Society (n = 412) and recruited from a university-affiliated MS comprehensive care clinic (n = 96; all sites in New Jersey) | Employed outside home: 41.9 ± 8.9 | | 22 conditions that impede work performance were identified by 5% or more of participants. Among those employed outside the home, 7% included high temperature as a condition/situation that impeded work performance, along with 11 other work-impeding items such as fatigue (50%), walking (12%), vision (12%), balance (10%), standing (8%), writing (8%), numbness (8%), insufficient time (7%), pain (6%), lifting (5%), and stiffness (5%). However, none of those employed outside the home included cool temperature as a work-enhancer. | Significant differences existed between work status groups with respect to self-reported age, MS duration, education, and walking ability. Several of these factors might conceivably be associated negatively or positively with temperature tolerance.
| | Data collection: All data collected by survey questionnaires, which included a personal data inventory, the ADL Self-Care MS Scale, and two open-ended questions about what conditions/situations make work or chores more difficult or easier to perform | Homemaker: 48.0 ± 9.2 | | High temperature was also cited as a work-impeding item by 6% of homemakers (along with 8 other items including fatigue, balance, weakness, walking, vision, pain, fine motor skills, and bending); and 8% of homemakers cited cool temperature as a work-enhancer. | Work status at time of MS diagnosis was not assessed.
| | | Unemployed: 48.8 ± 9.9 | | By contrast, high temperature was not among the 13 work-impeding items cited by the unemployed, nor among the 11 work-impeding items cited by the retired group; although 6% of the retired listed cool temperature as a work-enhancer. | Only descriptive statistics were provided regarding temperature intolerance. No statistical comparisons were reported of this or other specific work-impeding or enhancing factors between work status groups; such statistical comparisons may not have been warranted or may not have been within the scope of the study.
| | | Retired: 56.3 ± 7.0 | | | The concept and meaning of “work” in these questionnaire responses is necessarily general, subject to interpretation, and probably varies considerably between work group domains. For instance, the nature of work demands probably differs considerably for retired respondents versus those working outside the home.
| | | Sex: | | | Study comprised solely of direct reporting and content analysis of questionnaire responses
| | | Respondents were comprised of 371 females and 137 males. No sex differences were noted among the work groups regarding education, duration of MS since diagnosis, or walking ability. Males working outside the home were older than their female counterparts (mean age 45.14 vs. 39.48; p = 0.001), but among the unemployed, males were younger (45.85 vs. 50.23; p = 0.047); the same was true in the retired group (males 54.31 vs. females 59.22; p = 0.002) (too few males in the homemaker group [n = 6] for sex difference analysis). | | | QUALITY ASSESSMENT:
| | | Baseline measures of physical and mental functioning: | | | Study described as “population-based”?: Yes
| | | Walking ability (subscale of ADL Self-Care MS Scale; mean ± SD): | | | Follow up > 80%?: Yes “approximately 90%”
| | | Employed outside home: 20.5 ± 6.9 | | | Work outcomes assessed using a widely used scale?; Yes
| | | Homemaker: 12.7 ± 9.0 | | | Work outcomes assessed in a blind fashion?: NA
| | | Unemployed: 5.8 ±7.5 | | | If subgroups with different work ability identified:
| | | Retired: 8.9 ± 8.4 | | | Was there adjustment for important prognostic factors - No, although via inter-group differences in age, years since diagnosis, education and walking ability were reported
| | | Baseline work status (“work category/group”): | | | b) was there independent validation?: No
| | | Employed outside home: 110
| | | Homemaker: 209
| | | Unemployed: 110
| | | Retired: 79