# Appendix E. Evidence Table/Data Abstraction Templates

Question 1a: What is the reliability of new McDonald criteria (incorporating supplementary information from radiologic and laboratory studies including MRI, VEP, and CSF analyses) compared with long-term follow-up diagnosis of clinically definite MS according to the Poser criteria?

Study | Study Design | Patients | Clinical Presentation | Additional Data Used for Diagnosis [Abstractor please complete] | Results [Abstractor please complete] | Comments/Quality Scoring [Abstractor please complete]
Study ID | Prospective/ Retrospective cohort study | Prospective studies: | [Essentially inclusion criteria; see left hand column of McDonald table] | 1) MRI [indicate type of MRI; type of findings reported/analyzed; and frequency of repeat scans, if any] | [Describe data for each predictor/test considered. Report both relative measures (Hazard ratios, etc.) and absolute rates (e.g., percentages of patients with/without positive CSF who met Poser criteria at long-term follow up; sensitivity and specificity may also be reported); focus should be primarily on absolute rates. Bear in mind that data may be reported for more than one long-term follow-up time point.] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Case-control study | Total no. at start: | | 2) CSF [indicate how test conducted and how “abnormal” defined] | 1) | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION - please indicate when points discussed here were raised by authors themselves (e.g., “investigators noted that study was under-powered”)]
| Duration of follow up: | Dropouts: | | 3) VEP [indicate how test conducted and how “abnormal” defined] | 2) | [Please comment here on closeness of fit between clinical presentation and additional test data described in study and specific McDonald criteria.]
| Location: | Completed: | | | 3) | QUALITY ASSESSMENT:
| | Retrospective studies: | | | 4) | Patients evaluated using Poser criteria regardless of results on initial tests?: Yes/No/Unclear
| | N = (with indication of time point) | | | 5) | Follow up > 80%?: Yes/No/NR/NA (retrospective cohort study or case-control study)
| | Both types of studies: | | | 6) | This article is relevant to (please delete as appropriate):
| | Age: | | | | Question 1a
| | | | | | Question 1b
| | | | | | Question 2
| | | | | | Question 3a
| | | | | | Question 3b
| | | | | | Question 4
| | | | | | Question 5

Question 1b: What is the inter-rater reliability of diagnosis of MS according to Poser or McDonald criteria among neurologists or between neurologists and non-neurologist physicians?

Study | Study Design | Patients & Physicians | Patients' Clinical Presentation | Diagnostic Criteria and Data Available | Results [Abstractor please complete] | Comments/Quality Scoring [Abstractor please complete]
Study ID | Cross-sectional diagnostic test study | Patients: | [Essentially inclusion criteria; see left hand column of McDonald table] | 1) Diagnostic criteria used: Poser/McDonald/Other | [Describe data on agreement/ disagreement on MS diagnosis between evaluating physicians. If possible, report raw data needed to complete 2×2-type table, as well as agreement statistics (kappa scores, sensitivity, specificity, simple agreement, etc.).] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Multicenter/ Single-center | N = | | 2) Data available for diagnosis (clinical data, neuro exam, MRI, CSF, VEP, lab tests, other): | | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION please indicate when points discussed here were raised by authors themselves (e.g., “investigators noted that study was under-powered”)]
| Setting: | Age: | | | | [Please comment here on closeness of fit between clinical presentation and additional test data described in study and specific McDonald or Poser criteria.]
| Location: | Physicians: | | | | [Please note authors' speculations (if any) about possible sources/causes of observed agreement/disagreement.]
| | N = (broken down by specialty type) | | | | QUALITY ASSESSMENT:
| | | | | | Evaluating physicians blinded to one another's diagnosis?: Yes/No/Unclear
| | | | | | Did study sample include an appropriate spectrum of patients (not just “difficult” cases)?: Yes/No/Unclear
| | | | | | This article is relevant to (please delete as appropriate):
| | | | | | Question 1a
| | | | | | Question 1b
| | | | | | Question 2
| | | | | | Question 3a
| | | | | | Question 3b
| | | | | | Question 4
| | | | | | Question 5

Question 2: What clinical indicators, including particularly time-course of impairments, predict physical or mental impairment at 12 months?

Study | Selected Inclusion/ Exclusion Criteria | Study Design | Patients | Possible Predictors Considered | Results | Comments/Quality Scoring
Study ID | Inclusion: [MS dx, definite/probable, relapse frequency, EDSS] | Retrospective/ Prospective; population-based/ not population-based; cohort study (incl. RCTs)/ case series/ case-control study | Prospective studies: | 1) | [Describe data for each predictor considered. Report both relative measures (Hazard ratios, etc.) and absolute rates (e.g., percentages of men and women with EDSS > 6 at 12 mo), but focus primarily on absolute rates. Bear in mind that data may be reported for more than one time point in the 9- to 24-mo time frame of interest to us.] | IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE
| Exclusion: | Duration of follow up: | Total no. at start (if different diagnostic categories, give subtotals by diagnosis): | 2) | 1) | COMMENT ON BIASES, ETC AFFECTING CLINICAL INTERPRETATION (including dropout rate) - please indicate when points discussed here were raised by authors themselves (e.g., “investigators noted that study was under-powered”)
| | | Completed: | 3) | 2) | QUALITY ASSESSMENT:
| | | Dropouts: | 4) | 3) | Study described as “population-based”?: Yes/No
| | | Retrospective studies: | 5) | 4) | Sample of patients assembled at a common point in the course of their disease?: Yes/No/Unclear
| | | N = (with indication of timepoint) | 6) | 5) | Sample of patients assembled at an early point in the course of their disease?: Yes/No/Unclear
| | | Both types of studies: | | 6) | Follow up > 80%?: Yes/No/NR/NA (retrospective cohort or case-control study)
| | | Age: | | | Outcomes assessed using a widely used scale?: Yes/No
| | | Baseline measures of physical and mental functioning: | | | Outcomes assessed in a blind fashion?: Yes/No/Unclear
| | | | | | If subgroups with different prognoses identified:
| | | | | | a) was there adjustment for important prognostic factors? Yes/No/Unclear/NA
| | | | | | b) was there independent validation?: Yes/No/Unclear/NA
| | | | | | This article is relevant to (please delete as appropriate):
| | | | | | Question 1a
| | | | | | Question 1b
| | | | | | Question 2
| | | | | | Question 3a
| | | | | | Question 3b
| | | | | | Question 4
| | | | | | Question 5

Question 3a: Among patients with MS, do current disease-modifying treatments result in long-term improvements in physical or mental outcomes compared to placebo or usual care?

Study | Selected Inclusion/Exclusion Criteria | Study Design | Patients | Interventions | Outcomes/Results [Abstractor please complete] | Comments/Quality Scoring [Abstractor please complete]
Study ID | Inclusion: [MS dx, definite/probable, relapse frequency, EDSS] | RCT (parallel-group, open-label/double-blind, single-center/ multicenter) | No. of patients randomized: [if different diagnostic categories, give subtotals by diagnosis] | 1) Agent, route, dose | [If outcome/data not reported, type “NR.” For each outcome, please report quantitative data (e.g., means ± SD or proportions [numbers of patients/total]) and statistical significance (with direction of effect). Please specify time points at which outcomes measured (9–24 mo).] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Exclusion: | Duration of study treatment/follow up: | Dropouts: | 2) | 1) Physical functioning (primarily EDSS): | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION (including dropout rate) - please indicate when points discussed here were raised by authors themselves (e.g., “investigators noted that study was under-powered”)]
| | Provider specialty: | Completed: | 3) | Definition of “improvement”: | QUALITY ASSESSMENT:
| | Location: | Age: | | Proportion of patients with “improvement”: | Described as “randomized”? Yes/No
| | | Baseline EDSS: | | Other (non-improvement) outcomes [list outcome measures, do not report data]: | Method of randomization clearly described? Yes/No
| | | Baseline relapse rate: | | 2) Relapse frequency: | Concealment of allocation? Yes/No/Unclear
| | | | | Definition of “relapse”: | Described as “double-blind”? Yes/No
| | | | | Definition of “improvement” [includes decrease in relapse rate]: | Patients blinded? Yes/No/Unclear
| | | | | Proportion of patients with “improvement”: | Investigators blinded? Yes/No/Unclear
| | | | | Other (non-improvement) outcomes [report non-improvement data on relapse rates; otherwise simply list outcome measures]: | Outcome assessors blinded? Yes/No/Unclear
| | | | | 3) Cognitive functioning [describe scale/ instrument used]: | No. of withdrawals in each group stated? Yes/No
| | | | | Definition of “improvement”: | This article is relevant to (please delete as appropriate):
| | | | | Proportion of patients with “improvement”: | Question 1a
| | | | | Other (non-improvement) outcomes [list outcome measures, do not report data]: | Question 1b
| | | | | 4) Work or employment outcomes: | Question 2
| | | | | Definition of “improvement”: | Question 3a
| | | | | Proportion of patients with “improvement”: | Question 3b
| | | | | Other (non-improvement) outcomes [list outcome measures, do not report data]: | Question 4
| | | | | 5) Quality of life [describe scale/ instrument used]: | Question 5
| | | | | Definition of “improvement”:
| | | | | Proportion of patients with “improvement”:
| | | | | Other (non-improvement) outcomes [list outcome measures, do not report data]:
| | | | | 6) Adverse events (no. of pts reporting AEs, most common AEs [especially when significant between-group difference], and no. of dropouts due to AEs):

Question 3b: Among patients with MS, do treatments aimed at symptom management result in improvements in physical or mental outcomes compared to usual care?

Study | Selected Inclusion/ Exclusion Criteria | Study Design | Patients | Interventions | Outcomes/Results [Abstractor please complete] | Comments/Quality Scoring [Abstractor please complete]
Study ID | Inclusion: [MS dx, definite/probable, relapse frequency, EDSS] | RCT (crossover/ parallel-group, open-label/ double-blind, single-center/ multicenter) | No. of patients randomized: [if different diagnostic categories, give subtotals by diagnosis] | 1) Agent, route, dose | [If outcome/data not reported, type “NR.” For each outcome, please report quantitative data (e.g., means ± SD or proportions [numbers of patients/total]) and statistical significance (with direction of effect). Please specify time points at which outcomes measured (earlier time points acceptable).] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Exclusion: | Duration of study treatment/follow up: | Dropouts: | 2) | 1) Symptom-specific functional status/ quality-of-life outcomes [describe scale/instrument used]: | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION (including dropout rate) please indicate when points discussed here were raised by authors themselves (e.g., “investigators noted that study was under-powered”)]
| | Provider specialty: | Completed: | 3) | Definition of “improvement”: | QUALITY ASSESSMENT:
| | Location: | Age: | If crossover, was washout period described? | Proportion of patients with “improvement”: | Described as “randomized”? Yes/No
| | | Baseline EDSS: | | Other (non-improvement) outcomes [list outcome measures, do not report data]: | Method of randomization clearly described? Yes/No
| | | | | 2) Physical functioning (primarily EDSS): | Concealment of allocation? Yes/No/Unclear
| | | | | Definition of “improvement”: | Described as “double-blind”? Yes/No
| | | | | Proportion of patients with “improvement”: | Patients blinded? Yes/No/Unclear
| | | | | Other (non-improvement) outcomes [list outcome measures, do not report data]: | Investigators blinded? Yes/No/Unclear
| | | | | 3) Cognitive functioning [describe scale/ instrument used]: | Outcome assessors blinded? Yes/No/Unclear
| | | | | Definition of “improvement”: | No. of withdrawals in each group stated? Yes/No
| | | | | Proportion of patients with “improvement”: | Crossover trials only:
| | | | | Other (non-improvement) outcomes [list outcome measures, do not report data]: | Period or carry-over effects? Yes/No/Not discussed
| | | | | 4) Work or employment outcomes: | Washout period? Yes (give duration)/No
| | | | | Definition of “improvement”: | No. of patients in each sequence clearly described? Yes/No
| | | | | Proportion of patients with “improvement”: | Were patients who did not complete all of the periods excluded from the analysis? Yes/No/Unclear
| | | | | Other (non-improvement) outcomes [list outcome measures, do not report data]: | This article is relevant to (please delete as necessary):
| | | | | 5) Generic quality-of-life outcomes [describe scale/ instrument used]: | Question 1a
| | | | | Definition of “improvement”: | Question 1b
| | | | | Proportion of patients with “improvement”: | Question 2
| | | | | Other (non-improvement) outcomes [list outcome measures, do not report data]: | Question 3a
| | | | | 6) Adverse events (no. of pts reporting AEs, most common AEs [especially when significant between-group difference], and no. of dropouts due to AEs): | Question 3b
| | | | | | Question 4
| | | | | | Question 5

Question 4: Among individuals with MS, what physical, mental, laboratory, or radiographic findings have been associated with inability to work?

Study | Selected Inclusion/ Exclusion Criteria | Study Design | Patients | Findings Considered [Please verify/edit as needed] | Results [Abstractor please complete] | Comments/Quality Scoring [Abstractor please complete]
Study ID | Inclusion: [MS dx, definite/ probable, relapse frequency, EDSS] | Retrospective/ Prospective/ Cross-sectional; population-based/ not population-based; cohort study (incl. RCTs)/ case series/ case-control study | N = (if different diagnostic categories, give subtotals by diagnosis) | 1) Physical: | [Begin by indicating how work ability was assessed (stating explicitly whether the measure was direct or indirect). For each finding possibly associated with work ability, please report both relative measures of association (Hazard ratios, etc.) and absolute rates (e.g., percentages of patients with EDSS > or < 4 who reported that they are still employed), but focus primarily on absolute rates.] | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE]
| Exclusion: | Location/recruitment: | Age: | 2) Mental: | 1) | [COMMENT ON BIASES, ETC. AFFECTING CLINICAL INTERPRETATION - please indicate when points discussed here were raised by authors themselves (e.g., “investigators noted that study was under-powered”)]
| | Data collection: | Baseline measures of physical and mental functioning: | 3) Laboratory: | 2) | QUALITY ASSESSMENT:
| | | Baseline work status: | 4) Radiographic: | 3) | Study described as “population-based”?: Yes/No
| | | | 5) Other: | 4) | Follow up > 80%?: Yes/No/NR/NA
| | | | | 5) | Work outcomes assessed using a widely used scale?: Yes/No
| | | | | 6) | Work outcomes assessed in a blind fashion?: Yes/No/Unclear
| | | | | | If subgroups with different work ability identified:
| | | | | | a) was there adjustment for important prognostic factors? Yes/No/Unclear/NA
| | | | | | b) was there independent validation?: Yes/No/Unclear/NA
| | | | | | This article is relevant to (please delete as appropriate):
| | | | | | Question 1a
| | | | | | Question 1b
| | | | | | Question 2
| | | | | | Question 3a
| | | | | | Question 3b
| | | | | | Question 4
| | | | | | Question 5

Question 5: Among individuals with MS, how does elevated temperature or other environmental factors impair the capacity to work?

Study | Selected Inclusion/ Exclusion Criteria | Study Design | Patients | Environmental Factors Considered [Abstractor please complete] | Results [Abstractor please complete] | Comments/Quality Scoring [Abstractor please complete]
Study ID | Inclusion: [MS dx, definite/probable, relapse frequency, EDSS] | Retrospective/ Prospective; population-based/ not population-based; cohort study (incl. RCTs)/ case series/ case-control study | N = (if different diagnostic categories, give subtotals by diagnosis) | 1) Elevated temperature: | [Begin by indicating how work ability was assessed (stating explicitly whether the measure was direct or indirect). For each environmental factor possibly associated with work ability, please report both relative measures of association (Hazard ratios, etc.) and absolute rates (e.g., percentages of patients in jobs with hot vs. cool working environments who reported that they are still employed), but focus primarily on absolute rates.] | IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE
| Exclusion: | | Age: | 2) Other (please specify): | 1) | COMMENT ON BIASES, ETC AFFECTING CLINICAL INTERPRETATION (including dropout rate) - please indicate when points discussed here were raised by authors themselves (e.g., “investigators noted that study was under-powered”)
| | | Baseline measures of physical and mental functioning: | | 2) | QUALITY ASSESSMENT:
| | | | | 3) | Study described as “population-based”?: Yes/No
| | | | | 4) | Follow up > 80%?: Yes/No/NR/NA (retrospective cohort or case-control study)
| | | | | 5) | Work outcomes assessed using a widely used scale?: Yes/No
| | | | | 6) | Work outcomes assessed in a blind fashion?: Yes/No/Unclear
| | | | | | If subgroups with different work ability identified:
| | | | | | a) was there adjustment for important prognostic factors? Yes/No/Unclear/NA
| | | | | | b) was there independent validation?: Yes/No/Unclear/NA
| | | | | | This article is relevant to (please delete as appropriate):
| | | | | | Question 1a
| | | | | | Question 1b
| | | | | | Question 2
| | | | | | Question 3a
| | | | | | Question 3b
| | | | | | Question 4
| | | | | | Question 5