# Appendix D. Decision Rules for Full-text Screening

Version 3: June 5, 2003

GENERAL:

Study relevant to at least one of 5 key research questions?

- If yes, then include
- If no, then exclude

PATIENTS:

Are most of all of the patients in this study [underlined: adult] (over 17 years old)?

- If yes, then include
- If no, then exclude

Have some or all of the patients been [underlined: diagnosed with possible, probable or definite MS]?

- If yes, then include
- If no, then exclude

If the study includes a [underlined: mixed population] (MS + other underlying disease), then include if at least one of the following criteria are met:

- Reports results separately for MS population
- Explicitly states there is no difference in outcome between MS and other population
- MS population represents overwhelming majority (>90%) of total population

Otherwise, exclude.

QUESTION 1a:

Does study describe prospective validation of McDonald criteria or equivalent (MRI, VEP, or CSF analyses) according to long-term follow-up diagnosis of clinically-definite MS (according to Poser criteria)?

[underlined: Exclude] article if:

- Not a McDonald criterion (see attached Table 3 from McDonald article)
- Not a longitudinal study
- No long-term diagnosis of clinically definite MS
- Not standard MRI technology such as magnetization transfer. Note: “Standard” MRI technologies include increased T2 images, enhancement, or flare.

Otherwise, include. (Retrospective studies are okay if they include a McDonald criterion).

QUESTION 1b:

Does study describe inter-rater reliability (IRR) of MS diagnosis according to Poser or McDonald criteria among neurologists or between neurologists and non-neurologist physicians?

[underlined: Exclude] article if:

- Reports IRR for MRI techniques other than T2 or gadolinium enhancing. For example, volume and magnetization transfer would be excluded.

Otherwise, include.

QUESTION 2:

Does study describe the association of clinical indicators (signs, laboratory or other objective findings including clinical course, number or frequency of exacerbations) with physical/mental health impairment (e.g., EDSS, cognitive function, fatigue, 6-minute walk, depression scale) 9–24 months later? MUST BE LONGITUDINAL STUDIES; NO CROSS-SECTIONAL STUDIES.

[underlined: Exclude] article if:

- No longitudinal follow-up (e.g., cross-sectional design).
- Time frame is too long (> 24 mo) or too short (< 9 months). Article must report data for some point in time between 9 and 24 months.
- No candidate predictors of outcome are considered, i.e., signs, lab, or other objective findings, including clinical course.
- No assessment of physical or mental health outcomes.

Otherwise, include.

QUESTION 3:

Does study address question of efficacy of a treatment aimed at modifying the disease or alleviating a symptomatic manifestation of MS?

[underlined: Exclude] article if:

- Not a RCT

For disease modifying treatments:

[underlined: Exclude] article if:

- Not a “current” treatment, e.g. other than: beta interferon (Avonex, Betaseron, Rebif), glatiramer acetate (Copaxone), mitoxantrone (Novantrone), glucocorticoids.
  Apply this exclusion to disease modifying treatments only.
- Wrong time-frame, that is, too long (> 24 mo) or too short (< 9 mo)
  Apply this exclusion to disease modifying treatments only.
- Outcome measure is NOT a measure of improvement in physical or mental function (e.g., proportion of patients with improved EDSS ≥ 1 point). NOTE: Lack of progression is not sufficient for this purpose.

Otherwise, include.

For symptom management treatments:

Exclude article if:

- Not a long-term symptom management treatment, such as bladder management, spasticity; fatigue treatment (e.g. exercise); depression treatment; comprehensive rehabilitation program. Short-term symptom management (e.g., UTI treatment) would be excluded.

Otherwise, include.

QUESTIONS 4–5:

Does the study report direct or indirect measures of ability to work aimed at MS patients?

- If yes, then include
- If no, then exclude.

Note: “Indirect” measures would include self-reported information such as employment status; measuring performance of non-work tasks (e.g., 6-min walks, ADL) does not meet our definition of “indirect” measures of ability to work.