# Appendix C. Instructions for Title and Abstract Screening

Rate each citation as “include” or “exclude” If article doesn't meet criteria but you think it may provide useful background data or be a useful source to identify relevant articles (e.g. a recent on topic review article) then mark it as “include”.

Bear in mind the following questions and criteria. You do not need to indicate the question for which the citation is included.

[underlined: Question 1:]

a. What is the reliability of new McDonald criteria (incorporating supplementary information form radiologic and laboratory studies including MRI, VEP, and CSF analyses) compared with long-term follow-up diagnosis of clinically definite MS according to the Poser criteria?
  - Patients with suspected MS
  - Compare new McDonald criteria with clinical diagnosis (based on clinical follow-up)
  - At least 20 patients
b. What is the inter-rater reliability of diagnosis of MS according to Poser or McDonald criteria among neurologists or between neurologists and non-neurologist physicians?
  - Multiple physicians assess diagnosis of MS on same actual or simulated patients.

[underlined: Question 2:]

What clinical indicators, including particularly time-course of impairments, predict physical or mental impairment at 12 months?

- Patients with suspected MS
- Studies must have follow-up patients for at least 12 months and provide data in the 9–24 month time frame (studies that provide 5-year outcomes for example, would be too distant from the mandated 12-month or permanent time frame for SSA disability determination).
- Ideally, studies should have large numbers of patients, a population-based incidence cohort, and describe the clinical course in enough detail to assess the physical and mental abnormalities at around 12 months after baseline assessment (this does not need to be 12-months from time of diagnosis). Pragmatically, several types of studies might be useful.
  1. Large population based cohorts that are not necessarily incidence cohorts.
  2. Smaller studies with careful longitudinal follow-up at defined time points (e.g. RCTs)
  3. Retrospective case series
  4. Case-control studies comparing patients with continued impairments at 12-months to patients with recovery from exacerbations.

[underlined: Question 3:]

a. Among patients with MS, do current disease-modifying treatments result in long-term improvements in physical or mental outcomes compared to placebo or usual care?
  - Study design must be randomized controlled trial
  - No restriction on study population's degree of impairment (i.e. low EDSS ok)
  - Duration of study must be at least 12 months
  - Outcomes of interest would include measures of physical functioning (e.g. EDSS), cognitive functioning, and work/employment outcomes at 12 months or more, as well as relapse rate.
b. Among patient with MS, do treatments aimed at symptom management result in improvements in physical or mental outcomes compared to usual care?
  - Symptom management includes:
    - * Bladder management (but not short-term UTI)
    - * Spasticity treatment
    - * Fatigue treatment eg. exercise
    - * Depression treatment
    - * Comprehensive rehabilitation programs
  - Study design must be randomized controlled trial
  - Populations with impairments severe enough that they would clearly meet the current medical listing criteria (eg. EDSS≥6) may be excluded
  - Outcomes of interest would include measures of physical or mental functioning that are either generic, or specific to the symptom treated, as well as work/employment outcomes.
  - Duration of study may be less than 12 months (at least 3 weeks)

[underlined: Question 4:]

Among individuals with MS, what physical, mental, laboratory, or radiographic findings have been associated with inability to work?

- Study design may include cohort or case control studies or small series (ethnographic studies) and may be cross-sectional or longitudinal.
- Study must describe the association between work/employment status (by self-reported inability to work, work status, or by determination of disability) and certain physical or mental findings
- Would generally use univariate or multivariable analysis to determine association between work ability and a variety of physical or mental findings.
- We will not be exclusive with regard to the physical or mental findings considered.

[underlined: Question 5:]

Among individuals with MS, how does elevated temperature or other environmental factors impair the capacity to work?

- Elevated temperature (heat, hot environmental temperature, work conditions that might lead to elevated body temperature [eg. clothing]) is the only environmental issue that is particularly relevant to MS.
- Study must describe work/employment status (by self-reported inability to work, work status, or by determination of disability)