# Appendix B. Search Strategies

Search Strategy #1: Employment

Database: MEDLINE <1966 to April Week 4 2003>

1. multiple sclerosis/
2. multiple sclerosis.tw.
3. exp myelitis, transverse/
4. transverse myelitis.tw.
5. optic neuritis.tw.
6. exp optic neuritis/
7. or/1–6
8. disability evaluation/ or work capacity evaluation/
9. exp EMPLOYMENT/
10. “Activities of Daily Living”/
11. or/8–9
12. or/8–10
13. 7 and 11
14. limit 13 to (human and english language)
15. 7 and 10
16. 15 not 13
17. limit 16 to (human and english language)

Search #2: Reliability of diagnostic criteria for MS

Database: MEDLINE <1966 to April Week 4 2003>

1. multiple sclerosis/di (4293)
2. mcdonald.mp. (344)
3. multiple sclerosis/ (20934)
4. Reproducibility of Results/ or Observer Variation/ or Psychometrics/ (102929)
5. poser.mp. (116)
6. reliability.mp. (37919)
7. 4 or 6 (126832)
8. or/1–2,5 (4705)
9. 7 and 8 (149)
10. 2 or 5 (457)
11. 10 and 3 (102)
12. or/1,11 (4350)
13. 7 and 12 (143)
14. from 13 keep 1–143 (143)

Search #3: Effectiveness of treatment for fatigue in MS

Database: MEDLINE <1966 to April Week 4 2003>

1. multiple sclerosis.tw. (20468)
2. exp Multiple Sclerosis/ (21587)
3. Fatigue/ (8057)
4. fatigue.tw. (21592)
5. Amantadine/ (2571)
6. amantadine.tw. (1889)
7. Pemoline/ (408)
8. exp Aminopyridines/ (6784)
9. 4-aminopyridine.tw. (3341)
10. 3,4-diaminopyridine.mp. (385)
11. exp Potassium Channel Blockers/ (6598)
12. Antidepressive Agents/ or exp Antidepressive Agents, Tricyclic/ or Sertraline/ or Fluoxetine/ or Fluvoxamine/ or Paroxetine/ or exp Serotonin Uptake Inhibitors/ or ssri.mp. or exp Antidepressive Agents, Second-Generation/ (70859)
13. Central Nervous System Stimulants/ (5345)
14. modafinil.mp. (202)
15. or/5–14 (90835)
16. or/1–2 (24958)
17. 15 and 16 (189)
18. or/3–4 (25266)
19. 18 and 16 (367)
20. 17 and 19 (45)
21. from 20 keep 1,3–4,6–7,15,19,26 (8)
22. from 17 keep 1–189 (189)

Search #4: Other symptom therapy and disease-modifying therapies

Database: MEDLINE <1966 to June Week 3 2003>

1. randomized controlled trials/ (29246)
2. random allocation/ (48831)
3. double-blind method/ (74469)
4. single-blind method/ (7355)
5. randomized controlled trial.pt. (176910)
6. 1 or 2 or 3 or 4 or 5 (252007)
7. animal/ (3458955)
8. human/ (8124713)
9. 7 and 8 (776249)
10. 7 not 9 (2682706)
11. 6 not 10 (237650)
12. clinical trial.pt. (360658)
13. exp clinical trials/ (147492)
14. (clin$ adj trial$).tw. (71615)
15. ((singl$ or doubl$ or trebl$ or tripl$) adj (blind$ or mask$)).tw. (71153)
16. placebos/ (23020)
17. placebo$.tw. (79266)
18. random$.tw. (263309)
19. research design/ (37382)
20. 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 (621803)
21. 20 not 10 (578657)
22. comparative-study/ (1052532)
23. exp evaluation studies/ (462029)
24. follow-up studies/ (269186)
25. prospective-studies/ (162165)
26. (control$ or prospectiv$ or volunteer$).tw. (1344071)
27. 22 or 23 or 24 or 25 or 26 (2709523)
28. 27 not 10 (2072206)
29. 21 not 11 (350750)
30. 28 not (21 or 11) (1666124)
31. 19991$.em. (119004)
32. 200$.em. (1786129)
33. or/31–32 (1905133)
34. Anti-Dyskinesia Agents/ or Muscle Relaxants, Central/ or Baclofen/ or MUSCLE SPASTICITY/ or spasticity.mp. or Spasm/ or Botulinum Toxin Type A/ or Botulinum Toxins/ (19461)
35. Diazepam/tu [Therapeutic Use] (3612)
36. exp DEPRESSION/dh, dt, rh, th [Diet Therapy, Drug Therapy, Rehabilitation, Therapy] (10148)
37. exp REHABILITATION/ or exp REHABILITATION CENTERS/ or exp REHABILITATION, VOCATIONAL/ (139505)
38. bladder, neurogenic/ or urination disorders/ or exp urinary incontinence/ or urinary retention/ (24827)
39. or/34–38 (193826)
40. exp multiple sclerosis/ or multiple sclerosis.mp. (25332)
41. 39 and 40 (1544)
42. 11 and 41 (111)
43. 29 and 41 (150)
44. 30 and 41 (319)
45. 11 and 40 and 33 (277)
46. 42 or 45 (359)
47. limit 46 to english language (331)

Search #5: Predictive value of McDonald diagnostic criteria and components

Database: MEDLINE <1966 to April Week 4 2003>

1. multiple sclerosis/di (4293)
2. mcdonald.mp. (344)
3. multiple sclerosis/ (20934)
4. 2 and 3 (15)
5. Magnetic Resonance Imaging/ (103327)
6. 3 and 5 (2359)
7. follow-up studies/ (265132)
8. 6 and 7 (182)
9. prospective studies/ (158042)
10. 6 and 9 (88)
11. 8 or 10 (246)
12. “sensitivity and specificity”/ (98408)
13. 2 and 12 (3)
14. 12 and 1 (171)
15. or/4,11,13–14 (408)
16. or/4,8,13–14 (352)
17. 15 not 16 (56)
18. from 15 keep 1–408 (408)
19. Reproducibility of Results/ or Observer Variation/ or Psychometrics/ (102929)
20. poser.mp. (116)
21. 19 and 20 (4)
22. 19 and 2 (5)
23. 19 and 1 (112)
24. Evoked Potentials, Visual/ (8416)
25. 3 and 7 and 24 (37)
26. oligoclonal bands.mp. (535)
27. Cerebrospinal Fluid/ (9812)
28. 3 and 7 and 27 (4)
29. 3 and 7 and 26 (15)
30. or/15,21–23,25,28–29 (529)
31. limit 30 to (human and english language) (465)
32. from 31 keep 1–465 (465)