# List of Acronyms/Abbreviations

9-HPT | 9-Hole Peg Test
ADA | Americans with Disabilities Act
AHRQ | Agency for Healthcare Research and Quality
APOE | apolipoprotein E
BDI | Beck Depression Inventory
BRB-N | Brief Repeatable Battery
CI | confidence interval
CIS | clinically isolated syndrome
CSF | cerebrospinal fluid
CDMS | clinically definite multiple sclerosis
CT | computed tomography
Delta-9-THC | delta-9-tetrahydrocannabinol
DSS | Disability Status Scale
EDSS | Expanded Disability Status Scale
EPC | Evidence-based Practice Center
FIM | Functional Independence Measure
GNDS | Guy's Neurological Disability Scale
IgG | immunoglobulin-G
IgM | immunoglobulin-M
IL-2 | interleukin-2
IV | intravenous
MDI | Mobility Dysfunction Index
MeSH | Medical Subject Headings
MFIS | Modified Fatigue Impact Scale
MRI | magnetic resonance imaging
MS | multiple sclerosis
MSFC | Multiple Sclerosis Functional Composite
MS-FS | MS-Specific Fatigue Scale
NA | not applicable
NR | not reported
PASAT | Paced Auditory Serial Addition Test
PR | prevalence ratio
OR | odds ratio
QOL | quality of life
RCT | randomized controlled trial
SD | standard deviation
SDMT | Symbol Digit Modalities Test
SF-36 | Medical Outcomes Study 36-Item Short-Form Health Survey
SSA | Social Security Administration
SSDI | Social Security Disability Insurance
VEP | visual evoked potential