# List of Excluded Studies

All excluded articles listed below were reviewed in their full-text versions. Following each reference, in italics, is the primary reason for exclusion and the question (Q) for which the article was considered. If no Q is indicated, then the article was excluded a priori from the study for the reason given. Reasons for exclusion pertain only to the usefulness of articles for this study and are not intended as criticisms of the articles per se.“DA” indicates exclusion at the data abstraction stage. For reference, the questions are:
Question 1a: What is the reliability of new McDonald criteria (incorporating supplementary information form radiologic and laboratory studies including MRI, VEP, and CSF analyses) compared with long-term follow-up diagnosis of clinically definite MS according to the Poser criteria?
Question 1b: What is the inter-rater reliability of diagnosis of MS according to Poser or McDonald criteria among neurologists or between neurologists and non-neurologist physicians?
Question 2: What clinical indicators, including particularly time-course of impairments, predict physical or mental impairment at 12 months?
Question 3a: Among patients with MS, do current disease-modifying treatments result in long-term improvements in physical or mental outcomes compared to placebo or usual care?
Question 3b: Among patients with MS, do treatments aimed at symptom management result in improvements in physical or mental outcomes compared to usual care?
Question 4: Among individuals with MS, what physical, mental, laboratory, or radiographic findings have been associated with inability to work?
Question 5: Among individuals with MS, how does elevated temperature or other environmental factors impair the capacity to work?
Abel NA, Smith RA. Intrathecal baclofen for treatment of intractable spinal spasticity. Arch Phys Med Rehab. 1994;75(1):54-8. Exclude-Q3-no results for placebo patients.
Adams HP, Wagner S, Sobel DF, et al. Hypointense and hyperintense lesions on magnetic resonance imaging in secondary-progressive MS patients. Eur Neurol. 1999;42(1):52-63. Exclude-Q2-no predictor with outcome. [pmid: 10394049].
Albrecht H, Wotzel C, Erasmus LP, et al. Day-to-day variability of maximum walking distance in MS patients can mislead to relevant changes in the Expanded Disability Status Scale (EDSS): average walking speed is a more constant parameter. Mult Scler. 2001;7(2):105-9. Exclude-Q2-no long-term follow up. [pmid: 11424630].
Allanson J, Bass C, Wade DT. Characteristics of patients with persistent severe disability and medically unexplained neurological symptoms: a pilot study. J Neurol Neurosurg Psych. 2002;73(3):307-9. Exclude-no MS patients specified.
Allen K, Blascovich J. The value of service dogs for people with severe ambulatory disabilities. A randomized controlled trial. JAMA. 1996;275(13):1001-6. Exclude-no MS patients specified. [pmid: 8596231].
Alusi SH, Worthington J, Glickman S, et al. A study of tremor in multiple sclerosis. Brain. 2001;124(Pt 4):720-30. Exclude-Q2-no long-term follow up. [pmid: 11287372].
Alusi SH, Worthington J, Glickman S, et al. Evaluation of three different ways of assessing tremor in multiple sclerosis. J Neurol Neurosurg Psych. 2000;68(6):756-60. Exclude-Q2-no long-term follow up.
Amato MP, Fratiglioni L, Groppi C, et al. Interrater reliability in assessing functional systems and disability on the Kurtzke scale in multiple sclerosis. Arch Neurol. 1988;45(7):746-8. Exclude-Q2-background. [pmid: 3390030].
Amato MP, Ponziani G. Quantification of impairment in MS: discussion of the scales in use [review]. Mult Scler. 1999;5(4):216-9. Exclude-not relevant to study questions. [pmid: 10467378].
Amato MP, Ponziani G. A prospective study on the prognosis of multiple sclerosis. Neurol Sci. 2000;21(4 Suppl 2):S831-8. Exclude-Q2-wrong timeframe. [pmid: 11205358].
Amato MP, Ponziani G, Rossi F, et al. Quality of life in multiple sclerosis: the impact of depression, fatigue and disability. Mult Scler. 2001;7(5):340-4. Exclude-Q2-no long-term follow up. [pmid: 11724451].
Aminoff MJ, Davis SL, Panitch HS. Serial evoked potential studies in patients with definite multiple sclerosis. Clinical relevance. Arch Neurol. 1984;41(11):1197-202. Exclude-Q2-no analysis of predictors. [pmid: 6487104].
Andersson PB, Waubant E, Gee L, et al. Multiple sclerosis that is progressive from the time of onset: clinical characteristics and progression of disability. Arch Neurol. 1999;56(9):1138-42. Exclude-Q2-wrong timeframe. [pmid: 10488816].
Andersson T, Siden A, Persson A. A comparison of clinical and evoked potential (VEP and median nerve SEP) evolution in patients with MS and potentially related conditions. Acta Neurol Scand. 1991;84(2):139-45. Exclude-Q2-no physical or mental outcome reported. [pmid: 1950449].
Antel JP, Freedman MS, Brodovsky S, et al. Activated suppressor cell function in severely disabled patients with multiple sclerosis. Ann Neurol. 1989;25(2):204-7. Exclude-Q2-no long-term follow up. [pmid: 2521994].
Archibald CJ, McGrath PJ, Ritvo PG, et al. Pain prevalence, severity and impact in a clinic sample of multiple sclerosis patients. Pain. 1994;58(1):89-93. Exclude-Q4-vague measurements of work ability. [pmid: 7970843].
Armutlu K, Karabudak R, Nurlu G. Physiotherapy approaches in the treatment of ataxic multiple sclerosis: a pilot study. Neurorehab Neural Repair. 2001;15(3):203-11. Exclude-Q3-no long-term symptom management.
Arnold DL, Bouchard JP, Boyle CAJ, et al. Key issues in the diagnosis and treatment of multiple sclerosis-an overview. Neurology. 2002;59(6):U2-S33. Exclude-review-background.
Arnold DL, Matthews PM. MRI in the diagnosis and management of multiple sclerosis. Neurology. 2002;58(8):S23-S31. Exclude-review-background. [pmid: 11971123].
Aronson KJ. Quality of life among persons with multiple sclerosis and their caregivers. Neurology. 1997;48(1):74-80. Exclude-not relevant to study questions. [pmid: 9008497].
Aupperle RL, Beatty WW, Shelton FdeNAP, et al. Three screening batteries to detect cognitive impairment in multiple sclerosis. Mult Scler. 2002;8(5):382-9. Exclude-Q4-no findings relevant to question. [pmid: 12356204].
AUSTIMS Research Group. Interferon-alpha and transfer factor in the treatment of multiple sclerosis: a double-blind, placebo-controlled trial. J Neurol Neurosurg Psych. 1989;52(5):566-74. Exclude-Q3-not current therapy.
Baker DG. Multiple sclerosis and thermoregulatory dysfunction. J Appl Physiol. 2002;92(5):1779-80. Exclude-DA-Q5-review article. [pmid: 11960923].
Bakshi R, Benedict RH, Bermel RA, et al. Regional brain atrophy is associated with physical disability in multiple sclerosis: semiquantitative magnetic resonance imaging and relationship to clinical findings. J Neuroimag. 2001;11(2):129-36. Exclude-Q2-no long-term follow up.
Balcer LJ. Clinical outcome measures for research in multiple sclerosis [review]. J Neuro-Ophthalmol. 2001;21(4):296-301. Exclude-Q2-no long-term follow up.
Barkhof F. MRI in multiple sclerosis: correlation with expanded disability status scale (EDSS) [review]. Mult Scler. 1999;5(4):283-6. Exclude-Q2-no long-term follow up. [pmid: 10467389].
Barkhof F. The clinico-radiological paradox in multiple sclerosis revisited [review]. Curr Opinion Neurol. 2002;15(3):239-45. Exclude-Q2-no long-term follow up.
Barkhof F, Filippi M, van Waesberghe JH, et al. Interobserver agreement for diagnostic MRI criteria in suspected multiple sclerosis. Neuroradiology. 1999;41(5):347-50. Exclude-Q1b-no Poser or McDonald criteria. [pmid: 10379592].
Barkhof F, Filippi M, van Waesberghe JH, et al. Improving interobserver variation in reporting gadolinium-enhanced MRI lesions in multiple sclerosis. Neurology. 1997;49(6):1682-8. Exclude-Q1b-no Poser or McDonald criteria. [pmid: 9409366].
Barkhof F, Frequin ST, Hommes OR, et al. A correlative triad of gadolinium-DTPA MRI, EDSS, and CSF-MBP in relapsing multiple sclerosis patients treated with high-dose intravenous methylprednisolone. Neurology. 1992;42(1):63-7. Exclude-Q3-not RCT. [pmid: 1370864].
Barnes D, Hughes RA, Morris RW, et al. Randomised trial of oral and intravenous methylprednisolone in acute relapses of multiple sclerosis. Lancet. 1997;349(9056):902-6. Exclude-Q3-wrong timeframe. [pmid: 9093250].
Basmajian JV. Lioresal (baclofen) treatment of spasticity in multiple sclerosis. Am J Phys Med. 1975;54(4):175-7. Exclude-DA-Q3-data poorly described. [pmid: 1098477].
Basmajian JV, Shankardass K, Russell D. Ketazolam once daily for spasticity: double-blind cross-over study. Arch Phys Med Rehab. 1986;67(8):556-7. Exclude-DA-Q3-outcomes poorly described.
Basmajian JV, Shankardass K, Russell D, et al. Ketazolam treatment for spasticity: double-blind study of a new drug. Arch Phys Med Rehab. 1984;65(11):698-701. Exclude-DA-Q3-limited results reported for MS patients.
Basmajian JV, Yucel V. Effects of a GABA—derivative (BA-34647) on spasticity. Preliminary report of a double-blind cross-over study. Am J Phys Med. 1974;53(5):223-8. Exclude-DA-Q3-no separate results reported for MS patients. [pmid: 4153338].
Basso MR, Beason-Hazen S, Lynn J, et al. Screening for cognitive dysfunction in multiple sclerosis. Arch Neurol. 1996;53(10):980-4. Exclude-Q2-no long-term follow up. [pmid: 8859059].
Battaglia MA, Serpero P, Bordo G, et al. Evaluation of the minimal record of disability in multiple sclerosis patients in Genoa. Acta Neurol Scand Suppl. 1984;101:92-9. Exclude-Q2-no long-term follow up. [pmid: 6594922].
Bauer HJ, Krtsch U, Schipper R, et al. Disability rating with the IFMSS scales. Acta Neurol Scand Suppl. 1984;101:145-52. Exclude-Q2-no long-term follow up. [pmid: 6594905].
Baumhefner RW, Tourtellotte WW, Syndulko K, et al. Quantitative multiple sclerosis plaque assessment with magnetic resonance imaging. Its correlation with clinical parameters, evoked potentials, and intra-blood-brain barrier IgG synthesis. Arch Neurol. 1990;47(1):19-26. Exclude-Q2-no long-term follow up. [pmid: 2294889].
Becker KG. APOE genotype is a major predictor of long-term progression of disability in MS. Neurology. 2001;57(11):2148-9. Exclude-Q2-no long-term follow up. [pmid: 11739852].
Beenakker EA, Oparina TI, Hartgring A, et al. Cooling garment treatment in MS: clinical improvement and decrease in leukocyte NO production. Neurology. 2001;57(5):892-4. Exclude-DA-Q3-no specific symptom targeted. [pmid: 11552024].
Benedict RH, Shapiro A, Priore R, et al. Neuropsychological counseling improves social behavior in cognitively-impaired multiple sclerosis patients. Mult Scler. 2000;6(6):391-6. Exclude-DA-Q3-no comparison to usual care. [pmid: 11212135].
Benesova Y, Niedermayerova I. New approach to evaluation of clinical state in patients with multiple sclerosis. Bratislavske Lekarske Listy. 2001;102(8):370-1. Exclude-Q2-no long-term follow up. [pmid: 11763667].
Berg D, Maurer M, Warmuth-Metz M, et al. The correlation between ventricular diameter measured by transcranial sonography and clinical disability and cognitive dysfunction in patients with multiple sclerosis. Arch Neurol. 2000;57(9):1289-92. Exclude-Q2-no long-term follow up. [pmid: 10987895].
Bergamaschi R, Romani A, Versino M, et al. Clinical aspects of fatigue in multiple sclerosis. Funct Neurol. 1997;12(5):247-51. Exclude-Q2-no long-term follow up. [pmid: 9439942].
Berger JR, Sheremata WA. Persistent neurological deficit precipitated by hot bath test in multiple sclerosis. JAMA. 1983;249(13):1751-3. Exclude-review-background. [pmid: 6600798].
Bernardi S, Buttinelli C, Grasso MG, et al. Evolution and severity markers in 233 MS patients. Riv Neurol. 1987;57(3):197-200. Exclude-Q2-wrong timeframe. [pmid: 3672012].
Beutler E, Sipe J, Romine J, et al. Treatment of multiple sclerosis and other autoimmune diseases with cladribine. Sem Hematol. 1996;33(1 Suppl 1):45-52. Exclude-DA-Q3-incomplete data.
Bever CT Jr. The current status of studies of aminopyridines in patients with multiple sclerosis [review]. Ann Neurol. 1994;36(Suppl):S118-21. Exclude-review-background. [pmid: 8017870].
Bever CT Jr, Anderson PA, Leslie J, et al. Treatment with oral 3,4 diaminopyridine improves leg strength in multiple sclerosis patients: results of a randomized, double-blind, placebo-controlled, crossover trial. Neurology. 1996;47(6):1457-62. Exclude-Q3-no long-term symptom management. [pmid: 8960727].
Bever CT Jr, Leslie J, Camenga DL, et al. Preliminary trial of 3,4-diaminopyridine in patients with multiple sclerosis. Ann Neurol. 1990;27(4):421-7. Exclude-Q3-not RCT. [pmid: 2353797].
Bever CT Jr, Young D, Anderson PA, et al. The effects of 4-aminopyridine in multiple sclerosis patients: results of a randomized, placebo-controlled, double-blind, concentration-controlled, crossover trial. Neurology. 1994;44(6):1054-9. Exclude-Q3-wrong timeframe. [pmid: 8208399].
Bjuro T, Fugl-Meyer AR, Grimby G, et al. Domestic work in patients with neuromuscular handicap. Scand J Rehab Med Suppl. 1978;6:193-6. Exclude-Q4-no findings relevant to question.
Blake DJ, Bodine C. An overview of assistive technology for persons with multiple sclerosis. J Rehab Res Develop. 2002;39(2):299-312. Exclude-not relevant to study questions.
Blinkenberg M, Jensen CV, Holm S, et al. A longitudinal study of cerebral glucose metabolism, MRI, and disability in patients with MS. Neurology. 1999;53(1):149-53. Exclude-Q2-wrong timeframe. [pmid: 10408551].
Boggild M, Ford H. Multiple sclerosis. Clin Evid 2002;(7):1195–207. Exclude-review-background Q3
Bourdette DN, Prochazka AV, Mitchell W, et al. Health care costs of veterans with multiple sclerosis: implications for the rehabilitation of MS. VA Multiple Sclerosis Rehabilitation Study Group. Arch Phys Med Rehab. 1993;74(1):26-31. Exclude-Q2-no long-term follow up.
Bowen J, Gibbons L, Gianas A, et al. Self-administered Expanded Disability Status Scale with functional system scores correlates well with a physician-administered test. Mult Scler. 2001;7(3):201-6. Exclude-Q2-no long-term follow up. [pmid: 11475445].
Branas P, Jordan R, Fry-Smith A, et al. Treatments for fatigue in multiple sclerosis: a rapid and systematic review. Health Technol Assess (Winchester, England). 2000;4(27):1-61. Exclude-review-background.
Brassat D, Azais-Vuillemin C, Yaouanquestion J, et al. Familial factors influence disability in MS multiplex families. French Multiple Sclerosis Genetics Group. Neurology. 1999;52(8):1632-6. Exclude-Q2-no long-term follow up. [pmid: 10331690].
Brassington JC, Marsh NV. Neuropsychological aspects of multiple sclerosis [review]. Neuropsychol Rev. 1998;8(2):43-77. Exclude-review-background Q2. [pmid: 9658410].
Breitbart W, Rosenfeld B, Kaim M, et al. A randomized, double-blind, placebo-controlled trial of psychostimulants for the treatment of fatigue in ambulatory patients with human immunodeficiency virus disease. Arch Intern Med. 2001;161(3):411-20. Exclude-no MS patients. [pmid: 11176767].
Brex PA, Ciccarelli O, O'Riordan JI, et al. A longitudinal study of abnormalities on MRI and disability from multiple sclerosis. New Engl J Med. 2002;346(3):158-64. Exclude-Q2-wrong timeframe. [pmid: 11796849].
Brochet B, Guinot P, Orgogozo JM, et al. Double blind placebo controlled multicentre study of ginkgolide B in treatment of acute exacerbations of multiple sclerosis. The Ginkgolide Study Group in multiple sclerosis. J Neurol Neurosurg Psych. 1995;58(3):360-2. Exclude-Q2-wrong timeframe.
Brown JR. Recent studies in multiple sclerosis: inferences on rehabilitation and employability. Mayo Clinic Proc. 1969;44(10):758-65. Exclude-not relevant to study question.
Brown JR. Problems in evaluating new treatments for multiple sclerosis. Neurology. 1980;30(7):8-11. Exclude-not relevant to study question. [pmid: 6248820].
Brown MG, Murray TJ, Sketris IS, et al. Cost-effectiveness of interferon beta-1b in slowing multiple sclerosis disability progression. First estimates. Internat J Technol Assess Health Care. 2000;16(3):751-67. Exclude-not relevant to study question.
Brusaferri F, Candelise L. Steroids for multiple sclerosis and optic neuritis: a meta-analysis of randomized controlled clinical trials. J Neurol. 2000;247(6):435-42. Exclude-DA-Q3-meta-analysis. [pmid: 10929272].
Bryant D, Chiaravalloti ND, DeLuca J. Objective measurement of cognitive fatigue in multiple sclerosis. Rehab Psychol 2003;in press. Exclude-Q4-no measure of work ability
Burridge J, Taylor P, Hagan S, et al. Experience of clinical use of the Odstock dropped foot stimulator. Artificial Organs. 1997;21(3):254-60. Exclude-Q3-mixed population. [pmid: 9148719].
Calabresi PA. Considerations in the treatment of relapsing-remitting multiple sclerosis [review]. Neurology. 2002;58(8 Suppl 4):S10-22. Exclude-Q2-Other-background. [pmid: 11971122].
Camenga DL, Johnson KP, Alter M, et al. Systemic recombinant alpha-2 interferon therapy in relapsing multiple sclerosis. Arch Neurol. 1986;43(12):1239-46. Exclude-Q3-not current therapy. [pmid: 3535752].
Capello E, Gardella M, Leandri M, et al. Lowering body temperature with a cooling suit as symptomatic treatment for thermosensitive multiple sclerosis patients. Ital J Neurol Sci. 1995;16(8):533-9. Exclude-DA-Q5-no data on work status or ability. [pmid: 8613414].
Caramia F, Pantano P, Di Legge S, et al. A longitudinal study of MR diffusion changes in normal appearing white matter of patients with early multiple sclerosis. Magnet Reson Imag. 2002;20(5):383-8. Exclude-DA-Q1a-no long-term follow up using Poser.
Casanova B, Coret F, Valero C, et al. High clinical inflammatory activity prior to the development of secondary progression: a prospective 5-year follow-up study. Mult Scler. 2002;8(1):59-63. Exclude-Q2-no analysis of predictors. [pmid: 11939173].
Catalaa I, Fulton JC, Zhang X, et al. MR imaging quantitation of gray matter involvement in multiple sclerosis and its correlation with disability measures and neurocognitive testing. Am J Neuroradiol. 1999;20(9):1613-8. Exclude-Q2-no analysis of predictors. [pmid: 10543630].
Catanzaro M, Weinert C. Economic status of families living with multiple sclerosis. Internat J Rehab Res. 1992;15(3):209-18. Exclude-Q5-no data on work status or ability.
Cazzato G, Mesiano T, Antonello R, et al. Double-blind, placebo-controlled, randomized, crossover trial of high-dose methylprednisolone in patients with chronic progressive form of multiple sclerosis. Eur Neurol. 1995;35(4):193-8. Exclude-Q3-wrong timeframe. [pmid: 7671978].
Cazzullo CL, Ghezzi A, Marforio S, et al. Clinical picture of multiple sclerosis with late onset. Acta Neurol Scand. 1978;58(3):190-6. Exclude-Q2-wrong timeframe. [pmid: 716837].
Cendrowski W, Sobczyk W. Clonazepam, baclofen and placebo in the treatment of spasticity. Eur Neurol. 1977;16(16):257-62. Exclude-DA-Q3-not RCT. [pmid: 354938].
Cendrowski WS. Progression index and disability status in multiple sclerosis: a resurvey of 207 patients in central Poland. Schweiz Arch Neurol Psych. 1986;137(4):5-13. Exclude-Q2-no predictor with outcome.
Cercignani M, Inglese M, Pagani E, et al. Mean diffusivity and fractional anisotropy histograms of patients with multiple sclerosis. Am J Neuroradiol. 2001;22(5):952-8. Exclude-Q2-no long-term follow up. [pmid: 11337342].
Cervera-Deval J, Morant-Guillen MP, Fenollosa-Vasquez P, et al. Social handicaps of multiple sclerosis and their relation to neurological alterations. Arch Phys Med Rehab. 1994;75(11):1223-7. Exclude-review-background Q4.
CHAMPS Study Group. Interferon beta-1a for optic neuritis patients at high risk for multiple sclerosis. Am J Ophthalmol. 2001;132(4):463-71. Exclude-DA-Q1a-no relevant data. [pmid: 11589865].
CHAMPS Study Group. Baseline MRI characteristics of patients at high risk for multiple sclerosis: results from the CHAMPS trial. Mult Scler. 2002;8(4):330-8. Exclude-Q2-no long-term follow up. [pmid: 12166504].
Cheng EM, Hays RD, Myers LW, et al. Factors related to agreement between self-reported and conventional Expanded Disability Status Scale (EDSS) scores. Mult Scler. 2001;7(6):405-10. Exclude-not relevant to study question. [pmid: 11795463].
Chiba S, Ito M, Matsumoto H. Amantadine treatment for refractory pain and fatigue in patients with multiple sclerosis. Can J Neurol Sci. 1992;19(2):309. Exclude-Q3-Other-review. [pmid: 1623455].
Christensen O, Clausen J. Social remedial measures for multiple sclerosis patients in Denmark. Acta Neurol Scand. 1977;55(5):394-406. Exclude-DA-Q4-no correlation with findings relevant to question. [pmid: 140581].
Chwastiak L, Ehde DM, Gibbons LE, et al. Depressive symptoms and severity of illness in multiple sclerosis: epidemiologic study of a large community sample. Am J Psych. 2002;159(11):1862-8. Exclude-Q4-no correlation with findings relevant to question.
Ciccarelli O, Brex PA, Thompson AJ, et al. Disability and lesion load in MS: a reassessment with MS functional composite score and 3D fast FLAIR. J Neurol. 2002;249(1):18-24. Exclude-Q2-no long-term follow up. [pmid: 11954864].
Cid C, Alcazar A, Regidor I, et al. Neuronal apoptosis induced by cerebrospinal fluid from multiple sclerosis patients correlates with hypointense lesions on T1 magnetic resonance imaging. J Neurol Sci. 2002;193(2):103-9. Exclude-Q2-wrong timeframe. [pmid: 11790390].
Clanet M, Radue EW, Kappos L, et al. A randomized, double-blind, dose-comparison study of weekly interferon beta-1a in relapsing MS. Neurology. 2002;59(10):1507-17. Exclude-Q3-no control. [pmid: 12451189].
Clifford DB. Tetrahydrocannabinol for tremor in multiple sclerosis. Ann Neurol. 1983;13(6):669-71. Exclude-Q3-not RCT. [pmid: 6309074].
Clifford DB, Trotter JL. Pain in multiple sclerosis. Arch Neurol. 1984;41(12):1270-2. Exclude-Q2-no long-term follow up. [pmid: 6208884].
Coban O, Bahar S, Akman-Demir G, et al. A controlled study of reliability and validity of MRI findings in neuro-Behcet's disease. Neuroradiology. 1996;38(4):312-6. Exclude-Q1a-no MS patients. [pmid: 8738085].
Coban O, Bahar S, Akman-Demir G, et al. Masked assessment of MRI findings: is it possible to differentiate neuro-Behcet's disease from other central nervous system diseases? [corrected][erratum appears in Neuradiology 1999 Jul;41(7):550]. Neuroradiology. 1999;41(4):255-60. Exclude-Q1a-not longitudinal. [pmid: 10344509].
Cohen JA, Cutter GR, Fischer JS, et al. Use of the multiple sclerosis functional composite as an outcome measure in a phase 3 clinical trial. Arch Neurol. 2001;58(6):961-7. Exclude-review-background Q4. [pmid: 11405811].
Cohen RA, Kessler HR, Fischer M. The Extended Disability Status Scale (EDSS) as a predictor of impairments of functional activities of daily living in multiple sclerosis. J Neurol Sci. 1993;115(2):132-5. Exclude-review-background Q4. [pmid: 8482974].
Colosimo C, Millefiorini E, Grasso MG, et al. Fatigue in MS is associated with specific clinical features. Acta Neurol Scand. 1995;92(5):353-5. Exclude-Q2-no long-term follow up. [pmid: 8610485].
Comi G, Filippi M, Rovaris M, et al. Clinical, neurophysiological, and magnetic resonance imaging correlations in multiple sclerosis [review]. J Neurol Neurosurg Psych. 1998;64(Suppl 1):S21-5. Exclude-Q1a-non-standard technology.
Comi G, Filippi M, Wolinsky JS. EuropeanCanadian multicenter, double-blind, randomized, placebo-controlled study of the effects of glatiramer acetate on magnetic resonance imaging—measured disease activity and burden in patients with relapsing multiple sclerosis. EuropeanCanadian Glatiramer Acetate Study Group. Ann Neurol. 2001;49(3):290-7. Exclude-Q3-Other-no improvement. [pmid: 11261502].
Comi G, Leocani L, Rossi P, et al. Physiopathology and treatment of fatigue in multiple sclerosis [review]. J Neurol. 2001;248(3):174-9. Exclude-Q3-not RCT. [pmid: 11355149].
Confavreux C, Aimard G, Devic M. Course and prognosis of multiple sclerosis assessed by the computerized data processing of 349 patients. Brain. 1980;103(2):281-300. Exclude-Q2-wrong timeframe. [pmid: 7397479].
Confavreux C, Vukusic S, Moreau T, et al. Relapses and progression of disability in multiple sclerosis. New Engl J Med. 2000;343(20):1430-8. Exclude-Q2-wrong timeframe. [pmid: 11078767].
Confavreux C, Wolfson C. Mathematical models and individualized outcome estimates in multiple sclerosis. Biomed Pharmacother. 1989;43(9):675-80. Exclude-Q2-no physical or mental outcome. [pmid: 2624884].
Constantinescu CS, Mehta PD, Rostami AM. Urinary free kappa light chain levels in chronic progressive multiple sclerosis. Pathobiology. 1994;62(1):29-33. Exclude-Q2-wrong timeframe. [pmid: 8031473].
Cook SD, Devereux C, Troiano R, et al. Effect of total lymphoid irradiation in chronic progressive multiple sclerosis. Lancet. 1986;1(8495):1405-9. Exclude-Q3-not current therapy. [pmid: 2872516].
Cottrell DA, Kremenchutzky M, Rice GP, et al. The natural history of multiple sclerosis: a geographically based study. 5. The clinical features and natural history of primary progressive multiple sclerosis. Brain. 1999;122(Pt 4):625-39. Exclude-Q2-wrong timeframe. [pmid: 10219776].
Cutter GR, Baier ML, Rudick RA, et al. Development of a multiple sclerosis functional composite as a clinical trial outcome measure. Brain. 1999;122(Pt 5):871-82. Exclude-Q4-no data on work status or ability. [pmid: 10355672].
Dastidar P, Heinonen T, Lehtimaki T, et al. Volumes of brain atrophy and plaques correlated with neurological disability in secondary progressive multiple sclerosis. J Neurol Sci. 1999;165(1):36-42. Exclude-Q2-no long-term follow up. [pmid: 10426145].
Davis EC, Barnes MP. Botulinum toxin and spasticity. J Neurol Neurosurg Psych. 2000;69(2):143-7. Exclude-Q3-not RCT.
Davis FA, Stefoski D, Rush J. Orally administered 4-aminopyridine improves clinical signs in multiple sclerosis. Ann Neurol. 1990;27(2):186-92. Exclude-Q3-no long-term symptom management. [pmid: 2317014].
de Rham B. A contribution to assessment in MS. Study of 100 situations of MS persons through Incapacity Status and Environmental Status and their scales scores. Acta Neurol Scand Suppl. 1984;101:113-25. Exclude-Q4-instrument testing. [pmid: 6594901].
De Seze J, Stojkovic T, Ferriby D, et al. Devic's neuromyelitis optica: clinical, laboratory, MRI and outcome profile. J Neurol Sci. 2002;197(12):57-61. Exclude-no MS patients. [pmid: 11997067].
de Seze M, Wiart L, Joseph PA, et al. Capsaicin and neurogenic detrusor hyperreflexia: a double-blind placebo-controlled study in 20 patients with spinal cord lesions. Neurourol Urodynam. 1998;17(5):513-23. Exclude-Q3-mixed population.
De Souza LH. The development of a scale of the Guttman type for the assessment of mobility disability in multiple sclerosis. Clin Rehab. 1999;13(6):476-81. Exclude-Q2-no long-term follow up.
De Stefano N, Matthews PM, Fu L, et al. Axonal damage correlates with disability in patients with relapsing-remitting multiple sclerosis. Results of a longitudinal magnetic resonance spectroscopy study. Brain. 1998;121(Pt 8):1469-77. Exclude-Q2-no analysis of predictors. [pmid: 9712009].
De Stefano N, Narayanan S, Francis GS, et al. Evidence of axonal damage in the early stages of multiple sclerosis and its relevance to disability. Arch Neurol. 2001;58(1):65-70. Exclude-Q2-no long-term follow up. [pmid: 11176938].
Dean G. A double-blind trial with an antidepressant drug, imipramine, in multiple sclerosis. S A Med J. 1969;43(4):86-7. Exclude-Q3-patients not symptomatic.
Dehmeshki J, Barker GJ, Tofts PS. Classification of disease subgroup and correlation with disease severity using magnetic resonance imaging whole-brain histograms: application to magnetization transfer ratios and multiple sclerosis. IEEE Trans Med Imag. 2002;21(4):320-31. Exclude-Q2-no long-term follow up.
Dehmeshki J, Ruto AC, Arridge S, et al. Analysis of MTR histograms in multiple sclerosis using principal components and multiple discriminant analysis. Magnet Reson Med. 2001;46(3):600-9. Exclude-Q2-no long-term follow up.
Dehmeshki J, Silver NC, Leary SM, et al. Magnetisation transfer ratio histogram analysis of primary progressive and other multiple sclerosis subgroups. J Neurol Sci. 2001;185(1):11-7. Exclude-Q2-no long-term follow up. [pmid: 11266685].
Detels R, Clark VA, Valdiviezo NL, et al. Factors associated with a rapid course of multiple sclerosis. Arch Neurol. 1982;39(6):337-41. Exclude-Q2-wrong timeframe. [pmid: 7092610].
Doble SE, Fisk JD, Fisher AG, et al. Functional competence of community-dwelling persons with multiple sclerosis using the assessment of motor and process skills. Arch Phys Med Rehab. 1994;75(8):843-51. Exclude-Q4-no measurement of work ability.
Drislane FW. Use of evoked potentials in the diagnosis and follow-up of multiple sclerosis [review]. Clin Neurosci. 1994;2(34):196-201. Exclude-Q2-background. [pmid: 7749888].
Duffy JD, Campbell J. Bupropion for the treatment of fatigue associated with multiple sclerosis. Psychosomatics. 1994;35(2):170-1. Exclude-Q3-not RCT. [pmid: 8171179].
Dunevsky A, Perel AB. Gabapentin for relief of spasticity associated with multiple sclerosis. Am J Phys Med Rehab. 1998;77(5):451-4. Exclude-Q3-not RCT.
Durelli L, Bongioanni MR, Ferrero B, et al. Long term recombinant interferon alpha treatment in MS with special emphasis to side effects. Mult Scler. 1996;1(6):366-71. Exclude-Q3-not current therapy. [pmid: 9345419].
Durelli L, Verdun E, Barbero P, et al. Every-other-day interferon beta-1b versus once-weekly interferon beta-1a for multiple sclerosis: results of a 2-year prospective randomised multicentre study (INCOMIN). Lancet. 2002;359(9316):1453-60. Exclude-Q3-Other-no control. [pmid: 11988242].
Dyck I. Hidden geographies: the changing lifeworlds of women with multiple sclerosis. Soc Sci Med. 1995;40(3):307-20. Exclude-Q4-no findings relevant to question. [pmid: 7899943].
Ebers GC. Prognostic factors in multiple sclerosis. Trans Assoc Life Ins Med Directors Am. 1987;70:171-6. Exclude-Q2-wrong timeframe.
Ebers GC. Treatment of multiple sclerosis [review]. Lancet. 1994;343(8892):275-9. Exclude-review-background Q3. [pmid: 7905103].
Ebers GC. The natural history of multiple sclerosis [review]. Neurol Sci. 2000;21(4 Suppl 2):S815-7. Exclude-Q2-wrong timeframe. [pmid: 11205355].
Ebers GC, Koopman WJ, Hader W, et al. The natural history of multiple sclerosis: a geographically based study: 8: familial multiple sclerosis. Brain. 2000;123(Pt 3):641-9. Exclude-Q2-wrong timeframe. [pmid: 10686184].
Edwards SG, Gong QY, Liu C, et al. Infratentorial atrophy on magnetic resonance imaging and disability in multiple sclerosis. Brain. 1999;122(Pt 2):291-301. Exclude-Q2-no long-term follow up. [pmid: 10071057].
Ellger T, Bethke F, Frese A, et al. Event-related potentials in different subtypes of multiple sclerosis—a cross-sectional study. J Neurol Sci. 2002;205(1):35-40. Exclude-Q2-no long-term follow up. [pmid: 12409181].
Ellison GW, Myers LW, Mickey MR, et al. A placebo-controlled, randomized, double-masked, variable dosage, clinical trial of azathioprine with and without methylprednisolone in multiple sclerosis. Neurology. 1989;39(8):1018-26. Exclude-Q3-wrong timeframe. [pmid: 2668784].
Engell T, Raun NE, Thomsen M, et al. HLA and heterogeneity of multiple sclerosis. Neurology. 1982;32(9):1043-6. Exclude-Q2-wrong timeframe. [pmid: 6955632].
Evangelou N, Jackson M, Beeson D, et al. Association of the APOE epsilon4 allele with disease activity in multiple sclerosis. J Neurol Neurosurg Psych. 1999;67(2):203-5. Exclude-Q2-wrong timeframe.
Facchetti D, Mai R, Colombo A, et al. Limited clinical significance of traditional and quantitative EEG in multiple sclerosis. Acta Neurol Belg. 1994;94(4):245-50. Exclude-Q2-no long-term follow up. [pmid: 7839801].
Facchetti D, Mai R, Micheli A, et al. Motor evoked potentials and disability in secondary progressive multiple sclerosis. Can J Neurol Sci. 1997;24(4):332-7. Exclude-Q2-no long-term follow up. [pmid: 9398981].
Fazekas F, Offenbacher H, Fuchs S, et al. Criteria for an increased specificity of MRI interpretation in elderly subjects with suspected multiple sclerosis. Neurology. 1988;38(12):1822-5. Exclude-Q1a-not MacDonald criteria. [pmid: 3057397].
Feigenson JS, Scheinberg L, Catalano M, et al. The cost-effectiveness of multiple sclerosis rehabilitation: a model. Neurology. 1981;31(10):1316-22. Exclude-Q3b-not RCT. [pmid: 6810201].
Feinstein A, Kartsounis LD, Miller DH, et al. Clinically isolated lesions of the type seen in multiple sclerosis: a cognitive, psychiatric, and MRI follow up study. J Neurol Neurosurg Psych. 1992;55(10):869-76. Exclude-Q2-wrong timeframe.
Fernandez O, Antiquedad A, Arbizu T, et al. Treatment of relapsing-remitting multiple sclerosis with natural interferon beta: a multicenter, randomized clinical trial. Mult Scler. 1995;1(Suppl 1):S67-9. Exclude-Q3-wrong timeframe. [pmid: 9345404].
Ferreira E, Letwin SR. Desmopressin for nocturia and enuresis associated with multiple sclerosis [review]. Ann Pharmacotherapy. 1998;32(1):114-6. Exclude-Q3-not RCT.
Fierro B, Salemi G, Brighina F, et al. A transcranial magnetic stimulation study evaluating methylprednisolone treatment in multiple sclerosis. Acta Neurol Scand. 2002;105(3):152-7. Exclude-Q3-no control. [pmid: 11886356].
Filippi M. Predictive value of MRI findings in multiple sclerosis. Lancet Neurol. 2002;1(1):9. Exclude-Q1a-not longitudinal. [pmid: 12849538].
Filippi M. The role of magnetic resonance imaging in the assessment of patients with established multiple sclerosis. Neurol Sci. 2002;23(3):89-90. Exclude-Q1a-Other: review. [pmid: 12398067].
Filippi M, Alberoni M, Martinelli V, et al. Influence of clinical variables on neuropsychological performance in multiple sclerosis. Eur Neurol. 1994;34(6):324-8. Exclude-Q2-no long-term follow up. [pmid: 7851453].
Filippi M, Barker GJ, Horsfield MA, et al. Benign and secondary progressive multiple sclerosis: a preliminary quantitative MRI study. J Neurol. 1994;241(4):246-51. Exclude-Q2-no long-term follow up. [pmid: 8195825].
Filippi M, Bozzali M, Rovaris M, et al. Evidence for widespread axonal damage at the earliest clinical stage of multiple sclerosis. Brain. 2003;126:433-7. Exclude-not relevant to study question. [pmid: 12538409].
Filippi M, Colombo B, Rovaris M, et al. A longitudinal magnetic resonance imaging study of the cervical cord in multiple sclerosis. J Neuroimag. 1997;7(2):78-80. Exclude-Q2-no analysis of predictors.
Filippi M, Dousset V, McFarland HF, et al. Role of magnetic resonance imaging in the diagnosis and monitoring of multiple sclerosis: consensus report of the White Matter Study Group. J Magnet Reson Imag. 2002;15(5):499-504. Exclude-Q1a-consensus statement.
Filippi M, Grossman RI. MRI techniques to monitor MS evolution - the present and the future. Neurology. 2002;58(8):1147-53. Exclude-review-background Q2. [pmid: 11971079].
Filippi M, Horsfield MA, Bressi S, et al. Intra- and inter-observer agreement of brain MRI lesion volume measurements in multiple sclerosis. A comparison of techniques. Brain. 1995;118(Pt 6):1593-600. Exclude-Q1b-No T2 GAD enhancing. [pmid: 8595488].
Filippi M, Horsfield MA, Rovaris M, et al. Intraobserver and interobserver variability in schemes for estimating volume of brain lesions on MR images in multiple sclerosis. Am J Neuroradiol. 1998;19(2):239-44. Exclude-Q1b-No T2 GAD enhancing. [pmid: 9504472].
Filippi M, Miller DH. Magnetic resonance imaging in the differential diagnosis and monitoring of the treatment of multiple sclerosis [review]. Curr Opinion Neurol. 1996;9(3):178-86. Exclude-Q1a-review.
Filippi M, Paty DW, Kappos L, et al. Correlations between changes in disability and T2-weighted brain MRI activity in multiple sclerosis: a follow-up study. Neurology. 1995;45(2):255-60. Exclude-Q2-wrong timeframe. [pmid: 7854522].
Filippi M, Rocca MA, Gasperini C, et al. Interscanner variation in brain MR lesion load measurements in multiple sclerosis using conventional spin-echo, rapid relaxation-enhanced, and fast-FLAIR sequences. Am J Neuroradiol. 1999;20(1):133-7. Exclude-not relevant to study question. [pmid: 9974068].
Filippi M, Rossi P, Campi A, et al. Serial contrast-enhanced MR in patients with multiple sclerosis and varying levels of disability. Am J Neuroradiol. 1997;18(8):1549-56. Exclude-Q2-no candidate predictors. [pmid: 9296198].
Filippi M, Rovaris M, Gasperini C, et al. A preliminary study comparing the sensitivity of serial monthly enhanced MRI after standard and triple dose gadolinium-DTPA for monitoring disease activity in primary progressive multiple sclerosis. J Neuroimag. 1998;8(2):88-93. Exclude-Q2-no candidate predictors.
Filippi M, Rovaris M, Sormani MP, et al. Intraobserver and interobserver variability in measuring changes in lesion volume on serial brain MR images in multiple sclerosis. Am J Neuroradiol. 1998;19(4):685-7. Exclude-Q1b-No T2-GAD enhancing. [pmid: 9576654].
Filippini G, Brusaferri F, Sibley WA, et al. Corticosteroids or ACTH for acute exacerbations in multiple sclerosis [review]. Cochrane Database of Systematic Reviews 2000;(4):CD001331. Exclude-review-background Q3
Filippini G, Munari L, Incorvaia B, et al. Interferons in relapsing remitting multiple sclerosis: a systematic review. Lancet. 2003;361(9357):545-52. Exclude-review-background Q3. [pmid: 12598138].
Finlayson M, Impey MW, Nicolle C, et al. Self care, productivity and leisure limitations of people with multiple sclerosis in Manitoba. Can J Occup Ther. 1998;65:299-308. Exclude-DA-Q4-limited ability to interpret findings.
Fischer JS, LaRocca NG, Miller DM, et al. Recent developments in the assessment of quality of life in multiple sclerosis (MS) [review]. Mult Scler. 1999;5(4):251-9. Exclude-Q2-no long-term follow up. [pmid: 10467384].
Fischer JS, Rudick RA, Cutter GR, et al. The Multiple Sclerosis Functional Composite Measure (MSFC): an integrated approach to MS clinical outcome assessment. National MS Society Clinical Outcomes Assessment Task Force [review]. Mult Scler. 1999;5(4):244-50. Exclude-Q2-no long-term follow up. [pmid: 10467383].
Fisher E, Rudick RA, Cutter G, et al. Relationship between brain atrophy and disability: an 8-year follow-up study of multiple sclerosis patients. Mult Scler. 2000;6(6):373-7. Exclude-Q2-no candidate predictors. [pmid: 11212131].
Fisher E, Rudick RA, Simon JH, et al. Eight-year follow-up study of brain atrophy in patients with MS. Neurology. 2002;59(9):1412-20. Exclude-Q2-wrong timeframe. [pmid: 12427893].
Fisk JD, Pontefract A, Ritvo PG, et al. The impact of fatigue on patients with multiple sclerosis. Can J Neurol Sci. 1994;21(1):9-14. Exclude-Q2-no long-term follow up. [pmid: 8180914].
Flachenecker P, Reiners K, Krauser M, et al. Autonomic dysfunction in multiple sclerosis is related to disease activity and progression of disability. Mult Scler. 2001;7(5):327-34. Exclude-Q2-o analysis of predictors. [pmid: 11724449].
Fog T. A scoring system for neurological impairment in multiple sclerosis. Acta Neurol Scand Suppl. 1965;13(Pt 2):551-5. Exclude-not relevant to study question. [pmid: 5214333].
Francis DA, Bain P, Swan AV, et al. An assessment of disability rating scales used in multiple sclerosis. Arch Neurol. 1991;48(3):299-301. Exclude-not relevant to study question. [pmid: 2001188].
Franklin GM, Nelson LM, Filley CM, et al. Cognitive loss in multiple sclerosis. Case reports and review of the literature [review]. Arch Neurol. 1989;46(2):162-7. Exclude-Q4-no findings relevant to question. [pmid: 2644924].
Franklin GM, Heaton RK, Nelson LM, et al. Correlation of neuropsychological and MRI findings in chronic/progressive multiple sclerosis. Neurology. 1988;38(12):1826-9. Exclude-Q2-no long-term follow up. [pmid: 3194059].
Freal JE, Kraft GH, Coryell JK. Multiple sclerosis patients' assessment of their medical, psychological, social, and vocational needs. Arch Phys Med Rehab. 1980;61:487. Exclude-Q4-no findings relevant to question.
Freeman J, Langdon D, Hobart J, et al. The impact of rehabilitation on disability and handicap in progressive multiple sclerosis: a randomized controlled trial. Eur J Neurol. 1996;3(Suppl 2):15. Exclude-abstract.
Freeman JA, Langdon DW, Hobart JC, et al. Inpatient rehabilitation in multiple sclerosis: do the benefits carry over into the community?. Neurology. 1999;52(1):50-6. Exclude-Q3-not RCT. [pmid: 9921848].
Frith JA, McLeod JG, Basten A, et al. Transfer factor as a therapy for multiple sclerosis: a follow-up study. Clin Exper Neurol. 1986;22:149-54. Exclude-Q3-not current treatment. [pmid: 3555898].
Frohman EM, Goodin DS, Calabresi PA, et al. The utility of MRI in suspected MS: Report of the Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology. Neurology. 2003;61:602-11. Exclude-review-background. [pmid: 12963748].
Fu L, Matthews PM, De Stefano N, et al. Imaging axonal damage of normal-appearing white matter in multiple sclerosis. Brain. 1998;121(Pt 1):103-13. Exclude-Q2-no analysis of predictors. [pmid: 9549491].
Fuller GN, Bone I. Disease modifying treatment in multiple sclerosis. J Neurol Neurosurg Psych. 2001;71(Suppl 2):ii20-1. Exclude-no MS patients.
Fulton JC, Grossman RI, Udupa J, et al. MR lesion load and cognitive function in patients with relapsing-remitting multiple sclerosis. Am J Neuroradiol. 1999;20(10):1951-5. Exclude-Q2-no analysis of predictors. [pmid: 10588124].
Gajewski JB, Awad SA. Oxybutynin versus propantheline in patients with multiple sclerosis and detrusor hyperreflexia. J Urol. 1986;135(5):966-8. Exclude-Q3-not RCT. [pmid: 3959249].
Galetta SL. The controlled high risk Avonex multiple sclerosis trial (CHAMPS Study) [erratum appears in J Neuroophthalmol 2002 Mar;22(1):67]. J Neuro-Ophthalmol. 2001;21(4):292-5. Exclude-secondary publication.
Gasperini C, Paolillo A, Giugni E, et al. MRI brain volume changes in relapsing-remitting multiple sclerosis patients treated with interferon beta-1a. Mult Scler. 2002;8(2):119-23. Exclude-Q2-no analysis of predictors. [pmid: 11990868].
Ge Y, Grossman RI, Udupa JK, et al. Glatiramer acetate (Copaxone) treatment in relapsing-remitting MS: quantitative MR assessment. Neurology. 2000;54(4):813-7. Exclude-DA-Q3-no clinical outcomes. [pmid: 10690968].
Ge Y, Grossman RI, Udupa JK, et al. Brain atrophy in relapsing-remitting multiple sclerosis and secondary progressive multiple sclerosis: longitudinal quantitative analysis. Radiology. 2000;214(3):665-70. Exclude-Q2-no candidate predictors. [pmid: 10715027].
Gelenberg AJ, Poskanzer DC. The effect of dantrolene sodium on spasticity in multiple sclerosis. Neurology. 1973;23(12):1313-5. Exclude-DA-Q3-not randomized. [pmid: 4796610].
Gerschlager W, Beisteiner R, Deecke L, et al. Electrophysiological, neuropsychological and clinical findings in multiple sclerosis patients receiving interferon beta-1b: a 1-year follow-up. Eur Neurol. 2000;44(4):205-9. Exclude-Q2-no analysis of predictors. [pmid: 11096218].
Ghezzi A, Pozzilli C, Liguori M, et al. Prospective study of multiple sclerosis with early onset. Mult Scler. 2002;8(2):115-8. Exclude-Q2-wrong timeframe. [pmid: 11990867].
Gilchrist AC, Creed FH. Depression, cognitive impairment and social stress in multiple sclerosis. J Psychosom Res. 1994;38(3):193-201. Exclude-Q4-no findings relevant to question. [pmid: 8027959].
Giovannoni G, Bever CT. Patients with clinically isolated syndromes suggestive of MS - does MRI allow earlier diagnosis?. Neurology. 2003;60(1):6-7. Exclude-review-background Q1a. [pmid: 12525709].
Giovannoni G, Thorpe J. Is it multiple sclerosis or not?. Neurology. 2001;57(8):1357-8. Exclude-Q1a- no primary data. [pmid: 11673570].
Giugni E, Pozzilli C, Bastianello S, et al. MRI measures and their relations with clinical disability in relapsing-remitting and secondary progressive multiple sclerosis. Mult Scler. 1997;3(4):221-5. Exclude-Q2-no long-term follow up. [pmid: 9372503].
Gleeson RK. Underwriting multiple sclerosis [review]. Trans Assoc Life Ins Med Directors Am. 1984;66:111-8. Exclude-review-background-Q4.
Goldberg DP, Cooper B, Eastwood MR, et al. A standardized psychiatric interview for use in community surveys. Brit J Prev Soc Med. 1970;24(1):18-23. Exclude-Q4-no findings relevant to question. [pmid: 5435083].
Gonsette RE. Mitoxantrone immunotherapy in multiple sclerosis [review]. Mult Scler. 1996;1(6):329-32. Exclude-review-background Q3. [pmid: 9345411].
Gonsette RE. Mitoxantrone in progressive multiple sclerosis: when and how to treat? [Review]. J Neurol Sci. 2003;206(2):203-8. Exclude-Q3-not RCT. [pmid: 12559512].
Goodin DS. A questionnaire to assess neurological impairment in multiple sclerosis. Mult Scler. 1998;4(5):444-51. Exclude-Q2-no long-term follow up. [pmid: 9839306].
Goodin DS, Frohman EM, Garmany GP Jr, et al. Disease modifying therapies in multiple sclerosis: report of the Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology and the MS Council for Clinical Practice Guidelines. [erratum appears in Neurology 2002 Aug13;59(3):480]. Neurology. 2002;58(2):169-78. Exclude-review-background Q3. [pmid: 11805241].
Goodkin DC. Interferon beta-1b in secondary progressive MS: clinical and MRI results of a 3-year randomised controlled trial. Neurology. 2000;54:2352. Exclude-Q3-wrong timeframe.
Goodkin DE, Cookfair D, Wende K, et al. Inter- and intrarater scoring agreement using grades 1.0 to 3.5 of the Kurtzke Expanded Disability Status Scale (EDSS). Multiple Sclerosis Collaborative Research Group. Neurology. 1992;42(4):859-63. Exclude-Q2-background. [pmid: 1565242].
Goodkin DE, Hertsgaard D, Seminary J. Upper extremity function in multiple sclerosis: improving assessment sensitivity with box-and-block and nine-hole peg tests. Arch Phys Med Rehab. 1988;69(10):850-4. Exclude-Q2-background.
Goodkin DE, Plencner S, Palmer-Saxerud J, et al. Cyclophosphamide in chronic progressive multiple sclerosis. Maintenance vs nonmaintenance therapy. Arch Neurol. 1987;44(8):823-7. Exclude-DA-Q3-controls not randomized. [pmid: 2820359].
Goodkin DE, Rudick RA, VanderBrug Medendorp S, et al. Low-dose oral methotrexate in chronic progressive multiple sclerosis: analysisses of serial MRIs. Neurology. 1996;47(5):1153-7. Exclude-DA-Q3-no relevant data. [pmid: 8909421].
Gordon PA, Carroll DJ, Etches WS, et al. A double-blind controlled pilot study of plasma exchange versus sham apheresis in chronic progressive multiple sclerosis. Can J Neurol Sci. 1985;12(1):39-44. Exclude-DA-Q3-non-standard treatment. [pmid: 3884114].
Granger CV, Cotter AC, Hamilton BB, et al. Functional assessment scales: a study of persons with multiple sclerosis. Arch Phys Med Rehab. 1990;71(11):870-5. Exclude-Q2-no long-term follow up.
Grant I, McDonald WI, Trimble MR, et al. Deficient learning and memory in early and middle phases of multiple sclerosis. J Neurol Neurosurg Psych. 1984;47(3):250-5. Exclude-Q2-no long-term follow up.
Grimaud J, Barker GJ, Wang L, et al. Correlation of magnetic resonance imaging parameters with clinical disability in multiple sclerosis: a preliminary study. J Neurol. 1999;246(10):961-7. Exclude-Q2-no long-term follow up. [pmid: 10552247].
Groves L, Shellenberger MK, Davis CS. Tizanidine treatment of spasticity: a meta-analysis of controlled, double-blind, comparative studies with baclofen and diazepam. Adv Therapy. 1998;15(4):241-51. Exclude-review-background Q3.
Gronseth GS, Ashman EJ. Practice parameter: the usefulness of evoked potentials in identifying clinically silent lesions in patients with suspected multiple sclerosis (an evidence-based review): Report of the Quality Standards Subcommittee of the American Academy of Neurology. [Review]. Neurology. 2000;54(9):1720-5. Exclude-review-background. [pmid: 10802774].
Gulick EE. Reliability and validity of the work assessment scale for persons with multiple sclerosis. Nurs Res. 1991;40(2):107-12. Exclude-Q4-instrument validation-most subjects not employed. [pmid: 2003069].
Gulick EE. Model for predicting work performance among persons with multiple sclerosis. Nurs Res. 1992;41(5):266-72. Exclude-Q4-no relevant data. [pmid: 1523107].
Gulick EE. Correlates of quality of life among persons with multiple sclerosis. Nurs Res. 1997;46(6):305-11. Exclude-Q2-no long-term follow up. [pmid: 9422048].
Gulick EE, Cook SD, Troiano R. Comparison of patient and staff assessment of MS patients' health status. Acta Neurol Scand. 1993;88(2):87-93. Exclude-Q2-wrong timeframe. [pmid: 8213064].
Guthrie TC, Nelson DA. Influence of temperature changes on multiple sclerosis: critical review of mechanisms and research potential. [Review]. J Neurol Sci. 1995;129(1):1-8. Exclude-review-background. [pmid: 7751837].
Hammond SR, McLeod JG, Millingen KS, et al. The epidemiology of multiple sclerosis in three Australian cities: Perth, Newcastle and Hobart. Brain. 1988;111(Pt 1):1-25. Exclude-Q4-no findings relevant to question. [pmid: 3365543].
Hartelius L, Svensson P. Speech and swallowing symptoms associated with Parkinson's disease and multiple sclerosis: a survey. Folia Phoniatri Logoped. 1994;46(1):9-17. Exclude-Q2-no long-term follow up.
Hassan N, McLellan DL. Double-blind comparison of single doses of DS103-282, baclofen and placebo for suppression of spasticity. J Neurol Neurosurg Psych. 1980;43(12):1132-6. Exclude-Q3-mixed population.
Haughton VM, Yetkin FZ, Rao SM, et al. Quantitative MR in the diagnosis of multiple sclerosis. Magnet Reson Med. 1992;26(1):71-8. Exclude-Q2-no long-term follow up.
Haupts MR, Hardt C, Pohlau D, et al. Quality of life as a predictor for change in disability in MS. Neurology. 2001;56(9):1250. Exclude-Q2-letter. [pmid: 11342708].
Hawkins SA. Magnetisation transfer analysis and the disability resulting from multiple sclerosis. J Neurol Neurosurg Psych. 2000;69(6):715. Exclude-Q2-no primary data.
Hawkins SA, McDonnell GV. Benign multiple sclerosis? Clinical course, long term follow up, and assessment of prognostic factors. J Neurol Neurosurg Psych. 1999;67(2):148-52. Exclude-Q2-wrong timeframe.
Hebjørn S. Treatment of detrusor hyperreflexia in multiple sclerosis: a double-blind, crossover clinical trial comparing methantheline bromide (Banthine), flavoxate chloride (Urispas) and meladrazine tartrate (Lisidonil). Urologia Internationalis. 1977;32(23):209-17. Exclude-DA-Q3-drug no longer available. [pmid: 20683].
Hedley DW, Maroun JA, Espir ML. Evaluation of baclofen (Lioresal) for spasticity in multiple sclerosis. Postgrad Med J. 1975;51(599):615-8. Exclude-DA-Q3-not RCT. [pmid: 1105499].
Heide AC, Kraft GH, Slimp JC, et al. Cerebral N-acetylaspartate is low in patients with multiple sclerosis and abnormal visual evoked potentials. Am J Neuroradiol. 1998;19(6):1047-54. Exclude-Q2-no long-term follow up. [pmid: 9672010].
Henke AF, Cohle SD, Cottingham SL. Fatal hyperthermia secondary to sunbathing in a patient with multiple sclerosis. American Journal of Forensic Medicine & Pathology. 2000;21(3):204-6. Exclude-review-background. [pmid: 10990275].
Hirsch RL, Johnson KP, Camenga DL. The placebo effect during a double blind trial of recombinant alpha 2 interferon in multiple sclerosis patients: immunological and clinical findings. Internat J Neurosci. 1988;39(34):189-96. Exclude-Q3-not current therapy.
Hobart J, Freeman J, Thompson A. Kurtzke scales revisited: the application of psychometric methods to clinical intuition. Brain. 2000;123(Pt 5):1027-40. Exclude-Q2-no long-term follow up. [pmid: 10775547].
Hobart J, Lamping D, Fitzpatrick R, et al. The Multiple Sclerosis Impact Scale (MSIS-29): a new patient-based outcome measure. Brain. 2001;124(Pt 5):962-73. Exclude-Q4-prevalence data. [pmid: 11335698].
Hobart JC, Riazi A, Lamping DL, et al. Measuring the impact of MS on walking ability: the 12-Item MS Walking Scale (MSWS-12). Neurology. 2003;60(1):31-6. Exclude-Q2-no long-term follow up. [pmid: 12525714].
Hoenig H, Hoff J, McIntyre L, et al. The self-reported functional measure: Predictive validity for health care utilization in multiple sclerosis and spinal cord injury. Arch Phys Med Rehab. 2001;82(5):613-8. Exclude-Q2-no separate MS patient data.
Hogh P, Oturai A, Schreiber K, et al. Apoliprotein E and multiple sclerosis: impact of the epsilon-4 allele on susceptibility, clinical type and progression rate. Mult Scler. 2000;6(4):226-30. Exclude-Q2-wrong timeframe. [pmid: 10962542].
Hohol MJ, Orav EJ, Weiner HL. Disease steps in multiple sclerosis: a longitudinal study comparing disease steps and EDSS to evaluate disease progression. Mult Scler. 1999;5(5):349-54. Exclude-Q2-no candidate predictors. [pmid: 10516779].
Holland NJ, Francabandera F, Wiesel-Levison P. International scale for assessment of disability in multiple sclerosis. J Neurosci Nurs. 1986;18(1):39-44. Exclude-not relevant to study question. [pmid: 2936843].
Honig LS, Sheremata WA. Magnetic resonance imaging of spinal cord lesions in multiple sclerosis. J Neurol Neurosurg Psych. 1989;52(4):459-66. Exclude-Q2-no long-term follow up.
Hoogervorst EL, Kalkers NF, Uitdehaag BM, et al. A study validating changes in the multiple sclerosis functional composite. Arch Neurol. 2002;59(1):113-6. Exclude-Q2-background. [pmid: 11790238].
Hoogervorst EL, Kalkers NF, van Winsen LML, et al. Differential treatment effect on measures of neurologic exam, functional impairment and patient self-report in multiple sclerosis. Mult Scler. 2001;7(5):335-9. Exclude-Q3-not RCT. [pmid: 11724450].
Hoogervorst EL, van Winsen LM, Eikelenboom MJ, et al. Comparisons of patient self-report, neurologic examination, and functional impairment in MS. Neurology. 2001;56(7):934-7. Exclude-Q2-no long-term follow up. [pmid: 11294932].
Hughes RA. Interferon beta 1a for secondary progressive multiple sclerosis [review]. J Neurol Sci. 2003;206(2):199-202. Exclude-Q2-Other (poor review). [pmid: 12559511].
Hutchinson J, Hutchinson M. The Functional Limitations Profile may be a valid, reliable and sensitive measure of disability in multiple sclerosis. J Neurol. 1995;242(10):650-7. Exclude-Q2-wrong timeframe. [pmid: 8568526].
Iannucci G, Tortorella C, Rovaris M, et al. Prognostic value of MR and magnetization transfer imaging findings in patients with clinically isolated syndromes suggestive of multiple sclerosis at presentation. Am J Neuroradiol. 2000;21(6):1034-8. Exclude-Q2-no physical or mental outcome. [pmid: 10871009].
Indaco A, Iachetta C, Nappi C, et al. Chronic and acute pain syndromes in patients with multiple sclerosis. Acta Neurol. 1994;16(3):97-102. Exclude-Q2-no long-term follow up.
Ingle GT, Stevenson VL, Miller DH, et al. Two-year follow-up study of primary and transitional progressive multiple sclerosis. Mult Scler. 2002;8(2):108-14. Exclude-Q2-no analysis of predictors. [pmid: 11990866].
Inman RP. Disability indices, the economic costs of illness, and social insurance: the case of multiple sclerosis. Acta Neurol Scand Suppl. 1984;101:46-55. Exclude-no MS patients. [pmid: 6594916].
International Federation of Multiple Sclerosis Societies. IFMSS Minimal Record of Disability for multiple sclerosis. Interview protocol for Incapacity Status Scale, Environmental Status Scale 1983. Acta Neurol Scand Suppl. 1984;101:191-217. Exclude-Q2-background. [pmid: 6594910].
International Federation of Multiple Sclerosis Societies. International Federation of Multiple Sclerosis Societies. Minimal Record of Disability—1983. Acta Neurol Scand Suppl. 1984;101:169-90. Exclude-Q2-background. [pmid: 6594909].
Jacobs L, Salazar AM, Herndon R, et al. Multicentre double-blind study of effect of intrathecally administered natural human fibroblast interferon on exacerbations of multiple sclerosis. Lancet. 1986;2(852122):1411-3. Exclude-DA-Q3-non-standard treatment. [pmid: 2878272].
Jacobs L, Salazar AM, Herndon R, et al. Intrathecally administered natural human fibroblast interferon reduces exacerbations of multiple sclerosis. Results of a multicenter, double-blind study. Arch Neurol. 1987;44(6):589-95. Exclude-DA-Q3-non-standard treatment. [pmid: 3579676].
Jacobs LD, Beck RW, Simon JH, et al. Intramuscular interferon beta-1a therapy initiated during a first demyelinating event in multiple sclerosis. CHAMPS Study Group. New Engl J Med. 2000;343(13):898-904. Exclude-DA-Q1a-no relevant data. [pmid: 11006365].
Janardhan V, Bakshi R. Quality of life and its relationship to brain lesions and atrophy on magnetic resonance images in 60 patients with multiple sclerosis. Arch Neurol. 2000;57(10):1485-91. Exclude-Q2-no long-term follow up. [pmid: 11030802].
Janardhan V, Bakshi R. Quality of life in patients with multiple sclerosis: the impact of fatigue and depression. J Neurol Sci. 2002;205(1):51-8. Exclude-Q2-no long-term follow up. [pmid: 12409184].
Janknegt RA, Zweers HM, Delaere KP, et al. Oral desmopressin as a new treatment modality for primary nocturnal enuresis in adolescents and adults: a double-blind, randomized, multicenter study. Dutch Enuresis Study Group. J Urol. 1997;157(2):513-7. Exclude-no MS patients. [pmid: 8996345].
Johnson GS, Johnson RH. Social-services support for multiple sclerosis patients in West of Scotland. Lancet. 1977;1(8001):31-4. Exclude-Q4-no findings relevant to question. [pmid: 63666].
Johnson KP, Brooks BR, Ford CC, et al. Sustained clinical benefits of glatiramer acetate in relapsing multiple sclerosis patients observed for 6 years. Copolymer 1 Multiple Sclerosis Study Group. Mult Scler. 2000;6(4):255-66. Exclude-Q3-wrong timeframe. [pmid: 10962546].
Johnson RH, Lambie DG, Peace K, et al. Disability in multiple sclerosis and the provision of social and medical services: findings in Wellington, New Zealand. Acta Neurol Scand Suppl. 1984;101:105-12. Exclude-Q4-no correlation with findings relevant to question. [pmid: 6594900].
Johnson SK, Frederick J, Kaufman M, et al. A controlled investigation of bodywork in multiple sclerosis. J Alt Complement Med. 1999;5(3):237-43. Exclude-Q3-no long-term symptom management.
Jones B, Summerville J. Avenues and steps to do-it-yourself independence for the physically disabled. J Rehab. 1983;49(4):30-5. Exclude-DA-Q5-no MS patients. [pmid: 6228657].
Jones RE, Heron JR, Foster DH, et al. Effects of 4-aminopyridine in patients with multiple sclerosis. J Neurol Sci. 1983;60(3):353-62. Exclude-Q3-not RCT. [pmid: 6631441].
Joy JE, Johnston RB. Multiple sclerosis: current status and strategies for the future. Washington, DC: National Academy Press, 2003. Exclude-review-background
Juni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. Exclude-methods paper. [pmid: 10493204].
Kahl KG, Kruse N, Toyka KV, et al. Serial analysis of cytokine MRNA profiles in whole blood samples from patients with early multiple sclerosis. J Neurol Sci. 2002;200(12):53-5. Exclude-Q2-no physical or mental outcome. [pmid: 12127676].
Kalkers NF, Bergers E, Castelijns JA, et al. Optimizing the association between disability and biological markers in MS. Neurology. 2001;57(7):1253-8. Exclude-Q2-no long-term follow up. [pmid: 11591845].
Kalkers NF, de Groot V, Lazeron RH, et al. MS functional composite: relation to disease phenotype and disability strata. Neurology. 2000;54(6):1233-9. Exclude-Q2-no long-term follow up. [pmid: 10746590].
Kastrukoff LF, Oger JJ, Hashimoto SA, et al. Systemic lymphoblastoid interferon therapy in chronic progressive multiple sclerosis. I. Clinical and MRI evaluation. Neurology. 1990;40(3):479-86. Exclude-DA-Q3-non-standard treatment. [pmid: 2179764].
Kaufman M, Moyer D, Norton J. The significant change for the Timed 25-foot Walk in the multiple sclerosis functional composite. Mult Scler. 2000;6(4):286-90. Exclude-Q2-wrong timeframe. [pmid: 10962550].
Kemp BA, Gora ML. Amantadine and fatigue of multiple sclerosis [review]. Ann Pharmacotherapy. 1993;27(78):893-5. Exclude-Q3-review.
Khan OA, Tselis AC, Kamholz JA, et al. A prospective, open-label treatment trial to compare the effect of IFNbeta-1a (Avonex), IFNbeta-1b (Betaseron), and glatiramer acetate (Copaxone) on the relapse rate in relapsing—remitting multiple sclerosis: results after 18 months of therapy. Mult Scler. 2001;7(6):349-53. Exclude-Q3-not RCT. [pmid: 11795454].
Khatri BO, McQuillen MP, Hoffmann RG, et al. Plasma exchange in chronic progressive multiple sclerosis: a long-term study. Neurology. 1991;41(3):409-14. Exclude-Q3-not RCT. [pmid: 2006010].
Khoury SJ, Guttmann CR, Orav EJ, et al. Longitudinal MRI in multiple sclerosis: correlation between disability and lesion burden. Neurology. 1994;44(11):2120-4. Exclude-Q2-no analysis of predictors. [pmid: 7969970].
Khoury SJ, Guttmann CR, Orav EJ, et al. Changes in activated T cells in the blood correlate with disease activity in multiple sclerosis. Arch Neurol. 2000;57(8):1183-9. Exclude-Q2-no predictive data linkage. [pmid: 10927799].
Kidd D, Thompson AJ. Prospective study of neurorehabilitation in multiple sclerosis. J Neurol Neurosurg Psych. 1997;62(4):423-4. Exclude-Q3-not RCT.
Kidd D, Thorpe JW, Kendall BE, et al. MRI dynamics of brain and spinal cord in progressive multiple sclerosis. J Neurol Neurosurg Psych. 1996;60(1):15-9. Exclude-Q2-no analysis of predictors.
Klarskov P, Heely E, Nyholdt I, et al. Biofeedback treatment of bladder dysfunction in multiple sclerosis. A randomized trial. Scand J Urol Nephrol Suppl. 1994;157:61-5. Exclude-DA-Q3-no data for control group. [pmid: 7939455].
Knobler RL, Greenstein JI, Johnson KP, et al. Systemic recombinant human interferon-beta treatment of relapsing-remitting multiple sclerosis: pilot study analysis and six-year follow-up. J Interferon Res. 1993;13(5):333-40. Exclude-Q3-wrong timeframe. [pmid: 8301153].
Knobler RL, Panitch HS, Braheny SL, et al. Systemic alpha-interferon therapy of multiple sclerosis. Neurology. 1984;34(10):1273-9. Exclude-Q3-wrong timeframe. [pmid: 6384817].
Knutsson E, Martensson A, Gransberg L. Antiparetic and antispastic effects induced by tizanidine in patients with spastic paresis. J Neurol Sci. 1982;53(2):187-204. Exclude-Q3-mixed population. [pmid: 7035623].
Ko Ko C. Effectiveness of rehabilitation for multiple sclerosis [review]. Clin Rehab. 1999;13(Suppl 1):33-41. Exclude-Q3-not RCT.
Kobelt G, Jonsson L, Henriksson F, et al. Cost-utility analysis of interferon beta-1b in secondary progressive multiple sclerosis. Internat J Technol Assess Health Care. 2000;16(3):768-80. Exclude-Q4-no findings relevant to question.
Kobelt G, Jonsson L, Miltenburger C, et al. Cost-utility analysis of interferon beta-1B in secondary progressive multiple sclerosis using natural history disease data. Internat J Technol Assess Health Care. 2002;18(1):127-38. Exclude-Q4-no findings relevant to question.
Koch-Henriksen N, Sorensen PS. The Danish national project of interferon-beta treatment in relapsing-remitting multiple sclerosis. The Danish Multiple Sclerosis Group. Mult Scler. 2000;6(3):172-5. Exclude-Q3-no results. [pmid: 10871828].
Kohlmeier RE, DiMaio VJ, Kagan-Hallet K. Fatal hyperthermia in hot baths in individuals with multiple sclerosis. American Journal of Forensic Medicine & Pathology. 2000;21(3):201-3. Exclude-review-background. [pmid: 10990274].
Koudriavtseva T, Thompson AJ, Fiorelli M, et al. Gadolinium enhanced MRI predicts clinical and MRI disease activity in relapsing-remitting multiple sclerosis. J Neurol Neurosurg Psych. 1997;62(3):285-7. Exclude-Q2-wrong timeframe.
Koziol JA, Wagner S, Adams HP. Assessing information in T2-weighted MRI scans from secondary progressive MS patients. Neurology. 1998;51(1):228-33. Exclude-Q2-no analysis of predictors. [pmid: 9674807].
Kraft GH. Rehabilitation principles for patients with multiple sclerosis [review]. J Spinal Cord Medicine. 1998;21(2):117-20. Exclude-Q5-no data on work status or ability.
Kraft GH. Rehabilitation still the only way to improve function in multiple sclerosis. Lancet. 1999;354(9195):2016-7. Exclude-Q3-no data. [pmid: 10636362].
Kraft GH, Alquist AD. Effect of microclimate cooling on physical function in multiple sclerosis. Mult Scler Clin Lab Res. 1996;2:114-5. Exclude-Q5-no data on work status or ability.
Kraft GH, Fitts S. Electrical stimulation AFO for MS footdrop. J Clin Neurophys. 1992;9:301. Exclude-Q3-not RCT.
Kraft GH, Freal JE, Coryell JK. Disability, disease duration, and rehabilitation service needs in multiple sclerosis: patient perspectives. Arch Phys Med Rehab. 1986;67(3):164-8. Exclude-Q4-no relevant data.
Kraft GH, Freal JE, Coryell JK, et al. Multiple sclerosis: early prognostic guidelines. Arch Phys Med Rehab. 1981;62(2):54-8. Exclude-Q2-background.
Kremenchutzky M, Lee D, Rice GP, et al. Diagnostic brain MRI findings in primary progressive multiple sclerosis. Mult Scler. 2000;6(2):81-5. Exclude-Q2-wrong timeframe. [pmid: 10773852].
Krupp LB. Fatigue in multiple sclerosis: definition, pathophysiology and treament. CNS Drugs. 2003;17(4):225-34. Exclude-review-background Q2. [pmid: 12665396].
Krupp LB, Christodoulou C. Fatigue in multiple sclerosis [review]. Curr Neurol Neurosci Rep. 2001;1(3):294-8. Exclude-review-background Q3. [pmid: 11898532].
Krupp LB, Elkins LE. Fatigue and declines in cognitive functioning in multiple sclerosis. Neurology. 2000;55(7):934-9. Exclude-Q2-no long-term follow up. [pmid: 11061247].
Krupp LB, LaRocca NG, Muir-Nash J, et al. The fatigue severity scale. Application to patients with multiple sclerosis and systemic lupus erythematosus. Arch Neurol. 1989;46(10):1121-3. Exclude-Q5-mixed population. [pmid: 2803071].
Krupp LB, Rizvi SA. Symptomatic therapy for underrecognized manifestations of multiple sclerosis [review]. Neurology. 2002;58(8 Suppl 4):S32-9. Exclude-Q3—review. [pmid: 11971124].
Ku YT, Montgomery LD, Lee HC, et al. Physiologic and functional responses of MS patients to body cooling. Am J Phys Med Rehab. 2000;79(5):427-34. Exclude-DA-Q5-no data on work status or ability.
Kuroiwa Y, Itoyama Y, Shibasaki H, et al. Minimal record of disability in multiple sclerosis—application to Japanese patients. Acta Neurol Scand Suppl. 1984;101:100-4. Exclude-Q4-no correlation with findings relevant to question. [pmid: 6594899].
Kurtzke JF. Rating neurologic impairment in multiple sclerosis: an expanded disability status scale (EDSS). Neurology. 1983;33(11):1444-52. Exclude-Q4-no findings relevant to question. [pmid: 6685237].
Kurtzke JF. Disability rating scales in multiple sclerosis. Ann NY Acad Sci. 1984;436:347-60. Exclude-Q4-review. [pmid: 6598017].
Kurtzke JF. Neuroepidemiology. Part II: Assessment of therapeutic trials. Ann Neurol. 1986;19(4):311-9. Exclude-Q4-no data on work status or ability. [pmid: 3707082].
Kurtzke JF. Multiple sclerosis: what's in a name?. Neurology. 1988;38(2):309-14. Exclude-review-background. [pmid: 3340299].
Kurtzke JF. The Disability Status Scale for multiple sclerosis: apologia pro DSS sua. Neurology. 1989;39(2):291-302. Exclude-Q2-background. [pmid: 2644582].
Kurtzke JF. Patterns of neurologic involvement in multiple sclerosis. Neurology. 1989;39(9):1235-8. Exclude-review-background. [pmid: 2771075].
Kurtzke JF. Epidemiology of multiple sclerosis. Does this really point toward an etiology? Lectio Doctoralis. Neurol Sci. 2000;21(6):383-403. Exclude-review-background. [pmid: 11441577].
Kurtzke JF. Natural history and clinical outcome measures for multiple sclerosis studies. Why at the present time does EDSS scale remain a preferred outcome measure to evaluate disease evolution? [review]. Neurol Sci. 2000;21(6):339-41. Exclude-Q4-editorial. [pmid: 11441569].
Kurtzke JF. Epidemiology and multiple sclerosis. Rev Neurol. 2002;35(12):1177. Exclude-review-background. [pmid: 12587573].
Kurtzke JF, Beebe GW, Nagler B, et al. Studies on natural history of multiple sclerosis. 4. Clinical features of the onset bout. Acta Neurol Scand. 1968;44(4):467-94. Exclude-review-background. [pmid: 5687884].
Kurtzke JF, Beebe GW, Nagler B, et al. Studies on the natural history of multiple sclerosis. 6. Clinical and laboratory findings at first diagnosis. Acta Neurol Scand. 1972;48(1):19-46. Exclude-Q2-wrong timeframe. [pmid: 5019831].
Kurtzke JF, Beebe GW, Nagler B, et al. Prognosis in multiple sclerosis. Trans Am Neurol Assoc. 1973;98:272-4. Exclude-Q2-wrong timeframe. [pmid: 4784953].
Kurtzke JF, Beebe GW, Nagler B, et al. Studies on the natural history of multiple sclerosis. 7. Correlates of clinical change in an early bout. Acta Neurol Scand. 1973;49(3):379-95. Exclude-Q2-wrong timeframe. [pmid: 4747024].
Kurtzke JF, Beebe GW, Nagler B, et al. Studies on the natural history of multiple sclerosis VIII. Early prognostic features of the later course of the illness. J Chron Dis. 1977;30:819-30. Exclude-Q2-wrong timeframe. [pmid: 591609].
Kurtzke JF, Heltberg A. Multiple sclerosis in the Faroe Islands: an epitome. J Clin Epidemiol. 2001;54(1):1-22. Exclude-review-background. [pmid: 11165464].
La Mantia L, Milanese C, D'Amico R. Meta-analysis of clinical trials with copolymer 1 in multiple sclerosis. Eur Neurol. 2000;43(4):189-93. Exclude-review-background Q3. [pmid: 10828647].
La Mantia L, Milanese C, Mascoli N, et al. Cyclophosphamide for multiple sclerosis [review]. Cochrane Database of Systematic Reviews 2002;(4):CD002819. Exclude-review-background Q3
Lambert CP, Archer RL, Evans WJ. Muscle strength and fatigue during isokinetic exercise in individuals with multiple sclerosis. Med Sci Sports Exer. 2001;33(10):1613-9. Exclude-not relevant to study question.
Langdon DW, Thompson AJ. Multiple sclerosis: a preliminary study of selected variables affecting rehabilitation outcome. Mult Scler. 1999;5(2):94-100. Exclude-Q2-no long-term follow up. [pmid: 10335517].
LaRocca NG, Foley F. Development of a structured interview to accompany the minimal record. Acta Neurol Scand Suppl. 1984;101:165-8. Exclude-not relevant to study question. [pmid: 6594908].
LaRocca NG, Scheinberg LC, Slater RJ, et al. Field testing of a minimal record of disability in multiple sclerosis: the United States and Canada. Acta Neurol Scand Suppl. 1984;101:126-38. Exclude-Q2-no long-term follow up. [pmid: 6594902].
Lauer K, Firnhaber W. Epidemiological investigations into multiple sclerosis in Southern Hesse. V. Course and prognosis. Acta Neurol Scand. 1987;76(1):12-7. Exclude-Q2-no long-term follow up. [pmid: 3498287].
Lazeron RH, Langdon DW, Filippi M, et al. Neuropsychological impairment in multiple sclerosis patients: the role of (juxta)cortical lesion on FLAIR. Mult Scler. 2000;6(4):280-5. Exclude-Q2-no long-term follow up. [pmid: 10962549].
Leary SM, Thompson AJ. Interferon beta-1a in primary progressive multiple sclerosis. J Neurol Sci. 2003;206(2):215-6. Exclude-Q3-no data. [pmid: 12559514].
Leibowitz U, Alter M. Clinical factors associated with increased disability in multiple sclerosis. Acta Neurol Scand. 1970;46(1):53-70. Exclude-Q2-no long-term follow up. [pmid: 5412627].
Lennie P, Van Hemel S. Introduction. In: Visual Impairments Determining Eligibility for Social Security Benefits. National Academy Press: Washington DC, 2002, pp. 31–4. Exclude-review-background
Leocani L, Colombo B, Magnani G, et al. Fatigue in multiple sclerosis is associated with abnormal cortical activation to voluntary movement—EEG evidence. Neuroimage. 2001;13(6):1186-92. Exclude-Q2-no long-term follow up. [pmid: 11352624].
Lienert C, Lechner-Scott J, Schott D, et al. Use of composite scores in the quantification of deterioration in multiple sclerosis [review]. Mult Scler. 1999;5(4):220-2. Exclude-not relevant to study questions. [pmid: 10467379].
Lisak D. Overview of symptomatic management of multiple sclerosis [review]. J Neurosci Nurs. 2001;33(5):224-30. Exclude-Q3-not RCT. [pmid: 11668880].
Liu C, Blumhardt LD. Disability outcome measures in therapeutic trials of relapsing-remitting multiple sclerosis: effects of heterogeneity of disease course in placebo cohorts. J Neurol Neurosurg Psych. 2000;68(4):450-7. Exclude-DA-Q3-methods article.
Long KA, Weinert C. Descriptions and perceptions of health among rural and urban adults with multiple sclerosis. Res Nurs Health. 1992;15(5):335-42. Exclude-Q2-no long-term follow up. [pmid: 1529117].
Lord SE, Wade DT, Halligan PW. A comparison of two physiotherapy treatment approaches to improve walking in multiple sclerosis: a pilot randomized controlled study. Clin Rehab. 1998;12(6):477-86. Exclude-Q3-no long-term symptom management.
Losseff NA, Wang L, Lai HM, et al. Progressive cerebral atrophy in multiple sclerosis. A serial MRI study. Brain. 1996;119(Pt 6):2009-19. Exclude-Q2-no analysis of predictors. [pmid: 9010005].
Losseff NA, Webb SL, O'Riordan JI, et al. Spinal cord atrophy and disability in multiple sclerosis. A new reproducible and sensitive MRI method with potential to monitor disease progression. Brain. 1996;119(Pt 3):701-8. Exclude-Q2-no long-term follow up. [pmid: 8673483].
Lublin FD. The diagnosis of multiple sclerosis. Curr Opinion Neurol. 2002;15(3):253-6. Exclude-Q1a-no long-term diagnosis.
Lux JB, Leonardi M. The revision of the International Classification of Impairments, Disabilities and Handicaps and its application in MS [review]. Mult Scler. 1999;5(4):291-2. Exclude-Q2-no long-term follow up. [pmid: 10467391].
Lyseng-Williamson KA, Plosker GL. Management of relapsing-remitting multiple sclerosis - defining the role of subcutaneous recombinant interferon-beta-1a (Rebif (r)). Dis Manag Health Outcome. 2002;10(5):307-25. Exclude-Q3-not RCT.
Manova MG, Kostadinova II, Chalakova-Atanasova NT, et al. Clinico-electrophysiological correlates in patients with relapsing-remitting multiple sclerosis. Folia Med (Plovdiv). 2001;43(3):5-9. Exclude-Q3-wrong timeframe. [pmid: 11930834].
Matthews PM, Arnold DL. Magnetic resonance imaging of multiple sclerosis: new insights linking pathology to clinical evolution [review]. Curr Opinion Neurol. 2001;14(3):279-87. Exclude-Q2-background.
Mattioli F, Cappa SF, Cominelli C, et al. Serial study of neuropsychological performance and gadolinium-enhanced MRI in MS. Acta Neurol Scand. 1993;87(6):465-8. Exclude-Q2-wrong timeframe. [pmid: 8356876].
Mauch E, Kornhuber HH, Pfrommer U, et al. Effective treatment of chronically progressive multiple sclerosis with low-dose cyclophosphamide with minor side-effects. Eur Arch Psych Neurol Sci. 1989;238(3):115-7. Exclude-Q3-not RCT.
Maurer M, Kruse N, Giess R, et al. Gene polymorphism at position -308 of the tumor necrosis factor alpha promotor is not associated with disease progression in multiple sclerosis patients. J Neurol. 1999;246(10):949-54. Exclude-Q2-wrong timeframe. [pmid: 10552245].
McDonald WI, Compston A, Edan G, et al. Recommended diagnostic criteria for multiple sclerosis: guidelines from the International Panel on the Diagnosis of Multiple Sclerosis. Ann Neurol. 2001;50(1):121-7. Exclude-Q1a-not longitudinal. [pmid: 11456302].
McDonald WI, Miller DH, Thompson AJ. Are magnetic resonance findings predictive of clinical outcome in therapeutic trials in multiple sclerosis? The dilemma of interferon-beta [review]. Ann Neurol. 1994;36(1):14-8. Exclude-Q2- review. [pmid: 8024255].
McDonnell GV, Hawkins SA. Clinical study of primary progressive multiple sclerosis in Northern Ireland, UK. J Neurol Neurosurg Psych. 1998;64(4):451-4. Exclude-Q2-no long-term follow up.
McDonnell GV, Hawkins SA. An assessment of the spectrum of disability and handicap in multiple sclerosis: a population-based study. Mult Scler. 2001;7(2):111-7. Exclude-Q2-no long-term follow up. [pmid: 11424631].
McDonnell GV, Hawkins SA. Primary progressive multiple sclerosis: increasing clarity but many unanswered questions. J Neurol Sci. 2002;199(12):1-15. Exclude-Q2-no long-term follow up. [pmid: 12084436].
McFarland HF. Correlation between MR and clinical findings of disease activity in multiple sclerosis. Am J Neuroradiol. 1999;20(10):1777-8. Exclude-Q2-background. [pmid: 10588096].
McFarland HF. The emerging role of MRI in multiple sclerosis and the new diagnostic criteria. Mult Scler. 2002;8(1):71-2. Exclude-Q1a-review. [pmid: 11936491].
McIntosh-Michaelis SA, Roberts MH, Wilkinson SM, et al. The prevalence of cognitive impairment in a community survey of multiple sclerosis. Brit J Clin Psychol. 1991;30(Pt 4):333-48. Exclude-Q2-no long-term follow up. [pmid: 1777755].
McLeod JG, Hammond SR, Hallpike JF. Epidemiology of multiple sclerosis in Australia. With NSW and SA survey results. Med J Australia. 1994;160(3):117-22. Exclude-Q4-no findings relevant to question. [pmid: 8295576].
Merkelbach S, Sittinger H, Koenig J. Is there a differential impact of fatigue and physical disability on quality of life in multiple sclerosis?. J Nerv Mental Dis. 2002;190(6):388-93. Exclude-Q2-no long-term follow up.
Mertin J, Rudge P, Kremer M, et al. Double-blind controlled trial of immunosuppression in the treatment of multiple sclerosis: final report. Lancet. 1982;2(8294):351-4. Exclude-Q3-not current treatment. [pmid: 6124759].
Metz L, Hinrichs J, Harris C. Assessment of oral ondansetron in the treatment of cerebellar tremor in MS using the Canadian Occupational Performance Measure. MS Clin Lab Res. 1996;2:116. Exclude-Q3-not RCT.
Middel B, Kuipers-Upmeijer H, Bouma J, et al. Effect of intrathecal baclofen delivered by an implanted programmable pump on health related quality of life in patients with severe spasticity. J Neurol Neurosurg Psych. 1997;63(2):204-9. Exclude-DA-Q3-no separate results for MS patients.
Miki Y, Grossman RI, Udupa JK, et al. Computer-assisted quantitation of enhancing lesions in multiple sclerosis: correlation with clinical classification. Am J Neuroradiol. 1997;18(4):705-10. Exclude-Q2-no long-term follow up. [pmid: 9127034].
Milanese C, Salmaggi A, La Mantia L, et al. Double blind study of intrathecal beta-interferon in multiple sclerosis: clinical and laboratory results. J Neurol Neurosurg Psych. 1990;53(7):554-7. Exclude-DA-Q3-non-standard treatment.
Miller DH. Magnetic resonance imaging and spectroscopy in multiple sclerosis [review]. Curr Opinion Neurol. 1995;8(3):210-5. Exclude-not relevant to study questions.
Miller DH. Multiple sclerosis: use of MRI in evaluating new therapies [review]. Sem Neurol. 1998;18(3):317-25. Exclude-Q1a- review.
Miller DH, Khan OA, Sheremata WA, et al. A controlled trial of natalizumab for relapsing multiple sclerosis. New Engl J Med. 2003;348(1):15-23. Exclude-Q3-wrong timeframe. [pmid: 12510038].
Miller DH, Molyneux PD, Barker GJ, et al. Effect of interferon-beta1b on magnetic resonance imaging outcomes in secondary progressive multiple sclerosis: results of a European multicenter, randomized, double-blind, placebo-controlled trial. European Study Group on Interferon-beta1b in Secondary Progressive Multiple Sclerosis. Ann Neurol. 1999;46(6):850-9. Exclude-Q3-no improvement. [pmid: 10589537].
Miller DM, Weinstock-Guttman B, Bethoux F, et al. A meta-analysis of methylprednisolone in recovery from multiple sclerosis exacerbations. Mult Scler. 2000;6(4):267-73. Exclude-Q3-not RCT. [pmid: 10962547].
Milligan NM, Newcombe R, Compston DA. A double-blind controlled trial of high dose methylprednisolone in patients with multiple sclerosis: 1. Clinical effects. J Neurol Neurosurg Psych. 1987;50(5):511-6. Exclude-Q3-wrong timeframe.
Hartung HP, Gonsette R. MIMS Study Group. Mitoxantrone in progressive multiple sclerosis: a placebo-controlled, randomized observer-blind phase III trial: clinical results and three-year follow-up. Neurology. 1999;52(Suppl 2):A290. Exclude-abstract.
Minden SL, Moes EJ, Orav J, et al. Memory impairment in multiple sclerosis. J Clin Exper Neuropsychol. 1990;12(4):566-86. Exclude-Q2-no long-term follow up. [pmid: 2211978].
Mitchell JN. Multiple sclerosis and the prospects for employment. J Soc Occup Med. 1981;31(4):134-8. Exclude-DA-Q4-no data to predict work status. [pmid: 6460132].
Moher D, Schulz KF, Altman D, et al. The CONSORT Statement: Revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. 2001;285(15):1987-91. Exclude-methods paper. [pmid: 11308435].
Mohr DC, Goodkin DE, Islar J, et al. Treatment of depression is associated with suppression of nonspecific and antigen-specific T(H)1 responses in multiple sclerosis. Arch Neurol. 2001;58(7):1081-6. Exclude-Q3-not RCT. [pmid: 11448297].
Molyneux PD, Barker GJ, Barkhof F, et al. Clinical-MRI correlations in a European trial of interferon beta-1b in secondary progressive MS. Neurology. 2001;57(12):2191-7. Exclude-Q2-no analysis of predictors. [pmid: 11756596].
Molyneux PD, Filippi M, Barkhof F, et al. Correlations between monthly enhanced MRI lesion rate and changes in T2 lesion volume in multiple sclerosis [review]. Ann Neurol. 1998;43(3):332-9. Exclude-Q4-no findings relevant to question. [pmid: 9506550].
Moody GA, Probert CS, Jayanthi V, et al. The attitude of employers to people with inflammatory bowel disease. Soc Sci Med. 1992;34(4):459-60. Exclude-not relevant to study questions. [pmid: 1566127].
Murray TJ. Amantadine therapy for fatigue in multiple sclerosis. Can J Neurol Sci. 1985;12(3):251-4. Exclude-DA-Q3-not randomized. [pmid: 3902184].
Myers LW. Immunologic therapy for secondary and primary progressive multiple sclerosis [review]. Curr Neurol Neurosci Rep. 2001;1(3):286-93. Exclude-review-background. [pmid: 11898531].
Myhr KM, Riise T, Vedeler C, et al. Disability and prognosis in multiple sclerosis: demographic and clinical variables important for the ability to walk and awarding of disability pension. Mult Scler. 2001;7(1):59-65. Exclude-Q4-work ability not directly assessed. [pmid: 11321195].
Nagler B, Beebe GW, Kurtzke JF, et al. Studies on the natural history of multiple sclerosis. 1. Design and diagnosis. Acta Neurol Scand. 1966;42(Suppl 19):141-56. Exclude-review-background. [pmid: 5929914].
Nance PW, Sheremata WA, Lynch SG, et al. Relationship of the antispasticity effect of tizanidine to plasma concentration in patients with multiple sclerosis. Arch Neurol. 1997;54(6):731-6. Exclude-DA-Q3-dose comparison study. [pmid: 9193208].
National Multiple Sclerosis Society. About MS. Available at http:www.nationalmssociety.org/about. Accessed on October 16, 2003. Exclude-background
Nielsen JF, Klemar B, Hansen HJ, et al. A new treatment of spasticity with repetitive magnetic stimulation in multiple sclerosis. J Neurol Neurosurg Psych. 1995;58(2):254-5. Exclude-DA-Q3-not randomized.
Nortvedt MW, Riise T, Myhr KM, et al. Type I interferons and the quality of life of multiple sclerosis patients. Results from a clinical trial on interferon alfa-2a. Mult Scler. 1999;5(5):317-22. Exclude-DA-Q3-non-standard treatment. [pmid: 10516774].
Noseworthy J, Paty D, Wonnacott T, et al. Multiple sclerosis after age 50. Neurology. 1983;33(12):1537-44. Exclude-Q2-wrong timeframe. [pmid: 6606140].
Noseworthy JH. Clinical trials in multiple sclerosis [review]. Curr Opinion Neurol Neurosurg. 1993;6(2):209-15. Exclude-Q2-background.
Noseworthy JH. Clinical scoring methods for multiple sclerosis [review]. Ann Neurol. 1994;36(Suppl):S80-5. Exclude-Q2-background. [pmid: 8017893].
Noseworthy JH. Treatment of multiple sclerosis and related disorders: what's new in the past 2 years?. Clin Neuropharmacol. 2003;26(1):28-37. Exclude-not relevant to study questions. [pmid: 12567162].
Noseworthy JH, Vandervoort MK, Wong CJ, et al. Interrater variability with the Expanded Disability Status Scale (EDSS) and Functional Systems (FS) in a multiple sclerosis clinical trial. The Canadian Cooperation MS Study Group. Neurology. 1990;40(6):971-5. Exclude-not relevant to study questions. [pmid: 2189084].
Noseworthy JH, Wolinsky JS, Lublin FD, et al. Linomide in relapsing and secondary progressive MS: part I: trial design and clinical results. North American Linomide Investigators. Neurology. 2000;54(9):1726-33. Exclude-Q3-not current treatment. [pmid: 10802775].
Nuijten MJ, Hutton J. Cost-effectiveness analysis of interferon beta in multiple sclerosis: a Markov process analysis. Value Health. 2002;5(1):44-54. Exclude-Q3-not RCT. [pmid: 11873383].
Nuwer MR, Packwood JW, Myers LW, et al. Evoked potentials predict the clinical changes in a multiple sclerosis drug study. Neurology. 1987;37(11):1754-61. Exclude-Q2-no analysis of predictors. [pmid: 3313101].
O'Connor P, Marchetti P, Lee L, et al. Evoked potential abnormality scores are a useful measure of disease burden in relapsing-remitting multiple sclerosis. Ann Neurol. 1998;44(3):404-7. Exclude-Q2-no analysis of predictors. [pmid: 9749611].
O'Hara L, Cadbury H, DeSouza L, et al. Physical rehabilitation has a positive effect on disability in multiple sclerosis patients. Neurology. 2000;54(6):1396-7. Exclude-Q3-review. [pmid: 10746629].
O'Riordan JI, Doherty C, Javed M, et al. Do alpha-blockers have a role in lower urinary tract dysfunction in multiple sclerosis?. J Urol. 1995;153(4):1114-6. Exclude-DA-Q3-drug not available in US. [pmid: 7869476].
Offenbacher H, Fazekas F, Schmidt R, et al. Assessment of MRI criteria for a diagnosis of MS. Neurology. 1993;43(5):905-9. Exclude-Q1a-no longitudinal data. [pmid: 8274173].
Oliveri RL, Valentino P, Russo C, et al. Randomized trial comparing two different high doses of methylprednisolone in MS: a clinical and MRI study. Neurology. 1998;50(6):1833-6. Exclude-Q3-wrong timeframe. [pmid: 9633736].
Optic Neuritis Study Group. The 5-year risk of MS after optic neuritis. Experience of the optic neuritis treatment trial. Neurology. 1997;49(5):1404-13. Exclude-Q2-wrong timeframe. [pmid: 9371930].
Ordia JI, Fischer E, Adamski E, et al. Chronic intrathecal delivery of baclofen by a programmable pump for the treatment of severe spasticity. J Neurosurg. 1996;85(3):452-7. Exclude-Q3-RCT for single bolus only. [pmid: 8751632].
Packer TL, Sauriol A, Brouwer B. Fatigue secondary to chronic illness: postpolio syndrome, chronic fatigue syndrome, and multiple sclerosis. Arch Phys Med Rehab. 1994;75(10):1122-6. Exclude-Q4-no correlation with findings relevant to question.
Pan JW, Krupp LB, Elkins LE, et al. Cognitive dysfunction lateralizes with NAA in multiple sclerosis. Appl Neuropsychol. 2001;8(3):155-60. Exclude-Q2-no long-term follow up. [pmid: 11686650].
Panitch H, Goodin DS, Francis G, et al. Randomized, comparative study of interferon beta-1a treatment regimens in MS: The EVIDENCE Trial. Neurology. 2002;59(10):1496-506. Exclude-Q3-no control. [pmid: 12451188].
Paralyzed Veterans of America. Multiple sclerosis clinical practice guidelines: fatigue and multiple sclerosis: evidence-based management strategies for fatigue in multiple sclerosis. Washington, DC: Paralyzed Veterans of America. 1999. Exclude-Q3-not RCT
Patel UJ, Grossman RI, Phillips MD, et al. Serial analysis of magnetization-transfer histograms and Expanded Disability Status Scale scores in patients with relapsing-remitting multiple sclerosis. Am J Neuroradiol. 1999;20(10):1946-50. Exclude-Q2-no analysis of predictors. [pmid: 10588123].
Patten SB, Metz LM. Depression in multiple sclerosis [review]. Psychother Psychosom. 1997;66(6):286-92. Exclude-not relevant to study question. [pmid: 9403917].
Patten SB, Metz LM. SPECTRIMS Study Group. Interferon beta1a and depression in secondary progressive MS: data from the SPECTRIMS Trial. Neurology. 2002;59(5):744-6. Exclude-not relevant to study question. [pmid: 12221168].
Paty DW. Double-blind trial of linoleic acid in multiple sclerosis. Arch Neurol. 1983;40(11):693-4. Exclude-Q3-wrong timeframe. [pmid: 6354153].
Paty DW, Li DK. UBC MSMRI Study Group and IFNB Multiple Sclerosis Study Group. Interferon beta-lb is effective in relapsing-remitting multiple sclerosis. II. MRI analysis results of a multicenter, randomized, double-blind, placebo-controlled trial. 1993 [classical article]. Neurology. 2001;57(12 Suppl 5):S10-5. Exclude-Q3-no improvement. [pmid: 11902589].
Paty DW, Oger JJ, Kastrukoff LF, et al. MRI in the diagnosis of MS: a prospective study with comparison of clinical evaluation, evoked potentials, oligoclonal banding, and CT. Neurology. 1988;38(2):180-5. Exclude-Q1a-not McDonald criteria. [pmid: 3340277].
Patzold U, Pocklington PR. Course of multiple sclerosis. First results of a prospective study carried out of 102 MS patients from 1976-1980. Acta Neurol Scand. 1982;65(4):248-66. Exclude-Q2-wrong timeframe. [pmid: 7102254].
Pelletier J, Suchet L, Witjas T, et al. A longitudinal study of callosal atrophy and interhemispheric dysfunction in relapsing-remitting multiple sclerosis. Arch Neurol. 2001;58(1):105-11. Exclude-Q2-wrong timeframe. [pmid: 11176943].
Penman MF. Assessing the prevalence of cognitive impairment in multiple sclerosis: implications for patient management. AXON. 1991;13(2):45-9. Exclude-not relevant to study question. [pmid: 1764408].
Perkin GD, Aminoff MJ. A trial of brolitene in the treatment of spasticity. Brit J Clin Pharmacol. 1976;3(5):879-82. Exclude-DA-Q3-drug not available in US. [pmid: 788760].
Petro DJ, Ellenberger C Jr. Treatment of human spasticity with delta 9-tetrahydrocannabinol. J Clin Pharmacol. 1981;21(89 Suppl):413S-6S. Exclude-Q3-no long-term symptom management. [pmid: 6271839].
Pina Latorre MA, Ara JR, Modrego PJ, et al. Evaluation of handicap and socio-economic status in patients with multiple sclerosis—data from a population-based survey in the sanitary area of Calatayud, northern Spain. Wiener Mediz Wochenschr. 2001;151(910):224-7. Exclude-DA-Q4-no measure of work capacity.
Pinto OD, Polker M, Debono G. Results of international clinical trials with Lioresal. Postgrad Med J. 1972;48(Suppl 5):18-23. Exclude-DA-Q3-not RCT.
Plaut GS. Effectiveness of amantadine in reducing relapses in multiple sclerosis. J Roy Soc Med. 1987;80(2):91-3. Exclude-Q3-not RCT. [pmid: 3550084].
Plioplys AV, Plioplys S. Amantadine and L-carnitine treatment of Chronic Fatigue Syndrome. Neuropsychobiology. 1997;35(1):16-23. Exclude-Q3-no long-term symptom management. [pmid: 9018019].
Poehlau D, Federlein J, Postert T, et al. Intravenous immunoglobulin (IVIG) treatment for patients with primary or secondary progressive multiple sclerosis - outline of a double-blind randomized, placebo-controlled trial. Mult Scler. 1997;3(2):149-52. Exclude-DA-Q3-no results reported. [pmid: 9291171].
Polman CH, Bertelsmann FW, de Waal R, et al. 4-Aminopyridine is superior to 3,4-diaminopyridine in the treatment of patients with multiple sclerosis. Arch Neurol. 1994;51(11):1136-9. Exclude-Q3-no long-term symptom management. [pmid: 7980110].
Polman CH, Bertelsmann FW, van Loenen AC, et al. 4-aminopyridine in the treatment of patients with multiple sclerosis. Long-term efficacy and safety. Arch Neurol. 1994;51(3):292-6. Exclude-Q3-not RCT. [pmid: 8129642].
Poser CM, Brinar VV. Problems with diagnostic criteria for multiple sclerosis. Lancet. 2001;358(9295):1746-7. Exclude-Q1a-not longitudinal. [pmid: 11734228].
Poser CM, Paty DW, Scheinberg L, et al. New diagnostic criteria for multiple sclerosis: guidelines for research protocols. Ann Neurol. 1983;13(3):227-31. Exclude-Q4-no findings relevant to question. [pmid: 6847134].
Poser S, Bauer HJ, Ritter G, et al. Rehabilitation for patients with multiple sclerosis?. J Neurol. 1981;224(4):283-90. Exclude-Q4-no correlation with findings relevant to question. [pmid: 6162930].
Poser S, Herrmann-Gremmels I, Wikstrom J, et al. Clinical features of the spinal form of multiple sclerosis. Acta Neurol Scand. 1978;57(2):151-8. Exclude-Q4-methodology unclear. [pmid: 645350].
Poser S, Raun NE, Poser W. Age at onset, initial symptomatology and the course of multiple sclerosis. Acta Neurol Scand. 1982;66(3):355-62. Exclude-Q2-wrong timeframe. [pmid: 7136498].
Postma TJ, Oenema D, Terpstra S, et al. Cost analysis of the treatment of severe spinal spasticity with a continuous intrathecal baclofen infusion system. Pharmacoeconomics. 1999;15(4):395-404. Exclude-DA-Q3-no separate results for MS patients. [pmid: 10537958].
PRISMS Study Group and the University of British Columbia MSMRI Analysis Group. PRISMS-4: Long-term efficacy of interferon-beta-1a in relapsing MS [erratum appears in Neurology 2001 Sep 25;57(6):1146]. Neurology. 2001;56(12):1628-36. Exclude-Q3-no control. [pmid: 11425926].
Provinciali L, Ceravolo MG, Bartolini M, et al. A multidimensional assessment of multiple sclerosis: relationships between disability domains. Acta Neurol Scand. 1999;100(3):156-62. Exclude-Q2-no long-term follow up. [pmid: 10478578].
Pryse-Phillips W. Twenty questions about multiple sclerosis clinical trials methodologies [review]. Neurol Sci. 2001;22(2):187-93. Exclude-not relevant to study questions. [pmid: 11603625].
Pugnetti L, Mendozzi L, Motta A, et al. MRI and cognitive patterns in relapsing-remitting multiple sclerosis. J Neurol Sci. 1993;115 Suppl:S59-65. Exclude-Q2-no long-term follow up. [pmid: 8340795].
Rabey JM, Moriel EZ, Farkas A, et al. Detrusor hyperreflexia in multiple sclerosis. Alleviation by a combination of imipramine and propantheline, a clinico-laboratory study. Eur Neurol. 1979;18(1):33-7. Exclude-Q3-not RCT. [pmid: 436862].
Rammohan KW, Rosenberg JH, Lynn DJ, et al. Efficacy and safety of modafinil (Provigil) for the treatment of fatigue in multiple sclerosis: a two centre phase 2 study. J Neurol Neurosurg Psych. 2002;72(2):179-83. Exclude-DA-Q3-not randomized.
Ramsaransing G, Maurits N, Zwanikken C, et al. Early prediction of a benign course of multiple sclerosis on clinical grounds: a systematic review. Mult Scler. 2001;7(5):345-7. Exclude-Q2-no long-term follow up. [pmid: 11724452].
Rao SM, Leo GJ, Bernardin L, et al. Cognitive dysfunction in multiple sclerosis. I. Frequency, patterns, and prediction. Neurology. 1991;41(5):685-91. Exclude-Q4-no findings relevant to question. [pmid: 2027484].
Ravnborg M, Gronbech-Jensen M, Jonsson A. The MS Impairment Scale: a pragmatic approach to the assessment of impairment in patients with multiple sclerosis. Mult Scler. 1997;3(1):31-42. Exclude-Q2-no long-term follow up. [pmid: 9160344].
Ravnborg M, Liguori R, Christiansen P, et al. The diagnostic reliability of magnetically evoked motor potentials in multiple sclerosis. Neurology. 1992;42(7):1296-301. Exclude-Q2-no long-term follow up. [pmid: 1620337].
Reding MJ, LaRocca N, Madonna M. Acute-hospital care versus rehabilitation hospitalization for management on nonemergent complications in multiple sclerosis. J Neurol Rehab. 1987;1(1):13-7. Exclude-Q3b-not RCT.
Rice GP, Incorvaia B, Munari L, et al. Interferon in relapsing-remitting multiple sclerosis [review]. Cochrane Database of Systematic Reviews 2001;(4):CD002002. Exclude-review-background Q3
Richards RG, Sampson FC, Beard SM, et al. A review of the natural history and epidemiology of multiple sclerosis: implications for resource allocation and health economic models [review]. Health Technol Assess (Winchester, England). 2002;6(10):1-73. Exclude-not relevant to study questions.
Rio J, Nos C, Tintore M, et al. Assessment of different treatment failure criteria in a cohort of relapsing-remitting multiple sclerosis patients treated with interferon beta: implications for clinical trials. Ann Neurol. 2002;52(4):400-6. Exclude-Q2-no candidate predictors. [pmid: 12325067].
Robinson LR, Kraft GH, Fitts SS, et al. Body cooling may not improve somatosensory pathway function in multiple sclerosis. Am J Phys Med Rehab. 1997;76(3):191-6. Exclude-DA-Q5-no data on work status or ability.
Rodriguez M, Siva A, Ward J, et al. Impairment, disability, and handicap in multiple sclerosis: a population-based study in Olmsted County, Minnesota. Neurology. 1994;44(1):28-33. Exclude-Q2-no long-term follow up. [pmid: 8290086].
Roessler RT, Rumrill PD Jr. Multiple sclerosis and employment barriers: a systemic perspective on diagnosis and intervention. Work. 2003;21(1):17-23. Exclude-review-background. [pmid: 12897387].
Roessler RT, Rumrill PD Jr, Hennessey ML, et al. Perceived strengths and weaknesses in employment policies and services among people with multiple sclerosis: results of a national survey. Work. 2003;21(1):25-36. Exclude-review-background. [pmid: 12897388].
Ron MA, Callanan MM, Warrington EK. Cognitive abnormalities in multiple sclerosis: a psychometric and MRI study. Psychol Med. 1991;21(1):59-68. Exclude-Q2-no long-term follow up. [pmid: 2047506].
Rosenberg GA, Appenzeller O. Amantadine, fatigue, and multiple sclerosis. Arch Neurol. 1988;45(10):1104-6. Exclude-DA-Q3-treatment preference data only. [pmid: 2972270].
Rostami AM, Sater RA, Bird SJ, et al. A double-blind, placebo-controlled trial of extracorporeal photopheresis in chronic progressive multiple sclerosis. Mult Scler. 1999;5(3):198-203. Exclude-Q3-not current treatment. [pmid: 10408721].
Rovaris M, Rocca MA, Filippi M. Magnetic resonance-based techniques for the study and management of multiple sclerosis. Brit Med Bull. 2003;65:133-55. Exclude-Q1a- review. [pmid: 12697621].
Rudick RA, Cutter G, Baier M, et al. Use of the Multiple Sclerosis Functional Composite to predict disability in relapsing MS. Neurology. 2001;56(10):1324-30. Exclude-Q2-wrong timeframe. [pmid: 11376182].
Rudick RA, Cutter G, Reingold S. The multiple sclerosis functional composite: a new clinical outcome measure for multiple sderosis trials [review]. Mult Scler. 2002;8(5):359-65. Exclude-Q2-review. [pmid: 12356200].
Ruggieri RM, Palermo R, Vitello G, et al. Cognitive impairment in patients suffering from relapsing-remitting multiple sclerosis with EDSS ≤ 3. 5. Acta Neurol Scand. 2003;108:323-6. Exclude-Q4-no measurement of work ability. [pmid: 14616301].
Sailer M, Losseff NA, Wang L, et al. T1 lesion load and cerebral atrophy as a marker for clinical progression in patients with multiple sclerosis. A prospective 18 months follow-up study. Eur J Neurol. 2001;8(1):37-42. Exclude-Q2-no analysis of predictors. [pmid: 11509079].
Salan, SZ. Understanding Social Security Disability Programs. Presentation at Multidisciplinary Experts Meeting for the study of Criteria to Determine Disability Related to Multiple Sclerosis, sponsored by the Agency for Healthcare Research and Qualtiy Center for Outcomes and Evidence, Baltimore, MD, March 2003. Exclude-background
Salen BA, Spangfort EV, Nygren AL, et al. The Disability Rating Index: an instrument for the assessment of disability in clinical settings. J Clin Epidemiol. 1994;47(12):1423-35. Exclude-Q4-self-report of ability to work. [pmid: 7730851].
Sand PK, Appell R, Miklos JR, et al. Randomized, double-blind study to compare extended-release oxybutynin and tolterodine for overactive bladder. Obstet Gynecol. 2001;97(4 Suppl 1):S49. Exclude-no MS patients.
Sandyk R. Treatment with weak electromagnetic fields improves fatigue associated with multiple sclerosis. Internat J Neurosci. 1996;84(14):177-86. Exclude-Q3-not RCT.
Sater RA, Rostami AM, Galetta S, et al. Serial evoked potential studies and MRI imaging in chronic progressive multiple sclerosis. J Neurol Sci. 1999;171(2):79-83. Exclude-Q2-no analysis of predictors. [pmid: 10581371].
Schapiro RT. Pharmacologic options for the management of multiple sclerosis symptoms [review]. Neurorehab Neural Repair. 2002;16(3):223-31. Exclude-Q3-review.
Scheinberg L, Holland N, Larocca N, et al. Vocational disability and rehabilitation in multiple sclerosis. Internat J Rehab Res. 1981;4(1):61-4. Exclude-Q4-no findings relevant to question.
Schneitzer L. Rehabilitation of patients with multiple sclerosis. Arch Phys Med Rehab. 1978;59(9):430-7. Exclude-Q5-review.
Schuurman PR, Bosch DA, Bossuyt PM, et al. A comparison of continuous thalamic stimulation and thalamotomy for suppression of severe tremor. New Engl J Med. 2000;342(7):461-8. Exclude-Q3-no long-term symptom management. [pmid: 10675426].
Schuurman PR, Bruins J, Merkus MP, et al. A comparison of neuropsychological effects of thalamotomy and thalamic stimulation. Neurology. 2002;59(8):1232-9. Exclude-Q3-not RCT. [pmid: 12391352].
Schwartz CE, Vollmer T, Lee H. Reliability and validity of two self-report measures of impairment and disability for MS. North American Research Consortium on Multiple Sclerosis Outcomes Study Group. Neurology. 1999;52(1):63-70. Exclude-Q3-no longitudinal follow up. [pmid: 9921850].
Schwid SR, Covington M, Segal BM, et al. Fatigue in multiple sclerosis: current understanding and future directions [review]. J Rehab Res Develop. 2002;39(2):211-24. Exclude-Q3-review.
Schwid SR, Petrie MD, McDermott MP, et al. Quantitative assessment of sustained-release 4-aminopyridine for symptomatic treatment of multiple sclerosis. Neurology. 1997;48(4):817-21. Exclude-Q3-no long-term symptom management. [pmid: 9109861].
Scott TF, Nussbaum P, McConnell H, et al. Measurement of treatment response to sertraline in depressed multiple sclerosis patients using the Carroll scale. Neurol Res. 1995;17(6):421-2. Exclude-Q3-not RCT. [pmid: 8622794].
Shafey H. The effect of fluoxetine in depression associated with multiple sclerosis. Can J Psych. 1992;37(2):147-8. Exclude-Q3-not RCT.
Shakespeare DT, Young CA, Boggild M. Anti-spasticity agents for multiple sclerosis [retraction of Shakespeare DT, Boggild M, Young C. Cochrane Database Syst Rev. 2001;(4):CD001332; PMID: 11687107][review]. Cochrane Database of Systematic Reviews 2000;(4):CD001332. Exclude-review-background Q3
Sharrack B, Hughes RA, Morris RW, et al. The effect of oral and intravenous methylprednisolone treatment on subsequent relapse rate in multiple sclerosis. J Neurol Sci. 2000;173(1):73-7. Exclude-Q3-no control. [pmid: 10675582].
Sheean GL, Murray NM, Rothwell JC, et al. An open-labelled clinical and electrophysiological study of 3,4 diaminopyridine in the treatment of fatigue in multiple sclerosis. Brain. 1998;121(Pt 5):967-75. Exclude-Q3-not RCT. [pmid: 9619197].
Sheplan L, Ishmael C. Spasmolytic properties of dantrolene sodium: clinical evaluation. Military Medicine. 1975;140(1):26-9. Exclude-DA-Q3-no separate results for MS patients. [pmid: 804674].
Silver JM, Hales RE, Yudofsky SC. Psychopharmacology of depression in neurologic disorders [review]. J Clin Psych. 1990;51(Suppl):33-9. Exclude-Q3-review.
Simon JH. Contrast-enhanced MR imaging in the evaluation of treatment response and prediction of outcome in multiple sclerosis [review]. J Magnet Reson Imag. 1997;7(1):29-37. Exclude-Q2-background.
Simon JH. The contribution of spinal cord MRI to the diagnosis and differential diagnosis of multiple sclerosis [review]. J Neurol Sci. 2000;172(Suppl 1):S32-5. Exclude-Q1a-review. [pmid: 10606803].
Simon JH, Jacobs LD, Campion MK, et al. A longitudinal study of brain atrophy in relapsing multiple sclerosis. The Multiple Sclerosis Collaborative Research Group (MSCRG). Neurology. 1999;53(1):139-48. Exclude-Q2-no physical or mental outcome. [pmid: 10408550].
Simone IL, Carrara D, Tortorella C, et al. Course and prognosis in early-onset MS: comparison with adult-onset forms. Neurology. 2002;59(12):1922-8. Exclude-Q2-wrong timeframe. [pmid: 12499484].
Slade A, Tennant A, Chamberlain MA. A randomised controlled trial to determine the effect of intensity of therapy upon length of stay in a neurological rehabilitation setting. J Rehab Med. 2002;34(6):260-6. Exclude-Q3-mixed population.
Slater RJ. Criteria and uses of the Minimal Record of Disability in multiple sclerosis. Acta Neurol Scand Suppl. 1984;101:16-20. Exclude-Q2-background. [pmid: 6594907].
Smith ME, Stone LA, Albert PS, et al. Clinical worsening in multiple sclerosis is associated with increased frequency and area of gadopentetate dimeglumine-enhancing magnetic resonance imaging lesions. Ann Neurol. 1993;33(5):480-9. Exclude-Q2-wrong timeframe. [pmid: 8498825].
Smith PF, Darlington CL. Recent developments in drug therapy for multiple sclerosis [review]. Mult Scler. 1999;5(2):110-20. Exclude-Q3-review. [pmid: 10335520].
Smits RC, Emmen HH, Bertelsmann FW, et al. The effects of 4-aminopyridine on cognitive function in patients with multiple sclerosis: a pilot study. Neurology. 1994;44(9):1701-5. Exclude-Q3-no long-term symptom management. [pmid: 7936300].
Social Security Administration. Social Security Basic Facts, June 2003. Available at http:www.socialsecurity.govpressoffice. Last accessed October 14, 2003. Exclude-background
Social Security Administration. Disability Evaluation under Social Security January 2003. Baltimore, MD: Social Security Administration Office of Disability, 2003; SSA Pub. No. 64-039. Exclude-background
Social Security Administration. Fast Facts & Figures About Social Security. Baltimore, MD: Social Security Administration, Office of Policy, Office of Research, Evaluation, and Statistics., 2003. Exclude-background
Solari A, Amato MP, Bergamaschi R, et al. Accuracy of self-assessment of the minimal record of disability in patients with multiple sclerosis. Acta Neurol Scand. 1993;87(1):43-6. Exclude-Q2-no long-term follow up. [pmid: 8424310].
Solari A, Filippini G, Gagliardi L, et al. Interobserver agreement in the diagnosis of multiple sclerosis. Arch Neurol. 1989;46(3):289-92. Exclude-Q1b-no Poser or McDonald criteria. [pmid: 2919984].
Solari A, Uitdehaag B, Giuliani G, et al. Aminopyridines for symptomatic treatment in multiple sclerosis [review]. Cochrane Database of Systematic Reviews 2001;(4):CD001330. Exclude-review-background Q3
Sorensen PS, Fazekas F, Lee M. Intravenous immunoglobulin G for the treatment of relapsing-remitting multiple sclerosis: a meta-analysis. Eur J Neurol. 2002;9(6):557-63. Exclude-review-background Q3. [pmid: 12453069].
Sorensen PS, Wanscher B, Jensen CV, et al. Intravenous immunoglobulin G reduces MRI activity in relapsing multiple sclerosis. Neurology. 1998;50(5):1273-81. Exclude-Q3-wrong timeframe. [pmid: 9595974].
Sorensen PS, Wanscher B, Schreiber K, et al. A double-blind, cross-over trial of intravenous immunoglobulin G in multiple sclerosis: preliminary results. Mult Scler. 1997;3(2):145-8. Exclude-Q3-wrong timeframe. [pmid: 9291170].
Sormani MP, Molyneux PD, Barkhof F, et al. MRI enhancing lesion frequency from patients with MS enrolled in the placebo arms of clinical trials or in natural history studies. Magnet Reson Imag. 1999;17(8):1236-7. Exclude-Q2-no long-term follow up.
Sperling RA, Guttmann CR, Hohol MJ, et al. Regional magnetic resonance imaging lesion burden and cognitive function in multiple sclerosis: a longitudinal study. Arch Neurol. 2001;58(1):115-21. Exclude-Q2-no analysis of predictors. [pmid: 11176944].
Stangel M, Boegner F, Klatt CH, et al. Placebo controlled pilot trial to study the remyelinating potential of intravenous immunoglobulins in multiple sclerosis. J Neurol Neurosurg Psych. 2000;68(1):89-92. Exclude-Q3-wrong timeframe.
Stefoski D, Davis FA, Faut M, et al. 4-Aminopyridine improves clinical signs in multiple sclerosis. Ann Neurol. 1987;21(1):71-7. Exclude-Q3-no long-term symptom management. [pmid: 2435223].
Stefoski D, Davis FA, Fitzsimmons WE, et al. 4-Aminopyridine in multiple sclerosis: prolonged administration. Neurology. 1991;41(9):1344-8. Exclude-Q3-no long-term symptom management. [pmid: 1891078].
Stenager E, Knudsen L, Jensen K. Multiple sclerosis: the impact of physical impairment and cognitive dysfunction on social and sparetime activities. Psychother Psychosom. 1991;56(3):123-8. Exclude-Q2-no long-term follow up. [pmid: 1758955].
Stevenson VL, Miller DH. Magnetic resonance imaging in the monitoring of disease progression in multiple sclerosis [review]. Mult Scler. 1999;5(4):268-72. Exclude-not relevant to study question. [pmid: 10467387].
Stevenson VL, Miller DH, Leary SM, et al. One year follow up study of primary and transitional progressive multiple sclerosis. J Neurol Neurosurg Psych. 2000;68(6):713-8. Exclude-Q2-no analysis of predictors.
Strohle A, Kumpfel T, Sonntag A. Paroxetine for depersonalization associated with multiple sclerosis. Am J Psych. 2000;157(1):150. Exclude-Q3-case report.
Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: A proposal for reporting. JAMA. 2000;283(15):2008-12. Exclude-methods paper. [pmid: 10789670].
Stuifbergen AK. Healthpromoting behaviors and quality of life among individuals with multiple sclerosis. Scholar InquestionNurs Pract 1995;9(1):31–50; discussion 51–5. Exclude-Q2-no long-term follow up
Stuve O, Cree BC, Von Budingen HC, et al. Approved and future pharmacotherapy for multiple sclerosis. Neurologist. 2002;8(5):290-301. Exclude-Q3-review. [pmid: 12803676].
Susset V, Vobecky J, Black R. Disability outcome and self-assessment of disabled persons: an analysis of 506 cases. Arch Phys Med Rehab. 1979;60(2):50-6. Exclude-Q2-no long-term follow up.
Swinburn WR, Liversedge LA. Long-term treatment of multiple sclerosis with azathioprine. J Neurol Neurosurg Psych. 1973;36(1):124-6. Exclude-Q3-not RCT.
Syndulko K, Jafari M, Woldanski A, et al. Effects of temperature in multiple sclerosis: a review of the literature. J Neurol Rehab. 1996;10:23-34. Exclude-review-background.
Syndulko K, Ke D, Ellison GW, et al. Comparative evaluations of neuroperformance and clinical outcome assessments in chronic progressive multiple sclerosis: I. Reliability, validity and sensitivity to disease progression. Multiple Sclerosis Study Group. Mult Scler. 1996;2(3):142-56. Exclude-Q2-no analysis of predictors. [pmid: 9345379].
Then Bergh F, Kumpfel T, Grasser A, et al. Combined treatment with corticosteroids and moclobemide favors normalization of hypothalamo-pituitary-adrenal axis dysregulation in relapsing-remitting multiple sclerosis: a randomized, double blind trial. J Clin Endocrinol Metab. 2001;86(4):1610-5. Exclude-Q3-wrong timeframe. [pmid: 11297592].
Thompson AJ. Symptomatic treatment in multiple sclerosis [review]. Curr Opinion Neurol. 1998;11(4):305-9. Exclude-Q3-not RCT.
Thompson AJ. Measuring handicap in multiple sclerosis [review]. Mult Scler. 1999;5(4):260-2. Exclude-review-background-Q4. [pmid: 10467385].
Thompson AJ. Symptomatic management and rehabilitation in multiple sclerosis. J Neurol Neurosurg Psych. 2001;71(Suppl 2):ii22-7. Exclude-review-background Q3.
Thompson AJ. Progress in neurorehabilitation in multiple sclerosis [review]. Curr Opinion Neurol. 2002;15(3):267-70. Exclude-review-background Q2.
Thompson AJ, Brazil J, Whelan CA, et al. Peripheral blood T lymphocyte changes in multiple sclerosis: a marker of disease progression rather than of relapse?. J Neurol Neurosurg Psych. 1986;49(8):905-12. Exclude-Q2-no analysis of predictors.
Thorpe JW, Kidd D, Moseley IF, et al. Serial gadolinium-enhanced MRI of the brain and spinal cord in early relapsing-remitting multiple sclerosis. Neurology. 1996;46(2):373-8. Exclude-Q2-no analysis of predictors. [pmid: 8614497].
Trojano M, Liguori M, Bosco Zimatore G, et al. Age-related disability in multiple sclerosis. Ann Neurol. 2002;51(4):475-80. Exclude-Q2-wrong timeframe. [pmid: 11921053].
Tubridy N, Behan PO, Capildeo R, et al. The effect of anti-alpha4 integrin antibody on brain lesion activity in MS. The UK Antegren Study Group. Neurology. 1999;53(3):466-72. Exclude-Q3-wrong timeframe. [pmid: 10449105].
Tyndall A, Koike T. High-dose immunoablative therapy with hematopoietic stem cell support in the treatment of severe autoimmune disease: current status and future direction [review]. Intern Med. 2002;41(8):608-12. Exclude-Q3-not RCT. [pmid: 12211526].
Ungerleider JT, Andyrsiak T, Fairbanks L, et al. Delta-9-THC in the treatment of spasticity associated with multiple sclerosis. Adv Alcohol Substance Abuse. 1987;7(1):39-50. Exclude-DA-Q3-protocol not clear.
van der Werf SP, Jongen PJ, Lycklama a Nijeholt GJ, et al. Fatigue in multiple sclerosis: interrelations between fatigue complaints, cerebral MRI abnormalities and neurological disability. J Neurol Sci. 1998;160(2):164-70. Exclude-Q2-no long-term follow up. [pmid: 9849800].
Van Diemen HA, Polman CH, Koetsier JC, et al. 4-Aminopyridine in patients with multiple sclerosis: dosage and serum level related to efficacy and safety. Clin Neuropharmacol. 1993;16(3):195-204. Exclude-Q3-no long-term symptom management. [pmid: 8504436].
van Diemen HA, Polman CH, van Dongen MM, et al. 4-Aminopyridine induces functional improvement in multiple sclerosis patients: a neurophysiological study. J Neurol Sci. 1993;116(2):220-6. Exclude-Q3-no long-term symptom management. [pmid: 8336169].
van Diemen HA, Polman CH, van Dongen TM, et al. The effect of 4-aminopyridine on clinical signs in multiple sclerosis: a randomized, placebo-controlled, double-blind, cross-over study. Ann Neurol. 1992;32(2):123-30. Exclude-DA-Q3-no specific symptom targeted. [pmid: 1510353].
van Diemen HA, van Dongen MM, Dammers JW, et al. Increased visual impairment after exercise (Uhthoff's phenomenon) in multiple sclerosis: therapeutic possibilities. Eur Neurol. 1992;32(4):231-4. Exclude-Q3-not RCT. [pmid: 1324180].
Van Haver H, Lissoir F, Droissart C, et al. Transfer factor therapy in multiple sclerosis: a three-year prospective double-blind clinical trial. Neurology. 1986;36(10):1399-402. Exclude-DA-Q3-non-standard treatment. [pmid: 3093918].
van Walderveen MA, Barkhof F, Hommes OR, et al. Correlating MRI and clinical disease activity in multiple sclerosis: relevance of hypointense lesions on short-TRshort-TE (T1-weighted) spin-echo images. Neurology. 1995;45(9):1684-90. Exclude-Q2-no analysis of predictors. [pmid: 7675227].
Vartanian T. An examination of the results of the EVIDENCE, INCOMIN, and phase III studies of interferon beta products in the treatment of multiple sclerosis [review]. Clin Therap. 2003;25(1):105-18. Exclude-review-background Q3. [pmid: 12637114].
Vastag B. New diagnostic criteria for MS issued. JAMA. 2001;286(14):1703. Exclude-Q1a-not longitudinal. [pmid: 11594881].
Vercoulen JH, Hommes OR, Swanink CM, et al. The measurement of fatigue in patients with multiple sclerosis. A multidimensional comparison with patients with chronic fatigue syndrome and healthy subjects. Arch Neurol. 1996;53(7):642-9. Exclude-Q2-no long-term follow up. [pmid: 8929171].
Verjans E, Theys P, Delmotte P, et al. Clinical parameters and intrathecal IgG synthesis as prognostic features in multiple sclerosis. Part I. J Neurol. 1983;229(3):155-65. Exclude-Q2-wrong timeframe. [pmid: 6191007].
Vickrey BG, Hays RD, Harooni R, et al. A health-related quality of life measure for multiple sclerosis. Qual Life Res. 1995;4(3):187-206. Exclude-Q2-no long-term follow up. [pmid: 7613530].
Villar LM, Masjuan J, Gonzalez-Porque P, et al. Intrathecal IgM synthesis is a prognostic factor in multiple sclerosis. Ann Neurol. 2003;53(2):222-6. Exclude-Q2-wrong timeframe. [pmid: 12557289].
Visscher BR, Liu KS, Clark VA, et al. Onset symptoms as predictors of mortality and disability in multiple sclerosis. Acta Neurol Scand. 1984;70(5):321-8. Exclude-Q2-wrong timeframe. [pmid: 6507042].
Vukusic S, Confavreux C. Prognostic factors for progression of disability in the secondary progressive phase of multiple sclerosis [review]. J Neurol Sci. 2003;206(2):135-7. Exclude-Q2-wrong timeframe. [pmid: 12559500].
Wade DT, Robson P, House H, et al. A preliminary controlled study to determine whether whole-plant cannabis extracts can improve intractable neurogenic symptoms. Clin Rehab. 2003;17(1):21-9. Exclude-Q3-mixed population.
Wade DT, Young CA, Chaudhuri KR, et al. A randomised placebo controlled exploratory study of vitamin B-12, lofepramine, and L-phenylalanine (the “Cari Loder regime”) in the treatment of multiple sclerosis. J Neurol Neurosurg Psych. 2002;73(3):246-9. Exclude-Q3-wrong timeframe.
Warren S, Warren KG. Prevalence of multiple sclerosis in Barrhead County, Alberta, Canada. Can J Neurol Sci. 1992;19(1):72-5. Exclude-review-background Q2. [pmid: 1562911].
Weiner HL, Cohen JA. Treatment of multiple sclerosis with cyclophosphamide: critical review of clinical and immunologic effects [review]. Mult Scler. 2002;8(2):142-54. Exclude-review-background Q3. [pmid: 11990872].
Weiner HL, Dau PC, Khatri BO, et al. Double-blind study of true vs. sham plasma exchange in patients treated with immunosuppression for acute attacks of multiple sclerosis. Neurology. 1989;39(9):1143-9. Exclude-DA-Q3-no long-term data. [pmid: 2549450].
Weiner HL, Mackin GA, Orav EJ, et al. Intermittent cyclophosphamide pulse therapy in progressive multiple sclerosis: final report of the Northeast Cooperative Multiple Sclerosis Treatment Group. Neurology. 1993;43(5):910-8. Exclude-Q3a-no placebo group. [pmid: 8388090].
Weinshenker BG. Therapeutic plasma exchange for acute inflammatory demyelinating syndromes of the central nervous system [review]. J Clin Apheresis. 1999;14(3):144-8. Exclude-Q3-not current treatment. [pmid: 10540370].
Weinshenker BG. Plasma exchange for severe attacks of inflammatory demyelinating diseases of the central nervous system [review]. J Clin Apheresis. 2001;16(1):39-42. Exclude-Q3-not current treatment. [pmid: 11309833].
Weinshenker BG, Bass B, Rice GP, et al. The natural history of multiple sclerosis: a geographically based study. I. Clinical course and disability. Brain. 1989;112(Pt 1):133-46. Exclude-Q2-wrong timeframe. [pmid: 2917275].
Weinshenker BG, Bass B, Rice GP, et al. The natural history of multiple sclerosis: a geographically based study. 2. Predictive value of the early clinical course. Brain. 1989;112(Pt 6):1419-28. Exclude-Q2-no candidate predictors. [pmid: 2597989].
Weinshenker BG, Ebers GC. The natural history of multiple sclerosis [review]. Can J Neurol Sci. 1987;14(3):255-61. Exclude-Q2-wrong timeframe. [pmid: 3311324].
Weinshenker BG, Hader W, Carriere W, et al. The influence of pregnancy on disability from multiple sclerosis: a population-based study in Middlesex County, Ontario. Neurology. 1989;39(11):1438-40. Exclude-Q2-wrong timeframe. [pmid: 2812319].
Weinshenker BG, O'Brien PC, Petterson TM, et al. A randomized trial of plasma exchange in acute central nervous system inflammatory demyelinating disease. Ann Neurol. 1999;46(6):878-86. Exclude-Q3-wrong timeframe. [pmid: 10589540].
Weinstein R. Therapeutic apheresis in neurological disorders [review]. J Clin Apheresis. 2000;15(12):74-128. Exclude-Q3-not RCT. [pmid: 10767052].
Weinstock-Guttman B, Jacobs LD. What is new in the treatment of multiple sclerosis? [Review]. Drugs. 2000;59(3):401-10. Exclude-Q3-wrong timeframe. [pmid: 10776827].
White AT, Wilson TE, Petajan JH. Effect of pre-exercise cooling on physical function and fatigue in multiple sclerosis patients. Med Sci Sports Exer. 1997;29(Suppl 5):S83. Exclude-Q5-no data on work status or ability.
Wiart L, Joseph PA, Petit H, et al. The effects of capsaicin on the neurogenic hyperreflexic detrusor. A double blind placebo controlled study in patients with spinal cord disease. Preliminary results. Spinal Cord. 1998;36(2):95-9. Exclude-Q3-mixed population. [pmid: 9494998].
Wiebe S, Lee DH, Karlik SJ, et al. Serial cranial and spinal cord magnetic resonance imaging in multiple sclerosis. Ann Neurol. 1992;32(5):643-50. Exclude-Q2-no association of predictor with outcome at baseline. [pmid: 1449244].
Wiggs JW. Amantidine, the old anti-Parkinson medication, being useful in the fatigue syndrome that often accompanies multiple sclerosis. South Dakota J Med. 1991;44(9):279. Exclude-Q3-not RCT.
Wiles CM, Brown P, Chapel H, et al. Intravenous immunoglobulin in neurological disease: a specialist review. J Neurol Neurosurg Psych. 2002;72(4):440-8. Exclude-review-background Q3.
Wiles CM, Clarke CR, Irwin HP, et al. Hyperbaric oxygen in multiple sclerosis: a double blind trial. Brit Med J Clin Res Ed. 1986;292(6517):367-71. Exclude-Q3-wrong timeframe.
Williams ES, McKeran RO, Bellingham G. The uptake of available services and benefits for patients with multiple sclerosis in a south London borough. Public Health. 1988;102(2):169-75. Exclude-Q4-no findings relevant to question. [pmid: 3375416].
Wingerchuk DM, Noseworthy JH. Randomized controlled trials to assess therapies for multiple sclerosis [review]. Neurology. 2002;58(8 Suppl 4):S40-8. Exclude-review-background Q3. [pmid: 11971125].
Wingerchuk DM, Weinshenker BG. Multiple sclerosis: epidemiology, genetics, classification, natural history, and clinical outcome measures [review]. Neuroimag Clin NA 2000;10(4):611–24, vii. Exclude-review-background Q2
Wolf BA. Effects of temperature reduction on multiple sclerosis. Physical Therapy. 1970;50(6):808-12. Exclude-DA-Q3-no specific symptom targeted. [pmid: 4913537].
Wolfson C, Confavreux C. A probabilistic model of the natural history of multiple sclerosis. Am J Epidemiol. 1985;122:545-6. Exclude-Q2-model.
Wolinsky JS, Comi G, Filippi M, et al. Copaxone's effect on MRI-monitored disease in relapsing MS is reproducible and sustained. Neurology. 2002;59(8):1284-6. Exclude-Q3-not RCT. [pmid: 12391370].
Wolinsky JS, Narayana PA, Johnson KP, et al. United States open-label glatiramer acetate extension trial for relapsing multiple sclerosis: MRI and clinical correlates. Multiple Sclerosis Study Group and the MRI Analysis Center. Mult Scler. 2001;7(1):33-41. Exclude-Q2-wrong timeframe. [pmid: 11321192].
Wolinsky JS, Narayana PA, Noseworthy JH, et al. Linomide in relapsing and secondary progressive MS: part II: MRI results. MRI Analysis Center of the University of Texas-Houston, Health Science Center, and the North American Linomide Investigators. Neurology. 2000;54(9):1734-41. Exclude-Q3-not current treatment. [pmid: 10802777].
Wood PH. Assessing disablement status in multiple sclerosis. Acta Neurol Scand Suppl. 1984;101:154-64. Exclude-Q4-no findings relevant to question. [pmid: 6594906].
World Health Organization. International Classification of Functioning, Disability and Health: ICF. World Health Organization: Geneva, 2001. Exclude-background
World Health Organization. International Classification of Impairments, Disabilities, and Handicaps: A Manual of Classification Relating to the Consequences of Disease. World Health Organization: Geneva, 1980. Exclude-background
Worthington J, Jones R, Crawford M, et al. Pregnancy and multiple sclerosis—a 3-year prospective study. J Neurol. 1994;241(4):228-33. Exclude-Q2-no candidate predictors. [pmid: 8195822].
Yudkin PL, Ellison GW, Ghezzi A, et al. Overview of azathioprine treatment in multiple sclerosis. Lancet. 1991;338(8774):1051-5. Exclude-review-background Q3. [pmid: 1681364].
Zhao GJ, Li DK, Wolinsky JS, et al. Clinical and magnetic resonance imaging changes correlate in a clinical trial monitoring cyclosporine therapy for multiple sclerosis. The MS Study Group. J Neuroimag. 1997;7(1):1-7. Exclude-Q2-Other-no analysis of predictors.
Zifko UA, Rupp M, Schwarz S, et al. Modafinil in treatment of fatigue in multiple sclerosis. Results of an open-label study. J Neurol. 2002;249(8):983-7. Exclude-Q3-not RCT. [pmid: 12195441].
Zivadinov R, Rudick RA, De Masi R, et al. Effects of IV methylprednisolone on brain atrophy in relapsing-remitting MS. Neurology. 2001;57(7):1239-47. Exclude-Q3-wrong timeframe. [pmid: 11591843].