# References Cited in the Evidence Report

1 Salan SZ. Understanding Social Security Disability Programs. Presentation at Multidisciplinary Experts Meeting for the study of Criteria to Determine Disability Related to Multiple Sclerosis, sponsored by the Agency for Healthcare Research & Quality Center for Outcomes and Evidence, Baltimore, MD, March 2003.
2 Social Security Administration. Disability Evaluation under Social Security January 2003. Baltimore, MD: Social Security Administration Office of Disability, 2003; SSA Pub. No. 64-039.
3 World Health Organization. International Classification of Impairments, Disabilities, and Handicaps: A Manual of Classification Relating to the Consequences of Disease. World Health Organization: Geneva, 1980.
4 Poser CM, Paty DW, Scheinberg L, et al. New diagnostic criteria for multiple sclerosis: guidelines for research protocols. Ann Neurol. 1983;13(3):227-31. [pmid: 6847134].
5 McDonald WI, Compston A, Edan G, et al. Recommended diagnostic criteria for multiple sclerosis: guidelines from the International Panel on the Diagnosis of Multiple Sclerosis. Ann Neurol. 2001;50(1):121-7. [pmid: 11456302].
6 Jüni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. 1999;282(11):1054-60. [pmid: 10493204].
7 Moher D, Schulz KF, Altman D. for the CONSORT Group. The CONSORT Statement: Revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. 2001;285(15):1987-91. [pmid: 11308435].
8 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: A proposal for reporting. JAMA. 2000;283(15):2008-12. [pmid: 10789670].
9 Frohman EM, Goodin DS, Calabresi PA, et al. The utility of MRI in suspected MS: Report of the Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology. Neurology. 2003;61:602-11. [pmid: 12963748].
10 Gronseth GS, Ashman EJ. Practice parameter: the usefulness of evoked potentials in identifying clinically silent lesions in patients with suspected multiple sclerosis (an evidence-based review): Report of the Quality Standards Subcommittee of the American Academy of Neurology. [Review]. Neurology. 2000;54(9):1720-5. [pmid: 10802774].
11 Bakshi R, Benedict RH, Bermel RA, et al. Regional brain atrophy is associated with physical disability in multiple sclerosis: semiquantitative magnetic resonance imaging and relationship to clinical findings. J Neuroimag. 2001;11(2):129-36.
12 Berg D, Maurer M, Warmuth-Metz M, et al. The correlation between ventricular diameter measured by transcranial sonography and clinical disability and cognitive dysfunction in patients with multiple sclerosis. Arch Neurol. 2000;57(9):1289-92. [pmid: 10987895].
13 Catalaa I, Fulton JC, Zhang X, et al. MR imaging quantitation of gray matter involvement in multiple sclerosis and its correlation with disability measures and neurocognitive testing. Am J Neuroradiol. 1999;20(9):1613-8. [pmid: 10543630].
14 Cercignani M, Inglese M, Pagani E, et al. Mean diffusivity and fractional anisotropy histograms of patients with multiple sclerosis. Am J Neuroradiol. 2001;22(5):952-8. [pmid: 11337342].
15 Dehmeshki J, Barker GJ, Tofts PS. Classification of disease subgroup and correlation with disease severity using magnetic resonance imaging whole-brain histograms: application to magnetization transfer ratios and multiple sclerosis. IEEE Trans Med Imag. 2002;21(4):320-31.
16 Dehmeshki J, Ruto AC, Arridge S, et al. Analysis of MTR histograms in multiple sclerosis using principal components and multiple discriminant analysis. Magnet Reson Med. 2001;46(3):600-9.
17 Edwards SG, Gong QY, Liu C, et al. Infratentorial atrophy on magnetic resonance imaging and disability in multiple sclerosis. Brain. 1999;122(Pt 2):291-301. [pmid: 10071057].
18 Haughton VM, Yetkin FZ, Rao SM, et al. Quantitative MR in the diagnosis of multiple sclerosis. Magnet Reson Med. 1992;26(1):71-8.
19 Hawkins SA. Magnetisation transfer analysis and the disability resulting from multiple sclerosis. J Neurol Neurosurg Psych. 2000;69(6):715.
20 Iannucci G, Tortorella C, Rovaris M, et al. Prognostic value of MR and magnetization transfer imaging findings in patients with clinically isolated syndromes suggestive of multiple sclerosis at presentation. Am J Neuroradiol. 2000;21(6):1034-8. [pmid: 10871009].
21 Miller DH. Magnetic resonance imaging and spectroscopy in multiple sclerosis [review]. Curr Opinion Neurol. 1995;8(3):210-5.
22 Barkhof F, Filippi M, Miller DH, et al. Comparison of MRI criteria at first presentation to predict conversion to clinically definite multiple sclerosis. Brain. 1997;120(Pt 11):2059-69. [pmid: 9397021].
23 Brex PA, Miszkiel KA, O'Riordan JI, et al. Assessing the risk of early multiple sclerosis in patients with clinically isolated syndromes: the role of a follow up MRI. J Neurol Neurosurg Psych. 2001;70(3):390-3.
24 CHAMPS Study Group. MRI predictors of early conversion to clinically definite MS in the CHAMPS placebo group. Neurology. 2002;59(7):998-1005. [pmid: 12370452].
25 Comi G, Filippi M, Barkhof F, et al. Effect of early interferon treatment on conversion to definite multiple sclerosis: a randomised study. Lancet. 2001;357(9268):1576-82. [pmid: 11377645].
26 Dalton CM, Brex PA, Jenkins R, et al. Progressive ventricular enlargement in patients with clinically isolated syndromes is associated with the early development of multiple sclerosis. J Neurol Neurosurg Psych. 2002;73(2):141-7.
27 Dalton CM, Brex PA, Miszkiel KA, et al. Application of the new McDonald criteria to patients with clinically isolated syndromes suggestive of multiple sclerosis. Ann Neurol. 2002;52(1):47-53. [pmid: 12112046].
28 Filippi M, Horsfield MA, Morrissey SP, et al. Quantitative brain MRI lesion load predicts the course of clinically isolated syndromes suggestive of multiple sclerosis. Neurology. 1994;44(4):635-41. [pmid: 8164816].
29 Ghezzi A, Martinelli V, Torri V, et al. Long-term follow-up of isolated optic neuritis: the risk of developing multiple sclerosis, its outcome, and the prognostic role of paraclinical tests. J Neurol. 1999;246(9):770-5. [pmid: 10525973].
30 Morrissey SP, Miller DH, Kendall BE, et al. The significance of brain magnetic resonance imaging abnormalities at presentation with clinically isolated syndromes suggestive of multiple sclerosis. A 5-year follow-up study. Brain. 1993;116(Pt 1):135-46. [pmid: 8453454].
31 O'Riordan JI, Thompson AJ, Kingsley DP, et al. The prognostic value of brain MRI in clinically isolated syndromes of the CNS. A 10-year follow-up. Brain. 1998;121(Pt 3):495-503. [pmid: 9549525].
32 Optic Neuritis Study Group. The 5-year risk of MS after optic neuritis: experience of the optic neuritis treatment trial. 1997. Neurology. 2001;57(12 Suppl 5):S36-45. [pmid: 11902594].
33 Sastre-Garriga J, Tintoré M, Rovira A, et al. Conversion to multiple sclerosis after a clinically isolated syndrome of the brainstem: cranial magnetic resonance imaging, cerebrospinal fluid and neurophysiological findings. Mult Scler. 2003;9(1):39-43. [pmid: 12617267].
34 Tintoré M, Rovira A, Río J, et al. New diagnostic criteria for multiple sclerosis - application in first demyelinating episode. Neurology. 2003;60(1):27-30. [pmid: 12525713].
35 Paty DW, Oger JJ, Kastrukoff LF, et al. MRI in the diagnosis of MS: a prospective study with comparison of clinical evaluation, evoked potentials, oligoclonal banding, and CT. Neurology. 1988;38(2):180-5. [pmid: 3340277].
36 Fazekas F, Offenbacher H, Fuchs S, et al. Criteria for an increased specificity of MRI interpretation in elderly subjects with suspected multiple sclerosis. Neurology. 1988;38(12):1822-5. [pmid: 3057397].
37 Ford HL, Johnson MH, Rigby AS. Variation between observers in classifying multiple sclerosis. J Neurol Neurosurg Psych. 1996;61(4):418.
38 Zipoli V, Portaccio E, Siracusa G, et al. Interobserver agreement on Poser's and the new McDonald's diagnostic criteria for multiple sclerosis. Mult Scler. 2003;9:481-5. [pmid: 14582774].
39 Barkhof F, Filippi M, van Waesberghe JH, et al. Improving interobserver variation in reporting gadolinium-enhanced MRI lesions in multiple sclerosis. Neurology. 1997;49(6):1682-8. [pmid: 9409366].
40 Barkhof F, Filippi M, van Waesberghe JH, et al. Interobserver agreement for diagnostic MRI criteria in suspected multiple sclerosis. Neuroradiology. 1999;41(5):347-50. [pmid: 10379592].
41 Chapman J, Sylantiev C, Nisipeanu P, et al. Preliminary observations on APOE epsilon4 allele and progression of disability in multiple sclerosis. Arch Neurol. 1999;56(12):1484-7. [pmid: 10593303].
42 Cottrell DA, Kremenchutzky M, Rice GP, et al. The natural history of multiple sclerosis: a geographically based study. 6. Applications to planning and interpretation of clinical therapeutic trials in primary progressive multiple sclerosis. Brain. 1999a;122(Pt 4):641-7. [pmid: 10219777].
43 Cottrell DA, Kremenchutzky M, Rice GP, et al. The natural history of multiple sclerosis: a geographically based study. 5. The clinical features and natural history of primary progressive multiple sclerosis. Brain. 1999b;122(Pt 4):625-39. [pmid: 10219776].
44 Fuhr P, Borggrefe-Chappuis A, Schindler C, et al. Visual and motor evoked potentials in the course of multiple sclerosis. Brain. 2001;124(Pt 11):2162-8. [pmid: 11673318].
45 Goodkin DE, Hertsgaard D, Rudick RA. Exacerbation rates and adherence to disease type in a prospectively followed-up population with multiple sclerosis. Implications for clinical trials. Arch Neurol. 1989;46(10):1107-12. [pmid: 2679508].
46 Koziol JA, Wagner S, Sobel DF, et al. Predictive value of lesions for relapses in relapsing-remitting multiple sclerosis. Am J Neuroradiol. 2001;22(2):284-91. [pmid: 11156770].
47 Nortvedt MW, Riise T, Myhr KM, et al. Quality of life as a predictor for change in disability in MS. Neurology. 2000;55(1):51-4. [pmid: 10891905].
48 Rovaris M, Comi G, Ladkani D, et al. Short-term correlations between clinical and MR imaging findings in relapsing-remitting multiple sclerosis. Am J Neuroradiol. 2003;24(1):75-81. [pmid: 12533330].
49 Runmarker B, Andersson C, Odén A, et al. Prediction of outcome in multiple sclerosis based on multivariate models. J Neurol. 1994;241(10):597-604. [pmid: 7836963].
50 Stevenson VL, Leary SM, Losseff NA, et al. Spinal cord atrophy and disability in MS: a longitudinal study. Neurology. 1998;51(1):234-8. [pmid: 9674808].
51 Trotter JL, Clifford DB, McInnis JE, et al. Correlation of immunological studies and disease progression in chronic progressive multiple sclerosis. Ann Neurol. 1989;25(2):172-8. [pmid: 2521993].
52 Villar LM, Masjuan J, González-Porqué P, et al. Intrathecal IgM synthesis predicts the onset of new relapses and a worse disease course in MS. Neurology. 2002;59(4):555-9. [pmid: 12196648].
53 Achiron A, Gabbay U, Gilad R, et al. Intravenous immunoglobulin treatment in multiple sclerosis. Effect on relapses. Neurology. 1998;50(2):398-402. [pmid: 9484361].
54 Bastianello S, Pozzilli C, D'Andrea F, et al. A controlled trial of mitoxantrone in multiple sclerosis: serial MRI evaluation at one year. Can J Neurol Sci. 1994;21(3):266-70. [pmid: 8000984].
55 Bornstein MB, Miller A, Slagle S, et al. A pilot trial of Cop 1 in exacerbating-remitting multiple sclerosis. New Engl J Med. 1987;317(7):408-14. [pmid: 3302705].
56 Bornstein MB, Miller A, Slagle S, et al. A placebo-controlled, double-blind, randomized, two-center, pilot trial of Cop 1 in chronic progressive multiple sclerosis. Neurology. 1991;41(4):533-9. [pmid: 2011253].
57 British and Dutch Multiple Sclerosis Azathioprine Trial Group. Double-masked trial of azathioprine in multiple sclerosis. Lancet. 1988;2(8604):179-83. [pmid: 2899660].
58 Canadian Cooperative Multiple Sclerosis Study Group. The Canadian cooperative trial of cyclophosphamide and plasma exchange in progressive multiple sclerosis. Lancet. 1991;337(8739):441-6. [pmid: 1671468].
59 Cohen JA, Cutter GR, Fischer JS, et al. Benefit of interferon beta-1a on MSFC progression in secondary progressive MS. Neurology. 2002;59(5):679-87. [pmid: 12221157].
60 Currier RD, Haerer AF, Meydrech EF. Low dose oral methotrexate treatment of multiple sclerosis: a pilot study. [erratum appears in J Neurol Neurosurg Psychiatry 1994 Apr;57(4):528] J Neurol Neurosurg Psych 1993; 56(11):1217–8.
61 De Castro S, Cartoni D, Millefiorini E, et al. Noninvasive assessment of mitoxantrone cardiotoxicity in relapsing remitting multiple sclerosis. J Clin Pharmacol. 1995;35(6):627-32. [pmid: 7665724].
62 European Study Group on Interferon beta-1b in Secondary Progressive MS. Placebo-controlled multicentre randomised trial of interferon beta-1b in treatment of secondary progressive multiple sclerosis. Lancet. 1998;352(9139):1491-7. [pmid: 9820296].
63 Fazekas F, Deisenhammer F, Strasser-Fuchs S, et al. Randomised placebo-controlled trial of monthly intravenous immunoglobulin therapy in relapsing-remitting multiple sclerosis. Austrian Immunoglobulin in Multiple Sclerosis Study Group. Lancet. 1997a;349(9052):589-93. [pmid: 9057729].
64 Fazekas F, Deisenhammer F, Strasser-Fuchs S, et al. Treatment effects of monthly intravenous immunoglobulin on patients with relapsing-remitting multiple sclerosis: further analyses of the Austrian Immunoglobulin in MS study. Mult Scler. 1997b;3(2):137-41. [pmid: 9291168].
65 Fischer JS, Priore RL, Jacobs LD, et al. Neuropsychological effects of interferon beta-1a in relapsing multiple sclerosis. Multiple Sclerosis Collaborative Research Group. Ann Neurol. 2000;48(6):885-92. [pmid: 11117545].
66 Freeman JA, Thompson AJ, Fitzpatrick R, et al. Interferon-beta1b in the treatment of secondary progressive MS: impact on quality of life. Neurology. 2001;57(10):1870-5. [pmid: 11723278].
67 Ghezzi A, DiFalco MLC, et al. Clinical controlled randomized trial of azathioprine in multiple sclerosis. In: Gonsette RE, Delmotte P, eds. Recent Advances in Multiple Sclerosis Therapy. Amsterdam: Elsevier, 1989.
68 Goodkin DE, Bailly RC, Teetzen ML, et al. The efficacy of azathioprine in relapsing-remitting multiple sclerosis. Neurology. 1991;41(1):20-5. [pmid: 1985289].
69 Goodkin DE, Rudick RA, VanderBrug Medendorp S, et al. Low-dose (7. 5 mg) oral methotrexate reduces the rate of progression in chronic progressive multiple sclerosis. Ann Neurol. 1995;37(1):30-40. [pmid: 7818255].
70 Hartung HP, Gonsette R, König N, et al. Mitoxantrone in progressive multiple sclerosis: a placebo-controlled, double-blind, randomised, multicentre trial. Lancet. 2002;360(9350):2018-25. [pmid: 12504397].
71 Hauser SL, Dawson DM, Lehrich JR, et al. Intensive immunosuppression in progressive multiple sclerosis. A randomized, three-arm study of high-dose intravenous cyclophosphamide, plasma exchange, and ACTH. New Engl J Med. 1983;308(4):173-80. [pmid: 6294517].
72 IFNB Multiple Sclerosis Study Group. Interferon beta-1b is effective in relapsing-remitting multiple sclerosis. I. Clinical results of a multicenter, randomized, double-blind, placebo-controlled trial. Neurology. 1993;43(4):655-61. [pmid: 8469318].
73 IFNB Study Group, the University of British Columbia MS/MRI Analysis Group. Interferon beta-1b in the treatment of multiple sclerosis: final outcome of the randomized controlled trial. Neurology. 1995;45(7):1277-85. [pmid: 7617182].
74 IFNB Study Group, the University of British Columbia MS/MRI Analysis Group. Neutralizing antibodies during treatment of multiple sclerosis with interferon beta-1b: experience during the first three years. Neurology. 1996;47(4):889-94. [pmid: 8857714].
75 Jacobs L, Rudick R, Simon J. Extended observations on MS patients treated with IM interferon-beta1a (Avonex): implications for modern MS trials and therapeutics. J Neuroimmunol. 2000;107(2):167-73. [pmid: 10854652].
76 Jacobs LD, Cookfair DL, Rudick RA, et al. Intramuscular interferon beta-1a for disease progression in relapsing multiple sclerosis. The Multiple Sclerosis Collaborative Research Group (MSCRG) [erratum appears in Ann Neurol 1996 Sep;40(3):480]. Ann Neurol 1996;39(3):285–94.
77 Johnson KP, Brooks BR, Cohen JA, et al. Extended use of glatiramer acetate (Copaxone) is well tolerated and maintains its clinical effect on multiple sclerosis relapse rate and degree of disability. Copolymer 1 Multiple Sclerosis Study Group. Neurology. 1998;50(3):701-8. [pmid: 9521260].
78 Johnson KP, Brooks BR, Cohen JA, et al. Copolymer 1 reduces relapse rate and improves disability in relapsing-remitting multiple sclerosis: results of a phase III multicenter, double-blind, placebo-controlled trial. 1995 [classical article]. Neurology. 2001;57(12 Suppl 5):S16-24. [pmid: 11902590].
79 Kappos L, Polman C, Pozzilli C, et al. Final analysis of the European multicenter trial on IFNbeta-1b in secondary-progressive MS. Neurology. 2001;57(11):1969-75. [pmid: 11739811].
80 Khatri BO, McQuillen MP, Harrington GJ, et al. Chronic progressive multiple sclerosis: double-blind controlled study of plasmapheresis in patients taking immunosuppressive drugs. Neurology. 1985;35(3):312-9. [pmid: 3974889].
81 Leary SM, Miller DH, Stevenson VL, et al. Interferon beta-1a in primary progressive MS: an exploratory, randomized, controlled trial. Neurology. 2003;60(1):44-51. [pmid: 12525716].
82 Liu C, Blumhardt LD. Randomised, double blind, placebo controlled study of interferon beta-1a in relapsing-remitting multiple sclerosis analysed by area under disability/time curves. J Neurol Neurosurg Psych. 1999;67(4):451-6.
83 Liu C, Blumhardt LD. Benefits of glatiramer acetate on disability in relapsing-remitting multiple sclerosis. An analysis by area under disability/time curves. The Copolymer 1 Multiple Sclerosis Study Group. J Neurol Sci. 2000;181(12):33-7. [pmid: 11099709].
84 Liu C, Blumhardt LD. Randomized, double-blind, placebo-controlled study of subcutaneous interferon beta-1a in relapsing-remitting multiple sclerosis: a categorical disability trend analysis. Mult Scler. 2002;8(1):10-4. [pmid: 11936481].
85 Milanese C, La Mantia L, Salmaggi A, et al. Double blind controlled randomized study on azathioprine efficacy in multiple sclerosis. Preliminary results. Ital J Neurol Sci. 1988;9(1):53-7. [pmid: 3281916].
86 Millefiorini E, Gasperini C, Pozzilli C, et al. Randomized placebo-controlled trial of mitoxantrone in relapsing-remitting multiple sclerosis: 24-month clinical and MRI outcome. J Neurol. 1997;244(3):153-9. [pmid: 9050955].
87 Multiple Sclerosis Study Group. Efficacy and toxicity of cyclosporine in chronic progressive multiple sclerosis: a randomized, double-blinded, placebo-controlled clinical trial. Ann Neurol. 1990;27(6):591-605. [pmid: 2193613].
88 Noseworthy JH, O'Brien PC, Petterson TM, et al. A randomized trial of intravenous immunoglobulin in inflammatory demyelinating optic neuritis. Neurology. 2001;56(11):1514-22. [pmid: 11402108].
89 Patten SB, Metz LM. Interferon beta-1a and depression in relapsing-remitting multiple sclerosis: an analysis of depression data from the PRISMS clinical trial. Mult Scler. 2001;7(4):243-8. [pmid: 11548984].
90 Patti F, L'Episcopo MR, Cataldi ML, et al. Natural interferon-beta treatment of relapsing-remitting and secondary-progressive multiple sclerosis patients. A two-year study. Acta Neurol Scand. 1999;100(5):283-9. [pmid: 10536913].
91 Patzold U, Hecker H, Pocklington P. Azathioprine in treatment of multiple sclerosis. Final results of a 41/2-year controlled study of its effectiveness covering 115 patients. J Neurol Sci. 1982;54(3):377-94. [pmid: 7047686].
92 Pliskin NH, Hamer DP, Goldstein DS, et al. Improved delayed visual reproduction test performance in multiple sclerosis patients receiving interferon beta-1b. Neurology. 1996;47(6):1463-8. [pmid: 8960728].
93 PRISMS Study Group and the University of British Columbia MS/MRI Analysis Group. Randomised double-blind placebo-controlled study of interferon beta-1a in relapsing/remitting multiple sclerosis. PRISMS (Prevention of Relapses and Disability by Interferon beta-1a Subcutaneously in Multiple Sclerosis) Study Group. [erratum appears in Lancet 1999 Feb 20;353(9153):678] Lancet 1998;352(9139):1498–504.
94 Rice GP, Filippi M, Comi G. Cladribine and progressive MS: clinical and MRI outcomes of a multicenter controlled trial. Cladribine MRI Study Group. Neurology. 2000;54(5):1145-55. [pmid: 10720289].
95 Romine JS, Sipe JC, Koziol JA, et al. A double-blind, placebo-controlled, randomized trial of cladribine in relapsing-remitting multiple sclerosis. Proc Assoc Am Physic. 1999;111(1):35-44.
96 Rudick RA, Fisher E, Lee JC, et al. Brain atrophy in relapsing multiple sclerosis: relationship to relapses, EDSS, and treatment with interferon beta-1a. Mult Scler. 2000;6(6):365-72. [pmid: 11212130].
97 Rudick RA, Goodkin DE, Jacobs LD, et al. Impact of interferon beta-1a on neurologic disability in relapsing multiple sclerosis. The Multiple Sclerosis Collaborative Research Group (MSCRG). Neurology. 1997;49(2):358-63. [pmid: 9270562].
98 Schwartz CE, Coulthard-Morris L, Cole B, et al. The quality-of-life effects of interferon beta-1b in multiple sclerosis. An extended Q-TWiST analysis. Arch Neurol. 1997;54(12):1475-80. [pmid: 9400356].
99 Sipe JC, Romine JS, Koziol JA, et al. Cladribine in treatment of chronic progressive multiple sclerosis. Lancet. 1994;344(8914):9-13. [pmid: 7912347].
100 SPECTRIMS Study Group. Randomized controlled trial of interferon- beta-1a in secondary progressive MS: Clinical results. Neurology. 2001;56(11):1496-504. [pmid: 11402106].
101 Strasser-Fuchs S, Fazekas F, Deisenhammer F, et al. The Austrian Immunoglobulin in MS (AIMS) study: final analysis. Mult Scler. 2000;6(Suppl 2):S9-13. [pmid: 11188778].
102 van de Wyngaert FA, Beguin C, D'Hooghe MB, et al. A double-blind clinical trial of mitoxantrone versus methylprednisolone in relapsing, secondary progressive multiple sclerosis. Acta Neurol Belg. 2001;101(4):210-6. [pmid: 11851027].
103 Weinstein A, Schwid SI, Schiffer RB, et al. Neuropsychologic status in multiple sclerosis after treatment with glatiramer. Arch Neurol. 1999;56(3):319-24. [pmid: 10190822].
104 Bass B, Weinshenker B, Rice GP, et al. Tizanidine versus baclofen in the treatment of spasticity in patients with multiple sclerosis. Can J Neurol Sci. 1988;15(1):15-9. [pmid: 3345456].
105 Brar SP, Smith MB, Nelson LM, et al. Evaluation of treatment protocols on minimal to moderate spasticity in multiple sclerosis. Arch Phys Med Rehab. 1991;72(3):186-9.
106 Cartlidge NE, Hudgson P, Weightman D. A comparison of baclofen and diazepam in the treatment of spasticity. J Neurol Sci. 1974;23(1):17-24. [pmid: 4850175].
107 Cutter NC, Scott DD, Johnson JC, et al. Gabapentin effect on spasticity in multiple sclerosis: a placebo-controlled, randomized trial. Arch Phys Med Rehab. 2000;81(2):164-9.
108 Eyssette M, Rohmer F, Serratrice G, et al. Multi-centre, double-blind trial of a novel antispastic agent, tizanidine, in spasticity associated with multiple sclerosis. Curr Med Res Opinion. 1988;10(10):699-708.
109 Feldman RG, Kelly-Hayes M, Conomy JP, et al. Baclofen for spasticity in multiple sclerosis. Double-blind crossover and three-year study. Neurology. 1978;28(11):1094-8. [pmid: 362234].
110 From A, Heltberg A. A double-blind trial with baclofen (Lioresal) and diazepam in spasticity due to multiple sclerosis. Acta Neurol Scand. 1975;51(2):158-66. [pmid: 1090103].
111 Gambi D, Rossini PM, Calenda G, et al. Dantrolene sodium in the treatment of spasticity caused by multiple sclerosis or degenerative myelopathies: a double-blind, crossover study in comparison with placebo. Curr Therapeutic Res. 1983;33:835-40.
112 Hauser SL, Doolittle TH, Lopez-Bresnahan M, et al. An antispasticity effect of threonine in multiple sclerosis. Arch Neurol. 1992;49(9):923-6. [pmid: 1520082].
113 Hoogstraten MC, van der Ploeg RJ, vd Burg W, et al. Tizanidine versus baclofen in the treatment of spasticity in multiple sclerosis patients. Acta Neurol Scand. 1988;77(3):224-30. [pmid: 3376747].
114 Hyman N, Barnes M, Bhakta B, et al. Botulinum toxin (Dysport) treatment of hip adductor spasticity in multiple sclerosis: a prospective, randomised, double blind, placebo controlled, dose ranging study. J Neurol Neurosurg Psych. 2000;68(6):707-12.
115 Killestein J, Hoogervorst EL, Reif M, et al. Safety, tolerability, and efficacy of orally administered cannabinoids in MS. Neurology. 2002;58(9):1404-7. [pmid: 12011290].
116 Lee A, Patterson V. A double-blind study of L-threonine in patients with spinal spasticity. Acta Neurol Scand. 1993;88(5):334-8. [pmid: 8296531].
117 Levine IM, Jossmann PB, DeAngelis V. Liorseal, a new muscle relaxant in the treatment of spasticity-a double-blind quantitative evaluation. Dis Nerv System. 1977;38(12):1011-5.
118 Livesley E. Effects of electrical neuromuscular stimulation on functional performance in patients with multiple sclerosis. Physiotherapy. 1992;78(12):914-7.
119 Mondrup K, Pedersen E. The clinical effect of the GABA-agonist, progabide, on spasticity. Acta Neurol Scand. 1984b;69(4):200-6. [pmid: 6377802].
120 Mondrup K, Pedersen E. The effect of the GABA-agonist, progabide, on stretch and flexor reflexes and on voluntary power in spastic patients. Acta Neurol Scand. 1984a;69(4):191-9. [pmid: 6377801].
121 Mueller ME, Gruenthal M, Olson WL, et al. Gabapentin for relief of upper motor neuron symptoms in multiple sclerosis. Arch Phys Med Rehab. 1997;78(5):521-4.
122 Newman PM, Nogues M, Newman PK, et al. Tizanidine in the treatment of spasticity. Eur J Clin Pharmacol. 1982;23(1):31-5. [pmid: 6751834].
123 Nielsen JF, Sinkjaer T, Jakobsen J. Treatment of spasticity with repetitive magnetic stimulation; a double-blind placebo-controlled study. Mult Scler. 1996;2(5):227-32. [pmid: 9050361].
124 Ørsnes GB, Sørensen PS, Larsen TK, et al. Effect of baclofen on gait in spastic MS patients. Acta Neurol Scand. 2000;101(4):244-8. [pmid: 10770520].
125 Penn RD, Savoy SM, Corcos D, et al. Intrathecal baclofen for severe spinal spasticity. New Engl J Med. 1989;320(23):1517-21. [pmid: 2657424].
126 Rice GP. Tizanidine vs. baclofen in the treatment of spasticity in patients with multiple sclerosis. Can J Neurol Sci. 1989;16(4):451. [pmid: 2804809].
127 Rinne U. Tizanidine treatment of spasticity in multiple sclerosis and chronic myelopathy. Curr Therapeutic Res. 1980;28:827-36.
128 Rudick RA, Breton D, Krall RL. The GABA-agonist progabide for spasticity in multiple sclerosis. Arch Neurol. 1987;44(10):1033-6. [pmid: 3632375].
129 Sachais BA, Logue JN, Carey MS. Baclofen, a new antispastic drug. A controlled, multicenter trial in patients with multiple sclerosis. Arch Neurol. 1977;34(7):422-8. [pmid: 327987].
130 Sawa GM, Paty DW. The use of baclofen in treatment of spasticity in multiple sclerosis. Can J Neurol Sci. 1979;6(3):351-4. [pmid: 385132].
131 Schmidt RT, Lee RH, Spehlmann R. Treatment of spasticity in multiple sclerosis: comparison of dantrolene sodium and diazepam. Trans Am Neurol Assoc. 1975;100:235-7. [pmid: 1226625].
132 Schmidt RT, Lee RH, Spehlmann R. Comparison of dantrolene sodium and diazepam in the treatment of spasticity. J Neurol Neurosurg Psych. 1976;39(4):350-6.
133 Smith C, Birnbaum G, Carter JL, et al. Tizanidine treatment of spasticity caused by multiple sclerosis: results of a double-blind, placebo-controlled trial. US Tizanidine Study Group. Neurology 199;444(11 Suppl 9):S34–42; ; discussion S42–3.
134 Smolenski C, Muff S, Smolenski-Kautz S. A double-blind comparative trial of new muscle relaxant, tizanidine (DS 103–282), and baclofen in the treatment of chronic spasticity in multiple sclerosis. Curr Med Res Opinion. 1981;7(6):374-83.
135 Snow BJ, Tsui JK, Bhatt MH, et al. Treatment of spasticity with botulinum toxin: a double-blind study. Ann Neurol. 1990;28(4):512-5. [pmid: 2252363].
136 Stien R, Nordal HJ, Oftedal SI, et al. The treatment of spasticity in multiple sclerosis: a double-blind clinical trial of a new anti-spastic drug tizanidine compared with baclofen. Acta Neurol Scand. 1987;75(3):190-4. [pmid: 3554879].
137 United Kingdom Tizanidine Trial Group. A double-blind, placebo-controlled trial of tizanidine in the treatment of spasticity caused by multiple sclerosis. Neurology. 1994;44(11 Suppl 9):S70-8. [pmid: 7970014].
138 Zajicek J, Fox P, Sanders H, et al. Cannabinoids for treatment of spasticity and other symptoms related to multiple sclerosis (CAMS study): multicentre randomised placebo-controlled trial. Lancet. 2003;362:1517-26. [pmid: 14615106].
139 Francabandera FL, Holland NJ, Wiesel-Levison P, et al. Multiple sclerosis rehabilitation: inpatient vs. outpatient. Rehab Nurs. 1988;13(5):251-3.
140 Freeman JA, Langdon DW, Hobart JC, et al. The impact of inpatient rehabilitation on progressive multiple sclerosis. Ann Neurol. 1997;42(2):236-44. [pmid: 9266735].
141 O'Hara L, Cadbury H, De SL, et al. Evaluation of the effectiveness of professionally guided self-care for people with multiple sclerosis living in the community: a randomized controlled trial. Clin Rehab. 2002;16(2):119-28.
142 Patti F, Ciancio MR, Reggio E, et al. The impact of outpatient rehabilitation on quality of life in multiple sclerosis. J Neurol. 2002;249(8):1027-33. [pmid: 12195449].
143 Petajan JH, Gappmaier E, White AT, et al. Impact of aerobic training on fitness and quality of life in multiple sclerosis. Ann Neurol. 1996;39(4):432-41. [pmid: 8619521].
144 Pozzilli C, Brunetti M, Amicosante AM, et al. Home based management in multiple sclerosis: results of a randomised controlled trial. J Neurol Neurosurg Psych. 2002;73(3):250-5.
145 Solari A, Filippini G, Gasco P, et al. Physical rehabilitation has a positive effect on disability in multiple sclerosis patients. Neurology. 1999;52(1):57-62. [pmid: 9921849].
146 Stuifbergen AK, Becker H, Blozis S, et al. A randomized clinical trial of a wellness intervention for women with multiple sclerosis. Arch Phys Med Rehab. 2003;84(4):467-76.
147 Wassem R, Dudley W. Symptom management and adjustment of patients with multiple sclerosis: a 4-year longitudinal intervention study. Clin Nurs Res. 2003;12(1):102-17. [pmid: 12583502].
148 Wiles CM, Newcombe RG, Fuller KJ, et al. Controlled randomised crossover trial of the effects of physiotherapy on mobility in chronic multiple sclerosis. J Neurol Neurosurg Psych. 2001;70(2):174-9.
149 Crawford JD, McIvor GP. Group psychotherapy: benefits in multiple sclerosis. Arch Phys Med Rehab. 1985;66(12):810-3.
150 Foley FW, Bedell JR, LaRocca NG, et al. Efficacy of stress-inoculation training in coping with multiple sclerosis. J Consult Clin Psychol. 1987;55(6):919-22. [pmid: 3693660].
151 Larcombe NA, Wilson PH. An evaluation of cognitive-behaviour therapy for depression in patients with multiple sclerosis. Brit J Psych. 1984;145:366-71.
152 Mendoza RJ, Pittenger DJ, Weinstein CS. Unit management of depression of patients with multiple sclerosis using cognitive remediation strategies: a preliminary study. Neurorehab Neural Repair. 2001;15(1):9-14.
153 Mohr DC, Boudewyn AC, Goodkin DE, et al. Comparative outcomes for individual cognitive-behavior therapy, supportive-expressive group psychotherapy, and sertraline for the treatment of depression in multiple sclerosis. J Consult Clin Psychol. 2001;69(6):942-9. [pmid: 11777121].
154 Mohr DC, Likosky W, Bertagnolli A, et al. Telephone-administered cognitive-behavioral therapy for the treatment of depressive symptoms in multiple sclerosis. J Consult Clin Psychol. 2000;68(2):356-61. [pmid: 10780138].
155 Schiffer RB, Herndon RM, Rudick RA. Treatment of pathologic laughing and weeping with amitriptyline. New Engl J Med. 1985;312(23):1480-2. [pmid: 3887172].
156 Schiffer RB, Wineman NM. Antidepressant pharmacotherapy of depression associated with multiple sclerosis. Am J Psych. 1990;147(11):1493-7.
157 Canadian MS Research Group. A randomized controlled trial of amantadine in fatigue associated with multiple sclerosis. Can J Neurol Sci. 1987;14(3):273-8. [pmid: 2889518].
158 Cohen RA, Fisher M. Amantadine treatment of fatigue associated with multiple sclerosis. Arch Neurol. 1989;46(6):676-80. [pmid: 2730380].
159 Geisler MW, Sliwinski M, Coyle PK, et al. The effects of amantadine and pemoline on cognitive functioning in multiple sclerosis. Arch Neurol. 1996;53(2):185-8. [pmid: 8639070].
160 Gillson G, Richard TL, Smith RB, et al. A double-blind pilot study of the effect of Prokarin on fatigue in multiple sclerosis. Mult Scler. 2002;8(1):30-5. [pmid: 11936486].
161 Krupp LB, Coyle PK, Doscher C, et al. Fatigue therapy in multiple sclerosis: results of a double-blind, randomized, parallel trial of amantadine, pemoline, and placebo. Neurology. 1995;45(11):1956-61. [pmid: 7501140].
162 Rossini PM, Pasqualetti P, Pozzilli C, et al. Fatigue in progressive multiple sclerosis: results of a randomized, double-blind, placebo-controlled, crossover trial of oral 4-aminopyridine. Mult Scler. 2001;7(6):354-8. [pmid: 11795455].
163 Weinshenker BG, Penman M, Bass B, et al. A double-blind, randomized, crossover trial of pemoline in fatigue associated with multiple sclerosis. Neurology. 1992;42(8):1468-71. [pmid: 1641137].
164 Fredrikson S. Nasal spray desmopressin treatment of bladder dysfunction in patients with multiple sclerosis. Acta Neurol Scand. 1996;94(1):31-4. [pmid: 8874590].
165 Hilton P, Hertogs K, Stanton SL. The use of desmopressin (DDAVP) for nocturia in women with multiple sclerosis. J Neurol Neurosurg Psych. 1983;46(9):854-5.
166 Hoverd PA, Fowler CJ. Desmopressin in the treatment of daytime urinary frequency in patients with multiple sclerosis. J Neurol Neurosurg Psych. 1998;65(5):778-80.
167 Kinn AC, Larsson PO. Desmopressin: a new principle for symptomatic treatment of urgency and incontinence in patients with multiple sclerosis. Scand J Urol Nephrol. 1990;24(2):109-12. [pmid: 2192444].
168 Prasad RS, Smith SJ, Wright H. Lower abdominal pressure versus external bladder stimulation to aid bladder emptying in multiple sclerosis: a randomized controlled study. Clin Rehab. 2003;17(1):42-7.
169 Vahtera T, Haaranen M, Viramo-Koskela AL, et al. Pelvic floor rehabilitation is effective in patients with multiple sclerosis. Clin Rehab. 1997;11(3):211-9.
170 Valiquette G, Herbert J, Maede-D'Alisera P. Desmopressin in the management of nocturia in patients with multiple sclerosis. A double-blind, crossover trial. Arch Neurol. 1996;53(12):1270-5. [pmid: 8970454].
171 Lincoln NB, Dent A, Harding J, et al. Evaluation of cognitive assessment and cognitive intervention for people with multiple sclerosis. J Neurol Neurosurg Psych. 2002;72(1):93-8.
172 Beatty WW, Blanco CR, Wilbanks SL, et al. Demographic, clinical and cognitive characteristics of multiple sclerosis patients who continue to work. J Neurol Rehab. 1995;9:167-73.
173 Beukelman DR, Kraft GH, Freal J. Expressive communication disorders in persons with multiple sclerosis: a survey. Arch Phys Med Rehab. 1985;66(10):675-7.
174 Canadian Burden of Illness Study Group. Burden of illness of multiple sclerosis: Part I: Cost of illness. Can J Neurol Sci. 1998a;25(1):23-30. [pmid: 9532277].
175 Canadian Burden of Illness Study Group. Burden of illness of multiple sclerosis: Part II: Quality of life. Can J Neurol Sci. 1998b;25(1):31-8. [pmid: 9532278].
176 Dyck I, Jongbloed L. Women with multiple sclerosis and employment issues: a focus on social and institutional environments. Can J Occup Therapy. 2000;67(5):337-46.
177 Edgley K, Sullivan M, Dehoux E. A survey of multiple sclerosis: determinants of employment status. Can J Rehabil. 1991;4:127-32.
178 Freal JE, Kraft GH, Coryell JK. Symptomatic fatigue in multiple sclerosis. Arch Phys Med Rehab. 1984;65(3):135-8.
179 Genevie L, Kallos JE, Struening EL. Job retention among people with multiple sclerosis. J Neurol Rehab. 1987;1:131-5.
180 Grima DT, Torrance GW, Francis G, et al. Cost and health related quality of life consequences of multiple sclerosis. Mult Scler. 2000;6(2):91-8. [pmid: 10773854].
181 Grønning M, Hannisdal E, Mellgren SI. Multivariate analyses of factors associated with unemployment in people with multiple sclerosis. J Neurol Neurosurg Psych. 1990;53(5):388-90.
182 Gulick EE, Yam M, Touw MM. Work performance by persons with multiple sclerosis: conditions that impede or enable the performance of work. Internat J Nurs Stud. 1989;26(4):301-11.
183 Hammond SR, McLeod JG, Macaskill P, et al. Multiple sclerosis in Australia: socioeconomic factors. J Neurol Neurosurg Psych. 1996;61(3):311-3.
184 Jacobs LD, Wende KE, Brownscheidle CM, et al. A profile of multiple sclerosis: the New York State Multiple Sclerosis Consortium. Mult Scler. 1999;5(5):369-76. [pmid: 10516782].
185 Jongbloed L. Factors influencing employment status of women with multiple sclerosis. Can J Rehab 1996;9(213–22)
186 Kornblith AB, La Rocca NG, Baum HM. Employment in individuals with multiple sclerosis. Internat J Rehab Res. 1986;9(2):155-65.
187 LaRocca N, Kalb R, Kendall P, et al. The role of disease and demographic factors in the employment of patients with multiple sclerosis. Arch Neurol. 1982;39(4):256. [pmid: 7073539].
188 Miller DM, Rudick RA, Cutter G, et al. Clinical significance of the multiple sclerosis functional composite: relationship to patient-reported quality of life. Arch Neurol. 2000;57(9):1319-24. [pmid: 10987899].
189 Rao SM, Leo GJ, Ellington L, et al. Cognitive dysfunction in multiple sclerosis. II. Impact on employment and social functioning. Neurology. 1991;41(5):692-6. [pmid: 1823781].
190 Rozin R, Schiff Y, Cooper G, et al. Vocational rehabilitation of multiple sclerosis (MS) patients. I. Analysis of clinical and demographic factors. Internat Rehab Med. 1982;4(2):75-9.
191 Rozin R, Schiff Y, Kahana E, et al. Vocational status of multiple sclerosis patients in Israel. Arch Phys Med Rehab. 1975;56(7):300-4.
192 Scheinberg L, Holland N, Larocca N, et al. Multiple sclerosis; earning a living. NY State J Med. 1980;80(9):1395-400.
193 Verdier-Taillefer MH, Sazdovitch V, Borgel F, et al. Occupational environment as risk factor for unemployment in multiple sclerosis. Acta Neurol Scand. 1995;92(1):59-62. [pmid: 7572062].
194 Kurtzke JF. Rating neurologic impairment in multiple sclerosis: an expanded disability status scale (EDSS). Neurology. 1983;33(11):1444-52. [pmid: 6685237].
195 Richards RG, Sampson FC, Beard SM, et al. A review of the natural history and epidemiology of multiple sclerosis: implications for resource allocation and health economic models [review]. Health Technol Assess (Winchester, England). 2002;6(10):1-73.
196 Arnold DL, Bouchard JP, Boyle CAJ, et al. Key issues in the diagnosis and treatment of multiple sclerosis-an overview. Neurology. 2002;59(6):U2-S33.
197 Baker DG. Multiple sclerosis and thermoregulatory dysfunction. J Appl Physiol. 2002;92(5):1779-80. [pmid: 11960923].
198 Syndulko K, Jafari M, Woldanski A, et al. Effects of temperature in multiple sclerosis: a review of the literature. J Neurol Rehab. 1996;10:23-34.
199 Beenakker EA, Oparina TI, Hartgring A, et al. Cooling garment treatment in MS: clinical improvement and decrease in leukocyte NO production. Neurology. 2001;57(5):892-4. [pmid: 11552024].
200 Guthrie TC, Nelson DA. Influence of temperature changes on multiple sclerosis: critical review of mechanisms and research potential. [Review]. J Neurol Sci. 1995;129(1):1-8. [pmid: 7751837].
201 Robinson LR, Kraft GH, Fitts SS, et al. Body cooling may not improve somatosensory pathway function in multiple sclerosis. Am J Phys Med Rehab. 1997;76(3):191-6.
202 Capello E, Gardella M, Leandri M, et al. Lowering body temperature with a cooling suit as symptomatic treatment for thermosensitive multiple sclerosis patients. Ital J Neurol Sci. 1995;16(8):533-9. [pmid: 8613414].
203 Ku YT, Montgomery LD, Lee HC, et al. Physiologic and functional responses of MS patients to body cooling. Am J Phys Med Rehab. 2000;79(5):427-34.
204 Shakespeare DT, Young CA, Boggild M. Anti-spasticity agents for multiple sclerosis (Cochrane Review). In: The Cochrane Library, Issue 4, 2000. Oxford: Update Software.
205 Rammohan KW, Rosenberg JH, Lynn DJ, et al. Efficacy and safety of modafinil (Provigil) for the treatment of fatigue in multiple sclerosis: a two centre phase 2 study. J Neurol Neurosurg Psych. 2002;72(2):179-83.
206 Hill AB. The environment and disease: association or causation?. Proc R Soc Med. 2003;56(9):856-61.
207 Wald NJ, Hackshaw AK, Frost CD. When can a risk factor be used as a worthwhile screening test? [Review]. BMJ. 1999;319(7224):1562-5. [pmid: 10591726].
208 Rockhill B, Byrne C, Rosner B, et al. Breast cancer risk prediction with a log-incidence model: evaluation of accuracy. J Clin Epid. 2003;56(9):856-61.
209 Joy JE, Johnston RB. Multiple sclerosis: current status and strategies for the future. Washington, DC: National Academy Press, 2003.
210 National Multiple Sclerosis Society. About MS. Available at http:www.nationalmssociety.org/about. Accessed on October 16, 2003.
211 Hale TW, Hayghe HV, McNeil JM. Persons with disabilities: labor market activity, 1994. Monthly Lab Rev 1998;Sept:3–12
212 Smith K, Downs B, O'Connell M. Maternity leave and employment patterns: 1961-1995. Current Population Reports, pp 70–9, U.S. Census Bureau, Washington, DC., 2001. Curr Population Rep 2001;Nov:70–9
213 Cohen PN, Bianchi SM. Marriage, children, and women's employment: what do we know? Monthly Labor Rev 1999;Dec:22–31
214 Mitchell JN. Multiple sclerosis and the prospects for employment. J Soc Occup Med. 1981;31(4):134-8. [pmid: 6460132].
215 Berger JR, Sheremata WA. Persistent neurological deficit precipitated by hot bath test in multiple sclerosis. JAMA. 1983;249(13):1751-3. [pmid: 6600798].
216 Henke AF, Cohle SD, Cottingham SL. Fatal hyperthermia secondary to sunbathing in a patient with multiple sclerosis. Am J Forensic Med Pathol. 2000;21(3):204-6. [pmid: 10990275].
217 Kohlmeier RE, DiMaio VJ, Kagan-Hallet K. Fatal hyperthermia in hot baths in individuals with multiple sclerosis. Am J Forensic Med Pathol. 2000;21(3):201-3. [pmid: 10990274].
218 Lennie P, Van Hemel S. Introduction. In: Visual Impairments Determining Eligibility for Social Security Benefits. National Academy Press: Washington DC, 2002, pp. 31–4