# Evidence Tables

Evidence Tables Abbreviation Key

BB: beta-blockers

CA: calcium antagonists

CABG: coronary artery bypass graft

CAD: coronary artery disease

CNS: central nervous system

COPD: chronic obstructive pulmonary disease

Diff: difference

GI: gastrointestinal

MI: myocardial infarction

N: number

NI: nitrate

SD: standard deviation

Evidence Table 1. Study information: Beta-blockers vs. calcium antagonists

Study | Year | Primary institutions | Location of main Institutions | Funding source
Ahuja | 1993 | Dept. of Medicine, King George Medical College, Lucknow, India | Other | Other
Ardissino | 1995 | Division di Cardiologia, IRCCS, Policlinico San Matteo, Pavia, Italy | Europe | Industry
Ardissino | 1991 | Division of Cardiology, IRCCS Policlinico San Matteo, Pavia, Italy | Europe | No source given
Arnman | 1982 | Central Hospital, Skovde, Sweden | Europe | No source given
Bjerle | 1986 | Dept. of Clinical Physiology, Dept. of Cardiology, Umea Univ. Hospital, Umea, Sweden; Astra Syntex Scandinavia | Europe | No source given
Blake | 1991 | ICI Pharmaceuticals, Macclesfield, Cheshire, UK | United Kingdom | Industry
Bowles | 1981 | Northwick Park Hospital Clinical Research Centre, Harrow, Middlesex, England | United Kingdom | No source given
Bowles | 1983 | Dept. of Cardiology and Div. of Clinical Sciences, Northwick Park Hospital, Middlesex, England | United Kingdom | No source given
Brouwer | 1995 | Dept of Cardiology. Throaxcenter, Univ. Hospital Groningen; Cardiovascular Research Inst. COEUR, Dept. of Internal Medicine, Univ. Hospital DijkZigt, Rotterdam, The Netherlands | Europe | Industry
Catsipovic-Veselica | 1993 | Clinical Hospital Osijek, Osijek, Croatia | Europe | No source given
Cocco | 1979 | Dept. of Cardiology, General Medical and Therapeutic Clinic, Univ. of Ferrara Medical School, Ferrara, Italy; PHARMA Div, Dept. of Clinical Investigation and Development, F. Hoffmann-LaRoche, Basle, Switzerland | Europe | No source given
Crake | 1988 | National Heart Hospital, London, UK | United Kingdom | Industry
Dargie | 1996 | Univ. of Glasgow, UK Royal Brompton Hospital, London | United Kingdom | Industry
De Devitiis | 1987 | Univ. of Naples | Europe | No source given
de Vries | 1996 | Univ. Hospital Groningen, The Netherlands, Dept. of Cardiology/Thoraxcenter | Europe | Industry
Destors | 1989 | Unite de Pharmacologie Clinique, Hospital Neuro-Cardiologique, France | Europe | No source given
Di Somma | 1996 | Universita degli Studi "Frederico II," Napoli | Europe | No source given
Egstrup | 1993 | Dept. of Cardiology and Diagnostic Radiology, Univ. Hospital, Odense, Denmark | Europe | No source given
Egstrup | 1988 | Odense Univ. Hospital, Odense, Denmark | Europe | No source given
Findlay | 1986 | Western Infirmary, Glasgow | United Kingdom | No source given
Findlay | 1983 | Western Infirmary, Glasgow | United Kingdom | No source given
Findlay | 1987 | Western Infirmary | United Kingdom | No source given
Frishman | 1992 | Albert Einstein College of Medicine, NY | North America | No source given
Frishman | 1982 | Albert Einstein College of Medicine, NY | North America | Foundations
Hauf-Zachariou | 1997 | Univ. of Hauf-Zachariou Mannheim, Germany | Europe | No source given
Hetzel | 1994 | Univ. of Ulm | Europe | No source given
Higginbotham | 1989 | Duke Univ. Medical Center, Durham, NC | North America | Government
Hill | 1991 | Univ. of Florida, Gainesville, FL | North America | Industry
Hopkinson | 1991 | Dept. of Cardiology, George Eliot Hospital, Nuneaton, Warwickshire, UK | United Kingdom | Industry
Humen | 1991 | Univ. of Alberta, Edmonton Alberta | North America | Industry, Foundations
Hung | 1983 | Stanford Univ. | North America | Industry
Johnson | 1981 | Dept. of Internal Medicine, Cardiovascular Div. and Div. of Nuclear Medicine, Univ. of Texas Health Science Center & Parkland Memorial Hospital, Dallas, TX | North America | Other
Johnston | 1983 | Cardiac Investigation Unit, Univ. Hospital and the Dept. of Medicine, Univ. of Western Ontario, London, Ontario | North America | Other
Johnston | 1984 | Cardiac Investigation Unit, Univ. Hospital and Dept. of Medicine, Western Ontario | North America | No source given
Kawanishi | 1992 | Div. of Cardiology, Dept. of Medicine, Univ. of Southern California Medical Center, LA County and Univ. of Southern California Medical Center, Los Angeles, CA | North America | No source given
Kenmure | 1979 | Aberdeen Royal Infirmary, Scotland | United Kingdom | No source given
Kenny | 1985 | Kings College Hospital, London | United Kingdom | No source given
Khurmi | 1987 | Northwick Park Hospital, Harrow, Middlesex, UK | United Kingdom | No source given
Lai | 1992 | Univ. of Cagliari, Cagliari, Italy | Europe | No source given
Lai | 1988 | Institute of Cardiology, Univ. of Cagliari, Cagliari, Italy | Europe | No source given
Lessem | 1984 | Varnhem Hospital Heart Section, Malmo, Sweden | Europe | Industry
Livesley | 1973 | King's College Hospital, London | United Kingdom | No source given
Logan | 1986 | Hutt Hospital, Wellington Clinical School | Australia/New Zealand | No source given
Lynch | 1980 | Div. of Cardiovascular Disease, Royal Postgraduate Medical School, Hammersmith Hospital, London | United Kingdom | Foundations
McGill | 1986 | Dept. of Cardiovascular Medicine, Prince Henry Hospital, Sydney Australia | Australia/New Zealand | No source given
Meyer | 1991 | Heart Institute, Carmel Hospital, Univ. of Haifa, Israel | Other | No source given
Miller | 1988 | Univ. of Texas Health Science Center and VA Hospital, San Antonio, TX | North America | Government
Nadazin | 1994 | Cardiology Div., Dept. of Medicine, Royal Postgraduate Medical School Hammersmith Hospital, London | United Kingdom | No source given
O'Hara | 1984 | Dept. of Cardiology/Div. of Clinical Sciences Northwick Park Hospital and Clinical Research Centre, Harrow, Middlesex, England | United Kingdom | No source given
Parmeshwar | 1993 | Royal Brompton and National Heart Hospital, London | United Kingdom | No source given
Parker | 1986 | Queen's Univ., Kingston, Ontario | North America | No source given
Pflugfelder | 1987 | Dept. of Medicine, Div. of Cardiology, Univ. Hospital, Univ. of Western Ontario, London, Ontario, Canada | North America | Other
Rae | 1985 | Univ. Dept. of Medical Cardiology, Royal Infirmary, Glasgow, UK | United Kingdom | No source given
Southall | 1982 | Royal United Hospital, Bath, England | United Kingdom | Industry
Steffensen | 1993 | Dept. of Medicine, Div. of Cardiology, Univ. of Copenhagen, Denmark | Europe | Other
van der Does | 1992 | IST Institute, Manheim, Germany | Europe | Industry
van Dijk | 1988 | Univ. Hospital, Groningen, Netherlands | Europe | No source given
Vliegen | 1991 | Univ. Hospital Leiden, Leiden | Europe | No source given
Von Arnim | 1995 | Univ. of Munich, Red Cross Hospital, Munich, Germany | Other | Industry
Wallace | 1994 | Cardiology Unit, Depts. of Medicine and Radiology, Univ. of Rochester, Rochester, NY | North America | Industry
Wheatley | 1985 | General Practioner Research Group, Surrey, UK | United Kingdom | No source given
Wieshammer | 1991 | Mednische Klilnik und Poliklinik Universitat Ulm | Europe | No source given

Evidence Table 2. Study information: Nitrates vs. calcium antagonists

Study | Year | Primary institutions | Location of main Institutions | Funding source
Akhras | 1989 | Div. of Cardiology, Lewisham Hospital, St. Thomas St, London, UK | United Kingdom | No source given
Ankier | 1989 | Charterhouse Clinical Research Unit Ltd, Boundary House, London, UK | United Kingdom | Industry
Carboni | 1992 | Ospedale S Camillo, Roma, Italy | Europe | No source given
Connelly | 1995 | Hebrew Rehabilitation Center for the Aged and Beth Israel Hospital, Boston, MA | N. America | Industry and government
de Vries | 1994 | Dept. of Cardiology, Ignatius Hospital Breda, The Netherlands | Europe | Other
Eldridge | 1987 | Div. of Cardiology, Dept. of Nuclear Medicine, Dept. of Preventive Medicine and Biometrics, Univ. of Colorado | North America | Government
Emanuelsson | 1989 | Div. of Cardiology, Dept. of Medicine, Sahlgrenska Hospital, Univ. of Goteborg; Dept. of Clinical Research, AB Ferrosan, Univ. of Malmo, Sweden | Europe | Other
Friedensohn | 1991 | Heart Institute, Assaf Harofeh Medical Center, Zerifin, Tel-Aviv Univ., Tel-Aviv, Israel | Other | No source given
Liang | 1985 | Cardiology Research Labs. and the Cardiology Unit, Univ. of Rochester Medical Center, Rochester, NY | North America | Industry
Schneider | 1988 | Univ. Hospital, Frankfort FRG | Europe | No source given
Steffensen | 1997 | National Univ. Hospital, Rigshospitagt, Copenhagen, Hridorie Univ. Hospital Hridorie, Herler, Odense Univ. Hosp. Odense, Denmark | Europe | No source given
Von Arnim | 1988 | Ludwig-Maximillians Universitat, Munich, Germany, Medizinische Klinik, Groshadern | Europe | No source given

Evidence Table 3. Study information: Beta-blockers vs. nitrates

Study | Year | Primary institutions | Location of main Institutions | Funding source
Aubert | 1970 | Gjovik Hospital, Norway; AB Hassle Subsidiary of AB Astra Sweden, Gothenburg, Sweden | Europe | Industry
Binak | 1974 | Univ. of Istanbul, Turkey | Other | No source given
Goldbarg | 1969 | Univ. of Chicago, Chicago, IL | North America | Government
Krepp | 1991 | Stadtisches Krankenhause, Bobingen, FRG | Europe | No source given
van de Ven | 1995 | Dept. of Cardiology, Oostersingel 59, Netherlands | Europe | No source given
Waysbort | 1991 | Institute of Physiological Hygiene, Tel Aviv Univ., Dept. of Medicine, A. Edith Wolfson Hospital, Holon, Israel | Other | No source given

Evidence Table 4. Trial inclusion criteria: Beta-blockers vs. calcium antagonists

Study | Year | Evidence of CAD | Positive exercise test | Positive angiogram
Ahuja | 1993 | ✓ | ✓
Ardissino | 1995 | ✓ | ✓
Ardissiono | 1991 | ✓ | ✓
Arnman | 1982 | ✓ | ✓
Bjerle | 1986 | ✓ | ✓
Blake | 1991 | ✓ | ✓ | ✓
Bowles | 1981
Bowles | 1983 | ✓ | ✓ | ✓
Brouwer | 1995 | ✓ | ✓ | ✓
Catsipovic-Veselica | 1993
Cocco | 1979
Crake | 1988 | ✓ | ✓
Dargie | 1996 | ✓ | ✓
De Devitiis | 1987 | ✓ | ✓
de Vries | 1996 | ✓ | ✓
Destors | 1989 | ✓ | ✓ | ✓
Di Somma | 1996 | ✓ | ✓ | ✓
Egstrup | 1993
Egstrup | 1988 | ✓ | | ✓
Findlay | 1986
Findlay | 1983 | ✓ | ✓
Findlay | 1987 | ✓ | ✓
Frishman | 1992
Frishman | 1982 | ✓ | ✓ | ✓
Hauf-Zachariou | 1997 | ✓ | ✓
Hetzel | 1994 | ✓ | ✓ | ✓
Higginbotham | 1989 | ✓ | ✓
Hill | 1991 | ✓ | ✓ | ✓
Hopkinson | 1991 | ✓ | ✓
Humen | 1991 | ✓ | ✓
Hung | 1983 | ✓ | ✓
Johnson | 1981 | ✓
Johnston | 1983 | ✓ | ✓
Johnston | 1984 | ✓ | ✓
Kawanishi | 1992 | ✓ | ✓ | ✓
Kenmure | 1979
Kenny | 1985 | ✓ | ✓
Khurmi | 1987 | ✓ | ✓
Lai | 1992 | ✓ | ✓
Lai | 1988 | ✓ | ✓ | ✓
Lessem | 1984
Livesley | 1973 | ✓
Logan | 1986 | ✓ | ✓
Lynch | 1980 | ✓ | ✓
McGill | 1986 | ✓ | ✓
Meyer | 1991 | ✓ | ✓
Miller | 1988 | ✓ | ✓ | ✓
Nadazin | 1994 | ✓ | ✓ | ✓
O'Hara | 1984 | ✓ | ✓
Parameshwar | 1993 | ✓ | ✓
Parker | 1986 | ✓ | ✓
Pflugfelder | 1987 | ✓ | ✓ | ✓
Rae | 1985 | ✓ | ✓ | ✓
Rehnqvist | 1996 | ✓ | ✓
Riley | 1992 | ✓ | ✓
Romano | 1986 | ✓ | | ✓
Romano | 1988 | ✓ | | ✓
Rousseau | 1986 | ✓ | | ✓
Sadick | 1982 | ✓ | ✓
Savonitto | 1996 | ✓ | ✓
Shapiro | 1989 | ✓
Sigurd | 1984 | ✓ | ✓
Singh | 1993 | ✓ | ✓
Southall | 1982
Steffensen | 1993 | ✓ | ✓ | ✓
van der Does | 1992 | ✓ | ✓
van Dijk | 1988 | ✓ | ✓
Vliegen | 1991 | ✓ | ✓ | ✓
von Arnim | 1995 | ✓ | ✓
Wallace | 1994 | ✓ | ✓ | ✓
Wheatley | 1985 | ✓ | ✓
Weishammer | 1991 | ✓ | ✓ | ✓

Evidence Table 5. Trial inclusion criteria: Nitrates vs. calcium antagonists

Study | Year | Evidence of CAD | Positive exercise test | Positive angiogram
Akras | 1989 | ✓ | ✓ | ✓
Ankier | 1989
Carboni | 1992 | ✓ | ✓ | ✓
Connelly | 1995 | ✓
de Vries | 1994 | ✓ | ✓
Eldridge | 1987 | ✓ | ✓ | ✓
Emanuelsson | 1989 | ✓ | ✓
Friedensohn | 1991 | ✓ | ✓ | ✓
Liang | 1985 | ✓ | ✓ | ✓
Schneider | 1988 | ✓ | ✓
Sreffensen | 1997 | ✓ | ✓
von Arnim | 1988 | ✓ | | ✓

Evidence Table 6. Trial inclusion criteria: Beta-blockers vs. nitrates

Study | Year | Evidence of CAD | Positive exercise test | Positive angiogram
Aubert | 1970
Binak | 1974 | ✓ | ✓
Goldbarg | 1969 | ✓ | ✓
Krepp | 1991
van de Ven | 1995 | ✓ | ✓
Waysbort | 1991 | ✓ | ✓

Evidence Table 7. Trial exclusion criteria: Beta-blockers vs. calcium antagonists

Study | Year | Sex | Congestive heart failure | Supra-ventricular arrhythmia | Ventricular arrhythmia | Heart block/bradycardia | Recent MI | Post-revascularization | Disease with poor prognosis | COPD | Diabetes | Claudication
Ahuja | 1993
Ardissino | 1995 | | ✓ | | | | ✓ | | | ✓
Ardissino | 1991 | | ✓ | ✓ | | ✓ | ✓
Arnman | 1982
Bjerle | 1986 | | ✓
Blake | 1991 | | ✓ | ✓ | ✓ | ✓ | ✓ | | | ✓
Bowles | 1981
Bowles | 1983 | | ✓ | | | | ✓ | | ✓ | ✓
Brouwer | 1995 | | ✓ | ✓ | | ✓ | ✓
Catsipovic-Veselica | 1993 | | ✓ | | | ✓ | ✓ | ✓ | | ✓
Cocco | 1979
Crake | 1988
Dargie | 1996
De Devitiis | 1987 | | ✓ | | | ✓ | ✓ | | | ✓ | ✓
de Vries | 1996 | ✓ | | | | | ✓ | ✓
Destors | 1989
Di Somma | 1996 | | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓
Egstrup | 1993 | | ✓ | | | | ✓
Egstrup | 1988 | | ✓ | | | ✓ | ✓
Findlay | 1986 | | ✓ | | | ✓ | ✓ | | | ✓
Findlay | 1983
Findlay | 1987 | | ✓ | | | ✓ | ✓ | | | ✓
Frishman | 1992
Frishman | 1982
Hauf-Zachariou | 1997
Hetzel | 1994 | | | | | | ✓
Higginbotham | 1989
Hill | 1991 | | ✓ | | | | ✓
Hopkinson | 1991 | | ✓ | ✓ | ✓ | ✓ | ✓ | ✓ | | | | ✓
Humen | 1991 | | ✓
Hung | 1983 | | ✓ | | | | ✓ | | | ✓ | | ✓
Johnson | 1981 | | ✓ | | | ✓ | | | ✓ | | ✓
Johnston | 1983 | | ✓
Johnston | 1984
Kawanishi | 1992 | | | | | ✓ | ✓ | ✓ | | ✓ | ✓
Kenmure | 1979
Kenny | 1985 | | | | | ✓ | | | | ✓
Khurmi | 1987
Lai | 1992 | | ✓ | | | ✓ | ✓ | | | | ✓
Lai | 1988 | | ✓ | | | | | | | | ✓
Lessem | 1984
Livesley | 1973 | | ✓ | | | | ✓ | | | ✓ | ✓
Logan | 1986 | | | | | | | | | ✓
Lynch | 1980 | | ✓ | | | | ✓ | | | ✓
McGill | 1986 | | ✓ | | | ✓ | ✓ | | ✓ | | ✓
Meyer | 1991 | | | | | | ✓
Miller | 1988
Nadazin | 1994 | | ✓ | | | ✓ | ✓
O'Hara | 1984
Parameshwar | 1993
Parker | 1986
Pflugfelder | 1987 | | ✓ | | | ✓ | ✓
Rae | 1985 | | | | | | ✓
Rehnqvist | 1996 | | ✓ | | | | ✓ | ✓
Riley | 1992 | | | | | | | | | | | ✓
Romano | 1986 | | ✓ | | | ✓ | | | | ✓
Romano | 1988 | | ✓ | ✓ | | ✓ | | | | ✓
Rousseau | 1986
Sadick | 1982 | | ✓ | | | | | | | ✓ | ✓
Savonitto | 1996 | | ✓ | | | | ✓ | | ✓
Shapiro | 1989
Sigurd | 1984 | | | | | | | | | ✓ | ✓ | ✓
Singh | 1993 | | | | | | | | | ✓
Southall | 1982
Steffensen | 1993 | | ✓ | ✓ | | ✓ | | | ✓
van der Does | 1992 | | ✓ | | | | ✓ | | | ✓
van Dijk | 1988 | | ✓ | | ✓ | ✓ | ✓
Vliegen | 1991 | | ✓ | | | ✓ | ✓ | ✓ | ✓
von Arnim | 1995 | | | | | ✓ | ✓
Wallace | 1994 | | ✓ | | | | ✓ | ✓ | ✓
Wheatley | 1985 | | | ✓ | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | ✓
Wieshammer | 1991 | | | | | | ✓ | | | ✓

Evidence Table 8. Trial exclusion criteria: Nitrates vs. calcium antagonists

Study | Year | Sex | CHF | SVA | VA | Heart block/bradycardia | Recent MI | Post revascularization | Disease with poor prognosis | COPD | Diabetes | Claudication
Akhras | 1989 | | ✓ | | | ✓ | ✓ | | | | ✓
Ankier | 1989 | | ✓ | | | ✓ | ✓ | ✓ | ✓ | | ✓
Carboni | 1992
Connelly | 1995
de Vries | 1994 | | ✓ | | | ✓ | ✓ | ✓ | ✓ | ✓ | ✓
Eldridge | 1987
Emanuelsson | 1989 | | | | | ✓ | ✓ | | ✓
Friedensohn | 1991 | | ✓ | | | ✓
Liang | 1985 | | ✓ | ✓ | ✓ | | ✓ | | ✓
Schneider | 1988 | | ✓ | | | ✓
Steffensen | 1997 | | ✓ | ✓ | | ✓ | ✓ | | ✓
von Arnim | 1988

Evidence Table 9. Trial exclusion criteria: Beta-blockers vs. nitrates

Study | Year | Sex | CHF | SVA | VA | Heart block/bradycardia | Recent MI | Post revascularization | Disease with poor prognosis | COPD | Diabetes | Claudication
Aubert | 1970
Binak | 1974
Goldbarg | 1969 | | ✓ | | | | | | | ✓
Krepp | 1991
van de Ven | 1995 | | | | | | ✓
Waysbort | 1991

Evidence Table 10. Study information: Patient characteristics: Beta-blockers vs. calcium antagonists

Study | Year | Age mean/midpoint | Percent Male | Percent post-MI | Percent diabetes | Percent CABG
Ahuja | 1993 | 56 | 94 | 8 | 14
Ardissino | 1995 | 59 | 82 | 48 | 5
Ardissino | 1991 | 57 | 82 | 34 | 4
Arnman | 1982 | 55 | 79 | 29 | | 13
Bjerle | 1986 | 58 | 78 | 67
Blake | 1991 | 62 | 63
Bowles | 1981 | 55
Bowles | 1983 | 55 | 80
Brouwer | 1995 | 54 | 71 | 29
Catsipovic-Veselica | 1993 | 55 | | 31
Cocco | 1979 | 54 | 80
Crake | 1988 | 52 | 8 | 2
Dargie | 1996 | 59 | 86 | 33 | | 5
De Devitiis | 1987 | 54 | 81 | | 63 | 0
de Vries | 1996 | 62 | 100 | 35
Destors | 1989 | 56 | 66 | 34
Di Somma | 1996 | 57 | 60 | 25 | 25
Egstrup | 1993 | 55 | | 73
Egstrup | 1988 | 56 | | 62
Findlay | 1986 | 56 | 100 | 50
Findlay | 1983 | 56 | 100
Findlay | 1987 | 57 | 73 | 36
Frishman | 1992 | 59 | 94
Frishman | 1982 | 57 | 92 | 25
Hauf-Zachariou | 1997 | 60 | 78 | 68
Hetzel | 1994 | 58
Higginbotham | 1989 | 55 | 100
Hill | 1991 | 63 | 100 | | 33
Hopkinson | 1991 | 55 | 90
Humen | 1991 | 59 | 92 | 29 | 0
Hung | 1983 | 61 | 92 | 0 | 50 | 0
Johnson | 1981 | 58 | 88 | 44 | 0
Johnston | 1983 | 57 | 95 | 30 | | 10
Johnston | 1984 | 51 | 100
Kawanishi | 1992 | 54 | 66 | 62 | 0 | 14
Kenmure | 1979 | 55 | | 43
Kenny | 1985 | 57 | 100 | 27
Khurmi | 1987 | 61 | 79
Lai | 1992 | 61 | 100
Lai | 1988 | 59 | 100 | | 0
Lessem | 1984 | 58 | | 67
Livesley | 1973 | 52 | 78 | | 0
Logan | 1986 | 58 | 93 | 20
Lynch | 1980 | 58 | 88 | 94
McGill | 1986 | 61 | 92 | | 0
Meyer | 1991 | 59 | 77 | 13 | 13
Miller | 1988 | 61 | 94
Nadazin | 1994 | 62 | 87 | 13
O'Hara | 1984 | | 86
Parameshwar | 1993 | 61 | 97 | 23 | | 70
Parker | 1986 | 59 | 100
Pflugfelder | 1987 | 58 | 92
Rae | 1985 | 52 | 91 | 41
Rehnqvist | 1996 | 59 | 70 | 4 | 2 | 1
Riley | 1992 | 55 | 50 | 36
Romano | 1988 | 52 | 80 | 0
Romano | 1986 | 53 | 69 | 0
Rousseau | 1986 | 55 | 94
Sadick | 1982 | 54 | 94 | | 0
Savonitto | 1996 | 59 | 82 | 9 | 5
Shapiro | 1989 | 58 | 85 | 41
Sigurd | 1984
Singh | 1993 | 63 | 89
Southall | 1982 | 55 | 100 | 58
Steffensen | 1993 | 50 | 92
van der Does | 1992 | 57 | 57
van Dijk | 1988 | 59 | 100 | 27
Vliegen | 1991 | 61
von Arnim | 1995 | 57 | 85 | 29
Wallace | 1994 | 54 | 88 | 71
Wheatley | 1985 | 57 | 67 | | 0
Wieshammer | 1991 | 58 | 89

Evidence Table 11. Patient characteristics: Nitrates vs. calcium antagonists

Study | Year | Age mean/midpoint | Percent Male | Percent post-MI | Percent diabetes | Percent CABG
Akhras | 1989 | 60 | 89 | 56 | 0
Ankier | 1989 | 59 | 65 | | 0
Carboni | 1992 | 54 | 80 | 60
Connelly | 1995 | 76 | 65 | 41
de Vries | 1994 | 72 | 70 | 16 | 0
Eldridge | 1987 | 59 | 73 | 60 | | 7
Emanuelsson | 1989 | 63 | 84 | 38
Friedensohn | 1991 | 59 | 97
Liang | 1985 | 57 | 70 | 50 | 7
Schneider | 1988 | 58 | 100 | 43
Steffensen | 1997 | 61 | 71 | 51
von Arnim | 1988 | 62 | 65

Evidence Table 12. Patient characteristics: Beta-blockers vs. nitrates

Study | Year | Age mean/midpoint | Percent Male | Percent post-MI | Percent diabetes | Percent CABG
Aubert | 1970 | 56 | 90 | 52
Binak | 1974 | 57 | 87 | 47
Goldbarg | 1969 | 55 | 90 | 29 | 24
Krepp | 1991 | 58 | 60
van de Ven | 1995 | 61 | 74 | 30
Waysbort | 1991

Evidence Table 13. Study interventions: Beta-blockers vs. calcium antagonists

Study | Year | Therapy 1 | | | Therapy 2
Study | Year | Drug name | mg | Dose | Drugname | mg | Dose
Ahuja | 1993 | Metoprolol | 50 | 2x/day | Diltiazem | 60 | 3x/day
Ardissino | 1995 | Metoprolol | 200 | 1x/day | Nifedipine | 20 | 2x/day
Ardissino | 1991 | Metoprolol | 200 | 1x/day | Nifedipine | 20 | 2x/day
Arnman | 1982 | Metoprolol | 100 | 2x/day | Verapamil | 120 | 3x/day
Bjerle | 1986 | Nicardipine | 30 | 3x/day | Propranolol | 40 | 3x/day
Blake | 1991 | Epanolol | 200 | 1x/day | Nifedipine | 20 | 2x/day
Bowles | 1981 | Propranolol | 80 | 3x/day | Verapamil | 120 | 3x/day
Bowles | 1983 | Propranolol | 240 | 3x/day | Verapamil | 360 | 3x/day
Brouwer | 1995 | Metoprolol | 200 | 1x/day | Diltiazem | 60 | 4x/day
Catsipovic-Veselica | 1993 | Diltiazem | 180 | 3x/day | Penbutolol | 40 | 1x/day
Cocco | 1979 | Pindolol | 20 | 3x/day | Nifedipine | 20 | 3x/day
Crake | 1988 | Labetalol | 200 | 2x/day | Nifedipine | 10 | 3x/day
Dargie | 1996 | Atenolol | 50 | 2x/day | Nifedipine | 20 | 2x /day
De Devitiis | 1987 | Bisoprolol | 10 | 1x/day | Verapamil | 80 | 3x/day
de Vries | 1996 | Nifedipine | 30 | 1x/day | Atenolol | 50 | 1x/day
Destors | 1989 | Bepridil | 100 | 1x/day | Propranolol | 60 | 3x/day
Di Somma | 1996 | Metoprolol | 200 | 1x/day | Nifedipine | 20 | 2x/day
Egstrup | 1993 | Nifedipine | 10 | 3x/day | Metoprolol | 50 | 2x/day
Egstrup | 1988 | Metoprolol | 50 | 2x/day | Nifedipine | 10 | 3x/day
Findlay | 1986 | Nifedipine | 20 | 3x/day | Atenolol | 100 | 1x/day
Findlay | 1983 | Atenolol | 100 | 1x/day | Nifedipine | 20 | 3x/day
Findlay | 1987 | Verapamil | 120 | 3x/day | Atenolol | 100 | 1x/day
Frishman | 1992 | Bepridil | 200 | 1x/day | Propranolol | 20 | 4x/day
Frishman | 1982 | Verapamil | 80 | 4x/day | Propranolol | 20 | 4x/day
Hauf-Zachariou | 1997 | Carvedilol | 25 | 2x/day | Verapamil | 120 | 3x/day
Hetzel | 1994 | Nifedipine | 20 | 2x/day | Atenolol | 50 | 2x/day
Higginbotham | 1989 | Nifedipine | 10 | 3x/day | Propranolol | 80 | 3x/day
Hill | 1991 | Atenolol | 100 | 1x/day | Nifedipine | 20 | 3x/day
Hopkinson | 1991 | Verapamil | 360 | 1x/day | Atenolol | 100 | 1x/day
Humen | 1991 | Diltiazem | 120 | 3x/day | Propranolol | 80 | 3x/day
Hung | 1983 | Diltiazem | 30 | 4x/day | Propranolol | 20 | 4x/day
Johnson | 1981 | Propranolol | 40 | 4x/day | Verapamil | 80 | 4x/day
Johnston | 1983 | Propranolol | 40 | 4x/day | Verapamil | 120 | 3x/day
Johnston | 1984 | Propranolol | 40 | 4x/day | Verapamil | 5 | 2x/day
Kawanishi | 1992 | Nifedipine | 10 | 4x/day | Propranolol | 20 | 4x/day
Kenmure | 1979 | Propranolol | 80 | 3x/day | Nifedipine | 10 | 3x/day
Kenny | 1985 | Diltiazem | 60 | 3x/day | Propranolol | 80 | 3x/day
Khurmi | 1987 | Propranolol | 80 | 3x/day | Diltiazem | 60 | 3x/day
Lai | 1992 | Felodipine | 10 | 1x/day | Metoprolol | 200 | 1x/day
Lai | 1988 | Atenolol | 100 | 1x/day | Nifedipine | 10 | 3x/day
Lessem | 1984 | Atenolol | 200 | 1x/day | Verapamil | 120 | 3x/day
Livesley | 1973 | Propranolol | 100 | 3x/day | Verapamil | 80 | 3x/day
Logan | 1986 | Nicardipine | 30 | 3x/day | Atenolol | 100 | 1x/day
Lynch | 1980 | Nifedipine | 20 | 3x/day | Propranolol | 160 | 3x/day
McGill | 1986 | Propranolol | 40 | 3x/day | Nicardipine | 30 | 3x/day
Meyer | 1991 | Diltiazem | 30 | 4x/day | Bopindolol | 1 | 1x/day
Miller | 1988 | Diltiazem | 60 | 4x/day | Nadolol | 160 | 1x/day
Nadazin | 1994 | Atenolol | 50 | 2x/day | Diltiazem | 120 | 3x/day
O'Hara | 1984 | Propranolol | 80 | 3x/day | Diltiazem | 120 | 3x/day
Parameshwar | 1993 | Nicardipine | 20 | 3x/day | Atenolol | 50 | 1x/day
Parker | 1986 | Bepridil | 300 | 1x/day | Propranolol | 160 | 1x/day
Pflugfelder | 1987 | Bepridil | 200 | 1x/day | Nadolol | 120 | 1x/day
Rae | 1985 | Bepridil | 100 | 2x/day | Propranolol | 80 | 2x/day
Rehnqvist | 1996 | Metoprolol | 200 | 1x/day | Verapamil | 240 | 2x/day
Riley | 1992 | Diltiazem | 60 | 3x/day | Epanolol | 200 | 1x/day
Romano | 1986 | Propranolol | 40 | 3x/day | Diltiazem | 60 | 3x/day
Romano | 1988 | Nifedipine | 10 | 3x/day | Atenolol | 100 | 1x/day
Rousseau | 1986 | Nicardipine | 30 | 2x/day | Propranolol | 40 | 2x/day
Sadick | 1982 | Propranolol | 80 | 4x/day | Verapamil | 80 | 4x/day
Savonitto | 1996 | Metoprolol | 200 | 1x/day | Nifedipine | 20 | 3x/day
Shapiro | 1989 | Atenolol | 50 | 1x/day | Nifedipine | 10 | 3x/day
Sigurd | 1984 | Propranolol | 60 | 3x/day | Verapamil | 120 | 3x/day
Singh | 1993 | Amlodipine | 2.5 | 1x/day | Nadolol | 40 | 1x/day
Southall | 1982 | Verapamil | 120 | 3x/day | Propranolol | 160 | 2x/day
Steffensen | 1993 | Atenolol | 100 | 1x/day | Diltiazem | 120 | 2x/day
van der Does | 1992 | Carvedilol | 25 | 2x/day | Nifedipine | 20 | 2x/day
van Dijk | 1988 | Metoprolol | 100 | 2x/day | Diltiazem | 60 | 4x/day
Vliegen | 1991 | Diltiazem | 120 | 2x/day | Metoprolol | 100 | 2x/day
von Arnim | 1995 | Bisoprolol | 10 | 1x/day | Nifedipine | 20 | 2x/day
Wallace | 1994 | Nifedipine | 30 | 1x/day | Atenolol | 50 | 1x/day
Wheatley | 1985 | Diltiazem | 60 | 3x/day | Atenolol | 100 | 1x/day
Wieshammer | 1991 | Atenolol | 50 | 2x/day | Nifedipine | 20 | 2x/day

Evidence Table 14. Study interventions: Nitrates vs. calcium antagonists

Study | Year | Therapy 1 | | Therapy 2
Study | Year | Drug name | Dose | Drug name | Dose
Akhras | 1989 | Isosorbide mononitrate | 20 mg 2x/day | Nifedipine | 40 mg 2x/day
Ankier | 1989 | Isosorbide mononitrate | 20 mg 3x/day | Nifedipine | 20 mg 3x/day
Carboni | 1992 | Gallapomil | 50 mg 3x/day | Isosorbide mononitrate | 20 mg 3x/day
Connelly | 1995 | Isosorbide dinitrate | 20 mg 3x/day | Nicardipine | 20 mg 3x/day
deVries | 1994 | Felodipine | 5 mg 1x/day | Isosorbide mononitrate | 10 mg 2x/day
Eldridge | 1987 | NTG Patch | 10cm 1x/day | Nifedipine | 10 mg 3x/day
Emanuelsson | 1989 | Diltiazem | 120 mg 2x/day | Isosorbide mononitrate | 20 mg 2x/day
Friedensohn | 1991 | Isosorbide dinitrate | 120 mg 1x/day | Verapamil | 120 mg 1x/day
Liang | 1985 | Nifedipine | 10 mg 4x/day | Isosorbide dinitrate | 10 mg 4x/day
Schneider | 1988 | Isosorbide dinitrate | 40 mg 3x/day | Verapamil | 120 mg 3x/day
Steffensen | 1997 | Amlodipine | 5 mg 1x/day | Isosorbide dinitrate | 40 mg 2x/day
von Arnim | 1988 | Nifedipine | 20 mg 3x/day | Isosorbide mononitrate | 20 mg 3x/day

Evidence Table 15. Study interventions: Beta-blockers vs. nitrates

Study | Year | Therapy 1 | | Therapy 2
Study | Year | Drug name | Dose | Drug name | Dose
Aubert | 1970 | Aprenolol | 50mg 4x/day | Pentanitrol | 15mg 4x/day
Binak | 1974 | LB46 | 4mg 4x/day | Isosorbide dinitrate | 5mg 4x/day
Goldbarg | 1969 | Isosorbide dinitrate | 10mg 4x/day | Propranolol | 40mg 4x/day
Krepp | 1991 | Isosorbide mononitrate | 50mg 1x/day | Bupranolol | 100mg 1x/day
van de Ven | 1995 | Bisoprolol | 10mg 1x/day | Isosorbide dinitrate | 20mg 3x/day
Waysbort | 1991 | Isosorbide mononitrate | 40mg 2x/day | Atenolol | 100mg 1x/day

Evidence Table 16. Crossover trial execution description: Beta-blockers vs. calcium antagonists

Study | Year | Run-in period | Run-in period | | | Run-in period (weeks) | Treatment period (weeks)
Study | Year | Run-in period | Drug Used | No Drug | Placebo | Run-in period (weeks) | Treatment period (weeks)
Bjerle | 1986 | ✓ | | | ✓ | 2 | 4
Blake | 1991 | | | | | | 4
Bowles | 1983 | ✓ | | | ✓ | 2 | 4
Brouwer | 1995 | ✓ | | | ✓ | 2 | 3
Crake | 1988 | ✓ | Nitroglycerin PRN | | | 1 | 4
de Vries | 1996 | ✓ | | | ✓ | 1 | 4
Di Somma | 1996 | ✓ | | | ✓ | 2 | 4
Findlay | 1983 | ✓ | | | ✓ | 2 | 3
Findlay | 1986 | | | ✓ | ✓ | 2 | 3
Frishman | 1982 | | | | | | 3
Hetzel | 1994 | ✓ | | ✓ | | 0.5 | 2
Higginbotham | 1989 | ✓ | | ✓ | | 2 | 5
Hill | 1991 | ✓ | Nitroglycerin PRN | | | 2 | 2
Hopkinson | 1991 | ✓ | | | ✓ | 2 | 4
Humen | 1991 | ✓ | | | ✓ | | 3
Hung | 1983 | | | | | | 2
Johnson | 1981 | ✓ | | ✓ | | 2 | 2
Johnston | 1983 | ✓ | | ✓ | | 2 | 4
Johnston | 1984 | | | | | | 6
Kawanishi | 1992 | ✓ | Nitroglycerin PRN | | | 2 | 3
Kenmure | 1979 | ✓ | | | | 2 | 2
Kenny | 1985 | ✓ | | ✓ | | 1 | 4
Khurmi | 1987 | ✓ | | | ✓ | 2 | 4
Lai | 1988 | ✓ | | ✓ | | 2 | 4
Lai | 1992 | ✓ | | | ✓ | 2 | 1
Lessem | 1984 | ✓ | | | | 2 | 6
Lynch | 1980 | ✓ | | ✓ | | 2 | 4
McGill | 1986 | ✓ | | | ✓ | 2 | 4
Miller | 1988 | | | | | | 3
Nadazin | 1994 | ✓ | Long-acting nitrates | | | 1 | 3
O'Hara | 1984 | ✓ | | | ✓ | 2 | 4
Parameshwar | 1993 | ✓ | | ✓ | | >1 | 6
Pflugfelder | 1987 | ✓ | | ✓ | | 2 | 4
Riley | 1992 | ✓ | | ✓ | | 2 | 4
Romano | 1986 | | | ✓ | | 1.5 | 8
Romano | 1988 | ✓ | | ✓ | ✓ | 3 | 3
Sadick | 1982 | ✓ | | ✓ | | 2 | 3
Sigurd | 1984 | ✓ | | | ✓ | 2 | 4
Southall | 1982 | ✓ | Glyceryl trinitrate | | | 1 | 4
Steffensen | 1993 | | | | | | 3
van Dijk | 1988 | ✓ | | ✓ | | 2 | 6
Wallace | 1994 | ✓ | | | ✓ | 2 | 6
Wieshammer | 1991 | ✓ | | ✓ | | 0.5 | 2

Evidence Table 17. Crossover trial execution description: Nitrates vs. calcium antagonists

Study | Year | Run-in period | Run-in period | | | Run-in period (weeks) | Treatment period (weeks)
Study | Year | Run-in period | Drug Used | No Drug | Placebo | Run-in period (weeks) | Treatment period (weeks)
Akhras | 1989 | ✓ | | ✓ | | 1 | 2
Ankier | 1989 | ✓ | | | ✓ | 1 | 4
Carboni | 1992 | | | | | | 1
Connelly | 1995 | ✓ | Nitroglycerin PRN | | | 1 | 3
de Vries | 1994 | ✓ | | | ✓ | 2.5 | 4
Eldridge | 1987 | ✓ | Nitroglycerin PRN | | | 2 | 4
Emanuelsson | 1989 | ✓ | | | ✓ | 2 | 2
Friedensohn | 1991 | ✓ | Only nitrates allowed | | | 1 | 2
Liang | 1985 | ✓ | | | ✓ | 2 | 6
Schneider | 1988 | ✓ | | ✓ | | 0.5 | 2
Steffensen | 1997 | ✓ | Nitroglycerin PRN | | | 2 | 5
von Arnim | 1988 | | Unclear | | | | 1

Evidence Table 18. Crossover trial execution description: Beta-blockers vs. calcium antagonists

Study | Year | Run-in period | Run-in period | | | Run-in period (weeks) | Treatment period (weeks)
Study | Year | Run-in period | Drug Used | No Drug | Placebo | Run-in period (weeks) | Treatment period (weeks)
Aubert | 1970 | ✓ | | ✓ | | 4 | 4
Goldbarg | 1969 | | | | | | 4
van de Ven | 1995 | ✓ | | | ✓ | 2 | 6

Evidence Table 19. Quality indicators: Beta-blockers vs. calcium antagonists

Study | Year | Randomized | Double-blind | Randomization method described | Exclusions not mentioned
Ahuja | 1993 | Yes | No | No
Ardissino | 1995 | Yes | Yes | No
Ardissino | 1991 | Yes | Yes | No
Arnman | 1982 | Yes | Yes | No | ✓
Bjerle | 1986 | Yes | Yes | No
Blake | 1991 | Yes | Yes | No
Bowles | 1991 | No | Yes | No | ✓
Bowles | 1983 | Yes | No | No
Brouwer | 1995 | Yes | Yes | No
Catsipovic-Veselica | 1993 | Yes | No | No
Cocco | 1979 | Yes | No | No | ✓
Crake | 1988 | Yes | Yes | No | ✓
Dargie | 1996 | Yes | Yes | No
De Devitiis | 1987 | Yes | Yes | No
de Vries | 1996 | Yes | Yes | No
Destors | 1989 | Yes | Yes | Yes
Di Somma | 1996 | Yes | No | No
Egstrup | 1993 | Yes | Yes | No
Egstrup | 1988 | Yes | Yes | No
Findlay | 1986 | Yes | Yes | No
Findlay | 1983 | Yes | Yes | No | ✓
Findlay | 1987 | Yes | Yes | No
Frishman | 1992 | Yes | Yes | No | ✓
Frishman | 1982 | Yes | Yes | No | ✓
Hauf-Zachariou | 1997 | Yes | Yes | Yes | ✓
Hetzel | 1994 | Yes | No | No
Higginbotham | 1989 | Yes | Yes | No | ✓
Hill | 1991 | Yes | Yes | No
Hopkinson | 1991 | Yes | Yes | No
Humen | 1991 | Yes | Yes | No
Hung | 1983 | Yes | Yes | No
Johnson | 1981 | Yes | Yes | Yes
Johnston | 1983 | Yes | Yes | Yes
Johnston | 1984 | Yes | No | Yes
Kawanishi | 1992 | Yes | Yes | No
Kenmure | 1979 | No | Yes | No | ✓
Kenny | 1985 | Yes | Yes | No
Khurmi | 1987 | Yes | Yes | No | ✓
Lai | 1992 | Yes | Yes | No
Lai | 1988 | Yes | Yes | No
Lessem | 1984 | Yes | No | No | ✓
Livesley | 1973 | No | Yes | No
Logan | 1986 | Yes | Yes | No
Lynch | 1980 | Yes | Yes | No
McGill | 1986 | Yes | Yes | No
Meyer | 1991 | Yes | No | Yes
Miller | 1988 | Yes | Yes | No
Nadazin | 1994 | Yes | Yes | No
O'Hara | 1984 | Yes | Yes | No | ✓
Parameshwar | 1993 | Yes | Yes | No | ✓
Parker | 1986 | Yes | Yes | No | ✓
Pflugfelder | 1987 | Yes | Yes | No
Rae | 1985 | Yes | Yes | No
Rehnqvist | 1996 | Yes | Yes | No
Riley | 1992 | Yes | Yes | No
Romano | 1986 | Yes | Yes | No
Romano | 1988 | Yes | Yes | No
Rousseau | 1986 | Yes | Yes | Yes
Sadick | 1982 | Yes | Yes | No
Savonitto | 1996 | Yes | Yes | No
Shapiro | 1989 | Yes | Yes | No
Sigurd | 1984 | No | Yes | No
Singh | 1993 | Yes | Yes | No
Southall | 1982 | Yes | Yes | No | ✓
Steffensen | 1993 | Yes | No | No
van der Does | 1992 | Yes | Yes | No
van Dijk | 1988 | No | Yes | No
Vliegen | 1991 | Yes | Yes | No
von Arnim | 1995 | Yes | Yes | No
Wallace | 1994 | Yes | Yes | Yes
Wheatley | 1985 | Yes | Yes | No
Wieshammer | 1991 | Yes | No | No

Evidence Table 20. Quality Indicators: Nitrates vs. calcium antagonist

Study | Year | Randomized | Double-blind | Randomization method described | Exclusions not mentioned
Akhras | 1989 | Yes | Yes | No
Ankier | 1989 | Yes | Yes | Yes
Carboni | 1992 | Yes | Yes | No | ✓
Connelly | 1995 | Yes | Yes | No | ✓
de Vries | 1994 | Yes | Yes | No
Eldridge | 1987 | Yes | No | No | ✓
Emanuelsson | 1989 | Yes | Yes | No
Friedensohn | 1991 | Yes | Yes | No
Liang | 1985 | Yes | Yes | No
Schneider | 1988 | Yes | Yes | No
Steffensen | 1997 | Yes | Yes | No
von Arnim | 1988 | Yes | Yes | No | ✓

Evidence Table 21. Quality indicators: Beta-blockers vs. nitrates

Study | Year | Randomized | Double-blind | Randomization method described | Exclusions not mentioned
Aubert | 1970 | Yes | Yes | No | ✓
Binak | 1974 | Yes | Yes | No | ✓
Goldbarg | 1969 | Yes | Yes | No
Krepp | 1991 | Yes | Yes | No | ✓
van de Ven | 1995 | Yes | Yes | No
Waysbort | 1991 | Yes | Yes | No

Evidence Table 22. Outcomes results: Cardiac death or nonfatal MI, beta-blockers vs. calcium antagonists

Study | Year | Age | Percent male | Percent post-MI | Death/MI No. BB | Death/MI No. CA | OR <1 BB | CA | Favors BB | BB | CA
Ahuja | 1993 | 56 | 94 | 8 | 68 | 66 | 0 | 0 | 1.0 | Metoprolol | Diltiazem
Ardissino | 1995 | 59 | 82 | 48 | 145 | 135 | 0 | 0 | 1.0 | Metoprolol | Nifedipine
Ardissino | 1991 | 57 | 82 | 34 | 32 | 32 | 0 | 0 | 0.9 | Metoprolol | Nifedipine
Arnman | 1982 | 55 | 79 | 29 | 20 | 20 | 0 | 0 | 1.0 | Metoprolol | Verapamil
Blake | 1991 | 62 | 63 | | 562 | 558 | 0 | 0 | 1.0 | Epanolol | Nifedipine
Bowles | 1983 | 55 | 80 | | 25 | 25 | 0 | 1 | 0.1 | Propranolol | Verapamil
Brouwer | 1995 | 54 | 71 | 29 | 34 | 34 | 0 | 0 | 1.0 | Metoprolol | Diltiazem
Catsipovic-Veselica | 1993 | 55 | | 31 | 20 | 21 | 0 | 0 | 1.1 | Penbutolol | Diltiazem
Cocco | 1979 | 54 | 80 | | 20 | 22 | 0 | 0 | 1.1 | Pindolol | Nifedipine
Crake | 1988 | 52 | 8 | 2 | 11 | 11 | 0 | 0 | 1.0 | Labetalol | Nifedipine
Dargie | 1996 | 59 | 86 | 33 | 226 | 232 | 17 | 21 | 0.8 | Atenolol | Nifedepine
De Devitiis | 1987 | 54 | 81 | | 13 | 12 | 0 | 0 | 0.9 | Bisoprolol | Verapamil
de Vries | 1996 | 62 | 100 | 35 | 66 | 62 | 0 | 0 | 0.9 | Atenolol | Nifedipine
Di Somma | 1996 | 57 | 60 | 25 | 20 | 20 | 0 | 0 | 1.0 | Metoprolol | Nifedipine
Egstrup | 1988 | 56 | | 62 | 21 | 21 | 0 | 0 | 0.9 | Metoprolol | Nifedipine
Egstrup | 1993 | | | 73 | 9 | 8 | 0 | 0 | 1.0 | Metoprolol | Nifedipine
Frishman | 1982 | 57 | 92 | 25 | 12 | 12 | 0 | 0 | 1.0 | Propranolol | Verapamil
Hauf-Zachariou | 1997 | 60 | 78 | 68 | 126 | 122 | 0 | 2 | 0.0 | Carvedilol | Verapamil
Hetzel | 1994 | 58 | | | 27 | 27 | 0 | 0 | 1.0 | Atenolol | Nifedipine
Higginbotham | 1989 | 55 | 100 | | 24 | 240 | 0 | 0 | 1.0 | Propranolol | Nifedipine
Hill | 1991 | 63 | 100 | | 18 | 18 | 0 | 0 | 1.0 | Atenolol | Nifedipine
Hopkinson | 1991 | 55 | 90 | | 30 | 30 | 0 | 0 | 1.0 | Atenolol | Verapamil
Humen | 1991 | 59 | 92 | 29 | 24 | 24 | 0 | 0 | 1.0 | Propranolol | Diltiazem
Hung | 1983 | 61 | 92 | 0 | 12 | 12 | 0 | 0 | 1.0 | Propranolol | Diltiazem
Johnson | 1981 | 58 | 88 | 44 | 18 | 18 | 0 | 0 | 1.0 | Propranolol | Verapamil
Johnston | 1983 | 57 | 95 | 30 | 20 | 20 | 0 | 0 | 1.0 | Propranolol | Verapamil
Johnston | 1984 | 51 | 100 | | 23 | 23 | 0 | 0 | 1.0 | Propranolol | Verapamil
Kawanishi | 1992 | 54 | 66 | 62 | 74 | 74 | 0 | 0 | 1.0 | Propranolol | Nifedipine
Kenmure | 1979 | | | 43 | 21 | 21 | 0 | 0 | 1.0 | Propranolol | Nifedipine
Kenny | 1985 | 57 | 100 | 27 | 15 | 15 | 0 | 0 | 1.0 | Propranolol | Diltiazem
Lai | 1992 | | 100 | | 16 | 16 | 0 | 0 | 1.0 | Metoprolol | Felodipine
Lai | 1988 | 59 | 100 | | 10 | 10 | 0 | 0 | 1.0 | Atenolol | Nifedipine
Lessem | 1984 | 58 | | 67 | 18 | 18 | 0 | 0 | 1.0 | Atenolol | Verapamil
Logan | 1986 | 58 | 93 | 20 | 46 | 46 | 2 | 0 | 20.9 | Atenolol | Nicardipine
McGill | 1986 | 61 | 92 | | 25 | 25 | 0 | 0 | 1.0 | Propranolol | Nicardipine
Meyer | 1991 | 59 | 77 | 13 | 15 | 16 | 0 | 0 | 1.1 | Bopindolol | Diltiazem
Miller | 1988 | 61 | 94 | | 18 | 18 | 0 | 0 | 1.0 | Nadolol | Diltiazem
Nadazin | 1994 | 62 | 87 | 13 | 15 | 15 | 0 | 0 | 1.0 | Atenolol | Diltiazem
O'Hara | 1984 | | 86 | | 34 | 17 | 1 | 0 | 5.1 | Propranolol | Diltiazem
Parameshwar | 1993 | 61 | 97 | 23 | 30 | 30 | 0 | 0 | 1.0 | Atenolol | Nicardipine
Parker | 1986 | 59 | 100 | | 18 | 18 | 0 | 0 | 1.0 | Propranolol | Bepridil
Pflugfelder | 1987 | 58 | 92 | | 24 | 24 | 0 | 0 | 1.0 | Nadolol | Bepridil
Rae | 1985 | 52 | 91 | 41 | 12 | 10 | 0 | 1 | 0.1 | Propranolol | Bepridil
Rehnqvist | 1996 | 59 | 70 | 4 | 406 | 403 | 34 | 31 | 1.1 | Metoprolol | Verapamil
Riley | 1992 | 55 | 50 | 36 | 21 | 21 | 0 | 0 | 1.0 | Epanolol | Diltiazem
Romano | 1988 | 52 | 80 | 0 | 10 | 10 | 0 | 0 | 1.0 | Atenolol | Nifedipine
Rousseau | 1986 | 55 | 94 | | 18 | 17 | 0 | 0 | 0.9 | Propranolol | Verapamil
Sadick | 1982 | 54 | 94 | | 18 | 18 | 0 | 0 | 1.0 | Propranolol | Verapamil
Savonitto | 1996 | 59 | 82 | 9 | 77 | 74 | 2 | 1 | 1.9 | Metoprolol | Nifedipine
Shapiro | 1989 | 58 | 85 | 41 | 19 | 20 | 0 | 0 | 1.1 | Atenolol | Nifedipine
Sigurd | 1984 | | | | 18 | 18 | 0 | 0 | 1.0 | Propranolol | Verapamil
Singh | 1993 | 63 | 89 | | 40 | 40 | 0 | 0 | 1.0 | Nadolol | Amlodipine
Southall | 1982 | 55 | 100 | 58 | 19 | 19 | 0 | 0 | 1.0 | Propranolol | Verapamil
Steffensen | 1993 | 50 | 92 | | 25 | 25 | 0 | 0 | 1.0 | Atenolol | Diltiazem
van der Does | 1992 | 57 | 57 | | 84 | 79 | 0 | 0 | 0.9 | Carvedilol | Nifedipine
van Dijk | 1988 | 59 | 100 | 27 | 33 | 33 | 0 | 0 | 1.0 | Metoprolol | Diltiazem
Vliegen | 1991 | 61 | | | 26 | 30 | 0 | 1 | 0.1 | Metroprolol | Diltiazem
von Arnim | 1995 | 57 | 85 | 29 | 161 | 169 | 0 | 1 | 0.1 | Bisoprolol | Nifedipine
Wallace | 1994 | 54 | 88 | 71 | 22 | 22 | 0 | 0 | 1.0 | Atenolol | Nifedipine
Wheatley | 1985 | 57 | 67 | | 40 | 38 | 1 | 0 | 9.7 | Atenolol | Diltiazem
Wieshammer | 1991 | 58 | 89 | | 36 | 36 | 0 | 0 | 1.0 | Atenolol | Nifedipine

Evidence Table 23. Outcomes results: Angina episodes, beta-blockers vs. calcium antagonists

Study | Year | Age | Percent Male | Percent post-MI | No. BB | Mean BB | SD BB | No. CA | Mean CA | SD CA | Mean difference BB-CA | BB | CA
Ardissino | 1995 | 59 | 82 | 48 | 138 | 4.0 | 4.6 | 126 | 4.8 | 5.9 | -0.8 | Metoprolol | Nifedipine
Arnman | 1982 | 55 | 79 | 29 | 20 | 1.4 | 2.2 | 20 | 1.4 | 2.2 | 0.0 | Metoprolol | Verapamil
Bjerle | 1986 | | 78 | | 18 | 1.8 | 2.4 | 18 | 2.1 | 3.8 | -0.3 | Propranolol | Nicardipine
Bowles | 1983 | 55 | 80 | | 22 | 10.0 | 28.1 | 22 | 5 | 14.1 | 5.0 | Propranolol | Verapamil
Crake | 1988 | 52 | 8 | 2 | 11 | 7.9 | 7.2 | 11 | 7.8 | 6.8 | 0.1 | Labetalol | Nifedipine
De Deviitiis | 1987 | 54 | 81 | | 11 | 0.9 | 1.8 | 10 | 1.3 | 1.8 | -0.4 | Bisoprolol | Verapamil
Di Somma | 1996 | 57 | 60 | 25 | 18 | 0.9 | 1.4 | 18 | 0.8 | 1.3 | 0.1 | Metoprolol | Nifedipine
Findlay | 1983 | 56 | 100 | | 14 | 2.3 | 5.3 | 14 | 4 | 5.3 | -1.7 | Atenolol | Nifedipine
Findlay | 1987 | 57 | 73 | 36 | 11 | 1.5 | 2.5 | 11 | 3.4 | 3.7 | -1.9 | Atenolol | Verapamil
Findlay | 1986 | 56 | 100 | 50 | 16 | 6.6 | 4.6 | 16 | 5.6 | 4.6 | 1.0 | Atenolol | Nifedipine
Frishman | 1982 | 57 | 92 | 25 | 12 | 4.6 | 3.9 | 12 | 3.1 | 3.6 | 1.5 | Propranolol | Verapamil
Frishman | 1992 | 59 | 94 | | 69 | 4.2 | 6.6 | 69 | 2 | 2 | 2.2 | Propranolol | Bepridil
Hauf-Zachariou | 1997 | 60 | 78 | 68 | 107 | 2.1 | 4.7 | 105 | 2 | 4.9 | 0.1 | Carvedilol | Verapamil
Higginbotham | 1989 | 55 | 100 | | 21 | 4.0 | 7 | 21 | 3 | 4 | 1.0 | Propranolol | Nifedipine
Humen | 1991 | 59 | 92 | 29 | 24 | 6.1 | 8.8 | 24 | 6 | 7.4 | 0.1 | Propranolol | Diltiazem
Johnson | 1981 | 58 | 88 | 44 | 18 | 3.5 | 7.9 | 18 | 4.6 | 6.1 | -1.1 | Propranolol | Verapamil
Kawanishi | 1992 | 54 | 66 | 62 | 74 | 2.0 | 2.3 | 74 | 2.7 | 5.6 | -0.7 | Propranolol | Nifedipine
Kenny | 1985 | 57 | 100 | 27 | 15 | 2.0 | 3.9 | 15 | 3 | 3.9 | -1.0 | Propranolol | Diltiazem
Livesley B | 1973 | 52 | 78 | | 32 | 4.8 | 8.2 | 32 | 7.6 | 11.8 | -2.8 | Propranolol | Verapamil
Lynch | 1980 | 58 | 88 | 94 | 16 | 8.0 | 8 | 16 | 13.5 | 12 | -5.5 | Propranolol | Nifedipine
McGill | 1986 | 61 | 92 | | 22 | 3.5 | 4.7 | 22 | 3.8 | 6.1 | -0.3 | Propranolol | Nicardipine
Nadazin | 1994 | 62 | 87 | 13 | 15 | 5.4 | 5.9 | 15 | 3.5 | 4.1 | 1.9 | Atenolol | Diltiazem
Pflugfelder | 1987 | 58 | 92 | | 24 | 6.0 | 8 | 24 | 4 | 6 | 2.0 | Nadolol | Bepridil
Rae | 1985 | 52 | 91 | 41 | 8 | 8.0 | 21.2 | 9 | 5 | 9 | 3.0 | Propranolol | Bepridil
Savonitto | 1996 | 59 | 82 | 9 | 65 | 3.7 | 7 | 62 | 3.1 | 6 | 0.6 | Metoprolol | Nifedipine
Southall | 1982 | 55 | 100 | 58 | 19 | 4.9 | 4.8 | 19 | 4.9 | 4.8 | 0.0 | Propranolol | Verapamil
Steffensen | 1993 | 50 | 92 | | 25 | 5.5 | 9 | 25 | 4.3 | 6 | 1.2 | Atenolol | Diltiazem
van der Does | 1992 | 57 | 57 | | 74 | 0.7 | 2.1 | 69 | 1.4 | 3.5 | -0.7 | Carvedilol | Nifedipine
vanDijk | 1988 | 59 | 100 | 27 | 33 | 2.5 | 3 | 3.3 | 2.5 | 5.2 | 0.0 | Metoprolol | Diltiazem
von Arnim | 1995 | 57 | 85 | 29 | 118 | 2.8 | 5.1 | 122 | 4.4 | 6.7 | -1.6 | Bisoprolol | Nifedipine
Wallace | 1994 | 54 | 88 | 71 | 17 | 0.8 | 1.2 | 17 | 1.5 | 0.8 | -0.8 | Atenolol | Nifedipine
Wheatley | 1985 | 57 | 67 | | 40 | 5.7 | 6.6 | 38 | 6.7 | 7.4 | -1.0 | Atenolol | Diltiazem

Evidence Table 24. Outcomes results: Nitroglycerin use, beta=blockers vs. calcium antagonists

Study | Year | Age | Percent Male | Percent post-MI | No.BB | Mean BB | SD BB | No.CA | Mean CA | SD CA | Mean difference BB-CA | BB | CA
Arnman | 1982 | 55 | 79 | 29 | 20 | 1.1 | 2.2 | 20 | 1.0 | 2.2 | 0.1 | Metoprolol | Verapamil
Bowles | 1983 | 55 | 80 | | 22 | 12.0 | 23.5 | 22 | 3.0 | 9.4 | 9.0 | Propranolol | Verapamil
De Devitiis | 1987 | 54 | 81 | | 11 | 1.4 | 1.8 | 10 | 1.5 | 1.7 | -0.1 | Bisoprolol | Verapamil
Di Somma | 1996 | 57 | 60 | 25 | 18 | 1.0 | 2.0 | 18 | 1.0 | 1.5 | 0.0 | Metroprolol | Nifedipine
Findlay | 1986 | 56 | 100 | 50 | 16 | 2.0 | 9.9 | 16 | 3.3 | 4.0 | 1.6 | Atenolol | Nifedipine
Findlay | 1987 | 57 | 73 | 36 | 11 | 4.6 | 4.0 | 11 | 3.0 | 9.9 | -1.3 | Atenolol | Verapamil
Findlay | 1983 | 56 | 100 | | 14 | 1.4 | 1.9 | 14 | 2.8 | 3.3 | -1.4 | Atenolol | Nifedipine
Frishman | 1982 | 57 | 92 | 25 | 12 | 7.8 | 3.0 | 12 | 8.8 | 4.2 | -1.0 | Propranolol | Verapamil
Frishman | 1992 | 59 | 94 | | 69 | 1.9 | 4.3 | 69 | 0.9 | 1.7 | 1.0 | Propranolol | Bepridil
Hauf-Zachariou | 1997 | 60 | 78 | 68 | 107 | 1.7 | 3.5 | 105 | 2.1 | 3.8 | -0.4 | Carvedilol | Verapamil
Higginbotham | 1989 | 55 | 100 | | 21 | 4.0 | 4.0 | 21 | 3.0 | 4.0 | 1.0 | Propranolol | Nifedipine
Humen | 1991 | 59 | 92 | 29 | 24 | 6.0 | 8.6 | 24 | 5.7 | 7.3 | 0.3 | Propranolol | Diltiazem
Johnson | 1981 | 58 | 88 | 44 | 18 | 5.8 | 15.5 | 18 | 6.9 | 11.3 | -1.1 | Propranolol | Verapamil
Kawanishi | 1992 | 54 | 66 | 62 | 74 | 0.7 | 1.2 | 74 | 0.7 | 1.6 | 0.0 | Propranolol | Nifedipine
Kenny | 1985 | 57 | 100 | 27 | 15 | 1.0 | 3.9 | 15 | 3.0 | 3.9 | -2.0 | Propranolol | Diltiazem
Livesley B | 1973 | 52 | 78 | | 32 | 4.5 | 8.0 | 32 | 7.3 | 11.5 | -2.8 | Propranolol | Verapamil
Lynch | 1980 | 58 | 88 | 94 | 16 | 6.5 | 8.0 | 16 | 12.0 | 10.0 | -5.5 | Propranolol | Nifedipine
McGill | 1986 | 61 | 92 | | 22 | 2.6 | 5.6 | 22 | 1.5 | 2.3 | 1.1 | Propranolol | Nicardipine
Nazadin | 1994 | 62 | 87 | 13 | 15 | 5.6 | 5.3 | 15 | 2.2 | 2.2 | 3.4 | Atenolol | Diltiazem
Pflugfelder | 1987 | 58 | 92 | | 24 | 5.0 | 8.0 | 24 | 3.0 | 7.0 | 2.0 | Nadolol | Bepridil
Southall | 1982 | 55 | 100 | 58 | 19 | 4.0 | 4.4 | 19 | 4.0 | 4.4 | 0.0 | Propranolol | Verapamil
Steffensen | 1993 | 50 | 92 | | 25 | 3.9 | 7.0 | 25 | 3.4 | 10.0 | 0.5 | Atenolol | Diltiazem
van der Does | 1992 | 57 | 57 | | 74 | 1.4 | 3.5 | 69 | 1.4 | 3.5 | 0.0 | Carvedilol | Nifedipine
Wallace | 1994 | 54 | 88 | 71 | 17 | 0.2 | 1.2 | 17 | 0.5 | 0.4 | -0.3 | Atenolol | Nifedipine
Wheatley | 1985 | 57 | 67 | | 40 | 5.2 | 6.0 | 38 | 5.7 | 6.5 | -0.5 | Atenolol | Diltiazem

Evidence Table 25. Outcomes results: Exercise time to ischemia beta-blockers vs. calcium antagonists

Study | Year | Age | Percent Male | Percent post-MI | No.BB | Mean BB | SD BB | No.CA | Mean CA | SD CA | Mean difference BB-CA | BB | CA
Ahuja | 1993 | 56 | 94 | 30 | 68 | 8.8 | 2 | 66 | 8.2 | 2.7 | 0.23 | Metoprolol | Diltiazem
Bjerle | 1986 | 58 | 78 | 67 | 18 | 6.7 | 2.1 | 18 | 6.73 | 3 | -0.02 | Propranolol | Nicardipine
Bowles | 1983 | 55 | 80 | | 22 | 5.7 | 2.3 | 22 | 5.5 | 2.8 | 0.08 | Propranolol | Verapamil
Crake | 1988 | 52 | 8 | 2 | 11 | 5.3 | 2.2 | 11 | 6 | 2.4 | -0.3 | Labetalol | Nifedipine
Di Somma | 1996 | 57 | 60 | 25 | 18 | 339 | 208 | 18 | 330 | 169 | 0.05 | Metoprolol | Nifedipine
Egstrup | 1993 | 55 | | 73 | 9 | 10 | 3 | 8 | 7 | 4 | 0.86 | Metoprolol | Nifedipine
Hauf-Zachariou | 1997 | 60 | 78 | 68 | 107 | 298 | 124 | 105 | 302 | 123 | -0.03 | Carvedilol | Verapamil
Higginbotham | 1989 | 55 | 100 | | 21 | 8 | 3 | 21 | 9 | 3 | -0.33 | Propranolol | Nifedipine
Humen | 1991 | 59 | 92 | 29 | 24 | 345 | 94 | 24 | 376 | 123 | -0.28 | Propranolol | Diltiazem
Hung | 1983 | 61 | 92 | 0 | 12 | 479 | 138 | 12 | 532 | 150 | -0.37 | Propranolol | Diltiazem
Kenny | 1985 | 57 | 100 | 27 | 15 | 387 | 143 | 15 | 332 | 143 | 0.38 | Propranolol | Diltiazem
Lai | 1992 | 60 | 100 | | 16 | 625 | 160 | 16 | 571 | 176 | 0.32 | Metoprolol | Felodipine
McGill | 1986 | 61 | 92 | | 22 | 5.5 | 3.3 | 22 | 5.5 | 3.3 | 0 | Propranolol | Nicardipine
Nadazin | 1994 | 62 | 87 | 13 | 15 | 6.5 | 2.1 | 15 | 6.6 | 0.8 | -0.06 | Atenolol | Diltiazem
Parameshwar | 1993 | 60 | 97 | 23 | 30 | 446 | 150 | 30 | 472 | 138 | -0.04 | Atenolol | Nicardipine
Parker | 1986 | 59 | 100 | | 18 | 339 | 526 | 18 | 356 | 594 | -0.03 | Propranolol | Bepridil
Pflugfelder | 1987 | 58 | 92 | | 24 | 275 | 107 | 24 | 302 | 108 | -0.25 | Nadolol | Bepridil
Sadick | 1982 | 54 | 94 | | 18 | 7.4 | 1.4 | 18 | 6.6 | 1.9 | 0.48 | Propranolol | Verapamil
Steffensen | 1993 | 50 | 92 | | 25 | 9.1 | 2.5 | 25 | 7.9 | 3 | 0.43 | Atenolol | Diltiazem
van der Does | 1992 | 57 | 57 | | 74 | 4.8 | 1.8 | 69 | 4.5 | 2.3 | 0.15 | Carvedilol | Nifedipine

Evidence Table 26. Outcomes results: Adverse events, beta-blockers vs. calcium antagonists

Study | Year | Age | Percent male | Percent post-MI | No. BB | No. CA | Events BB | Events CA | Odds ratio <1 favors BB | BB | CA
Ahuja | 1993 | 56 | 94 | 8 | 68 | 66 | 6 | 6 | 1 | Metoprolol | Diltiazem
Ardissino | 1995 | 59 | 82 | 48 | 145 | 135 | 1 | 2 | 0.5 | Metoprolol | Nifedipine
Ardissino | 1991 | 57 | 82 | 34 | 32 | 32 | 7 | 9 | 0.7 | Metoprolol | Nifedipine
Arnman | 1982 | 55 | 79 | 29 | 20 | 20 | 0 | 0 | 1 | Metoprolol | Verapamil
Blake | 1991 | 62 | 63 | | 562 | 558 | 38 | 71 | 0.4 | Epanolol | Nifedipine
Bowles | 1983 | 55 | 80 | | 25 | 25 | 2 | 1 | 2.1 | Propranolol | Verapamil
Brouwer | 1995 | 54 | 71 | 29 | 34 | 34 | 4 | 6 | 0 | Metoprolol | Diltiazem
Catsipovic-Veselica | 1993 | 55 | | 31 | 20 | 21 | 0 | 0 | 1.1 | Penbutolol | Diltiazem
Cocco | 1979 | 54 | 80 | | 20 | 22 | 1 | 1 | 1.1 | Pindolol | Nifedipine
Dargie | 1996 | 59 | 86 | 33 | 226 | 232 | 60 | 93 | 0.5 | Atenolol | Nifedipine
De Devitiis | 1987 | 54 | 81 | | 13 | 12 | 2 | 2 | 0 | Bisoprolol | Verapamil
de Vries | 1996 | 62 | 100 | 35 | 66 | 62 | 5 | 1 | 5 | Atenolol | Nifedipine
Destors | 1989 | 56 | 66 | 34 | 78 | 78 | 17 | 15 | 1.3 | Propranolol | Bepridil
Di Somma | 1996 | 57 | 60 | 25 | 20 | 20 | 1 | 1 | 1 | Metoprolol | Nifedipine
Egstrup | 1988 | 56 | | 62 | 21 | 21 | 0 | 0 | 0.9 | Metoprolol | Nifedipine
Egstrup | 1993 | 55 | | 73 | 9 | 8 | 0 | 1 | 0.1 | Metoprolol | Nifedipine
Frishman | 1982 | 57 | 92 | 25 | 12 | 12 | 0 | 0 | 1 | Propranolol | Verapamil
Hauf-Zachariou | 1997 | 60 | 78 | 68 | 126 | 122 | 21 | 22 | 0.7 | Carvedilol | Verapamil
Higginbotham | 1989 | 55 | 100 | | 24 | 24 | 1 | 1 | 1 | Propranolol | Nifedipine
Hill | 1991 | 63 | 100 | | 18 | 18 | 0 | 0 | 1 | Atenolol | Nifedipine
Hopkinson | 1991 | 55 | 90 | | 30 | 30 | 4 | 0 | 33.2 | Atenolol | Verapamil
Humen | 1991 | 59 | 92 | 29 | 24 | 24 | 0 | 0 | 1 | Propranolol | Diltiazem
Hung | 1983 | 61 | 92 | 0 | 12 | 12 | 0 | 0 | 1 | Propranolol | Diltiazem
Johnson | 1981 | 58 | 88 | 44 | 18 | 18 | 0 | 0 | 1 | Propranolol | Verapamil
Johnston | 1983 | 57 | 95 | 30 | 20 | 20 | 0 | 1 | 0.1 | Propranolol | Verapamil
Kenmure | 1979 | | | 43 | 21 | 21 | 0 | 0 | 1 | Propranolol | Nifedipine
Kenny | 1985 | 57 | 100 | 27 | 15 | 15 | 0 | 0 | 1 | Propranolol | Diltiazem
Khurmi | 1987 | 61 | 79 | | 14 | 14 | 0 | 0 | 1 | Propranolol | Diltiazem
Lai | 1992 | | | | 16 | 16 | 0 | 0 | 1 | Metoprolol | Felodipine
Lessem | 1984 | 58 | | 67 | 18 | 18 | 0 | 0 | 1 | Atenolol | Verapamil
Logan | 1986 | 58 | 93 | 20 | 46 | 46 | 0 | 0 | 1.5 | Atenolol | Nicardipine
Meyer | 1991 | 59 | 77 | 13 | 15 | 16 | 2 | 1 | 2.3 | Bopindolol | Diltiazem
Miller | 1988 | 61 | 94 | | 18 | 18 | 0 | 1 | 0 | Nadolol | Diltiazem
O'Hara | 1984 | | 86 | | 34 | 17 | 2 | 0 | 11 | Propranolol | Diltiazem
Parker | 1986 | 59 | | | 18 | 18 | 0 | 0 | 1 | Propranolol | Bepridil
Pflugfelder | 1987 | 58 | 92 | | 24 | 24 | 0 | 0 | 1 | Nadolol | Bepridil
Rae | 1985 | 52 | 91 | 41 | 12 | 10 | 4 | 1 | 4.5 | Propranolol | Bepridil
Rehnqvist | 1996 | 59 | 70 | 4 | 406 | 403 | 45 | 59 | 0.7 | Metoprolol | Verapamil
Riley | 1992 | 55 | 50 | 36 | 21 | 21 | 5 | 3 | 10.5 | Epanolol | Diltiazem
Rousseau | 1986 | | | | 18 | 17 | 1 | 2 | 0.4 | Propranolol | Nicardipine
Sadick | 1982 | 54 | 94 | | 18 | 18 | 0 | 0 | 1 | Propranolol | Verapamil
Shapiro | 1989 | 58 | 85 | 41 | 19 | 20 | 2 | 2 | 0.5 | Atenolol | Nifedipine
Sigurd | 1984 | | | | 18 | 18 | 1 | 2 | 0.5 | Propranolol | Verapamil
Singh | 1993 | 63 | 89 | | 40 | 40 | 11 | 8 | 1.3 | Nadolol | Amlodipine
Southall | 1982 | 55 | 100 | 58 | 19 | 19 | 0 | 0 | 1 | Propranolol | Verapamil
Steffensen | 1993 | 50 | 92 | | 25 | 25 | 0 | 0 | 1 | Atenolol | Diltiazem
van der Does | 1992 | 57 | 57 | | 84 | 79 | 10 | 10 | 1.9 | Carvedilol | Nifedipine
Vliegen | 1991 | 61 | | | 26 | 30 | 8 | 9 | 1 | Metoprolol | Diltiazem
von Arnim | 1995 | 57 | 85 | 29 | 161 | 169 | 61 | 64 | 1 | Bisoprolol | Nifedipine
Wallace | 1994 | 54 | 88 | 71 | 22 | 22 | 1 | 4 | 0.3 | Atenolol | Nifedipine
Wheatley | 1985 | 57 | 67 | | 40 | 38 | 4 | 0 | 42.1 | Atenolol | Diltiazem

Evidence Table 27. Outcomes results: Side effects, beta-blockers vs. calcium antagonists

Author | Year | No. BB | BB | No. CA | CA | Worse angina | | Headache | | CNS | | GI | | Edema
Author | Year | No. BB | BB | No. CA | CA | BB | CA | BB | CA | BB | CA | BB | CA | BB | CA
Ardissino | 1995 | 02 | Metoprolol | 135 | Nifedipine | 2 | 3 | | 1 | | | | | | 1
Bowles | 1983 | 25 | Propranolol | 25 | Verapamil | | 1 | | | | | | 8
Cocco | 1979 | 20 | Pindolol | 22 | Nifedipine | | | 2 | 6 | | | 3 | 3
De Devitiis | 1987 | 13 | Bisoprolol | 12 | Verapamil | | | | 3 | | 1 | 1 | 4
de Vries | 1996 | 66 | Atenolol | 62 | Nifedipine | | 1 | 2 | 7 | 6 | 2 | 2
Destors | 1989 | 78 | Propranolol | 78 | Bepridil | | | | | | | 10 | 5
Di Somma | 1996 | 20 | Metoprolol | 20 | Nifedipine | | | | 3
Higginbotham | 1989 | 24 | Propranolol | 24 | Nifedipine | | | | | 4 | 10
Hopkinson | 1991 | 30 | Atenolol | 30 | Verapamil | | | 4 | 3 | 1 | 1 | 4 | 3
Humen | 1991 | 24 | Propranolol | 24 | Diltiazem | | | 1 | 2 | | | 1 | 2 | | 1
Johnston | 1983 | 20 | Propranolol | 20 | Verapamil | 13 | 11 | | | | | | 5
Lynch | 1980 | 16 | Propranolol | 16 | Nifedipine | | | 5 | 5 | | | | | | 8
McGill | 1986 | 25 | Propranolol | 25 | Nicardipine | | | 1 | 1 | 4 | 1 | 1 | 1
Meyer | 1991 | 15 | Bopindolol | 16 | Diltiazem | 2 | 1 | | | | | | | | 1
Rehnqvist | 1996 | 02 | Metoprolol | 403 | Verapamil | 10 | 7 | 3 | 4 | | | 10 | 22
Riley | 1992 | 21 | Epanolol | 21 | Diltiazem | 1
Sadick | 1982 | 18 | Propranolol | 18 | Verapamil | | | | | 1 | | | 1
Singh | 1993 | 40 | Nadolol | 40 | Amlodipine | | | 7 | 9 | | | | | 2 | 4
van der Does | 1992 | 84 | Carvedilol | 79 | Nifedipine | | | 1 | 3 | | 8 | 3 | 3 | | 2
Wallace | 1994 | 22 | Atenolol | 22 | Nifedipine | | | 1 | 1 | | | 3 | 3 | | 5

Evidence Table 28. Outcomes results: Cardiac death or nonfatal MI, nitrates vs. calcium antagonists

Study | Year | Age | Percent male | Percent post-MI | No. NI | No. CA | Death/MI NI | Death/MI CA | Odds ratio <1 favors NI | NI | CA
Akhras | 1989 | 60 | 89 | 56 | 17 | 17 | 0 | 0 | 1.0 | Isosorbide mononitrate | Nifedipine
Ankier | 1989 | 59 | 65 | | 126 | 124 | 0 | 0 | 1.0 | Isosorbide mononitrate | Nifedipine
Connely | 1995 | 76 | 65 | 41 | 17 | 17 | 0 | 0 | 1.0 | Isosorbide dinitrate | Nicardipine
de Vries | 1994 | 72 | 70 | 16 | 45 | 45 | 0 | 0 | 1.0 | Isosorbide mononitrate | Felodipine
Eldridge | 1987 | 59 | 73 | 60 | 15 | 15 | 0 | 0 | 1.0 | NTG patch | Nifedipine
Emanuelsson | 1989 | 63 | 84 | 38 | 32 | 32 | 0 | 0 | 1.0 | Isosorbide mononitrate | Diltiazem
Liang | 1985 | 57 | 70 | 50 | 32 | 33 | 0 | 0 | 1.0 | Isosorbide dinitrate | Nifedipine
Schneider | 1988 | 58 | 100 | 43 | 14 | 14 | 0 | 0 | 1.0 | Isosorbide dinitrate | Verapamil
Steffensen | 1997 | 61 | 71 | 51 | 59 | 59 | 0 | 0 | 1.0 | Isosorbide dinitrate | Amlodipine
von Arnim | 1988 | 62 | 65 | | 20 | 20 | 0 | 0 | 1.0 | Isosorbide mononitrate | Nifedepine

Evidence Table 29. Outcomes results: Angina episodes, nitrates vs. calcium antagonists

Study | Year | Age | Percent male | Percent post-MI | No. NI | Mean NI | SD NI | No. CA | Mean CA | SD CA | Mean difference NI-CA | NI | CA
Akhras | 1989 | 60 | 89 | 56 | 17 | 6.6 | 7.2 | 17 | 7.2 | 7.6 | -0.6 | Isosorbide mononitrate | Nifedipine
Eldridge | 1987 | 59 | 73 | 60 | 15 | 1.8 | 3.3 | 15 | 1.2 | 2.4 | 0.6 | NTG patch | Nifedipine
Emanuelsson | 1989 | 63 | 84 | 38 | 32 | 10 | 8.5 | 32 | 7.5 | 8.5 | 2.5 | Isosorbide mononitrate | Diltiazem
Liang | 1985 | 57 | 70 | 50 | 30 | 1.8 | 1.1 | 30 | 1.4 | 1.6 | 0.4 | Isosorbide dinitrate | Nifedipine
Steffensen | 1997 | 61 | 71 | 51 | 49 | 5.9 | 10.5 | 49 | 3.9 | 4.2 | 2.0 | Isosorbide dinitrate | Amlodipine

Evidence Table 30. Outcomes results: Nitroglycerin use, nitrates vs. calcium antagonists

Study | Year | Age | Percent male | Percent post-MI | No. NI | Mean NI | SD NI | No. CA | Mean CA | SD CA | Mean difference NI-CA | NI | CA
Akhras | 1989 | 60 | 89 | 56 | 17 | 6.1 | 8.2 | 17 | 5.8 | 8.0 | 0.3 | Isosorbide mononitrate | Nifedipine
Eldridge | 1987 | 59 | 73 | 60 | 15 | 2.3 | 4.5 | 15 | 1.2 | 2.0 | 0.1 | NTG patch | Nifedipine
Emanuelsson | 1989 | 63 | 84 | 38 | 32 | 8.0 | 8.5 | 32 | 5.0 | 8.0 | 3.0 | Isosorbide mononitrate | Diltiazem
Liang | 1985 | 57 | 70 | 50 | 30 | 1.2 | 0.5 | 30 | 1.1 | 1.0 | 1.1 | Isosorbide dinitrate | Nifedipine
Steffensen | 1997 | 61 | 71 | 51 | 49 | 6.8 | 11.5 | 49 | 5.2 | 7.0 | 1.6 | Isosorbide dinitrate | Amlodipine

Evidence Table 31. Outcomes results: Exercise time to ischemia, nitrates vs. calcium antagonists

Study | Year | Age | Percent male | Percent post-MI | No. NI | Mean NI | SD NI | No. CA | Mean CA | SD CA | Mean difference (NI-CA)/SD | NI | CA
Akhras | 1989 | 60 | 89 | 56 | 17.0 | 287.0 | 119.6 | 17.0 | 299.0 | 123.7 | -0.1 | Isosorbide mononitrate | Nifedipine
Eldridge | 1987 | 59 | 73 | 60 | 15.0 | 398.0 | 210.0 | 15.0 | 416.0 | 183.0 | -0.1 | NTG patch | Nifedipine
Steffensen | 1997 | 61 | 71 | 51 | 49.0 | 292.0 | 147.0 | 49.0 | 332.0 | 161.0 | -0.3 | Isosorbide dinitrate | Amlodipine

Evidence Table 32. Outcomes results: Adverse events, nitrates vs. calcium antagonists

Study | Year | Age | Percent male | Percent post-MI | No. NI | No. CA | Events NI | Events CA | Odds ratio <1 favors NI | NI | CA
Akhras | 1989 | 60 | 89 | 56 | 17 | 17 | 0 | 0 | 1.0 | Isosorbide mononitrate | Nifedipine
Ankier | 1989 | 60 | 65 | | 126 | 124 | 6 | 3 | 1.7 | Isosorbide mononitrate | Nifedipine
Carboni | 1992 | 54 | 80 | 60 | 15 | 15 | 0 | 0 | 1.0 | Isosorbide mononitrate | Gallapomil
Connely | 1995 | 76 | 65 | 41 | 17 | 17 | 0 | 0 | 1.0 | Isosorbide dinitrate | Nicardipine
de Vries | 1994 | 72 | 70 | 16 | 45 | 45 | 8 | 7 | 2.0 | Isosorbide mononitrate | Felodipine
Eldridge | 1987 | 59 | 73 | 60 | 15 | 15 | 0 | 1 | 0.1 | NTG patch | Nifedipine
Liang | 1985 | 57 | 70 | 50 | 32 | 33 | 2 | 2 | 1.0 | Isosorbide dinitrate | Nifedipine
Schneider | 1988 | 58 | 100 | 43 | 14 | 14 | 0 | 0 | 1.0 | Isosorbide dinitrate | Verapamil
Steffensen | 1997 | 61 | 71 | 51 | 59 | 59 | 8 | 7 | 1.5 | Isosorbide dinitrate | Amlodipine

Evidence Table 33. Outcomes results: Side effects, nitrates vs. calcium antagonists

Author | Year | No. CA | CA | No. NI | NI | Worse angina | | Headache | | CNS | | GI | | Edema
Author | Year | No. CA | CA | No. NI | NI | CA | NI | CA | NI | CA | NI | CA | NI | CA | NI
Ankier | 1989 | 126 | Nifedipine | 124 | Isosorbide mononitrate | 1 | 2 | 22 | 22 | | 6 | 2 | 5
Emanuelsson | 1989 | 32 | Diltiazem | 32 | Isosorbide mononitrate | | | | 13 | | | 3 | 2
Liang | 1985 | 33 | Nifedipine | 32 | Isosorbide dinitrate | | | 1 | 2

Evidence Table 34. Outcomes results: Cardiac death or nonfatal MI, beta-blockers vs. nitrates

Study | Year | Mean Age | Percent male | Percent post-MI | No. BB | No. NI | Death/MI BB | Death/MI NI | Odds ratio <1 favors BB | BB | NI
Aubert | 1970 | 56 | 90 | 52 | 22 | 22 | 0 | 0 | 1.0 | Alprenolol | Pentanitrol
Binak | 1974 | 57 | 87 | 47 | 5 | 5 | 0 | 0 | 1.0 | LB46 | Isosorbide dinitrate
Goldbarg | 1969 | 55 | 90 | 29 | 29 | 29 | 1 | 0 | 10.3 | Propanolol | Isosorbide dinitrate
Krepp | 1991 | 58 | 60 | | 15 | 15 | 0 | 0 | 1.0 | Bupranolol | Isosorbide mononitrate
van de Ven | 1995 | 61 | 74 | 30 | 30 | 30 | 0 | 1 | 0.1 | Bisoprolol | Isosorbide dinitrate
Waysbort | 1991 | | | | 28 | 28 | 0 | 0 | 1.0 | Atenolol | Isosorbide mononitrate

Evidence Table 35. Outcomes results: Angina episodes, beta-blockers vs. nitrates

Study | Year | Age | Percent male | Percent post-MI | No. NI | Mean NI | SD NI | No. BB | Mean BB | SD BB | Mean difference BB-NI | NI | BB
Aubert | 1970 | 56 | 90 | 52 | 18 | 9.4 | 10.0 | 20 | 7.5 | 9.0 | -1.9 | Pentanitrol | Alprenolol
Binak | 1974 | 57 | 87 | 47 | 5 | 3.9 | 2.0 | 5 | 3.8 | 5.4 | -0.1 | Isosorbide dinitrate | LB46
Goldbarg | 1969 | 55 | 90 | 29 | 21 | 16.8 | 20.0 | 21 | 7.0 | 11.5 | -9.8 | Isosorbide dinitrate | Propanolol
Krepp | 1991 | 58 | 60 | | 13 | 3.0 | 2.0 | 13 | 8.0 | 6.0 | 5 | Isosorbide mononitrate | Bupranolol
van de Ven | 1995 | 61 | 74 | 30 | 27 | 6.2 | 2.0 | 27 | 3.9 | 2.6 | -2.3 | Isosorbide dinitrate | Bisoprolol

Evidence Table 36. Outcomes results: Angina episodes, beta-blockers vs. nitrates

Study | Year | Age | Percent male | Percent post-MI | No. BB | Mean BB | SD BB | No. NI | Mean NI | SD NI | Mean difference BB-NI | BB | NI
Binak | 1974 | 57 | 87 | 47 | 5 | 0.0 | 0.0 | 5 | 0.4 | 0.3 | -0.4 | LB46 | Isosorbide dinitrate
Goldbarg | 1969 | 55 | 90 | 29 | 21 | 4.4 | 6.4 | 21 | 9.2 | 8.7 | -4.8 | Propanolol | Isosorbide dinitrate
van de Ven | 1995 | 61 | 74 | 30 | 27 | 3.3 | 2.1 | 27 | 5.8 | 1.6 | -2.5 | Bisoprolol | Isosorbide dinitrate

Evidence Table 37. Outcomes results: Exercise time to ischemia, beta-blockers vs. nitrates

Study | Year | Age | Percent male | Percent post-MI | No. BB | Mean BB | SD BB | No. NI | Mean NI | SD NI | Mean difference (BB-NI)/SD | BB | NI
van de Ven | 1995 | 61 | 74 | 30 | 27 | 499 | 924.9 | 27 | 400 | 737.9 | 0.12 | Bisoprolol | Isosorbide dinitrate

Evidence Table 38. Outcomes results: Adverse events, beta-blockers vs. nitrates

Study | Year | Age | Percent male | Percent post-MI | No. BB | No. NI | Events BB | Events NI | Odds ratio <1 favors BB | BB | NI
Aubert | 1970 | 56 | 90 | 52 | 22 | 22 | 0 | 1 | 0.1 | Alprenolol | Pentanitrol
Goldbarg | 1969 | | | | 29 | 29 | 2 | 4 | 0.5 | Propanolol | Isosorbide dinitrate
Krepp | 1991 | | | | 15 | 15 | 2 | 2 | 1.0 | Bupranolol | Isosorbide mononitrate
van de Ven | 1995 | 61 | 74 | 30 | 30 | 30 | 0 | 3 | 0.0 | Bisoprolol | Isosorbide dinitrate
Waysbort | 1991 | | | | 28 | 28 | 2 | 3 | 0.6 | Atenolol | Isosorbide mononitrate

Evidence Table 39. Outcomes results: Side effects, beta-blockers vs. nitrates

Author | Year | No. CA | CA | No. NI | NI | Worse angina | | Headache | | CNS | | GI | | Edema
Author | Year | No. CA | CA | No. NI | NI | BB | NI | BB | NI | BB | NI | BB | NI | BB | NI
Krepp | 1991 | 15 | Bupranolol | 15 | Isosorbide mononitrate | | | 2 | 4
van de Ven | 1995 | 30 | Bisoprolol | 30 | Isosorbide mononitrate | | | | 10 | | | | 1