# Bibliography

Ahuja RC, Sinha N, Kumar RR, et al. Effect of metoprolol and diltiazem on the total ischaemic burden in patients with chronic stable angina: a randomized controlled trial. Int J Cardiol. 1993;41(3):191-9. [pmid: 8288408].
Akhras F, Chambers J, Jefferies S, et al. A randomised double-blind crossover study of isosorbide mononitrate and nifedipine retard in chronic stable angina. Int J Cardiol. 1989;24(2):191-6. [pmid: 2504673].
Alderman MH, Cohen H, Roque R, et al. Effect of long-acting and short-acting calcium antagonists on cardiovascular outcomes in hypertensive patients [see comments]. Lancet. 1997;349(9052):594-8. [pmid: 9057730].
Ankier SI, Fay L, Warrington SJ, et al. A multicentre open comparison of isosorbide-5-mononitrate and nifedipine given prophylactically to general practice patients with chronic stable angina pectoris. J Int Med Res. 1989;17(2):172-8. [pmid: 2656333].
Ardissino D, Savonitto S, Egstrup K, et al. Transient myocardial ischemia during daily life in rest and exertional angina pectoris and comparison of effectiveness of metoprolol versus nifedipine. Am J Cardiol. 1991;67(11):946-52. [pmid: 2018012].
Ardissino D, Savonitto S, Egstrup K, et al Selection of medical treatment in stable angina pectoris: results of the International Multicenter Angina Exercise (IMAGE) Study J Am Coll Cardiol 1995 25(7) 1516 21View this and related citations using 7759701
Arnman K, Ryden L. Comparison of metoprolol and verapamil in the treatment of angina pectoris. Am J Cardiol. 1982;49(4):821-7. [pmid: 6801951].
Aronow WS. Management of stable angina. N Engl J Med. 1973;289(10):516-20. [pmid: 4206255].
Aubert A, Nyberg G, Slaastad R, et al. Prophylactic treatment of angina pectoris. A double-blind cross-over comparison of alprenolol and pentanitrol. BMJ. 1970;1(690):203-6. [pmcid: 30582]. [pmid: 4391702].
Ballegaard S, Meyer CN, Trojaborg W. Acupuncture in angina pectoris: does acupuncture have a specific effect?. J Intern Med. 1991;229(4):357-62. [pmid: 2026989].
Ballegaard S, Pedersen F, Pietersen A, et al. Effects of acupuncture in moderate, stable angina pectoris: a controlled study. J Intern Med. 1990;227(1):25-30. [pmid: 2105371].
Binak K, Sirmaci N, Tavsanoglu S, et al. Beta-adrenergic-blocker LB46 and isosorbide dinitrate synergism in angina pectoris. New Istanbul Contrib Clin Sci. 1974;11(1):8-23. [pmid: 4614222].
Bjerle P, Olofsson B, Glimvik O. Nicardipine and propranolol in angina pectoris: a comparative study with special reference to ergometer working capacity tests. Br J Clin Pharmacol. 1986;22:339S-43S.
Blake P, Berry SC, Readman A, et al. A comparison of epanolol and nifedipine in stable angina patients: results of a multicentre trial. Cardiology. 1991;79(4):249-55. [pmid: 1685942].
Borhani NO, Mercuri M, Borhani PA, et al. Final outcome results of the Multicenter Isradipine Diuretic Atherosclerosis Study (MIDAS). A randomized controlled trial [see comments]. JAMA. 1996;276(10):785-91. [pmid: 8769587].
Bowles MJ, Bala Subramanian V, Davies AB, et al. Double-blind randomized crossover trial of verapamil and propranolol in chronic stable angina. Am Heart J. 1983;106(6):1297-306. [pmid: 6359843].
Bowles MJ, Subramanian VB, Davies AB, et al. Comparison of antianginal actions of verapamil and propranolol. BMJ. 1981;282.
Brouwer J, Viersma JW, van Veldhuisen DJ, et al. Usefulness of heart rate variability in predicting drug efficacy (metoprolol vs. diltiazem) in patients with stable angina pectoris. Am J Cardiol. 1995;76(11):759-63. [pmid: 7572650].
Cai PY, Xu BT, Shen BY. [A clinical study of hehuantang in treating coronary heart disease]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1996;16(4):204-6. [pmid: 9206240].
Califf RM, Kramer JM. What have we learned from the calcium channel blocker controversy? [editorial; comment]. Circulation. 1998;97(16):1529-31. [pmid: 9593555].
Carboni GP, Saltarocchi ML, Risa AL, et al. Combined gallopamil and isosorbide-5-mononitrate in "mixed" angina pectoris. J Cardiovasc Pharmacol. 1992;20(Suppl 7):S64-70. [pmid: 1284159].
Catsipovic-Veselica K, Skrinjaric-Cincar S, Catipovic B. Efficacy of diltiazem and penbutolol in myocardial ischemia of patients with stable angina pectoris. Croat Med J. 1993;34(4):319-24.
Chan PK, Heo JY, Garibian G, et al. The role of nitrates, beta-blockers, and calcium antagonists in stable angina pectoris. Am Heart J. 1988;116(3):838-48. [pmid: 2901214].
Chen K, Zhou WQ, Gao P. [Clinical study on the effect of shuxuening tablet in treatment of coronary heart disease]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1996;16(1):24-6. [pmid: 8732126].
Cocco G, Strozzi C, Chu D, et al. Therapeutic effects of pindolol and nifedipine in patients with stable angina pectoris and asymptomatic resting ischemia. Eur J Cardiol. 1979;10(1):59-69. [pmid: 111940].
Connelly CM, Waksmonski C, Gagnon MM, et al. Effects of isosorbide dinitrate and nicardipine hydrochloride on postprandial blood pressure in elderly patients with stable angina pectoris or healed myocardial infarction. Am J Cardiol. 1995;75(4):291-3. [pmid: 7832144].
Crake T, Mulcahy D, Wright C, et al. Labetalol in the treatment of stable exertional angina pectoris: a comparison with nifedipine. Eur Heart J. 1988;9(11):1200-5. [pmid: 3069466].
Dargie HJ, Ford I, Fox KM. Total Ischaemic Burden European Trial (TIBET). Effects of ischaemia and treatment with atenolol, nifedipine SR and their combination on outcome in patients with chronic stable angina. The TIBET Study Group. Eur Heart J. 1996;17(1):104-12. [pmid: 8682116].
Dargie HJ, Lynch PG, Krikler DM, et al. Nifedipine and propranolol: a beneficial drug interaction. Am J Med. 1981;71(4):676-82. [pmid: 7025625].
De Divitiis O, Liguori V, Di Somma S, et al. Bisoprolol in the treatment of angina pectoris: a double blind comparison with verapamil. Eur Heart J. 1987;8(Suppl M):43-54.
de Vries RJ, Dunselman PH, van Veldhuisen DJ, et al. Comparison between felodipine and isosorbide mononitrate as adjunct to beta blockade in patients > 65 years of age with angina pectoris. Am J Cardiol. 1994;74(12):1201-6. [pmid: 7977090].
de Vries RJ, van den Heuvel AF, Lok DJ et al. Nifedipine gastrointestinal therapeutic system versus atenolol in stable angina pectoris. The Netherlands Working Group on Cardiovascular Research (WCN). Int J Cardiol. 1996;57(2):143-50. [pmid: 9013266].
Deanfield J, Wright C, Krikler S, et al. Cigarette smoking and the treatment of angina with propranolol, atenolol, and nifedipine. N Engl J Med. 1984;310(15):951-4. [pmid: 6366561].
DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
Destors JM, Boissel JP, Philippon AM, et al. Controlled clinical trial of bepridil, propranolol and placebo in the treatment of exercise induced angina pectoris. B.I.S. Research Group. Fundam Clin Pharmacol. 1989;3(6):597-611. [pmid: 2515136].
Di Somma S, de Divitiis M, Bertocchi F, et al. Treatment of hypertension associated with stable angina pectoris: favourable interaction between new metoprolol formulation (OROS) and nifedipine. Cardiologia. 1996;41(7):635-43. [pmid: 8831181].
Donaldson KM, Dawkins KD, Waller DG. A comparison of nisoldipine and nifedipine, in combination with atenolol, in the management of myocardial ischaemia. Eur Heart J. 1993;14(4):534-9. [pmid: 8472719].
Easterbrook PJ, Berlin JA, Gopalan R, et al. Publication bias in clinical research. Lancet. 1991;337(8746):867-72. [pmid: 1672966].
Egger M, Zellweger-Zahner T, Schneider M, et al. Language bias in randomised controlled trials published in English and German. Lancet. 1997;350(9074):326-9. [pmid: 9251637].
Egstrup K. Randomized double-blind comparison of metoprolol, nifedipine, and their combination in chronic stable angina: effects on total ischemic activity and heart rate at onset of ischemia. Am Heart J. 1988;116(4):971-8. [pmid: 3177196].
Egstrup K, Andersen PE Jr. Transient myocardial ischemia during nifedipine therapy in stable angina pectoris, and its relation to coronary collateral flow and comparison with metoprolol. Am J Cardiol. 1993;71(2):177-83. [pmid: 8421980].
Eldridge JE, Burdick DC, Jones RH, et al. Comparison of nitroglycerin patches and nifedipine. J Cardiovasc Pharmacol. 1987;10(3):315-9. [pmid: 2444780].
el-Tamimi H, Davies GJ. Optimal control of myocardial ischaemia: the benefit of a fixed combination of atenolol and nifedipine in patients with chronic stable angina. Br Heart J. 1992;68(3):291-5. [pmid: 1389761].
Emanuelsson H, Ake H, Kristi M, et al. Effects of diltiazem and isosorbide-5-mononitrate, alone and in combination, on patients with stable angina pectoris. Eur J Clin Pharmacol. 1989;36(6):561-6. [pmid: 2506059].
Fang J, Jiang J, Luo DC. [Effect of sheng mai decoction on left ventricular function in patients with coronary heart disease. A randomized, double-blind, placebo-controlled, crossover trial]. Chung Hua Nei Ko Tsa Chih. 1987;26(7):403-6, 445. [pmid: 3322707].
Findlay IN, Dargie HJ. The effects of nifedipine, atenolol and that combination on left ventricular function. Postgrad Med J. 1983;59(Suppl 2):70-3. [pmid: 6412224].
Findlay IN, MacLeod K, Ford M, et al. Treatment of angina pectoris with nifedipine and atenolol: efficacy and effect on cardiac function. Br Heart J. 1986;55(3):240-5. [pmid: 3082344].
Findlay IN, MacLeod K, Gillen G, et al. A double blind placebo controlled comparison of verapamil, atenolol, and their combination in patients with chronic stable angina pectoris. Br Heart J. 1987;57(4):336-43. [pmid: 3555566].
Fox KM, Jespersen CM, Ferrari R, et al. How European cardiologists perceive the role of calcium antagonists in the treatment of stable angina. Eur Heart J. 1997;18(Suppl A):A113-6. [pmid: 9049546].
Fox KM, Mulcahy D, Findlay I, et al. The Total Ischaemic Burden European Trial (TIBET). Effects of atenolol, nifedipine SR and their combination on the exercise test and the total ischaemic burden in 608 patients with stable angina. The TIBET Study Group. Eur Heart J. 1996;17(1):96-103. [pmid: 8682138].
Friedensohn A, Meshulam R, Schlesinger Z. Randomized double-blind comparison of the effects of isosorbide dinitrate retard, verapamil sustained-release, and their combination on myocardial ischemic episodes. Cardiology. 1991;79(Suppl 2):31-40.
Frishman WH. Comparative efficacy and concomitant use of bepridil and beta blockers in the management of angina pectoris. Am J Cardiol. 1992;69(11):50D-5D.
Frishman WH, Klein NA, Klein P, et al. Comparison of oral propranolol and verapamil for combined systemic hypertension and angina pectoris. A placebo-controlled double-blind randomized crossover trial. Am J Cardiol. 1982;50(5):1164-72. [pmid: 6127946].
Furberg CD, Psaty BM. Corrections to the nifedipine meta-analysis. Circulation. 1996;93(7):1475-6. [pmid: 8641044].
Furberg CD, Psaty BM, Meyer JV. Nifedipine. Dose-related increase in mortality in patients with coronary heart disease. Circulation. 1995;92(5):1326-31. [pmid: 7648682].
Gersh B, Braunwald E, Rutherford J. Chronic coronary artery disease. In: Braunwald E, editor. Heart disease. 5th ed. Philadelphia: W.B. Saunders; 1997. p. 1289-1365.
Goldbarg AN, Moran JF, Butterfield TK, et al. Therapy of angina pectoris with propranolol and long-acting nitrates. Circulation. 1969;40(6):847-53.
Gorlin R. Treatment of chronic stable angina pectoris. Am J Cardiol. 1992;70(17):26G-31G. [pmid: 1615865].
Hauf-Zachariou U, Blackwood RA, Gunawardena KA, et al. Carvedilol versus verapamil in chronic stable angina: a multicentre trial. Eur J Clin Pharmacol. 1997;52(2):95-100. [pmid: 9174677].
Heart and Stroke Statistical Update, 1998. Dallas, TX: American Heart Association. 1998.
Hedges L. Fixed effects models. In: Cooper H, Hedges L, editors. The handbook of research synthesis. 5th ed. New York: Russel Sage Foundation; 1994. p. 285-300.
Hetzel M, Wieshammer S, Barnikel U, et al. Effects of antianginal therapy with atenolol and slow-release nifedipine on respiratory gas exchange and on the ventilatory requirements for aerobic exercise. Z Kardiol. 1994;83(Suppl 3):83-7.
Higginbotham MB, Morris KG, Coleman RE, et al. Chronic stable angina monotherapy. Nifedipine versus propranolol. Am J Med. 1989;86(1A):1-5.
Hill JA, Gonzalez JI, Kolb R, et al. Effects of atenolol alone, nifedipine alone and their combination on ambulant myocardial ischemia. Am J Cardiol. 1991;67(8):671-5. [pmid: 2006616].
Hoekenga D, Abrams J. Rational medical therapy for stable angina pectoris. Am J Med. 1984;76(2):309-14. [pmid: 6141729].
Hopkinson ND, Hui KP, Smith MP, et al. A comparison of sustained release verapamil versus atenolol for 24 h protection from exercise-induced angina pectoris. Eur Heart J. 1991;12(12):1273-7. [pmid: 1778191].
Humen DP, Kostuk WJ. Clinical response and effects on left ventricular function of isosorbide dinitrate added to propranolol or diltiazem monotherapy in patients with chronic stable angina. Can J Cardiol. 1991;7(2):74-80. [pmid: 2049686].
Humen DP, O'Brien P, Purves P, et al Effort angina with adequate beta-receptor blockade: comparison with diltiazem alone and in combination J Am Coll Cardiol 1986 7(2) 329 35View this and related citations using 2868030
Hung J, Lamb IH, Connolly SJ, et al. The effect of diltiazem and propranolol, alone and in combination, on exercise performance and left ventricular function in patients with stable effort angina: a double-blind, randomized, and placebo-controlled study. Circulation. 1983;68(3):560-7. [pmid: 6872168].
IMS Health. National Disease and Therapeutic Index. Electronic file. Plymouth Meeting, PA: IMS Health, Inc; 1998. Report No: NDTI Audit.
Johnson SM, Mauritson DR, Corbett JR, et al. Double-blind, randomized, placebo-controlled comparison of propranolol and verapamil in the treatment of patients with stable angina pectoris. Am J Med. 1981;71(3):443-51. [pmid: 7282732].
Johnston DL, Gebhardt VA, Donald A, et al. Comparative effects of propranolol and verapamil alone and in combination on left ventricular function and volumes in patients with chronic exertional angina: a double-blind, placebo-controlled, randomized, crossover study with radionuclide ventriculography. Circulation. 1983;68(6):1280-9. [pmid: 6315259].
Johnston DL, Manyari DE, Kostuk WJ. The clinical and hemodynamic effects of propranolol, pindolol and verapamil in the treatment of exertional angina pectoris. Can Med Assoc J. 1984;130(11):1449-55. [pmid: 6145515].
Kannel WB, Feinleib M. Natural history of angina pectoris in the Framingham study. Prognosis and survival. Am J Cardiol. 1972;29(2):154-63. [pmid: 5058341].
Karliner J. Stable angina pectoris. In: Chatterjee K, Cheitlin M, Karliner J, et al., editors. Cardiology. Philadelphia: J.B. Lippincott; 1991. p. 752-74.
Kawanishi DT, Reid CL, Morrison EC, et al. Response of angina and ischemia to long-term treatment in patients with chronic stable angina: a double-blind randomized individualized dosing trial of nifedipine, propranolol and their combination. J Am Coll Cardiol. 1992;19(2):409-17. [pmid: 1732370].
Kenmure AC, Scruton JH. A double-blind controlled trial of the anti-anginal efficacy of nifedipine compared with propranolol. Br J Clin Pract. 1979;33(2):49-51. [pmid: 387058].
Kenny J, Kiff P, Holmes J, et al. Beneficial effects of diltiazem and propranolol, alone and in combination, in patients with stable angina pectoris. Br Heart J. 1985;53(1):43-6. [pmid: 3881104].
Keyrilainen O, Nyberg G, Uusitalo AJ. Effects of alprenolol and isosorbide dinitrate in angina pectoris. A comparative study with methodological considerations. Acta Med Scand. 1973;193(4):281-92. [pmid: 4197870].
Khurmi NS, O'Hara MJ, Bowles MJ, et al. Effect of diltiazem and propranolol on myocardial ischaemia during unrestricted daily life in patients with effort-induced chronic stable angina pectoris. Eur J Clin Pharmacol. 1987;32(5):443-7. [pmid: 3622594].
Krepp HP. Evaluation of the antianginal and anti-ischemic efficacy of slow-release isosorbide-5-mononitrate capsules, bupranolol and their combination, in patients with chronic stable angina pectoris. Cardiology. 1991;79(Suppl 2):14-8. [pmid: 1760823].
Krikler DM. Calcium antagonists for chronic stable angina pectoris. Am J Cardiol. 1987;59(3):95B-100B.
Lai C, Onnis E, Orani E, et al. Felodipine improves the anti-ischaemic effect of metoprolol in stable effort-induced angina. Drug Invest. 1992;4(1):30-3.
Lai C, Onnis E, Pirisi R, et al. Anti-ischaemic and anti-anginal activity of atenolol, nifedipine and their combination in stable, chronic effort angina. Drugs Exp Clin Res. 1988;14(11):699-705. [pmid: 3073077].
Leenen FH. 1,4-Dihydropyridines versus beta-blockers for hypertension: are either safe for the heart? [editorial]. Cardiovasc Drugs Ther. 1996;10(4):397-402. [pmid: 8924051].
Lessem J. Combined therapy with Ca-antagonists and beta-adrenergic receptor blocking agents in chronic stable angina. Acta Med Scand Suppl. 1984;681:83-90. [pmid: 6428171].
Liang CS, Coplin B, Wellington K. Comparison of antianginal efficacy of nifedipine and isosorbide dinitrate in chronic stable angina: a long-term, randomized, double-blind, crossover study. Am J Cardiol. 1985;55(12):9E-14E.
Liao JZ, Chen JJ, Wu ZM, et al. Clinical and experimental studies of coronary heart disease treated with yi-qi huo-xue injection. J Tradit Chin Med. 1989;9(3):193-8. [pmid: 2615456].
Licciardello G, Privitera A, Calvi V, et al. Amlodipine vs nifedipine. A crossover study of efficacy and tolerability in patients with stable angina pectoris. Clin Drug Invest. 1997;13(Suppl 1):119-25.
Livesley B, Catley PF, Campbell RC, et al. Double-blind evaluation of verapamil, propranolol, and isosorbide dinitrate against a placebo in the treatment of angina pectoris. BMJ. 1973;1(850):375-8. [pmcid: 30582]. [pmid: 4570671].
Logan R, Ikram H, Webster M, et al. Comparative efficacy of nicardipine hydrochloride and atenolol in the treatment of chronic stable angina. Br J Clin Pharmac. 1986;22:345S-50S.
Lynch P, Dargie H, Krikler S, et al. Objective assessment of antianginal treatment: a double-blind comparison of propranolol, nifedipine, and their combination. BMJ. 1980;281(6234):184-7. [pmcid: 313898]. [pmid: 6773613].
Management of stable angina pectoris. Recommendations of the Task Force of the European Society of Cardiology. Eur Heart J. 1997;18(3):394-413. [pmid: 9076376].
McGill D, McKenzie W, McCredie M. Comparison of nicardipine and propranolol for chronic stable angina pectoris. Am J Cardiol. 1986;57(1):39-43. [pmid: 3510524].
McNamara JJ, Molot MA, Stremple JF, et al. Coronary artery disease in combat casualties in Vietnam. JAMA. 1971;216(7):1185-7. [pmid: 5108403].
Meyer EC, Makov UE, Palant A. Monotherapy of stable angina pectoris with bopindolol in comparison with diltiazem. Cardiology. 1991;78(3):179-84. [pmid: 1678316].
Miller WE, Vittitoe J, O'Rourke RA, et al. Nadolol versus diltiazem and combination for preventing exercise-induced ischemia in severe angina pectoris. Am J Cardiol. 1988;62(7):372-6. [pmid: 3414514].
Nadazdin A, Davies GJ. Investigation of therapeutic mechanisms of atenolol and diltiazem in patients with variable-threshold angina. Am Heart J. 1994;127(2):312-7. [pmid: 8296698].
North of England evidence-based guidelines development project: summary version of evidence-based guideline for the primary care management of angina. North of England Stable Angina Guideline Development Group. BMJ. 1996;312(7034):827-32. [pmcid: 128944]. [pmid: 8608294].
O'Hara MJ, Khurmi NS, Bowles MJ, et al. Comparison of diltiazem at two dose levels with propranolol for treatment of stable angina pectoris. Am J Cardiol. 1984;54(6):477-81. [pmid: 6383000].
O'Rourke RA. Cost-effective management of chronic stable angina. Clin Cardiol. 1996;19(6):497-501. [pmid: 8790956].
Pandolfo L, Pajes G, Zardi D, et al. Anti-ischaemic efficacy of amlodipine vs nifedipine in the treatment of patients with stable exertional angina. Clin Drug Invest. 1997;13(Suppl 1):113-8.
Parameshwar J, Keegan J, Mulcahy D, et al. Atenolol or nicardipine alone is as efficacious in stable angina as their combination: a double blind randomised trial. Int J Cardiol. 1993;40(2):135-41. [pmid: 8349376].
Parker JD, Parker JO. Nitrate therapy for stable angina pectoris. N Engl J Med. 1998;338(8):520-31. [pmid: 9468470].
Parker JO, Farrell B. Comparative antianginal effects of bepridil and propranolol in angina pectoris. Am J Cardiol. 1986;58(6):449-52. [pmid: 3529909].
Petitti D. Statistical methods in meta-analysis. In: Meta-analysis, decision analysis and cost-effectiveness analysis. New York: Oxford University Press; 1994. p. 90-114.
Pflugfelder PW, Humen DP, O'Brien PA, et al. Comparison of bepridil with nadolol for angina pectoris. Am J Cardiol. 1987;59(15):1283-8. [pmid: 3296724].
Physicians' desk reference. Montvale, NJ: Medical Economics Company; 1998.
Psaty BM, Heckbert SR, Koepsell TD, et al. The risk of myocardial infarction associated with antihypertensive drug therapies. JAMA. 1995;274(8):620-5. [pmid: 7637142].
Rae AP, Beattie JM, Lawrie TD, et al. Comparative clinical efficacy of bepridil, propranolol and placebo in patients with chronic stable angina. Br J Clin Pharmacol. 1985;19(3):343-52. [pmid: 3885985].
Rehnqvist N, Hjemdahl P, Billing E, et al. Effects of metoprolol vs. verapamil in patients with stable angina pectoris. The Angina Prognosis Study in Stockholm (APSIS). Eur Heart J. 1996;17(1):76-81. [pmid: 8682134].
Richter A, Herlitz J, Hjalmarson A. Effect of acupuncture in patients with angina pectoris. Eur Heart J. 1991;12(2):175-8.
Riley M, Elborn JS, Khan MM, et al. Comparative effects of epanolol and diltiazem on exercise performance and respiratory gas exchange in angina pectoris. Eur Heart J. 1992;13(8):1116-22. [pmid: 1354616].
Roberts R. Stable angina as a manifestation of ischemic heart disease: medical management. Circulation. 1985;72(6 Pt 2):V145-54. [pmid: 2866048].
Romano M, Di Maro T, Carella G, et al. Atenolol and/or nifedipine in effort angina: which is the treatment of choice for exercise coronary protection?. Int J Clin Pharmacol Ther Toxicol. 1988;26(9):468-70. [pmid: 3198303].
Romano M, di Maro T, Cotecchia MR, et al. Long-term management of exercise-induced myocardial ischemia. Diltiazem versus propranolol, a double-blind, crossover study. Int J Clin Pharmacol Ther Toxicol. 1986;24(10):551-4. [pmid: 3781675].
Rousseau MF, Hanet C, Pardonge-Lavenne E, et al. Changes in myocardial metabolism during therapy in patients with chronic stable angina: a comparison of long-term dosing with propranolol and nicardipine. Circulation. 1986;73(6):1270-80. [pmid: 3698257].
Sadick NN, Tan AT, Fletcher PJ, et al. A double-blind randomized trial of propranolol and verapamil in the treatment of effort angina. Circulation. 1982;66(3):574-9. [pmid: 7046990].
Savonitto S, Ardissiono D, Egstrup K, et al Combination therapy with metoprolol and nifedipine versus monotherapy in patients with stable angina pectoris. Results of the International Multicenter Angina Exercise (IMAGE) Study J Am Coll Cardiol 1996 27(2) 311 6View this and related citations using 8557899
Schneider W, Maul FD, Bussmann WD, et al. Comparison of the antianginal efficacy of isosorbide dinitrate (ISDN) 40 mg and verapamil 120 mg three times daily in the acute trial and following two-week treatment. Eur Heart J. 1988;9(2):149-58.
Schulte KL. 24 h anti-anginal and anti-ischaemic effects with once daily felodipine. A double-blind comparison with nifedipine, twice daily, and placebo in patients with stable exercise-induced angina pectoris. Eur Heart J. 1995;16(2):171-6. [pmid: 7744087].
Shadish W, Haddock C. Combining estimates of effect size. In: Cooper H, Hedges L, editors. Handbook of research synthesis. 5th ed. New York: Russel Sage Foundation; 1994. p. 261-82.
Shapiro W, Narahara KA, Kostis JB, et al. Comparison of atenolol and nifedipine in chronic stable angina pectoris. Am J Cardiol. 1989;64(3):186-90. [pmid: 2662743].
Shub C. Stable angina pectoris: 3. Medical treatment. Mayo Clin Proc. 1990;65(2):256-73. [pmid: 1968113].
Sigurd B, Hansen JF. Verapamil or propranolol in the treatment of stable angina pectoris of effort. Acta Med Scand Suppl. 1984;681:75-81. [pmid: 6428170].
Singh S. Long-term double-blind evaluation of amlodipine and nadolol in patients with stable exertional angina pectoris. The Investigators of Study 152. Clin Cardiol. 1993;16(1):54-8. [pmid: 8416762].
Siu SC, Jacoby RM, Phillips RT, et al. Comparative efficacy of nifedipine gastrointestinal therapeutic system versus diltiazem when added to beta-blockers in stable angina pectoris. Am J Cardiol. 1993;71(11):887-92. [pmid: 8096670].
Southall E, Nutt NR, Thomas RD. Chronic stable angina: comparison of verapamil and propranolol. J Int Med Res. 1982;10(5):361-6. [pmid: 6754509].
Steffensen R, Grande P, Pedersen F, et al. Effects of atenolol and diltiazem on exercise tolerance and ambulatory ischaemia. Int J Cardiol. 1993;40(2):143-53. [pmid: 8349377].
Steffensen R, Melchior T, Bech J, et al. Effects of amlodipine and isosorbide dinitrate on exercise-induced and ambulatory ischemia in patients with chronic stable angina pectoris. Cardiovasc Drugs Ther. 1997;11(5):629-35. [pmid: 9493700].
Stone PH, Gibson RS, Glasser SP, et al. Comparison of propranolol, diltiazem, and nifedipine in the treatment of ambulatory ischemia in patients with stable angina. Differential effects on ambulatory ischemia, exercise performance, and anginal symptoms. The ASIS Study Group. Circulation. 1990;82(6):1962-72. [pmid: 2122926].
Strauss WE, Parisi AF. Superiority of combined diltiazem and propranolol therapy for angina pectoris. Circulation. 1985;71(5):951-7. [pmid: 3921278].
Subramanian VB, Bowles MJ, Davies AB, et al. Calcium channel blockade as primary therapy for stable angina pectoris. A double-blind placebo-controlled comparison of verapamil and propranolol. Am J Cardiol. 1982;50(5):1158-63. [pmid: 6127945].
Thadani U. Management of patients with chronic stable angina at low risk for serious cardiac events. Am J Cardiol. 1997;79(12B):24-30. [pmid: 9223354].
Uusitalo A, Arstila M, Bae EA, et al. Metoprolol, nifedipine, and the combination in stable effort angina pectoris. Am J Cardiol. 1986;57(10):733-7. [pmid: 3083664].
van de Ven LL, Vermeulen A, Tans JG, et al. Which drug to choose for stable angina pectoris: a comparative study between bisoprolol and nitrates. Int J Cardiol. 1995;47(3):217-23. [pmid: 7721498].
van der Does R, Eberhardt R, Derr I, et al. Treatment of chronic stable angina with carvedilol in comparison with nifedipine s. r. Eur Heart J. 1991;12(1):60-4.
van der Does R, Eberhardt R, Derr I, et al. Efficacy and safety of carvedilol in comparison with nifedipine sustained-release in chronic stable angina. J Cardiovasc Pharmacol. 1992;19(Suppl 1):S122-7.
van Dijk RB, Lie KI, Crijns HJ. Diltiazem in comparison with metoprolol in stable angina pectoris. Eur Heart J. 1988;9(11):1194-9. [pmid: 3234411].
Vetrovec GW, Parker VE. Alternative medical treatment for patients with angina pectoris and adverse reactions to beta blockers. Usefulness of nifedipine. Am J Med. 1986;81(4A):20-7.
Vlay SC, Olson LC. Nifedipine and isosorbide dinitrate alone and in combination for patients with chronic stable angina: a double-blind crossover study. Am Heart J. 1990;120(2):303-7. [pmid: 2200253].
Vliegen HW, van der Wall EE, Kragten JA, et al. Comparison of diltiazem standard formulation and diltiazem controlled release in patients with stable angina pectoris: a randomized, double-blind, cross-over, multicenter study. J Cardiovasc Pharmacol. 1993;21(4):552-9. [pmid: 7681899].
von Arnim T Medical treatment to reduce total ischemic burden: Total Ischemic Burden Bisoprolol Study (TIBBS), a multicenter trial comparing bisoprolol and nifedipine. The TIBBS Investigators J Am Coll Cardiol 1995 25(1) 231 8View this and related citations using 7798508
von Arnim T, Erath A, Reuschel-Janetschek E. Isosorbide-5-mononitrate and nifedipine can reduce ischaemic ST-segment changes during Holter monitoring in patients with spontaneous angina pectoris. Eur Heart J. 1988;9(Suppl A):113-8.
Wallace WA, Wellington KL, Chess MA, et al. Comparison of nifedipine gastrointestinal therapeutic system and atenolol on antianginal efficacies and exercise hemodynamic responses in stable angina pectoris. Am J Cardiol. 1994;73(1):23-8. [pmid: 8279372].
Wang XF, Shi DZ, Tu XH. [Clinical observation of wenxin decoction in treating 82 patients with spontaneous angina pectoris]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1996;16(4):201-3. [pmid: 9206239].
Waysbort J, Meshulam N, Brunner D. Isosorbide-5-mononitrate and atenolol in the treatment of stable exertional angina. Cardiology. 1991;79(Suppl 2):19-26. [pmid: 1760824].
Weidemann H, Schober B, Schuon J. Comparative study of long-term effects of Molsidomin 8 mg (slow release form) and ISDN 40 mg (slow release form) on angina pectoris and ischaemic ST-segment depression during maximal bicycle-ergometry in patients with coronary insufficiency. Eur Heart J. 1987;8(Suppl G):63-9.
Wheatley D. A comparison of diltiazem and atenolol in angina. Postgrad Med J. 1985;61(719):785-9. [pmid: 3903709].
Wieshammer S, Hetzel M, Barnikel U, et al. Effects of atenolol, slow-release nifedipine, and their combination on respiratory gas exchange and exercise tolerance in stable effort angina. Klin Wochenschr. 1991;69(14):645-51. [pmid: 1749203].
Willerson JT. Stable angina pectoris: recent advances in predicting prognosis and treatment. Adv Intern Med. 1998;43:175-202. [pmid: 9506182].
Wu Y. [Clinical study on xintongkang capsule in treating angina pectoris of coronary heart disease]. Chung Hsi I Chieh Ho Tsa Chih. 1990;10(7):387, 395-8.
Zanolla L, Franceschini L, Rossi L, et al. Nifedipine GITS versus diltiazem in chronic stable angina: a randomised multicentre study. Br J Clin Pract Suppl. 1997;88:27-35. [pmid: 9519505].
Zhang H, Liang MJ, Ma ZX. [Clinical study on effects of buyang huanwu decoction on coronary heart disease]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1995;15(4):213-5. [pmid: 7647542].
Zhou XQ, Liu JX. [Metrological analysis for efficacy of acupuncture on angina pectoris]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1993;13(4):196, 212-4.
Zhu HG. [Clinical study on xinkening in treating asymptomatic myocardial ischemia in coronary heart disease]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1994;14(4):196, 213-5.