# References

Alderman MH, Cohen H, Roque R, et al. Effect of long-acting and short-acting calcium antagonists on cardiovascular outcomes in hypertensive patients [see comments]. Lancet. 1997;349(9052):594-8. [pmid: 9057730].
Ballegaard S, Meyer CN, Trojaborg W. Acupuncture in angina pectoris: does acupuncture have a specific effect?. J Intern Med. 1991;229(4):357-62. [pmid: 2026989].
Ballegaard S, Pedersen F, Pietersen A, et al. Effects of acupuncture in moderate, stable angina pectoris: a controlled study. J Intern Med. 1990;227(1):25-30. [pmid: 2105371].
Cai PY, Xu BT, Shen BY. [A clinical study of hehuantang in treating coronary heart disease]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1996;16(4):204-6. [pmid: 9206240].
Chan PK, Heo JY, Garibian G, et al. The role of nitrates, beta-blockers, and calcium antagonists in stable angina pectoris. Am Heart J. 1988;116(3):838-48. [pmid: 2901214].
Chen K, Zhou WQ, Gao P. [Clinical study on the effect of shuxuening tablet in treatment of coronary heart disease]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1996;16(1):24-6. [pmid: 8732126].
Dargie HJ, Ford I, Fox KM. Total Ischaemic Burden European Trial (TIBET). Effects of ischaemia and treatment with atenolol, nifedipine SR and their combination on outcome in patients with chronic stable angina. The TIBET Study Group. Eur Heart J. 1996;17(1):104-12. [pmid: 8682116].
DerSimonian R, Laird N. Meta-analysis in clinical trials. Controlled Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
Donaldson KM, Dawkins KD, Waller DG. A comparison of nisoldipine and nifedipine, in combination with atenolol, in the management of myocardial ischaemia. Eur Heart J. 1993;14(4):534-9. [pmid: 8472719].
Easterbrook PJ, Berlin JA, Gopalan R, et al. Publication bias in clinical research. Lancet. 1991;337(8746):867-72. [pmid: 1672966].
Egger M, Zellweger-Zahner T, Schneider M, et al. Language bias in randomised controlled trials published in English and German. Lancet. 1997;350(9074):326-9. [pmid: 9251637].
Fang J, Jiang J, Luo DC. [Effect of sheng mai decoction on left ventricular function in patients with coronary heart disease. A randomized, double-blind, placebo-controlled, crossover trial]. Chung Hua Nei Ko Tsa Chih. 1987;26(7):403-6, 445. [pmid: 3322707].
Fox KM, Jespersen CM, Ferrari R, et al. How European cardiologists perceive the role of calcium antagonists in the treatment of stable angina. Eur Heart J. 1997;18 Suppl A:A113-6. [pmid: 9049546].
Furberg CD, Psaty BM. Corrections to the nifedipine meta-analysis. Circulation. 1996;93(7):1475-6. [pmid: 8641044].
Furberg CD, Psaty BM, Meyer JV. Nifedipine. Dose-related increase in mortality in patients with coronary heart disease. Circulation. 1995;92(5):1326-31. [pmid: 7648682].
Gersh B, Braunwald E, Rutherford J. Chronic coronary artery disease. In: Braunwald E, editor. Heart disease. 5th ed. Philadelphia: W.B. Saunders; 1997. p. 1289-1365.
Hedges L. Fixed effects models. In: Cooper H, Hedges L, editors. The handbook of research synthesis. 5th ed. New York: Russel Sage; 1994. p. 285-300.
Hoekenga D, Abrams J. Rational medical therapy for stable angina pectoris. Am J Med. 1984;76(2):309-14. [pmid: 6141729].
IMS Health. National Disease and Therapeutic Index. Electronic file. Plymouth Meeting, PA: IMS Health; 1998. Report No: NDTI Audit.
Karliner J. Stable angina pectoris. In: Chatterjee K, Cheitlin M, Karliner J, et al., editors. Cardiology. Philadelphia: J.B. Lippincott; 1991. p. 752-74.
Liao JZ, Chen JJ, Wu ZM, et al. Clinical and experimental studies of coronary heart disease treated with yi-qi huo-xue injection. J Tradit Chin Med. 1989;9(3):193-8. [pmid: 2615456].
Licciardello G, Privitera A, Calvi V, et al. Amlodipine vs nifedipine. A crossover study of efficacy and tolerability in patients with stable angina pectoris. Clin Drug Invest. 1997;13(Suppl 1):119-25.
Management of stable angina pectoris. Recommendations of the Task Force of the European Society of Cardiology. Eur Heart J. 1997;18(3):394-413. [pmid: 9076376].
North of England evidence-based guidelines development project: summary version of evidence-based guideline for the primary care management of angina. North of England Stable Angina Guideline Development Group. BMJ. 1996;312(7034):827-32. [pmcid: 128944]. [pmid: 8608294].
Pandolfo L, Pajes G, Zardi D, et al. Anti-ischaemic efficacy of amlodipine vs nifedipine in the treatment of patients with stable exertional angina. Clin Drug Invest. 1997;13(Suppl 1):113-8.
Petitti D. Statistical methods in meta-analysis. In: Meta-analysis, decision analysis and cost-effectiveness analysis. New York: Oxford University Press; 1994. p. 90-114.
Physicians' desk reference. Montvale, NJ: Medical Economics Company; 1998.
Psaty BM, Heckbert SR, Koepsell TD, et al. The risk of myocardial infarction associated with antihypertensive drug therapies. JAMA. 1995;274(8):620-5. [pmid: 7637142].
Rehnqvist N, Hjemdahl P, Billing E, et al. Effects of metoprolol vs verapamil in patients with stable angina pectoris. The Angina Prognosis Study in Stockholm (APSIS). Eur Heart J. 1996;17(1):76-81. [pmid: 8682134].
Richter A, Herlitz J, Hjalmarson A. Effect of acupuncture in patients with angina pectoris. Eur Heart J. 1991;12(2):175-8.
Roberts R. Stable angina as a manifestation of ischemic heart disease: medical management. Circulation. 1985;72(6 Pt 2):V145-54. [pmid: 2866048].
Schulte KL. 24 h anti-anginal and anti-ischaemic effects with once daily felodipine. A double-blind comparison with nifedipine, twice daily, and placebo in patients with stable exercise-induced angina pectoris. Eur Heart J. 1995;16(2):171-6. [pmid: 7744087].
Shadish W, Haddock C. Combining estimates of effect size. In: Cooper H, Hedges L, editors. Handbook of research synthesis. 5th ed. New York: Russel Sage Foundation; 1994. p. 261-82.
Siu SC, Jacoby RM, Phillips RT, et al. Comparative efficacy of nifedipine gastrointestinal therapeutic system versus diltiazem when added to beta-blockers in stable angina pectoris. Am J Cardiol. 1993;71(11):887-92. [pmid: 8096670].
Thadani U. Management of patients with chronic stable angina at low risk for serious cardiac events. Am J Cardiol. 1997;79(12B):24-30. [pmid: 9223354].
Wallace WA, Wellington KL, Chess MA, et al. Comparison of nifedipine gastrointestinal therapeutic system and atenolol on antianginal efficacies and exercise hemodynamic responses in stable angina pectoris. Am J Cardiol. 1994;73(1):23-8. [pmid: 8279372].
Wang XF, Shi DZ, Tu XH. [Clinical observation of wenxin decoction in treating 82 patients with spontaneous angina pectoris]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1996;16(4):201-3. [pmid: 9206239].
Wu Y. [Clinical study on xintongkang capsule in treating angina pectoris of coronary heart disease]. Chung Hsi I Chieh Ho Tsa Chih. 1990;10(7):387, 395-8.
Zanolla L, Franceschini L, Rossi L, et al. Nifedipine GITS versus diltiazem in chronic stable angina: a randomised multicentre study. Br J Clin Pract Suppl. 1997;88:27-35. [pmid: 9519505].
Zhang H, Liang MJ, Ma ZX. [Clinical study on effects of buyang huanwu decoction on coronary heart disease]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1995;15(4):213-5. [pmid: 7647542].
Zhou XQ, Liu JX. [Metrological analysis for efficacy of acupuncture on angina pectoris]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1993;13(4):212-4, 196. [pmid: 8400769].
Zhu HG. [Clinical study on xinkening in treating asymptomatic myocardial ischemia in coronary heart disease]. Chung Kuo Chung Hsi I Chieh Ho Tsa Chih. 1994;14(4):213-5, 196. [pmid: 7950196].