# Acknowledgments

This report was developed with support from the Agency for Health Care Policy and Research, now the Agency for Healthcare Research and Quality. Dr. Heidenreich is supported by a career development award from the Veterans Affairs Health Services Research and Development Service. The authors thank Lyn Dupré, Mary Grady, and the peer reviewers for comments on the manuscript, and the members of the University of California, San Francisco (UCSF)-Stanford EPC Governing Council for their suggestions. The authors also thank Francis Chesley, M.D., and the members and support staff of the Stable Angina Guidelines Committee (American College of Cardiology, American Heart Association, American College of Physicians) for guidance throughout the project; Dr. Drummond Rennie and Dr. Lisa Bero for developing a peer review process for evidence reports; and Dr. Patricia Huston for developing a coherent and constructive synthesis of peer review commentaries.