# Conclusions and Future Research

## Discussion of Findings

This quantitative overview shows that calcium antagonists were associated with a greater number of angina episodes and adverse events when compared with beta-blockers in trials of patients who have stable angina. Beta-blockers and nonnifedipine calcium antagonists had similar effects on adverse events, symptoms, and exercise tolerance. Trial duration was too short to determine differences in long-term rates of survival or myocardial infarction between calcium antagonists and beta-blockers.

Our finding that beta-blockers were tolerated as well as calcium antagonists was not expected. Past reviews have noted frequent side effects with beta-blockers ( Hoekenga and Abrams, 1984 ), whereas calcium antagonists have been recommended and widely used because of their low side-effect profile ( Chan, Heo, Garibian, et al., 1988 ; Fox, Jespersen, Ferrari, et al., 1997 ). Our findings must be tempered by noting that patients who were thought unlikely to tolerate beta-blockers (patients with congestive heart failure, heart block, or significant pulmonary disease) were generally excluded from the randomized studies. Thus, our findings cannot be extrapolated to patients who have these conditions. However, our findings suggest that patients who do not have these contraindications should have equal or greater success in finding angina relief and freedom from adverse events when they use a beta-blocker instead of a calcium antagonist.

Recently, the safety of calcium antagonists for patients who have coronary artery disease has been questioned. Prior meta-analyses and case-control studies have demonstrated an increased risk of myocardial infarction in hypertensive patients who take short-acting calcium antagonists ( Psaty, Heckbert, Koepsell, et al., 1995 ). In patients who have acute coronary syndromes, mortality increased with increasingly large doses of short-acting nifedipine ( Furberg and Psaty, 1996 ; Furberg, Psaty, and Meyer, 1995 ). In a recent case-control study, short-acting calcium antagonists were associated with a four-fold increase in the risk of cardiovascular deaths and of hospital admission when compared with the risk from beta-blockers ( Alderman, Cohen, Roque, et al., 1997 ). Our study was unable to determine whether important differences in mortality or myocardial infarction rates exist in the stable angina population between anti-anginals because followup was less than 6 months in all but two studies. This important question will have to be addressed by larger, long-term comparisons of these agents.

Our study suggests that nifedipine may not be as well tolerated as other calcium antagonists. This finding is consistent with past investigations of long-acting nifedipine. In six small randomized studies of at least 1-week duration that compared long-acting nifedipine with other calcium antagonists, long-acting nifedipine was associated with more symptoms and side effects in two studies ( Licciardello, Privitera, Calvi, et al., 1997 ; Pandolfo, Pajes, Zardi, et al., 1997) and was equivalent to other calcium antagonists in four studies ( Donaldson, Dawkins, and Waller, 1993 ; Schulte, 1995 ; Siu, Jacoby, Phillips, et al., 1993 ; Zanolla, Franceschini, Rossi, et al., 1997 ).

European data are consistent with the U.S. findings that calcium blockers are preferred over beta-blockers for first-line therapy for patients who have stable angina ( Fox, Jespersen, Ferrari, et al., 1997 ). These findings contrast with our results that beta-blockers were equivalent to or better than long-acting nitrates and calcium antagonists in tolerability and in angina reduction. Because patients frequently tolerate the first drug with which they are treated, it is likely that the reported drug use data reflect the physicians' first choice of agents. An alternative explanation for the disparity is that effectiveness and tolerability differ substantially between the trial and practice setting, such that patients are frequently switched from beta-blockers to other therapy because of problems not measured in the trials.

The choice of a first-line agent for use in patients who have stable angina has been addressed by recent clinical guidelines. The European Society of Cardiology recommends beta-blockers for patients who have clear-cut effort-related angina or a prior myocardial infarction ( Management of stable angina pectoris, 1997 ). The North of England Stable Angina Guideline Development Group recommends beta-blockers for all patients who have no contraindications ( North of England evidence-based guidelines, 1996 ), citing evidence that beta-blockers lower mortality after myocardial infarction, reduce mortality for patients who do have a subsequent infarction while on medication, and reduce adverse vascular events in patients who have hypertension. Data from our study support these recommendations. We add evidence that beta-blockers are tolerated as well as or better than calcium antagonists and long-acting nitrates, and they provide angina relief equivalent to these agents.

Despite the effectiveness of current medical treatment, there are patients whose symptoms are refractory to beta-blockers, calcium antagonists, nitrates, and revascularization, or who are unable to tolerate these conventional treatments. These patients may seek nonconventional (alternative) treatments for their angina. Although patients frequently note relief with these therapies, often it is not clear whether the benefit is caused by a direct effect of the therapy or a placebo effect. Randomized placebo-controlled trials are needed to separate direct effect from placebo. Our review identified only two therapies (acupuncture and herbal therapy) that have been examined with this degree of rigor. In two small trials, traditional acupuncture was found to be superior to sham acupuncture in terms of improved exercise time but was not shown to affect symptoms. Our review of herbal therapy is limited because the few trials using placebo, calcium antagonist, or nitrate controls were published in Chinese, and the English abstracts were unclear. Randomized trials of alternative treatments for angina are just beginning, and only a limited number of patients have been evaluated. Thus, at this time we have no clear indication of the benefit or harm from these therapies for patients who have stable angina.

## Limitations

Like those of any meta-analysis, our findings may have been affected by publication bias ( Easterbrook, Berlin, Gopalan, et al., 1991 ). It is possible that studies that failed to demonstrate significant differences were not submitted or were not accepted for publication. However, few (25 percent) of the studies included in the meta-analysis demonstrated significant differences between drugs, suggesting that any such bias may be small. Rarely did the studies include patients who had congestive heart failure, chronic obstructive lung disease, or nonexertional chest pain; thus, our findings are not applicable to these types of patients. Only a few small studies compared long-acting nitrates with calcium antagonists or beta-blockers. Therefore, our analysis was unlikely to detect any clinically important differences between these agents.

The majority of patients enrolled in the trials were men; thus, it is unclear if women respond similarly to treatment. Outcomes for each trial were not listed separately by age, sex, or ethnicity subgroup so that the effect of these variables on response to treatment could not be determined. Our search strategy using MEDLINE and EMBASE may not have identified all randomized trials of alternative therapies. We did not include studies reported in foreign-language publications in our meta-analysis. A recent study has found that studies published in English are more likely to have p values < 0.05 ( Egger, Zellweger-Zahner, Schneider, et al., 1997 ). However, a review of the English abstracts that were available (50 percent of foreign language studies) did not demonstrate a difference in significant findings.

Our study did not examine measures of quality of life. Although adverse events severe enough to lead to withdrawal from the study occurred less frequently in patients treated with beta-blockers than in those treated with calcium antagonists, less severe side effects were not consistently reported, so we could not adequately measure differences in their rates. Commonly reported side effects were similar or greater in patients treated with calcium antagonists compared with patients who were given beta-blockers. Longer term studies are required if we are to determine differences in safety between classes of anti-anginals. Since the studies in our analyses were predominantly of short duration, cardiac events were rare and the power to detect differences in cardiac events was low.

## Summary

Our quantitative review suggests that beta-blockers provide equivalent or greater reduction in angina episodes per week and lead to similar or reduced rates of adverse events, when compared with either calcium antagonists or long-acting nitrates. The differences in rate of adverse events and frequency of angina between beta-blockers and calcium antagonists are accounted for in large part by nifedipine, which was associated with a higher rate of adverse events and angina symptoms. There were no differences in angina episodes per week or adverse event rates between nonnifedipine calcium antagonists and beta-blockers. Further studies are required to determine whether the different therapies are associated with a significant difference in mortality in patients who have stable angina. There is insufficient evidence to comment on the effectiveness of alternative therapies.

## Future Research

Few long-term studies have compared treatment with beta-blockers, calcium antagonists, and long-acting nitrates in patients who have stable angina. Additional large randomized trials are needed to determine if clinically important differences in patient survival exist between classes of anti-anginal medication. Further studies are needed to examine the effects of treatments for stable angina in patients with comorbidity such as heart failure or chronic obstructive pulmonary disease. Additional randomized controlled trials of alternative therapies in this patient population are necessary to reach conclusions about efficacy and safety.