# Methodology

## Data Sources

We searched MEDLINE (1966-1997) and EMBASE (1974-1997) and reviewed cited references of retrieved articles to identify published studies. Our search criteria were (1) the MESH heading "angina pectoris" or the text word "angina" and (2) publication type "randomized controlled trial" or text word containing a form of the word "random." Using this criteria set, we searched MEDLINE, then EMBASE. We also performed searches replacing the second criterion with (3) publication type "controlled clinical trial" or (4) text word "double-blind." Finally, we reviewed the bibliographies of identified trials to locate other relevant studies.

To search for alternative therapies for stable angina treatments, we used the same search criteria noted above with the following key words: meditation, prayer, naturopathy, chiropractic, osteopathic, holistic, natural medicine, homeopathy, mind-body, unorthodox, integrative ayurvedic, acupuncture, herbal, relaxation, and chelation.

## Study Selection: Traditional Therapies

We restricted our review to controlled trials that directly compared drugs from two or three of the major anti-anginal drug classes: long-acting nitrates, beta-blockers, and calcium antagonists. Trials were included if they enrolled patients who had a history of stable angina. Studies of parallel design were included if they were randomized. We limited the parallel trials to those that were randomized because, unlike cohort and case-control studies, the randomized trial design is not limited by confounding. Blinded crossover studies, in which each patient receives both therapies, were included. Studies of the following designs were excluded: one drug versus placebo, dose comparison of one drug, and one drug versus a two-drug combination. These trial designs do not allow a direct comparison between different drug classes. Studies with duration of less than 1 week were excluded because the short duration would not allow adequate measures of effectiveness and adverse events. We excluded trials that used a study medication during a run-in period prior to randomization because the randomized portion did not include any patients who developed side effects early.

## Study Selection: Alternative Therapies

We included all randomized trials of alternative therapies compared with placebo, nitrates, calcium antagonists, or beta-blockers in patients who had stable angina. We abstracted data from these trials. Because few alternative therapy trials fit these criteria, shorter duration (< 1 week) studies were not excluded.

## Outcome Measures

We examined measures of anti-anginal efficacy and tolerability, conducting separate meta-analyses for each outcome. Anti-anginal efficacy measures were number of angina episodes per week (patient recorded), number of nitroglycerin uses per week (patient recorded), total exercise time, and time to 1-mm ST depression on a treadmill or upright bicycle. The tolerability measure was the rate of subject withdrawal from the study as a result of adverse events (cardiac and noncardiac symptoms and death), exclusive of protocol violations or loss to followup. All side effects from the following classes were recorded: worsening angina, headache, other central nervous system (CNS) disturbance, gastrointestinal disturbance, and peripheral edema. We also examined the combined endpoint of cardiac death or nonfatal myocardial infarction for studies in which either was reported.

## Data Extraction

Titles of identified articles were reviewed by the project director and one other cardiologist. Candidate abstracts were then reviewed and appropriate studies were selected for data retrieval. Two independent reviewers extracted data from each article. The reviewers compared their results and settled any differences by consensus. One of the two reviewers had cardiology training; the other had training in epidemiology or health services research. All outcomes data were abstracted a third time by the project director or another cardiologist.

## Subgroup Comparisons

We examined several subgroups of trials to determine their contribution to the summary differences between beta-blockers and calcium antagonists. The two prespecified comparisons of interest were nifedipine versus non-nifedipine calcium antagonists and short- versus long-acting calcium antagonists. Short-acting preparations were defined as those with usual dosing of three or more times per day according to the Physicians' Desk Reference (1998). We also grouped calcium antagonists as dihydropyridine and non-dihydropyridine. Additional comparisons were made based on funding source (industry versus other), location of trial (Europe versus the United States), and a quality indicator (randomization and double-blinding stated versus both not stated). Because several of the trials examined drugs that are rarely used for stable angina, we repeated our analysis after limiting the trials to those agents most commonly used in the United States. To determine market share, we obtained pharmaceutical data from the National Disease and Therapeutic Index that described the frequency of medications prescribed during the first quarter of 1998 for stable angina (in the absence of hypertension) (IMS Health, 1998). Based on these data, the common (2 percent or more market share) therapies were limited to four calcium antagonists (amlodipine, diltiazem, nifedipine, and verapamil) and five beta-blockers (atenolol, carvedilol, propranolol, metoprolol, and nadolol). We did not evaluate subgroups of long-acting nitrates because of the small number of trials for this class of agents.

## Statistical Analysis

We combined estimates of the mean difference for number of angina episodes and number of nitroglycerin tablets used per week; the standardized mean difference for exercise time; and the odds ratio for adverse events, cardiac death, and myocardial infarction (Shadish and Haddock, 1994). The mean difference between the treatment and control group is difference_i_ = mean_ti_ - mean_ci_ where t is the treatment and c the control group for the ith study. The estimated variance is v_i_ = ^2^_i_(1/n_ti_ + 1/n_ci_), where n is the within-study sample size for the treatment and control groups and ^2^ is estimated as the pooled within-group variance.

We used the standardized mean difference to compare exercise times because exercise protocols varied widely across studies. This measure expresses the difference in mean exercise time as a fraction of the standard deviation. The measure is calculated as d_i_ = (mean_ti_ - mean_ti_)/ pooled SD where SD is the standard deviation. The variance for this value is estimated as v_i_ = [(n_ti_ + n_ci_)/ n_ti_n_ci_] + [d_i_^2^ /2(n_ti_ + n_ci_)] . For this comparison, a positive value indicates increased exercise time in the treatment group. We pooled both mean differences and standardized mean differences by weighting the individual differences by the inverse of the variance.

We used the DerSimonian-Laird (random-effects) and Peto (fixed-effects) methods to estimate summary odds ratios for the outcomes of death or myocardial infarction and withdrawal caused by adverse events (DerSimonian and Laird, 1986; Petitti, 1994). Fixed results are presented unless otherwise stated. For studies that reported no events, we substituted 0.1 in place of 0 for the random-effects calculation. Because events were rare, we chose a value below the more commonly used 0.5. We tested homogeneity of study effect size using the Q statistic (Petitti, 1994). A summary rate difference was calculated for trials with one or more adverse events (Petitti, 1994). This measure complements the odds ratio by providing an absolute difference in the adverse event rate. We examined differences between study subgroups of trials using analysis of variance (Hedges, 1994). We did not pool data on individual side effects that did not lead to study withdrawal because these data were inconsistently reported.

For the outcomes of cardiac death, myocardial infarction, and adverse events, the study sample size was defined as the number of patients randomized. For the outcomes of angina episodes, nitroglycerin use, and time spent exercising, the sample size was defined as the number of patients who completed the study. Data are presented as summary odds ratio or summary rate difference (95 percent confidence interval). Reported p values are two-tailed with statistical significance at p < 0.05.

## Key Questions

1 Is one class of anti-anginals (beta-blockers, nitrates, or calcium antagonists) superior as monotherapy in terms of occurrence of angina, nitroglycerin use, exercise tolerance, or adverse events leading to study withdrawal in patients with stable angina?
2 Is one class of drugs superior when longer term outcomes such as recurrent myocardial infarction or death are examined?
3 Are any alternative medical treatments including chelation therapy, acupuncture, herbal medications, and garlic superior to placebo in any outcome measure for patients with stable angina?

## Quality Control

In addition to the double abstraction method described above, we examined a random sample of 16 studies to determine errors in abstraction or database entry. Few errors were found in abstraction of primary outcomes. However, because of the importance of this area of abstraction to the evidence report, we rechecked all articles for endpoints of mortality, angina episodes, nitroglycerin use, exercise time, and adverse events.

## Peer Review

Selected independent experts in the fields of internal medicine, family practice, cardiology, epidemiology, and systematic reviews reviewed the draft manuscript of the evidence report. In addition, the following organizations were invited to nominate individuals to review the manuscript: American Academy of Family Physicians (reviewed), American Academy of Medical Acupuncture and Medical Acupuncture Research Foundation (reviewed), American Academy of Nursing, American Association of Pharmaceutical Scientists (reviewed), American College of Cardiology, American College of Chest Physicians, American College of Clinical Pharmacology, American College of Physicians, American Geriatrics Society (reviewed), American Heart Association, American Nurses Foundation (reviewed), American Society of Health-System Pharmacists (reviewed), Council of Colleges for Acupuncture and Oriental Medicine (reviewed), and the Gerontological Society of America.

The San Francisco Cochrane Center coordinated these reviews and sent them to a criticism editor for synthesis and commentary. We then responded to the editor's commentary and revised the document to its current form.