# References

Burk JR, Lucas EA, Axe JR, Behbehani K, Yen F-C. Auto-CPAP in the treatment of obstructive sleep apnea: a new approach [abstract]. J Sleep Res. 1992;21.
Chesson AL, Ferber RA, Fry JM, Grigg-Damberger M, Hartse KM, Hurwitz TD, Johnson S, Kader GA, Littner M, Rosen G, Sangal B, et al. The indications for polysomnography and related procedures [An American Sleep Disorders Association Review]. Sleep. 1997;20(6):423-487. [pmid: 9302726].
Cook DJ, Guyatt GH, Laupacis A, Sackett DL. Rules of evidence and clinical recommendations on the use of antithrombotic agents. Chest. 1992;102:305S-311S. [pmid: 1395818].
Cook DJ, Mulrow CD, Haynes RB. Systematic reviews: synthesis of best evidence for clinical decisions. Ann Intern Med. 1997;126:376-380. [pmid: 9054282].
Ferber R, Millman R, Coppola M, Fleetham J, Murray C, Iber C, McCall V, Nino-Murcia G, Pressman M, Sanders M, Strohl K, Votteri B, Williams A. Portable recording in the assessment of obstructive sleep apnea. ASDA Standards of Practice. Sleep. 1994;17 (4):378-392. [pmid: 7973323].
Fleiss, J. Statistical methods for rates and proportions. John Wiley & Sons; 1973.
Flemons WW, Remmers JE. The diagnosis of sleep apnea: questionnaires and home studies. Sleep. 1996;19(10):S243-S247. [pmid: 9085522].
He J, Kryger MH, Zorick FJ, Conway W, Roth T. Mortality and apnea index in obstructive sleep apnea. Experience in 385 male patients. Chest. 1988;94:9-14. [pmid: 3289839].
Iber C, O'Brien C, Schluter J, Davies S, Leatherman J, Mahowald M. Single night studies in obstructive sleep apnea. Sleep. 1991;14:383-385. [pmid: 1759089].
Irwig L, Tosteson ANA, Gatsonis C, Lau J, Colditz G, Chalmers TC, Mosteller F. Guidelines for meta-analyses evaluating diagnostic tests. Ann Intern Med. 1994;120:667-676. [pmid: 8135452].
Lindblom SS. Adults who snore. Postgrad Med. 1997;101:171-2, 174, 183-4. [pmid: 9194872].
Littenberg B, Moses LE. Estimating diagnostic accuracy from multiple conflicting reports: a new meta-analytic method. Med Decis Making. 1993;13:313-321. [pmid: 8246704].
Littenberg B, Mushlin AI, Diagnostic Technology Assessment Consortium. Technetium bone scanning in the diagnosis of osteomyelitis: a meta-analysis of test performance. J Gen Intern Med. 1992;7:158-163. [pmid: 1487763].
Moses LE, Shapiro D. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med. 1993;12:1293-1316. [pmid: 8210827].
Mulrow CD, Cook DJ, Davidoff F. Systematic reviews: critical links in the great chain of evidence [editorial]. Ann Intern Med. 1997;126:389-391. [pmid: 9054284].
Mulrow CD, Oxman AD, editors. Cochrane Collaboration handbook (updated 9 December 1996). The Cochrane Collaboration; Issue 1. Oxford: Update Software; 1997.
National Commission on Sleep Disorders Research. Wake up America: a national sleep alert. Washington DC: Government Printing Office; 1993.
Pack AI. Simplifying the diagnosis of obstructive sleep apnea [editorial; comment]. Ann Intern Med. 1993;119:528-529. [pmid: 8204127].
Phillipson EA. Sleep apnea - a major public health problem [editorial]. N Engl J Med. 1993;328:1271-1273. [pmid: 8464440].
Polysomnography Task Force, American Sleep Disorders Association Standards of Practice Committee. Practice parameters for the indications for polysomnography and related procedures [An American Sleep Disorders Association Report]. Sleep. 1997;20(6):406-422. [pmid: 9302725].
Sacks HS, Berrier J, Reitman D, Ancona-Berk V, Chalmers T. Meta-analyses of randomized controlled trials. N Engl J Med. 1987;316:450-455. [pmid: 3807986].
Schafer H, Ewig S, Haspr E, Luderitz B. Predictive diagnostic value of clinical assessment and nonlaboratory monitoring system recordings in patients with symptoms suggestive of obstructive sleep apnea syndrome. Respiration. 1997;64:194-199. [pmid: 9154670].
Young T, Palta M, Dempsey J, Skatrud J, Weber S, and Badr S. The occurrence of sleep-disordered breathing among middle-aged adults. N Engl J Med. 1993;328:1230-1235. [pmid: 8464434].