# Conclusions

This systematic review of the best available evidence suggests the answers to the questions posed at the start of the project are as follows:

- What diagnostic and screening tests are presently available? And what is the strength of the evidence in support of each? Numerous diagnostic strategies have been reported, but the published evidence for most is still insufficient. There is some evidence in a relatively small number of patients, which should be expanded with more studies, which suggests that a full PSG may not be necessary to diagnose SA. Rather that sleep laboratory measured oximetry, thoracoabdominal respiratory movements, and airflow alone (partial channel PSG), in the context of clinical suspicions of SA, may have sufficient sensitivity and specificity. There is still insufficient evidence that any multi-channel portable device can be used reliably in the home setting. With regard to all the other types of assessments which were hoped to be somehow predictive of SA, including anthropomorphic signs, ENT and dental assessments, and radiologic measures, the etiologic relevance of most is at best controversial. While statistically significant associations have been noted in some studies, causal associations have not been proven. Flow volume loops do not appear to be useful diagnostic tests in SA. Lastly, sensitivity and specificity were good for clinical prediction rules in general, but additional studies would be required to build the evidence base to justify widespread adoption of any single model.
- What is the predictive ability of these tests in different populations? This cannot be answered, given the fact that nearly all "tests of tests" were performed in patients suspected of having SA on the basis of clinical signs and symptoms. There are very few studies of different tests in different populations that are validated against a PSG diagnosis of SA.
- What are the implications of certain PSG results in terms of serious clinical events occurring as comorbidities or as sequelae in association with a diagnosis of SA? This question cannot be definitively answered. While there are very few follow-up studies available, the few included here suggested that the prevalence of coronary artery disease and hypertension are both quite high. It is not clear, however, whether SA is an independent risk factor for these conditions.