# Results

## Search Results

The initial search through MEDLARS and Current Contents® yielded 3,730 citations. An additional 202 citations were identified from a manual search of reference lists. After screening these citations, 937 studies were potentially eligible. Most citations were rejected at Level I screening due to reasons of ineligible patient populations, treatment studies, or not relating to SA syndrome. Screening may be duplicated at Level II when the abstract is unclear as to its primary focus and it is then necessary to review the full publication before excluding it. During the second level of screening, some papers initially believed to be eligible were determined to be treatment papers and therefore were rendered ineligible. Seven hundred twenty-two studies were excluded after Level II screening for the following reasons: <10 patients=56; other (language, publication date <1980, incorrect citation, pediatric studies, confounding disease, duplicate population, statistical paper)=20; pathophysiology=31; not SA=76; letters, editorials, commentaries, abstracts=69; reviews and meta-analyses=147; treatment studies=46; not diagnostic studies=51; outcomes not extractable=111; no correlation to gold standard PSG=50; evidence scores <16=65. Refer to Evidence Table 1 for a display of the rejection reasons. All accepted studies are listed in the bibliography displayed in Appendix E. The screening process is charted in Flow Diagram 3. All studies rejected at Level II screening are listed in the bibliography as the study reject log (Appendix F). The eligibility of 135 studies still remains pending (Appendix G). These studies had not yet arrived via interlibrary loan at the time of locking of the database.

Evidence Table 1: Reject reasons

Number of studies | Reject reason
56 | < 10 patients
20 | Other (language, publication date <1980, incorrect citation, pediatric study, confounding disease, duplicate population, statistical paper)
31 | Pathophysiology papers
76 | Not sleep apnea
69 | Letters/editorials/commentaries/abstracts
147 | Reviews and meta-analyses
46 | Treatment studies
51 | Not diagnostic
111 | Outcomes not extractable
50 | No correlations to gold standard PSG
65 | Evidence score less than 16

Flow Diagram 3: Study Screening

From the 937 potentially eligible studies, 495 initially appeared to fit all inclusion criteria of the protocol (k=249 diagnostic test studies, k=246 prevalence/comorbidity studies). Of these 249 diagnostic studies, 65 were low scorers on the rating instrument and did not proceed to data extraction (listed in Appendix F). Of the 184 that did proceed to data extraction, 147 were eventually accepted for the data matrix, the remainder rejected by the extractors as being unextractable or otherwise ineligible. Of the 147 diagnostic studies fully extracted and displayed in the data matrix,^(1)^ 71 reported outcomes with sensitivity, specificity, and/or correlations, and relative to a standard PSG. These studies were chosen for further statistical analysis (see "Characteristics of Diagnostic Studies").

1 The data matrix for diagnostic studies is contained in Appendix H; a similar matrix for prevalence and outcome studies is contained in Appendix I. They are available upon request and without charge from the AHCPR Publications Clearinghouse at 1-800-358-9295 and are accessible on the AHCPR web site (http://www.ahcpr.gov). A legend (Appendix J) explaining the symbols used in each matrix is also provided.

## Characteristics of Diagnostic Studies

Of the 147 diagnostic studies accepted for data extraction, 129 were in English, and 18 were in other languages (12 German, 3 French, and 3 Spanish). Forty-nine studies were performed in the United States, 63 in Europe, and 35 elsewhere, including Australia, Israel, and Japan. The years of publication spanned 1981 through 1997, with 106 studies published since 1991. The average score on the diagnostic evidence rating instrument was 20.0 ± 3.9 (range 16 to 34). The total number of patients enrolled in these studies was 17,679 (range 10 to 1,409), and the average enrolled per study was 120.3 ± 184.6. Industry sponsorship was noted in only 5 studies. Study designs were almost entirely cross-sectional diagnostic assessments at one point in time, and only 7 used a randomized study design.

Of the 71 diagnostic studies reporting outcome formats required for inclusion in the analyzable dataset (sensitivity and specificity, or correlation coefficients), 63 were in English, 5 in German, and 3 in Spanish. Locations of study were Europe in 33, the United States in 21, and elsewhere in 17. These studies were published from 1981 to 1997, and 52 of them were published after 1990. The average diagnostic evidence score was 20.6 (range 16 to 34). Study level covariates for the extracted studies are summarized in Evidence Table 2. In total, there were 7,572 patients enrolled, and the average number of patients per study was 106.6 (± 115.0). Only 3 studies stated industry sponsorship. There were 25 studies with results of portable monitoring devices, 3 of partial channel PSGs, 12 oximetry alone studies, 7 partial time PSGs, 5 reporting radiologic test results (1 MRI, 3 cephalometry, and 1 reporting CT and cephalometry), 17 studies with clinical measures (including flow volume loops and global impressions), only 1 study with chemical assay, and 3 studies with focused questionnaires. Also, 8 studies reported results of multivariate models as predictors of PSG results.

Evidence Table 2: Overall study level covariates

Covariate | Extracted studies (k=147) | Data set for analysis (k=71)
Location
Europe | 63 (43%) | 33 (47%)
United States | 49 (33%) | 21 (30%)
Other | 35 (24%) | 17 (23%)
Language
English | 129 (88%) | 63 (89%)
German | 12 (8%) | 5 (7%)
Spanish | 3 (2%) | 3 (4%)
French | 3 (2%) | 0 (0%)
Sponsor
Industry | 5 (96%) | 3 (4%)
Not industry | 142 (4%) | 68 (96%)
Year published
>1990 | 106 (72%) | 52 (73%)
1981-1990 | 41 (28%) | 19 (27%)

### Patient Characteristics

Of the 147 accepted diagnostic studies, gender was reported in 130, of which the majority of patients were male (79 percent). Of 136 studies that reported age, the average age was 48.8 ±8.0 years (range, 20 to 95). Most patients were referred to a sleep laboratory or were already sleep clinic patients at the time of the study. In the dataset of 71 studies considered for analysis, of the 4,400 patients who entered with a suspected sleep disorder, a PSG diagnosis of SA was made in 2,037 (49 percent), using the lowest AI or AHI diagnostic thresholds reported. Note the PSG definitions of apnea and hypopnea varied somewhat from study to study, and the AI or AHI thresholds for diagnosis varied more widely from study to study, from 5/hour up to 40/hour. The severity of SA and thresholds for same were too infrequently reported to analyze further. Similarly, historical information on patients was not usually reported; so no analyses could be made of the relationships of patients' medical histories to test results.

In the majority of studies, the presence of relevant symptoms at study entry was not consistently reported. The presence of daytime sleepiness, involuntary falling asleep, nocturnal snoring, gasping or choking, and observed apneas were most frequently mentioned as reasons for suspecting SA. The relationship of symptoms to diagnostic test results could not be measured for each test, due to insufficient reporting.

Of the 71 considered for analysis, there were 7,572 patients: mean age was 49.0 ± 5.1 years (range, 36 to 60). Of the 61 studies in this set which reported gender, 81 percent of patients were male. BMI was reported in 44 of these studies, and averaged 30.9 kg/m^2^ (range, 26.2 to 40.0). Patient level covariates are summarized in Evidence Table 3.

Evidence Table 3: Summary of patient level covariates

Study sets | K | Mean quality score (range) | Number of patients | Percentage males (k) | Mean age (k) | Mean BMI (k) | Sensitivity percentage | Specificity percentage
Analyzable | 71 | 20.6 (16-34) | 7,572 | 81 (61) | 49.0 ± 5.1 (65) | 30.9 ± 3 (44) | ND | ND
Oximetry | 12 | 20 (16-32) | 1,784 | 83 (10) | 50.6 ± 4.7 (11) | 31.7 ± 1.1 (12) | 87.4 ± 3.8 | 64.9 ± 6.7
Partial channel PSG | 3 | 17.7 (17-19) | 213 | 81 (3) | 51.7 ± 1.2 (3) | 32.0 ± 1.0 (3) | ND | ND
Partial day/night PSG | 7 | 18.6 (17-20) | 505 | 86 (6) | 51.4 ± 3.5 (7) | 33.9 ± 5.5 (5) | 69.7 ± 5.3 | 87.4 ± 5.4
Portable devices | 25 | 22.1 (16-34) | 1,631 | 84 (21) | 48.5 ± 5.5 (24) | 30.0 ± 1.6 (15) | ND | ND
Flow volume loop | 4 | 18.3 (17-20) | 594 | 79 (4) | 50.0 ± 1.6 (4) | 29.0 (1) | 39.1 ± 25.3 | 60.5 ± 23.7
Global impression | 4 | 23.3 (19-28) | 1,139 | 67 (4) | 47.7 ± 2.1 (3) | 29.4 ± 0.7 (3) | 58.9 ± 4.2 | 65.6 ± 4.8
Chemical | 1 | 18 | 88 | 49 | 58 | 28 | ND | ND
Other clinical | 9 | 19.8 (18-22) | 815 | 91 (8) | 47.4 ± 6.9 (8) | 30.3 ± 1.5 (6) | ND | ND
Radiologic | 5 | 18.5 (17-20) | 296 | 73 (3) | 43.0 ± 4.7 (4) | 30.5 ± 4.4 (4) | ND | ND
Questionnaire | 3 | 19.0 (17-21) | 576 | 58 (2) | 45.3 ± 4.7 (2) | 28.0 (1) | ND | ND
Prediction equations | 8 | 21.5 (17-30) | 1,908 | 77 (8) | 49.4 ± 4.0 (8) | 31.4 ± 3.4 (8) | 66.5 ± 14.0 | 88.7 ± 4.9

Eight studies (#9098- Garcia-Diaz, et al., 1997, #9218- Gugger, 1997, #9255- Gyulay, et al., 1993, #9372- Hoffstein and Szalai, 1993, #11888- Pracharktam, et al., 1996, #10565- Schafer, et al., 1997, #10849- Svanborg, et al., 1990, #10986- Viner, et al., 1991) report results for more than 1 test; consequently the sum of all the categories is greater than 71.

ND = Not done.

### Diagnostic Test Characteristics

All included diagnostic studies were required to report results of a standard PSG. However, criteria that constitute a standard PSG varied among the studies. Most studies monitored respiratory activity (chest and abdominal movements and airflow) and oxygen saturation (oximetry). All included measures of sleep (EEG, EOG, or submental EMG), and some included measures of cardiac activity (ECG). Tibial EMG, snoring, and body position were less frequently monitored. Most noted that the traditional scoring system for sleep stages of Rechstahffen and Kales was used, and PSG data were assessed manually in nearly all cases. Nearly all studies based the AI (or AHI) upon the time asleep, as opposed to the time spent in bed, in contrast with the portable devices intended for home use, which are described further below. All standard PSGs were performed in the sleep laboratory, which was either a free-standing unit or a hospital setting with trained attendants present. Different thresholds for AI or AHI (or RDI) were used in different settings to make a diagnosis of SA, ranging from 5 to 15 for AI and 5 to 40 for AHI. Some studies required the presence of signs or symptoms of sleep disturbance in concert with an elevated AI (or AHI) for SA diagnosis, and some did not. Most did not report distinctions between obstructive SA, central SA, or mixed SA.