# Appendix J Legend for Data Matrices

Abn=abnormal

abn sleep movt=abnormal sleep movement

AI=apnea index

AHI=apnea-hypopnea index

ap=apnea

AP/T=anterior posterio/transverse

BP=blood pressure

Br=breathing

CAD=coronary artery disease

Categorization of papers:

- 1=Testing tests
- 2=Signs and symptoms for sleep apnea
- 3=Outcomes of sleep apnea

Cephalometric measurements :

- MP-H=distance from mandibular plane to hyoid bone (in mm)
- PAL=length of soft palate measured on cephalometric x-ray - distance from posterior nasal spine to top of soft palate

Cephalometric measurements :

- PAS=posterior airway space (in mm) defined as the space behind the base of the tongue space (in mm)
- PNS-P=distance from posterior nasal spine to the tip of the soft palate (in mm)
- SNA=angle measurement from sella, nasion, subspinale (point A)
- SNB=angle measurement from sella(s), nasion(N), supramentele (point B) Cranial base: VI SN=length of anterior cranial base V2 BaN=overall length of cranial base V3 BaSN=angulation of cranial base Face: V7 SNA=angle of maxillary prognathism V8 SNB=angle of mandibular prognathism V9 ANB=difference in prognathism V10 PnsA=maxillary length V11 BaA=sagittal dimension of median upper face from Ba to A

Cephalometric measurements :

- Face:
- V12 DcA=sagittal dimension of median upper face from Dc to A
- V13 DcGn=overall length of mandible
- Face Height:
- V14=upper face height
- V15=lower face height
- Upper Pharynx:
- V4 BaPns=dimension of bony pharynx
- V5 BaH=depth of soft tissue in front of basion
- V6 HPns=airway opening on BaPns line
- [RS]=retroglossal space
- [MRH]=mandibular plane to hyoid (mm)
- [HP-CS]=head flexion, hard palate to spine

CHD=coronary heart disease

Circum=circumference

Cm=centimeters

Comp=computer scoring

COPD=chronic obstructive pulmonary disease

Corr=correlation

CPAP=continuous positive airway pressure

CT=computed tomography

CT_90_ =% of time spent at SaO_2_ below 90%

CVA=cardiovascular accident

D=diastolic (blood pressure, mmHG)

DBR=disordered breathing rate

Desat=desaturation

DI=desaturation index

HRA=difference of heart rate during apnea in non-REM sleep (min^-1^ )

HRB=difference of heart rate during breatholding (min^-1^ )

HRM=diffrence of heart rate during Mueller maneuver

HRV=difference of heart rate during Valsalva maneuver

Diff=difference

Disrupt=disruptively

DSat=desaturation

Dur=duration

DX=diagnosis

ED=Erectile dysfunction

ERV=expiratory reserve volume

ESRD=end stage renal disease

Ev=event

Expir=expiratory

FeF_50_ /FIF_50_ =ratio of forced expiratory flow at 50% of vital capacity

FEV_1_ =maximum forced expiratory volume in 1 second

FN=false negative

FP=false positive

FR=flow rates

FRC=functional residual capacity

FVC=forced vital capacity

Fx=failure

Gnrl=general population

H=hour

HBP=high blood pressure

HR=heart rate (beats/minute)

HMS=home monitoring system

HTN=hypertension

Hx=history

Hypophar=hypopharynx

Imprd=impairment

In=inches

Intell deterior=intellectual deterioration

LPR=laboratory portable recording

M=meters

Ma/H=movement arousals/Hour

Manu=manufacturer's criteria

Med=median

MESAM=Madaus Electronics Sleep Apnea Monitor

MI=myocardial infarction

MM=milimeters

Mod=moderate

MRI=magnetic resonance imaging

MSLT=multiple sleep latency test

MWT=maintenance of wakefulness test

MVCFR= ratio of the maximal expiratory flow at 50% of vital capacity to maximal inspiration flow at 50% of vital capacity

Nasophar=nasopharynx

NM=nocturnal myoclonus

NMS=neuromuscular disorder

NPV=negative predictive value

NTRR=night time respiratory recording

Orophar=oropharynx

Oscill=oscillations

PA=pharyngeal area

PFT=pulmonary function test

phar=pharyngeal

PHR=portable home recording

PPV=positive predictive value

Pros=prospective study

PSG=polysomnogram

RDI=respiratory disturbance index

Reflect=reflection

Reg=regular

Rel=related

Resist=resistance

Resp=respiratory

Retro=retrospective study

RV=residual volume

RVH=right ventricular hypertrophy

S=systolic (blood pressure, mm HG)

S=second

SA=sleep apnea

SaO_2_ =saturation of O_2_

SCSB=static charge sensitive bed

SIDAS=recording instrument for diagnosing sleep-related breathing disorders

SIT=Saturation impairment index

Sl=sleep

Snore=snoring

Spcl=special population

Tc=treated for hypertentsion, but remained high

T_c_ PO_2_ =transcutaneous arterial oxygen tension

T_c_ PCO_2_ =transcutaneous carbon dioxide tension

Th=treated for hypertension and under control

TN=true negative

TP=true positive

TST=total sleep time

VC=vital capacity

VPB=ventricular premature beats

VIS=visual scoring

W/=with

*comparison with PSG AHI>10; **comparison with PSG AHI>20