# Appendix I AHCPR Data Matrix of Prevalence or Outcomes of Sleep Apnea Studies

This appendix is no longer available.