# Appendix H AHCPR Data Matrix

This appendix is no longer available.