# REFERENCES

3M (3M Company). (2000a). Sanitized report: Exploratory 28-day oral toxicity study with telomer alcohol, telomer acrylate, PFHS and PFOS (positive control) by daily gavage in the rat followed by a 14/28-day recovery period [TSCA Submission]. (FYI-0500-01378 B; DCN 84000000018). St. Paul, MN. https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearchView/05ADDF3067814C978525703B004B4119.
3M (3M Company). (2000b). Support: Protocol & report of data for exploratory 28-day oral toxicity study in rats: Telomer alcohol, telomer acrylate, [ ], PFHS, PFOS, w/ attachments, cvr ltr dated 050400 [TSCA Submission]. (EPA/OTS Doc #8EHQ-0800-0373). St. Paul, MN. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS020492910.xhtml.
3M (3M Company). (2003). Oral (gavage) combined repeated dose toxicity study of T-7706 with the reproduction/developmental toxicity screening test [TSCA Submission]. (89-000811850U; 8EHQ-0903-00373). St. Paul, MN.
3M (3M Company). (2004). 28-day repeated dermal contact study of 3m test articles in Sprague-Dawley rats final report 01G00002 with letter dated 10/04/2004 [TSCA Submission]. (8EHQ-04-00373BJ). Washington, D.C.: TSCA. https://java.epa.gov/oppt_chemical_search/proxy?filename=2004-10-8EHQ-04-00373BJ_8ehq_1004_00373bj.pdf.
3M (3M Company). (2010). TSCA 8(e) substantial risk notice: Sulfonate-based and carboxylic-based fluorochemicals, docket 8EHQ-0598-373 - Results from a mechanistic investigation of the effect of PFBS, PFHS, and PFOS on lipid and lipoprotein metabolism in transgenic mice [TSCA Submission]. (8EHQ-10-00373DH). St. Paul, MN.
Abraham, K; Mielke, H; Fromme, H; Völkel, W; Menzel, J; Peiser, M; Zepp, F; Willich, SN; Weikert, C. (2020). Internal exposure to perfluoroalkyl substances (PFASs) and biological markers in 101 healthy 1-year-old children: associations between levels of perfluorooctanoic acid (PFOA) and vaccine response. Arch Toxicol 94: 2131–2147. 10.1007/s00204-020-02715-4.32227269
ACOG (American College of Obstetricians and Gynecologists). (2019). The use of antimüllerian hormone in women not seeking fertility care. Am J Obstet Gynecol 133: e274–e278.
Afzali, A; Weiss, NS; Boyko, EJ; Ioannou, GN. (2010). Association between serum uric acid level and chronic liver disease in the United States. Hepatology 52: 578–589. 10.1002/hep.23717.20683957
AG, B; E, K. (1982). Prevalence of oligomenorrhea and amenorrhea in a college population. Am J Obstet Gynecol 144: 98–102. 10.1016/0002-9378(82)90402-1.7114117
Aimuzi, R; Luo, K; Chen, Q; Wang, H; Feng, L; Ouyang, F; Zhang, J. (2019). Perfluoroalkyl and polyfluoroalkyl substances and fetal thyroid hormone levels in umbilical cord blood among newborns by prelabor caesarean delivery. Environ Int 130: 104929. 10.1016/j.envint.2019.104929.31228788
Aimuzi, R; Luo, K; Huang, R; Huo, XN; Nian, M; Ouyang, FX; Du, YT; Feng, LP; Wang, WY; Zhang, J. (2020). Perfluoroalkyl and polyfluroalkyl substances and maternal thyroid hormones in early pregnancy. Environ Pollut 264: 114557. 10.1016/j.envpol.2020.114557.32388293
Alberti, KG; Eckel, RH; Grundy, SM; Zimmet, PZ; Cleeman, JI; Donato, KA; Fruchart, JC; James, WP; Loria, CM; Smith, SC. (2009). Harmonizing the metabolic syndrome: A joint interim statement of the International Diabetes Federation Task Force on Epidemiology and Prevention; National Heart, Lung, and Blood Institute; American Heart Association; World Heart Federation; International Atherosclerosis Society; and International Association for the Study of Obesity. Circulation 120: 1640–1645. 10.1161/CIRCULATIONAHA.109.192644.19805654
Alderete, TL; Jin, R; Walker, DI; Valvi, D; Chen, Z; Jones, DP; Peng, C; Gilliland, FD; Berhane, K; Conti, DV; Goran, MI; Chatzi, L. (2019). Perfluoroalkyl substances, metabolomic profiling, and alterations in glucose homeostasis among overweight and obese Hispanic children: A proof-of-concept analysis. Environ Int 126: 445–453. 10.1016/j.envint.2019.02.047.30844580
Alesio, JL; Slitt, A; Bothun, GD. (2022). Critical new insights into the binding of poly- and perfluoroalkyl substances (PFAS) to albumin protein. Chemosphere 287: 131979. 10.1016/j.chemosphere.2021.131979.34450368
Alkhalawi, E; Kasper-Sonnenberg, M; Wilhelm, M; Völkel, W; Wittsiepe, J. (2016). Perfluoroalkyl acids (PFAAs) and anthropometric measures in the first year of life: Results from the Duisburg Birth Cohort. J Toxicol Environ Health A 79: 1041–1049. 10.1080/15287394.2016.1219552.27924715
Amacher, DE. (2002). A toxicologist’s guide to biomarkers of hepatic response. Hum Exp Toxicol 21: 253–262. 10.1191/0960327102ht247oa.12141396
American Heart Association. (2022). What is Cholesterol? Dallas, TX. https://www.heart.org/en/health-topics/cholesterol/about-cholesterol#:~:text=High%20cholesterol%20is%20one%20of,the%20higher%20your%20overall%20risk.
Ammitzbøll, C; Börnsen, L; Petersen, ER; Oturai, AB; Søndergaard, HB; Grandjean, P; Sellebjerg, F. (2019). Perfluorinated substances, risk factors for multiple sclerosis and cellular immune activation. J Neuroimmunol 330: 90–95. 10.1016/j.jneuroim.2019.03.002.30852181
Anderson, RH; Long, GC; Porter, RC; Anderson, JK. (2016). Occurrence of select perfluoroalkyl substances at U.S. Air Force aqueous film-forming foam release sites other than fire-training areas: Field-validation of critical fate and transport properties. Chemosphere 150: 678–685. 10.1016/j.chemosphere.2016.01.014.26786021
Angrish, MM; Kaiser, JP; Mcqueen, CA; Chorley, BN. (2016). Tipping the balance: Hepatotoxicity and the 4 apical key events of hepatic steatosis [Review]. Toxicol Sci 150: 261–268. 10.1093/toxsci/kfw018.26980302
Arbuckle, TE; Macpherson, S; Foster, WG; Sathyanarayana, S; Fisher, M; Monnier, P; Lanphear, B; Muckle, G; Fraser, WD. (2020). Prenatal Perfluoroalkyl Substances and Newborn Anogenital Distance in a Canadian Cohort. Reprod Toxicol 94: 31–39. 10.1016/j.reprotox.2020.03.011.32283250
Ashley-Martin, J; Dodds, L; Arbuckle, TE; Bouchard, MF; Fisher, M; Morriset, AS; Monnier, P; Shapiro, GD; Ettinger, AS; Dallaire, R; Taback, S; Fraser, W; Platt, RW. (2017). Maternal concentrations of perfluoroalkyl substances and fetal markers of metabolic function and birth weight. Am J Epidemiol 185: 185–193. 10.1093/aje/kww213.28172036
Ashley-Martin, J; Dodds, L; Levy, AR; Platt, RW; Marshall, JS; Arbuckle, TE. (2015). Prenatal exposure to phthalates, bisphenol A and perfluoroalkyl substances and cord blood levels of IgE, TSLP and IL-33. Environ Res 140: 360–368. 10.1016/j.envres.2015.04.010.25913155
ASRM (American Society of Reproductive Medicine). (2024a). Current evaluation of amenorrhea: A committee opinion [Review]. Fertil Steril 122: 52–61. 10.1016/j.fertnstert.2024.02.001.38456861
ASRM (American Society of Reproductive Medicine). (2024b). Reasons why young women in the United States choose their contraceptive method. J Womens Health 30: 64–72. 10.1089/jwh.2019.8182.
ATSDR (Agency for Toxic Substances and Disease Registry). (2021). Toxicological profile for perfluoroalkyls [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. 10.15620/cdc:59198.
ATSDR (Agency for Toxic Substances and Disease Registry). (2024). PFAS: Information for clinicians [Fact Sheet]. https://www.atsdr.cdc.gov/pfas/docs/PFAS-info-for-clinicians-508.pdf.
Attanasio, R. (2019a). Association between perfluoroalkyl acids and liver function: Data on sex differences in adolescents. Data in Brief 27: 104618. 10.1016/j.dib.2019.104618.31687437
Attanasio, R. (2019b). Sex differences in the association between perfluoroalkyl acids and liver function in US adolescents: Analyses of NHANES 2013-2016. Environ Pollut 254: 113061. 10.1016/j.envpol.2019.113061.31454574
Augustsson, A; Lennqvist, T; Osbeck, CMG; Tibblin, P; Glynn, A; Nguyen, MA; Westberg, E; Vestergren, R. (2021). Consumption of freshwater fish: A variable but significant risk factor for PFOS exposure. Environ Res 192: 10284–10284.
Averina, M; Brox, J; Huber, S; Furberg, AS. (2021). Exposure to perfluoroalkyl substances (PFAS) and dyslipidemia, hypertension and obesity in adolescents. The Fit Futures study. Environ Res 195: 110740. 10.1016/j.envres.2021.110740.33460636
Aycan, MF. (2019). Comparison of biomechanical properties of implant systems used in treatment of proximal femur fractures. Gazi Universitesi Muhendislik Mimarlik Fakultesi Dergisi 34: 812–818. 10.17341/gazimmfd.416539.
B, D; ES, F. (2018). Chapter 19 - The Mammary Gland. In WMHCGRBB Matthew A. Wallig (Ed.), Fundamentals of Toxicologic Pathology (3 ed., pp. 547–563). Research Triangle Park, NC: Innogenics, Inc., Harvard, MA, United States National Institute of Environmental Health Sciences. 10.1016/B978-0-12-809841-7.00019-8.
Bach, CC; Bech, BH; Nohr, EA; Olsen, J; Matthiesen, NB; Bonefeld-Jørgensen, EC; Bossi, R; Henriksen, TB. (2016). Perfluoroalkyl acids in maternal serum and indices of fetal growth: The Aarhus Birth Cohort. Environ Health Perspect 124: 848–854. 10.1289/ehp.1510046.26495857
Bach, CC; Bech, BH; Nohr, EA; Olsen, J; Matthiesen, NB; Bossi, R; Uldbjerg, N; Bonefeld-Jørgensen, EC; Henriksen, TB. (2015). Serum perfluoroalkyl acids and time to pregnancy in nulliparous women. Environ Res 142: 535–541. 10.1016/j.envres.2015.08.007.26282225
Bach, CC; Matthiesen, NB; Olsen, J; Henriksen, TB. (2018). Conditioning on parity in studies of perfluoroalkyl acids and time to pregnancy: An example from the Danish national birth cohort. Environ Health Perspect 126: 117003. 10.1289/EHP1493.30417653
Baduel, C; Paxman, CJ; Mueller, JF. (2015). Perfluoroalkyl substances in a firefighting training ground (FTG), distribution and potential future release. J Hazard Mater 296: 46–53. 10.1016/j.jhazmat.2015.03.007.25966923
Bailey, SA; Zidell, RH; Perry, RW. (2004). Relationships between organ weight and body/brain weight in the rat: What is the best analytical endpoint? Toxicol Pathol 32: 448–466. 10.1080/01926230490465874.15204968
Bangma, J; Eaves, LA; Oldenburg, K; Reiner, JL; Manuck, T; Fry, RC. (2020). Identifying Risk Factors for Levels of Per- and Polyfluoroalkyl Substances (PFAS) in the Placenta in a High-Risk Pregnancy Cohort in North Carolina. Environ Sci Technol 54: 8158–8166. 10.1021/acs.est.9b07102.32469207
Banjabi, AA; Li, AJ; Kumosani, TA; Yousef, JM; Kannan, K. (2020). Serum concentrations of perfluoroalkyl substances and their association with osteoporosis in a population in Jeddah, Saudi Arabia. Environ Res 187: 109676. 10.1016/j.envres.2020.109676.32485360
Bao, WW; Qian, ZM; Geiger, SD; Liu, E; Liu, Y; Wang, SQ; Lawrence, WR; Yang, BY; Hu, LW; Zeng, XW; Dong, GH. (2017). Gender-specific associations between serum isomers of perfluoroalkyl substances and blood pressure among Chinese: Isomers of C8 Health Project in China. Sci Total Environ 607–608: 1304–1312. 10.1016/j.scitotenv.2017.07.124.
Barber, JL; Berger, U; Chaemfa, C; Huber, S; Jahnke, A; Temme, C; Jones, KC. (2007). Analysis of per- and polyfluorinated alkyl substances in air samples from Northwest Europe. J Environ Monit 9: 530–541. 10.1039/b701417a.17554424
Barbier, P; Zejneli, O; Martinho, M; Lasorsa, A; Belle, V; Smet-Nocca, C; Tsvetkov, PO; Devred, F; Landrieu, I. (2019). Role of Tau as a microtubule-associated protein: Structural and functional aspects. Front Aging Neurosci 11: 204. 10.3389/fnagi.2019.00204.31447664
Barrett, ES; Chen, C; Thurston, SW; Haug, LS; Sabaredzovic, A; Fjeldheim, FN; Frydenberg, H; Lipson, SF; Ellison, PT; Thune, I. (2015). Perfluoroalkyl substances and ovarian hormone concentrations in naturally cycling women. Fertil Steril 103: 1261–1270.e1263. 10.1016/j.fertnstert.2015.02.001.25747128
Bartell, SM. (2012). Bias in half-life estimates using log concentration regression in the presence of background exposures, and potential solutions. J Expo Sci Environ Epidemiol 22: 299–303. 10.1038/jes.2012.2.22333729
Bassett, JHD; Clement-Lacroix, P; Samarut, J; Chassande, O; Williams, GR; O’Shea, PJ; Sriskantharajah, S; Rabier, B; Boyde, A; Howell, PGT; Weiss, R, oyE; Roux, JP; Malaval, L, uc. (2007). Thyroid hormone excess rather than thyrotropin deficiency induces osteoporosis in hyperthyroidism. Mol Endocrinol 1095–1107. 10.1210/me.2007-0033.
Batt, AM; Ferrari, L. (1995). Manifestations of chemically-induced liver-damage. Clin Chem 41: 1882–1887.7497649
Batzella, E; Girardi, P; Russo, F; Pitter, G; Da Re, F; Fletcher, T; Canova, C. (2022). Perfluoroalkyl substance mixtures and cardio-metabolic outcomes in highly exposed male workers in the Veneto Region: A mixture-based approach. Environ Res 212: 113225. 10.1016/j.envres.2022.113225.35390304
Beck, IH; Timmermann, CAG; Nielsen, F; Schoeters, G; Jøhnk, C; Kyhl, HB; Høst, A; Jensen, TK. (2019). Association between prenatal exposure to perfluoroalkyl substances and asthma in 5-year-old children in the Odense Child Cohort. Environ Health 18: 97. 10.1186/s12940-019-0541-z.31730470
Beglarian, E; Costello, E; Walker, DI; Wang, H; Alderete, TL; Chen, Z; Valvi, D; Baumert, BO; Rock, S; Rubbo, B; Aung, MT; Gilliland, FD; Goran, MI; Jones, DP; McConnell, R; Eckel, SP; Conti, DV; Goodrich, JA; Chatzi, L. (2024). Exposure to perfluoroalkyl substances and longitudinal changes in bone mineral density in adolescents and young adults: A multi-cohort study. Environ Res 244: 117611. 10.1016/j.envres.2023.117611.38061983
Benskin, JP; De Silva, AO; Martin, LJ; Arsenault, G; Mccrindle, R; Riddell, N; Mabury, SA; Martin, JW. (2009). Disposition of perfluorinated acid isomers in Sprague-Dawley rats; part 1: single dose. Environ Toxicol Chem 28: 542–554. 10.1897/08-239.1.18939892
Berbel, P; Navarro, D; Ausó, E; Varea, E; Rodríguez, AE; Ballesta, JJ; Salinas, M; Flores, E; Faura, CC; de Escobar, GM. (2010). Role of late maternal thyroid hormones in cerebral cortex development: An experimental model for human prematurity. Cereb Cortex 20: 1462–1475. 10.1093/cercor/bhp212.19812240
Berg, V; Nøst, TH; Pettersen, RD; Hansen, S; Veyhe, AS; Jorde, R; Odland, JØ; Sandanger, TM. (2017). Persistent organic pollutants and the association with maternal and infant thyroid homeostasis: a multipollutant assessment. Environ Health Perspect 125: 127–133. 10.1289/EHP152.27219111
Bessone, F; Razori, MV; Roma, MG. (2019). Molecular pathways of nonalcoholic fatty liver disease development and progression. Cell Mol Life Sci 76: 99–128. 10.1007/s00018-018-2947-0.30343320
Bijland, S; Rensen, PCN; Pieterman, EJ; Maas, ACE; van Der Hoorn, JW; van Erk, MJ; Havekes, LM; Willems van Dijk, K; Chang, SC; Ehresman, DJ; Butenhoff, JL; Princen, HMG. (2011). Perfluoroalkyl sulfonates cause alkyl chain length-dependent hepatic steatosis and hypolipidemia mainly by impairing lipoprotein production in APOE*3-Leiden CETP mice. Toxicol Sci 123: 290–303. 10.1093/toxsci/kfr142.21705711
Bil, W; Zeilmaker, MJ; Bokkers, BGH. (2022). Internal Relative Potency Factors for the Risk Assessment of Mixtures of Per- and Polyfluoroalkyl Substances (PFAS) in Human Biomonitoring. Environ Health Perspect 130: 77005. 10.1289/EHP10009.35881550
Birukov, A; Andersen, LB; Andersen, MS; Nielsen, JH; Nielsen, F; Kyhl, HB; Jørgensen, JS; Grandjean, P; Dechend, R; Jensen, TK. (2021). Exposure to perfluoroalkyl substances and blood pressure in pregnancy among 1436 women from the Odense Child Cohort. Environ Int 151: 106442. 10.1016/j.envint.2021.106442.33610053
Bischel, HN; Macmanus-Spencer, LA; Luthy, RG. (2010). Noncovalent Interactions of Long-Chain Perfluoroalkyl Acids with Serum Albumin. Environ Sci Technol 44: 5263–5269. 10.1021/es101334s.20540534
Bischel, HN; Macmanus-Spencer, LA; Zhang, CJ; Luthy, RG. (2011). Strong associations of short-chain perfluoroalkyl acids with serum albumin and investigation of binding mechanisms. Environ Toxicol Chem 30: 2423–2430. 10.1002/etc.647.21842491
Bizzarro, MJ; Gross, I. (2004). Effects of hormones on fetal lung development [Review]. Obstet Gynecol Clin North Am 31: 949–961, xii. 10.1016/j.ogc.2004.08.001.15550344
Bjerregaard-Olesen, C; Bach, CC; Long, M; Wielsøe, M; Bech, BH; Henriksen, TB; Olsen, J; Bonefeld-Jørgensen, EC. (2019). Associations of Fetal Growth Outcomes with Measures of the Combined Xenoestrogenic Activity of Maternal Serum Perfluorinated Alkyl Acids in Danish Pregnant Women. Environ Health Perspect 127: 17006. 10.1289/EHP1884.30676078
Bjork, JA; Dawson, DA; Krogstad, JO; Wallace, KB. (2021). Transcriptional effects of binary combinations of PFAS in FaO cells. Toxicology 464: 152997. 10.1016/j.tox.2021.152997.34695511
Blake, BE; Pinney, SM; Hines, EP; Fenton, SE; Ferguson, KK. (2018). Associations between longitudinal serum perfluoroalkyl substance (PFAS) levels and measures of thyroid hormone, kidney function, and body mass index in the Fernald Community Cohort. Environ Pollut 242: 894–904. 10.1016/j.envpol.2018.07.042.30373035
Blomberg, A; Mortensen, J; Weihe, P; Grandjean, P. (2022). Bone mass density following developmental exposures to perfluoroalkyl substances (PFAS): a longitudinal cohort study. Environ Health 21: 113. 10.1186/s12940-022-00929-w.36402982
Blomberg, AJ; Haug, LS; Lindh, C; Sabaredzovic, A; Pineda, D; Jakobsson, K; Nielsen, C. (2023). Changes in perfluoroalkyl substances (PFAS) concentrations in human milk over the course of lactation: A study in Ronneby mother-child cohort. Environ Res 219: 115096. 10.1016/j.envres.2022.115096.36529327
Blomberg, AJ; Shih, YH; Messerlian, C; Jørgensen, LH; Weihe, P; Grandjean, P. (2021). Early-life associations between per- and polyfluoroalkyl substances and serum lipids in a longitudinal birth cohort. Environ Res 200: 111400. 10.1016/j.envres.2021.111400.34081971
Bloom, MS; Commodore, S; Ferguson, PL; Neelon, B; Pearce, JL; Baumer, A; Newman, RB; Grobman, W; Tita, A; Roberts, J; Skupski, D; Palomares, K; Nageotte, M; Kannan, K; Zhang, C; Wapner, R; Vena, JE; Hunt, KJ. (2022). Association between gestational PFAS exposure and Children’s adiposity in a diverse population. Environ Res 203: 111820. 10.1016/j.envres.2021.111820.34343551
Bloom, MS; Kannan, K; Spliethoff, HM; Tao, L; Aldous, KM; Vena, JE. (2010). Exploratory assessment of perfluorinated compounds and human thyroid function. Physiol Behav 99: 240–245. 10.1016/j.physbeh.2009.02.005.19419669
Bonefeld-Jørgensen, EC; Long, M; Fredslund, SO; Bossi, R; Olsen, J. (2014). Breast cancer risk after exposure to perfluorinated compounds in Danish women: a case-control study nested in the Danish National Birth Cohort. Cancer Causes Control 25: 1439–1448. 10.1007/s10552-014-0446-7.25148915
Boone, L; Meyer, D; Cusick, P; Ennulat, D; Bolliger, AP; Everds, N; Meador, V; Elliott, G; Honor, D; Bounous, D; Jordan, H. (2005). Selection and interpretation of clinical pathology indicators of hepatic injury in preclinical studies [Review]. Vet Clin Pathol 34: 182–188. 10.1111/j.1939-165X.2005.tb00041.x.16134065
Borghese, MM; Liang, CL; Owen, J; Fisher, M. (2022). Individual and mixture associations of perfluoroalkyl substances on liver function biomarkers in the Canadian Health Measures Survey. Environ Health 21: 85. 10.1186/s12940-022-00892-6.36104725
Borghese, MM; Walker, M; Helewa, ME; Fraser, WD; Arbuckle, TE. (2020). Association of perfluoroalkyl substances with gestational hypertension and preeclampsia in the MIREC study. Environ Int 141: 105789. 10.1016/j.envint.2020.105789.32408216
Braun, JM; Chen, A; Romano, ME; Calafat, AM; Webster, GM; Yolton, K; Lanphear, BP. (2016). Prenatal perfluoroalkyl substance exposure and child adiposity at 8 years of age: The HOME study. Obesity (Silver Spring) 24: 231–237. 10.1002/oby.21258.26554535
Braun, JM; Eliot, M; Papandonatos, GD; Buckley, JP; Cecil, KM; Kalkwarf, HJ; Chen, A; Eaton, CB; Kelsey, K; Lanphear, BP; Yolton, K. (2020). Gestational perfluoroalkyl substance exposure and body mass index trajectories over the first 12 years of life. Int J Obes (Lond) 45: 25–35. 10.1038/s41366-020-00717-x.33208860
Braun, JM; Kalkbrenner, AE; Just, AC; Yolton, K; Calafat, AM; Sjödin, A; Hauser, R; Webster, GM; Chen, A; Lanphear, BP. (2014). Gestational exposure to endocrine-disrupting chemicals and reciprocal social, repetitive, and stereotypic behaviors in 4- and 5-year-old children: the HOME study. Environ Health Perspect 122: 513–520. 10.1289/ehp.1307261.24622245
Buck Louis, GM; Zhai, S; Smarr, MM; Grewal, J; Zhang, C; Grantz, KL; Hinkle, SN; Sundaram, R; Lee, S; Honda, M; Oh, J; Kannan, K. (2018). Endocrine disruptors and neonatal anthropometry, NICHD Fetal Growth Studies - Singletons. Environ Int 119: 515–526. 10.1016/j.envint.2018.07.024.30055518
Buck, RC; Franklin, J; Berger, U; Conder, JM; Cousins, IT; de Voogt, P; Jensen, AA; Kannan, K; Mabury, SA; van Leeuwen, SP. (2011). Perfluoroalkyl and polyfluoroalkyl substances in the environment: terminology, classification, and origins [Review]. Integr Environ Assess Manag 7: 513–541. 10.1002/ieam.258.21793199
Buckley, JP; Kuiper, JR; Lanphear, BP; Calafat, AM; Cecil, KM; Chen, A; Xu, Y; Yolton, K; Kalkwarf, HJ; Braun, JM. (2021). Associations of maternal serum perfluoroalkyl substances concentrations with early adolescent bone mineral content and density: The Health Outcomes and Measures of the Environment (HOME) study. Environ Health Perspect 129: 97011. 10.1289/EHP9424.34585601
Budtz-Jørgensen, E; Grandjean, P. (2018). Application of benchmark analysis for mixed contaminant exposures: Mutual adjustment of perfluoroalkylate substances associated with immunotoxicity. PLoS ONE 13: e0205388. 10.1371/journal.pone.0205388.30339706
Bueters, R; Bael, A; Gasthuys, E; Chen, C; Schreuder, MF; Frazier, KS. (2020). Ontogeny and Cross-species Comparison of Pathways Involved in Drug Absorption, Distribution, Metabolism, and Excretion in Neonates (Review): Kidney [Review]. Drug Metab Dispos 48: 353–367. 10.1124/dmd.119.089755.32114509
Bulka, CM; Avula, V; Fry, RC. (2021). Associations of exposure to perfluoroalkyl substances individually and in mixtures with persistent infections: Recent findings from NHANES 1999-2016. Environ Pollut 275: 116619. 10.1016/j.envpol.2021.116619.33578314
Buser, MC; Scinicariello, F. (2016). Perfluoroalkyl substances and food allergies in adolescents. Environ Int 88: 74–79. 10.1016/j.envint.2015.12.020.26722671
Butenhoff, JL; Chang, SC; Ehresman, DJ; York, RG. (2009). Evaluation of potential reproductive and developmental toxicity of potassium perfluorohexanesulfonate in Sprague Dawley rats. Reprod Toxicol 27: 331–341. 10.1016/j.reprotox.2009.01.004.19429404
Byrne, S; Seguinot-Medina, S; Miller, P; Waghiyi, V; von Hippel, FA; Buck, CL; Carpenter, DO. (2017). Exposure to polybrominated diphenyl ethers and perfluoroalkyl substances in a remote population of Alaska Natives. Environ Pollut 231: 387–395. 10.1016/j.envpol.2017.08.020.28818814
Cakmak, S; Lukina, A; Karthikeyan, S; Atlas, E; Dales, R. (2022). The association between blood PFAS concentrations and clinical biochemical measures of organ function and metabolism in participants of the Canadian Health Measures Survey (CHMS). Sci Total Environ 827: 153900. 10.1016/j.scitotenv.2022.153900.35218824
Callan, AC; Rotander, A; Thompson, K; Heyworth, J; Mueller, JF; Odland, JØ; Hinwood, AL. (2016). Maternal exposure to perfluoroalkyl acids measured in whole blood and birth outcomes in offspring. Sci Total Environ 569–570: 1107–1113. 10.1016/j.scitotenv.2016.06.177.
Campbell, S; Raza, M; Pollack, AZ. (2016). Perfluoroalkyl substances and endometriosis in US women in NHANES 2003-2006. Reprod Toxicol 65: 230–235. 10.1016/j.reprotox.2016.08.009.27544573
Canova, C; Barbieri, G; Zare Jeddi, M; Gion, M; Fabricio, A; Daprà, F; Russo, F; Fletcher, T; Pitter, G. (2020). Associations between perfluoroalkyl substances and lipid profile in a highly exposed young adult population in the Veneto Region. Environ Int 145: 106117. 10.1016/j.envint.2020.106117.32971418
Canova, C; Di Nisio, A; Barbieri, G; Russo, F; Fletcher, T; Batzella, E; Dalla Zuanna, T; Pitter, G. (2021). PFAS Concentrations and Cardiometabolic Traits in Highly Exposed Children and Adolescents. Int J Environ Res Public Health 18. 10.3390/ijerph182412881.
Cao, W; Liu, X; Liu, X; Zhou, Y; Zhang, X; Tian, H; Wang, J; Feng, S; Wu, Y; Bhatti, P; Wen, S; Sun, X. (2018). Perfluoroalkyl substances in umbilical cord serum and gestational and postnatal growth in a Chinese birth cohort. Environ Int 116: 197–205. 10.1016/j.envint.2018.04.015.29698896
Cardenas, A; Gold, DR; Hauser, R; Kleinman, KP; Hivert, MF; Calafat, AM; Ye, X; Webster, TF; Horton, ES; Oken, E. (2017). Plasma concentrations of per- and polyfluoroalkyl substances at baseline and associations with glycemic indicators and diabetes incidence among high-risk adults in the Diabetes Prevention Program trial. Environ Health Perspect 125: 107001. 10.1289/EHP1612.28974480
Cariou, R; Veyrand, B; Yamada, A; Berrebi, A; Zalko, D; Durand, S; Pollono, C; Marchand, P; Leblanc, JC; Antignac, JP; Le Bizec, B. (2015). Perfluoroalkyl acid (PFAA) levels and profiles in breast milk, maternal and cord serum of French women and their newborns. Environ Int 84: 71–81. 10.1016/j.envint.2015.07.014.26232143
Carlson, LA; Angrish, M; Shirke, AV; Radke, EG; Schulz, B; Kraft, A; Judson, R; Patlewicz, G; Blain, R; Lin, C; Vetter, N; Lemeris, C; Hartman, P; Hubbard, H; Arzuaga, X; Davis, A; Dishaw, LV; Druwe, IL; Hollinger, H; … Thayer, KA. (2022). Systematic evidence map for over one hundred and fifty per- and polyfluoroalkyl substances (PFAS) [Review]. Environ Health Perspect 130: 56001. 10.1289/EHP10343.35580034
Caron-Beaudoin, É; Ayotte, P; Laouan Sidi, EA; Simon, CoL; Nation, CoWLPF; Nutashkuan, CTKo; Shipu, CoU; Gros-Louis McHugh, N; Lemire, M. (2019). Exposure to perfluoroalkyl substances (PFAS) and associations with thyroid parameters in First Nation children and youth from Quebec. Environ Int 128: 13–23. 10.1016/j.envint.2019.04.029.31029975
Carwile, JL; Seshasayee, SM; Ahrens, KA; Hauser, R; Driban, JB; Rosen, CJ; Gordon, CM; Fleisch, AF. (2022). Serum PFAS and urinary phthalate biomarker concentrations and bone mineral density in 12-19 year olds: 2011-2016 NHANES. J Clin Endocrinol Metab 107: e3343–e3352. 10.1210/clinem/dgac228.35511700
Carwile, JL; Seshasayee, SM; Aris, IM; Rifas-Shiman, SL; Claus Henn, B; Calafat, AM; Sagiv, SK; Oken, E; Fleisch, AF. (2021). Prospective associations of mid-childhood plasma per- and polyfluoroalkyl substances and pubertal timing. Environ Int 156: 106729. 10.1016/j.envint.2021.106729.34171588
Cassone, CG; Vongphachan, V; Chiu, S; Williams, KL; Letcher, RJ; Pelletier, E; Crump, D; Kennedy, SW. (2012). In ovo effects of perfluorohexane sulfonate and perfluorohexanoate on pipping success, development, mRNA expression, and thyroid hormone levels in chicken embryos. Toxicol Sci 127: 216–224. 10.1093/toxsci/kfs072.22302310
Cattley, RC; Cullen, JM. (2018). Chapter 8. Liver and gall bladder. In MA Wallig; WM Haschek; CG Rousseaux; B Bolon (Eds.), Fundamentals of toxicologic pathology (3rd ed., pp. 125–151). Cambridge, MA: Academic Press. 10.1016/B978-0-12-809841-7.00008-3.
CDC (Centers for Disease Control and Prevention). (2022). National report on human exposure to environmental chemicals. Atlanta, GA: U.S. Department of Health and Human Services. https://www.cdc.gov/exposurereport/.
Chan, E; Burstyn, I; Cherry, N; Bamforth, F; Martin, JW. (2011). Perfluorinated acids and hypothyroxinemia in pregnant women. Environ Res 111: 559–564. 10.1016/j.envres.2011.01.011.21310403
Chang, CJ; Barr, DB; Ryan, PB; Panuwet, P; Smarr, MM; Liu, K; Kannan, K; Yakimavets, V; Tan, Y; Ly, V; Marsit, CJ; Jones, DP; Corwin, EJ; Dunlop, AL; Liang, D. (2022). Per- and polyfluoroalkyl substance (PFAS) exposure, maternal metabolomic perturbation, and fetal growth in African American women: A meet-in-the-middle approach. Environ Int 158: 106964. 10.1016/j.envint.2021.106964.34735953
Chang, S; Butenhoff, JL; Parker, GA; Coder, PS; Zitzow, JD; Krisko, RM; Bjork, JA; Wallace, KB; Seed, JG. (2018). Reproductive and developmental toxicity of potassium perfluorohexanesulfonate in CD-1 mice. Reprod Toxicol 78: 150–168. 10.1016/j.reprotox.2018.04.007.29694846
Charles, D; Berg, V; Nøst, TH; Huber, S; Sandanger, TM; Rylander, C. (2020). Pre- and post-diagnostic blood profiles of perfluoroalkyl acids in type 2 diabetes mellitus cases and controls. Environ Int 145: 106095. 10.1016/j.envint.2020.106095.32919259
Chen, A; Jandarov, R; Zhou, L; Calafat, AM; Zhang, G; Urbina, EM; Sarac, J; Augustin, DH; Caric, T; Bockor, L; Petranovic, MZ; Novokmet, N; Missoni, S; Rudan, P; Deka, R. (2019a). Association of perfluoroalkyl substances exposure with cardiometabolic traits in an island population of the eastern Adriatic coast of Croatia. Sci Total Environ 683: 29–36. 10.1016/j.scitotenv.2019.05.250.31129329
Chen, F; Yin, S; Kelly, BC; Liu, W. (2017). Isomer-specific transplacental transfer of perfluoroalkyl acids: Results from a survey of paired maternal, cord sera, and placentas. Environ Sci Technol 51: 5756–5763. 10.1021/acs.est.7b00268.28434222
Chen, L; Tong, C; Huo, X; Zhang, J; Tian, Y. (2021). Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and birth outcomes: A longitudinal cohort with repeated measurements. Chemosphere 267: 128899. 10.1016/j.chemosphere.2020.128899.33220988
Chen, Q; Huang, R; Hua, L; Guo, Y; Huang, L; Zhao, Y; Wang, X; Zhang, J. (2018a). Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and childhood atopic dermatitis: A prospective birth cohort study. Environ Health 17: 1–12. 10.1186/s12940-018-0352-7.29301538
Chen, Q; Zhang, X; Zhao, Y; Lu, W; Wu, J; Zhao, S; Zhang, J; Huang, L. (2019b). Prenatal exposure to perfluorobutanesulfonic acid and childhood adiposity: A prospective birth cohort study in Shanghai, China. Chemosphere 226: 17–23. 10.1016/j.chemosphere.2019.03.095.30908964
Chen, S; Guo, X; Yu, S; Sun, G; Yang, H; Li, Z; Sun, Y. (2016). Association between Serum Uric Acid and Elevated Alanine Aminotransferase in the General Population. Int J Environ Res Public Health 13: 841. 10.3390/ijerph13090841.27563918
Chen, WL; Bai, FY; Chang, YC; Chen, PC; Chen, CY. (2018b). Concentrations of perfluoroalkyl substances in foods and the dietary exposure among Taiwan general population and pregnant women. J Food Drug Anal 26: 994–1004. 10.1016/j.jfda.2017.12.011.29976417
Chevrier, J. (2013). Invited commentary: Maternal plasma polybrominated diphenyl ethers and thyroid hormones--challenges and opportunities [Comment]. Am J Epidemiol 178: 714–719. 10.1093/aje/kwt138.23924577
Chiu, WA; Lynch, MT; Lay, CR; Antezana, A; Malek, P; Sokolinski, S; Rogers, RD. (2022). Bayesian estimation of human population toxicokinetics of PFOA, PFOS, PFHxS, and PFNA from studies of contaminated drinking water. Environ Health Perspect 130: 127001. 10.1289/EHP10103.36454223
Christensen, JVR; Bangash, KK; Weihe, P; Grandjean, P; Nielsen, F; Jensen, TK; Petersen, MS. (2021). Maternal exposure to perfluoroalkyl chemicals and anogenital distance in the offspring: A Faroese cohort study. Reprod Toxicol 104: 52–57. 10.1016/j.reprotox.2021.06.016.34182087
Christensen, KY; Maisonet, M; Rubin, C; Holmes, A; Calafat, AM; Kato, K; Flanders, WD; Heron, J; McGeehin, MA; Marcus, M. (2011). Exposure to polyfluoroalkyl chemicals during pregnancy is not associated with offspring age at menarche in a contemporary British cohort. Environ Int 37: 129–135. 10.1016/j.envint.2010.08.007.20843552
Christensen, KY; Raymond, M; Blackowicz, M; Liu, Y; Thompson, BA; Anderson, HA; Turyk, M. (2017). Perfluoroalkyl substances and fish consumption. Environ Res 154: 145–151. 10.1016/j.envres.2016.12.032.28073048
Christensen, KY; Raymond, M; Meiman, J. (2019). Perfluoroalkyl substances and metabolic syndrome. Int J Hyg Environ Health 222: 147–153. 10.1016/j.ijheh.2018.08.014.30290996
Christensen, KY; Raymond, M; Thompson, BA; Anderson, HA. (2016). Perfluoroalkyl substances in older male anglers in Wisconsin. Environ Int 91: 312–318. 10.1016/j.envint.2016.03.012.27003842
Cluett, R; Seshasayee, SM; Rokoff, LB; Rifas-Shiman, SL; Ye, X; Calafat, AM; Gold, DR; Coull, B; Gordon, CM; Rosen, CJ; Oken, E; Sagiv, SK; Fleisch, AF. (2019). Per- and Polyfluoroalkyl Substance Plasma Concentrations and Bone Mineral Density in Midchildhood: A Cross-Sectional Study (Project Viva, United States). Environ Health Perspect 127: 87006. 10.1289/EHP4918.31433236
Colicino, E; Pedretti, NF; Busgang, SA; Gennings, C. (2020). Per- and poly-fluoroalkyl substances and bone mineral density: Results from the Bayesian weighted quantile sum regression. Environmental Epidemiology 4: 1. 10.1097/EE9.0000000000000092.
Conway, B; Innes, KE; Long, D. (2016). Perfluoroalkyl substances and beta cell deficient diabetes. J Diabetes Complications 30: 993–998. 10.1016/j.jdiacomp.2016.05.001.27311784
Conway, BN; Badders, AN; Costacou, T; Arthur, JM; Innes, KE. (2018). Perfluoroalkyl substances and kidney function in chronic kidney disease, anemia, and diabetes. Diabetes Metab Syndr Obes 11: 707–716. 10.2147/DMSO.S173809.30532572
Coperchini, F; Awwad, O; Rotondi, M; Santini, F; Imbriani, M; Chiovato, L. (2017). Thyroid disruption by perfluorooctane sulfonate (PFOS) and perfluorooctanoate (PFOA) [Review]. J Endocrinol Invest 40: 105–121. 10.1007/s40618-016-0572-z.27837466
Costa, O; Iñiguez, C; Manzano-Salgado, CB; Amiano, P; Murcia, M; Casas, M; Irizar, A; Basterrechea, M; Beneito, A; Schettgen, T; Sunyer, J; Vrijheid, M; Ballester, F; Lopez-Espinosa, MJ. (2019). First-trimester maternal concentrations of polyfluoroalkyl substances and fetal growth throughout pregnancy. Environ Int 130: 104830. 10.1016/j.envint.2019.05.024.31247476
Crawford, NM; Fenton, SE; Strynar, M; Hines, EP; Pritchard, DA; Steiner, AZ. (2017). Effects of perfluorinated chemicals on thyroid function, markers of ovarian reserve, and natural fertility. Reprod Toxicol 69: 53–59. 10.1016/j.reprotox.2017.01.006.28111093
Crofton, KM. (2004). Developmental disruption of thyroid hormone: Correlations with hearing dysfunction in rats. Risk Anal 24: 1665–1671. 10.1111/j.0272-4332.2004.00557.x.15660619
Cuevas, E; Ausó, E; Telefont, M; De Escobar, GM; Sotelo, C; Berbel, P. (2005). Transient maternal hypothyroxinemia at onset of corticogenesis alters tangential migration of medial ganglionic eminence-derived neurons. Eur J Neurosci 22: 541–551. 10.1111/j.1460-9568.2005.04243.x.16101736
Dalla Zuanna, T; Savitz, DA; Barbieri, G; Pitter, G; Zare Jeddi, M; Daprà, F; Fabricio, ASC; Russo, F; Fletcher, T; Canova, C. (2021). The association between perfluoroalkyl substances and lipid profile in exposed pregnant women in the Veneto region, Italy. Ecotoxicol Environ Saf 209: 111805. 10.1016/j.ecoenv.2020.111805.33360787
Dalsager, L; Christensen, N; Halekoh, U; Timmermann, CAG; Nielsen, F; Kyhl, HB; Husby, S; Grandjean, P; Jensen, TK; Andersen, HR. (2021a). Exposure to perfluoroalkyl substances during fetal life and hospitalization for infectious disease in childhood: A study among 1,503 children from the Odense Child Cohort. Environ Int 149: 106395. 10.1016/j.envint.2021.106395.33508532
Dalsager, L; Christensen, N; Husby, S; Kyhl, H; Nielsen, F; Høst, A; Grandjean, P; Jensen, TK. (2016). Association between prenatal exposure to perfluorinated compounds and symptoms of infections at age 1-4years among 359 children in the Odense Child Cohort. Environ Int 96: 58–64. 10.1016/j.envint.2016.08.026.27608427
Dalsager, L; Jensen, TK; Nielsen, F; Grandjean, P; Bilenberg, N; Andersen, HR. (2021b). No association between maternal and child PFAS concentrations and repeated measures of ADHD symptoms at age 2½ and 5 years in children from the Odense Child Cohort. Neurotoxicol Teratol 88: 107031. 10.1016/j.ntt.2021.107031.34563660
Darrow, DC; Soule, HC; Buckman, TE. (1928). Blood volume in normal infants and children. J Clin Invest 5: 243–258. 10.1172/JCI100156.16693790
Das, KP; Wood, CR; Lin, MT; Starkov, AA; Lau, C; Wallace, KB; Corton, JC; Abbott, BD. (2017). Perfluoroalkyl acids-induced liver steatosis: Effects on genes controlling lipid homeostasis. Toxicology 378: 37–52. 10.1016/j.tox.2016.12.007.28049043
Daston, GP; Kimmel, CA. (1998). An evaluation and interpretation of reproductive endpoints for human health risk assessment. In An evaluation and interpretation of reproductive endpoints for human health risk assessment. Washington, DC: ILSI Press.
Daugherty, A; Tall, AR; Daemen, MJA; Falk, E; Fisher, EA; García-Cardeña, G; Lusis, AJ; Owens, AP, III; Rosenfeld, ME; Virmani, R. (2017). Recommendation on design, execution, and reporting of animal atherosclerosis studies: A scientific statement from the American Heart Association [Review]. Arterioscler Thromb Vasc Biol 37: e131–e157. 10.1161/ATV.0000000000000062.28729366
Davies, B; Morris, T. (1993). Physiological parameters in laboratory animals and humans [Review]. Pharm Res 10: 1093–1095. 10.1023/A:1018943613122.8378254
De Boo, HA; Harding, JE. (2006). The developmental origins of adult disease (Barker) hypothesis [Review]. Aust N Z J Obstet Gynaecol 46: 4–14. 10.1111/j.1479-828X.2006.00506.x.16441686
De Vito, P; Incerpi, S; Pedersen, JZ; Luly, P; Davis, FB; Davis, PJ. (2011). Thyroid hormones as modulators of immune activities at the cellular level [Review]. Thyroid 21: 879–890. 10.1089/thy.2010.0429.21745103
Dean, A; Sharpe, RM. (2013). Clinical review: Anogenital distance or digit length ratio as measures of fetal androgen exposure: relationship to male reproductive development and its disorders [Review]. J Clin Endocrinol Metab 98: 2230–2238. 10.1210/jc.2012-4057.23569219
Dent, MP; Carmichael, PL; Jones, KC; Martin, FL. (2015). Towards a non-animal risk assessment for anti-androgenic effects in humans [Review]. Environ Int 83: 94–106. 10.1016/j.envint.2015.06.009.26115536
di Masi, A; De Marinis, E; Ascenzi, P; Marino, M. (2009). Nuclear receptors CAR and PXR: Molecular, functional, and biomedical aspects [Review]. Mol Aspects Med 30: 297–343. 10.1016/j.mam.2009.04.002.19427329
Ding, N; Harlow, SD; Randolph, JF; Mukherjee, B; Batterman, S; Gold, EB; Park, SK. (2022). Perfluoroalkyl Substances and Incident Natural Menopause in Midlife Women: The Mediating Role of Sex Hormones. Am J Epidemiol 191: 1212–1223. 10.1093/aje/kwac052.35292812
Domazet, SL; Jensen, TK; Wedderkopp, N; Nielsen, F; Andersen, LB; Grøntved, A. (2020). Exposure to perfluoroalkylated substances (PFAS) in relation to fitness, physical activity, and adipokine levels in childhood: The European youth heart study. Environ Res 191: 110110. 10.1016/j.envres.2020.110110.32871146
Dong, GH; Tung, KY; Tsai, CH; Liu, MM; Wang, D; Liu, W; Jin, YH; Hsieh, WS; Lee, YL; Chen, PC. (2013). Serum polyfluoroalkyl concentrations, asthma outcomes, and immunological markers in a case-control study of Taiwanese children. Environ Health Perspect 121: 507–513, 513e501–508. 10.1289/ehp.1205351.23309686
Dong, H; You, SH; Williams, A; Wade, MG; Yauk, CL; Zoeller, RT. (2015). Transient maternal hypothyroxinemia potentiates the transcriptional response to exogenous thyroid hormone in the fetal cerebral cortex before the onset of fetal thyroid function: A messenger and microRNA profiling study. Cereb Cortex 25: 1735–1745. 10.1093/cercor/bht364.24436321
Dong, Z; Wang, H; Yu, YY; Li, YB; Naidu, R; Liu, Y. (2019). Using 2003-2014 U.S. NHANES data to determine the associations between per- and polyfluoroalkyl substances and cholesterol: Trend and implications. Ecotoxicol Environ Saf 173: 461–468. 10.1016/j.ecoenv.2019.02.061.30798190
Donley, GM; Taylor, E; Jeddy, Z; Namulanda, G; Hartman, TJ. (2019). Association between in utero perfluoroalkyl substance exposure and anti-Müllerian hormone levels in adolescent females in a British cohort. Environ Res 177: 108585. 10.1016/j.envres.2019.108585.31376627
Duan, Y; Sun, H; Yao, Y; Meng, Y; Li, Y. (2020). Distribution of novel and legacy per-/polyfluoroalkyl substances in serum and its associations with two glycemic biomarkers among Chinese adult men and women with normal blood glucose levels. Environ Int 134: 105295. 10.1016/j.envint.2019.105295.31726357
Dufour, P; Pirard, C; Seghaye, MC; Charlier, C. (2018). Association between organohalogenated pollutants in cord blood and thyroid function in newborns and mothers from Belgian population. Environ Pollut 238: 389–396. 10.1016/j.envpol.2018.03.058.29579638
Dunder, L; Lind, PM; Salihovic, S; Stubleski, J; Kärrman, A; Lind, L. (2022). Changes in plasma levels of per- and polyfluoroalkyl substances (PFAS) are associated with changes in plasma lipids - A longitudinal study over 10 years. Environ Res 211: 112903. 10.1016/j.envres.2022.112903.35231461
Dzierlenga, AL; Robinson, VG; Waidyanatha, S; Devito, MJ; Eifrid, MA; Gibbs, ST; Granville, CA; Blystone, CR. (2019). Toxicokinetics of perfluorohexanoic acid (PFHxA), perfluorooctanoic acid (PFOA) and perfluorodecanoic acid (PFDA) in male and female Hsd:Sprague dawley SD rats following intravenous or gavage administration. Xenobiotica 50: 1–11. 10.1080/00498254.2019.1683776.31625424
Dzierlenga, M, .W.; Crawford, L,.; Longnecker, M, .P. (2020). Birth weight and perfluorooctane sulfonic acid: a random-effects meta-regression analysis. Environmental Epidemiology 4: e095. 10.1097/EE9.0000000000000095.33778349
Eick, SM; Demicco, E; Valeri, L; Woodruff, TJ; Morello-Frosch, R; Hom Thepaksorn, EK; Izano, MA; Cushing, LJ; Wang, Y; Smith, SC; Gao, S; Park, JS; Padula, AM. (2020). Associations between prenatal maternal exposure to per- and polyfluoroalkyl substances (PFAS) and polybrominated diphenyl ethers (PBDEs) and birth outcomes among pregnant women in San Francisco. Environ Health 19: 100–100. 10.1186/s12940-020-00654-2.32938446
Elavarasi, SB; Mariam, D; Momeen, MU; Hu, J; Guin, M. (2019). Effect of fluorination on bandgap, first and second order hyperpolarizabilities in lithium substituted adamantane: A time dependent density functional theory. Chem Phys Lett 715: 310–316. 10.1016/j.cplett.2018.11.034.
EMEA (European Medicines Agency). (2008). Non-clinical guideline on drug induced hepatotoxicity. (EMEA/CHMP/SWP/150115/2006). London, UK. http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500003355.pdf.
Ernst, A; Brix, N; Lauridsen, LLB; Olsen, J; Parner, ET; Liew, Z; Olsen, LH; Ramlau-Hansen, CH. (2019). Exposure to perfluoroalkyl substances during fetal life and pubertal development in boys and girls from the Danish National Birth Cohort. Environ Health Perspect 127: 17004. 10.1289/EHP3567.30628845
Fàbrega, F; Kumar, V; Benfenati, E; Schuhmacher, M; Domingo, JL; Nadal, M. (2015). Physiologically based pharmacokinetic modeling of perfluoroalkyl substances in the human body. Toxicol Environ Chem 97: 814–827. 10.1080/02772248.2015.1060976.
Fan, S; Wu, Y; Bloom, MS; Lv, J; Chen, L; Wang, W; Li, Z; Jiang, Q; Bu, L; Shi, J; Shi, T; Zeng, X; Zhang, L; Zhang, Z; Yang, B; Dong, G; Feng, W. (2023). Associations of per- and polyfluoroalkyl substances and their alternatives with bone mineral density levels and osteoporosis prevalence: A community-based population study in Guangzhou, Southern China. Sci Total Environ 862: 160617–160617. 10.1016/j.scitotenv.2022.160617.36462653
Fan, Y; Lu, C; Li, X; Xu, Q; Zhang, Y; Yang, X; Han, X; Du, G; Xia, Y; Wang, X. (2020). Serum albumin mediates the effect of multiple per- and polyfluoroalkyl substances on serum lipid levels. Environ Pollut 266 Pt 2: 115138. 10.1016/j.envpol.2020.115138.
Faqi, AS; Hoberman, A; Lewis, E; Stump, D. (2017). Chapter 9 - developmental and reproductive toxicology. In A Comprehensive Guide to Toxicology in Nonclinical Drug Development (Second Edition). Cambridge, Maddschusetts: Academic Press. 10.1016/B978-0-12-803620-4.00009-8.
Finken, MJ; van Eijsden, M; Loomans, EM; Vrijkotte, TG; Rotteveel, J. (2013). Maternal hypothyroxinemia in early pregnancy predicts reduced performance in reaction time tests in 5- to 6-year-old offspring. J Clin Endocrinol Metab 98: 1417–1426. 10.1210/jc.2012-3389.23408575
Fisher, M; Arbuckle, TE; Wade, M; Haines, DA. (2013). Do perfluoroalkyl substances affect metabolic function and plasma lipids?--Analysis of the 2007-2009, Canadian Health Measures Survey (CHMS) Cycle 1. Environ Res 121: 95–103. 10.1016/j.envres.2012.11.006.23266098
Fleisch, AF; Rifas-Shiman, SL; Mora, AM; Calafat, AM; Ye, X; Luttmann-Gibson, H; Gillman, MW; Oken, E; Sagiv, SK. (2017). Early-life exposure to perfluoroalkyl substances and childhood metabolic function. Environ Health Perspect 125: 481–487. 10.1289/EHP303.27586368
Forsthuber, M; Kaiser, AM; Granitzer, S; Hassl, I; Hengstschläger, M; Stangl, H; Gundacker, C. (2020). Albumin is the major carrier protein for PFOS, PFOA, PFHxS, PFNA and PFDA in human plasma. Environ Int 137: 105324. 10.1016/j.envint.2019.105324.32109724
Foster, P; Gray, LE, Jr. (2013). Toxic responses of the reproductive system. In CD Klaassen (Ed.), Casarett & Doull’s toxicology: The basic science of poisons (8th ed., pp. 861–906). New York, NY: McGraw-Hill Education. https://www.mheducation.com/highered/product/casarett-doull-s-toxicology-basic-science-poisons-9th-edition-klaassen/9781259863745.html.
Friis-Hansen, B. (1961). Body water compartments in children: Changes during growth and related changes in body composition. Pediatrics 28: 169–181.13702099
Fromme, H; Mosch, C; Morovitz, M; Alba-Alejandre, I; Boehmer, S; Kiranoglu, M; Faber, F; Hannibal, I; Genzel-Boroviczény, O; Koletzko, B; Völkel, W. (2010). Pre- and postnatal exposure to perfluorinated compounds (PFCs). Environ Sci Technol 44: 7123–7129. 10.1021/es101184f.20722423
Fruchart, JC; Nierman, MC; Stroes, ES; Kastelein, JJ; Duriez, P. (2004). New risk factors for atherosclerosis and patient risk assessment [Review]. Circulation 109: III15–III19. 10.1161/01.CIR.0000131513.33892.5b.15198961
Fu, J; Gao, Y; Cui, L; Wang, T; Liang, Y; Qu, G; Yuan, B; Wang, Y; Zhang, A; Jiang, G. (2016). Occurrence, temporal trends, and half-lives of perfluoroalkyl acids (PFAAs) in occupational workers in China. Sci Rep 6: 38039. 10.1038/srep38039.27905562
Fuentes, S; Colomina, MT; Vicens, P; Franco-Pons, N; Domingo, JL. (2007). Concurrent exposure to perfluorooctane sulfonate and restraint stress during pregnancy in mice: effects on postnatal development and behavior of the offspring. Toxicol Sci 98: 589–598. 10.1093/toxsci/kfm121.17504768
Funes, SC; Ríos, M; Fernández-Fierro, A; Rivera-Pérez, D; Soto, JA; Valbuena, JR; Altamirano-Lagos, MJ; Gómez-Santander, F; Jara, EL; Zoroquiain, P; Roa, JC; Kalergis, AM; Riedel, CA. (2022). Female offspring gestated in hypothyroxinemia and infected with human Metapneumovirus (hMPV) suffer a more severe infection and have a higher number of activated CD8+ T lymphocytes. Front Immunol 13: 966917. 10.3389/fimmu.2022.966917.36159799
Gad, SC. (2015). Cardiovascular toxicology and its evaluation. In MB Abou-Donia (Ed.), Mammalian Toxicology. West Sussex, United Kingdom: John Wiley & Sons.
Gale, AJ. (2011). Continuing Education Course #2: Current Understanding of Hemostasis [Review]. Toxicol Pathol 39: 273–280. 10.1177/0192623310389474.21119054
Gallo, E; Amidei, CB; Barbieri, G; Fabricio, ASC; Gion, M; Pitter, G; Daprà, F; Russo, F; Gregori, D; Fletcher, T; Canova, C. (2022). Perfluoroalkyl substances and thyroid stimulating hormone levels in a highly exposed population in the Veneto Region. Environ Res 203: 111794. 10.1016/j.envres.2021.111794.34358507
Gao, K, e; Zhuang, T; Liu, X; Fu, J; Zhang, J; Fu, J, ie; Wang, L; Zhang, A; Liang, Y; Song, M; Jiang, G. (2019). Prenatal Exposure to Per- and Polyfluoroalkyl Substances (PFASs) and Association between the Placental Transfer Efficiencies and Dissociation Constant of Serum Proteins-PFAS Complexes. Environ Sci Technol 53: 6529–6538. 10.1021/acs.est.9b00715.31099564
Gao, Y; Fu, J; Cao, H; Wang, Y; Zhang, A; Liang, Y; Wang, T; Zhao, C; Jiang, G. (2015). Differential Accumulation and Elimination Behavior of Perfluoroalkyl Acid Isomers in Occupational Workers in a Manufactory in China. Environ Sci Technol 49: 6953–6962. 10.1021/acs.est.5b00778.25927957
Gao, Y; Luo, J; Zhang, Y; Pan, C; Ren, Y; Zhang, J; Tian, Y; Cohort, SB. (2022). Prenatal Exposure to Per- and Polyfluoroalkyl Substances and Child Growth Trajectories in the First Two Years. Environ Health Perspect 130: 37006. 10.1289/EHP9875.35285689
Gardener, H; Sun, Q; Grandjean, P. (2021). PFAS concentration during pregnancy in relation to cardiometabolic health and birth outcomes. Environ Res 192: 110287. 10.1016/j.envres.2020.110287.33038367
Geng, Y; Faber, KN; de Meijer, VE; Blokzijl, H; Moshage, H. (2021). How does hepatic lipid accumulation lead to lipotoxicity in non-alcoholic fatty liver disease? [Review]. Hepatology International 15: 21–35. 10.1007/s12072-020-10121-2.33548031
Genova R, G, arza RF. (2024). Breast Fat Necrosis. In StatPearls. Treasure Island, FL: StatPearls Publishing LLC. https://www.ncbi.nlm.nih.gov/books/NBK542191/.
Germolec, DR; Lebrec, H; Anderson, SE; Burleson, GR; Cardenas, A; Corsini, E; Elmore, SE; Kaplan, BLF; Lawrence, BP; Lehmann, GM; Maier, CC; McHale, CM; Myers, LP; Pallardy, M; Rooney, AA; Zeise, L; Zhang, L; Smith, MT. (2022). Consensus on the key characteristics of immunotoxic agents as a basis for hazard identification. Environ Health Perspect 130: 105001. 10.1289/EHP10800.36201310
Getz, GS; Reardon, CA. (2012). Animal models of atherosclerosis [Review]. Arterioscler Thromb Vasc Biol 32: 1104–1115. 10.1161/ATVBAHA.111.237693.22383700
Ghisari, M; Long, M; Røge, DM; Olsen, J; Bonefeld-Jørgensen, EC. (2017). Polymorphism in xenobiotic and estrogen metabolizing genes, exposure to perfluorinated compounds and subsequent breast cancer risk: A nested case-control study in the Danish National Birth Cohort. Environ Res 154: 325–333. 10.1016/j.envres.2017.01.020.28157646
Gilbert, ME; Sanchez-Huerta, K; Wood, C. (2016). Mild thyroid hormone insufficiency during development compromises activity-dependent neuroplasticity in the hippocampus of adult male rats. Endocrinology 157: 774–787. 10.1210/en.2015-1643.26606422
Girum, T; Wasie, A. (2018). Return of fertility after discontinuation of contraception: a systematic review and meta-analysis [Review]. 3: 9. 10.1186/s40834-018-0064-y.
Gleason, J, essie A. Cooper, K.,eith R. Klotz, J.,udith B. Post, G.,loria B. Van Orden, G.,eorge New Jersey Drinking Water Quality Institute (NJDWQI). (2017). Health-based maximum contaminant level support document: Perfluorooctanoic acid (PFOA): Appendix A. New Jersey Drinking Water Quality Institute (NJDWQI), Health Effects Subcommittee. https://www.state.nj.us/dep/watersupply/pdf/pfoa-appendixa.pdf.
Gleason, JA; Post, GB; Fagliano, JA. (2015). Associations of perfluorinated chemical serum concentrations and biomarkers of liver function and uric acid in the US population (NHANES), 2007-2010. Environ Res 136: 8–14. 10.1016/j.envres.2014.10.004.25460614
Glynn, A; Berger, U; Bignert, A; Ullah, S; Aune, M; Lignell, S; Darnerud, PO. (2012). Perfluorinated alkyl acids in blood serum from primiparous women in Sweden: serial sampling during pregnancy and nursing, and temporal trends 1996-2010. Environ Sci Technol 46: 9071–9079. 10.1021/es301168c.22770559
Goeden, HM; Greene, CW; Jacobus, JA. (2019). A transgenerational toxicokinetic model and its use in derivation of Minnesota PFOA water guidance. J Expo Sci Environ Epidemiol 29: 183–195. 10.1038/s41370-018-0110-5.30631142
Goodrich, JA; Alderete, TL; Baumert, BO; Berhane, K; Chen, Z; Gilliland, FD; Goran, MI; Hu, X; Jones, DP; Margetaki, K; Rock, S; Stratakis, N; Valvi, D; Walker, DI; Conti, DV; Chatzi, L. (2021). Exposure to Perfluoroalkyl Substances and Glucose Homeostasis in Youth. Environ Health Perspect 129: 97002. 10.1289/EHP9200.34468161
Goudarzi, H; Miyashita, C; Okada, E; Kashino, I; Chen, CJ; Ito, S; Araki, A; Kobayashi, S; Matsuura, H; Kishi, R. (2017). Prenatal exposure to perfluoroalkyl acids and prevalence of infectious diseases up to 4 years of age. Environ Int 104: 132–138. 10.1016/j.envint.2017.01.024.28392064
Goudarzi, H; Miyashita, C; Okada, E; Kashino, I; Kobayashi, S; Chen, CJ; Ito, S; Araki, A; Matsuura, H; Ito, YM; Kishi, R. (2016). Effects of prenatal exposure to perfluoroalkyl acids on prevalence of allergic diseases among 4-year-old children. Environ Int 94: 124–132. 10.1016/j.envint.2016.05.020.27236407
Graber, JM; Alexander, C; Laumbach, RJ; Black, K; Strickland, PO; Georgopoulos, PG; Marshall, EG; Shendell, DG; Alderson, D; Mi, Z; Mascari, M; Weisel, CP. (2019). Per and polyfluoroalkyl substances (PFAS) blood levels after contamination of a community water supply and comparison with 2013-2014 NHANES. J Expo Sci Environ Epidemiol 29: 172–182. 10.1038/s41370-018-0096-z.30482936
Grandjean, P; Andersen, EW; Budtz-Jørgensen, E; Nielsen, F; Mølbak, K; Weihe, P; Heilmann, C. (2012). Serum vaccine antibody concentrations in children exposed to perfluorinated compounds. JAMA 307: 391–397. 10.1001/jama.2011.2034.22274686
Grandjean, P; Bateson, T. (2021). RE: Benchmark analysis for PFAS immunotoxicity.
Grandjean, P; Heilmann, C; Weihe, P; Nielsen, F; Mogensen, UB; Budtz-Jørgensen, E. (2017a). Serum vaccine antibody concentrations in adolescents exposed to perfluorinated compounds. Environ Health Perspect 125: 077018. 10.1289/EHP275.28749778
Grandjean, P; Heilmann, C; Weihe, P; Nielsen, F; Mogensen, UB; Timmermann, A; Budtz-Jørgensen, E. (2017b). Estimated exposures to perfluorinated compounds in infancy predict attenuated vaccine antibody concentrations at age 5-years. J Immunotoxicol 14: 188–195. 10.1080/1547691X.2017.1360968.28805477
Grandjean, P; Timmermann, CAG; Kruse, M; Nielsen, F; Vinholt, PJ; Boding, L; Heilmann, C; Mølbak, K. (2020). Severity of COVID-19 at elevated exposure to perfluorinated alkylates. PLoS ONE 15: e0244815. 10.1371/journal.pone.0244815.33382826
Granum, B; Haug, LS; Namork, E; Stølevik, SB; Thomsen, C; Aaberge, IS; van Loveren, H; Løvik, M; Nygaard, UC. (2013). Pre-natal exposure to perfluoroalkyl substances may be associated with altered vaccine antibody levels and immune-related health outcomes in early childhood. J Immunotoxicol 10: 373–379. 10.3109/1547691X.2012.755580.23350954
Gross, RS; Ghassabian, A; Vandyousefi, S; Messito, MJ; Gao, C; Kannan, K; Trasande, L. (2020). Persistent organic pollutants exposure in newborn dried blood spots and infant weight status: A case-control study of low-income Hispanic mother-infant pairs. Environ Pollut 267: 115427. 10.1016/j.envpol.2020.115427.33254620
Grynnerup, AG; Lindhard, A; Sørensen, S. (2012). The role of anti-Müllerian hormone in female fertility and infertility - an overview [Review]. Acta Obstet Gynecol Scand 91: 1252–1260. 10.1111/j.1600-0412.2012.01471.x.22646322
Gump, BB; Wu, Q; Dumas, AK; Kannan, K. (2011). Perfluorochemical (PFC) exposure in children: Associations with impaired response inhibition. Environ Sci Technol 45: 8151–8159. 10.1021/es103712g.21682250
Guo, J; Zhang, J; Wang, Z; Zhang, L; Qi, X; Zhang, Y; Chang, X; Wu, C; Zhou, Z. (2021). Umbilical cord serum perfluoroalkyl substance mixtures in relation to thyroid function of newborns: Findings from Sheyang Mini Birth Cohort Study. Chemosphere 273: 129664. 10.1016/j.chemosphere.2021.129664.33493812
Gupta, V; Lee, M. (2011). Central hypothyroidism. Indian J Endocrinol Metab 15: S99–S106. 10.4103/2230-8210.83337.21966662
Guyatt, G; Oxman, AD; Akl, EA; Kunz, R; Vist, G; Brozek, J; Norris, S; Falck-Ytter, Y; Glasziou, P; DeBeer, H; Jaeschke, R; Rind, D; Meerpohl, J; Dahm, P; Schünemann, HJ. (2011). GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol 64: 383–394. 10.1016/j.jclinepi.2010.04.026.21195583
Gyllenhammar, I; Diderholm, B; Gustafsson, J; Berger, U; Ridefelt, P; Benskin, JP; Lignell, S; Lampa, E; Glynn, A. (2018). Perfluoroalkyl acid levels in first-time mothers in relation to offspring weight gain and growth. Environ Int 111: 191–199. 10.1016/j.envint.2017.12.002.29223808
Gyllenhammar I, G, lynn A, L.,ignell S, A.,une M, C.,antillana T, F.,ridén U, L.,ampa E. (2017). Utvärdering av samband mellan mammors POP-belastning under graviditets- och amningsperioden och deras barns hälsa. (2215-17-008). Swedish Environmental Protection Agency.
Hack, M; Klein, NK; Taylor, HG. (1995). Long-term developmental outcomes of low birth weight infants [Review]. Future Child 5: 176–196. 10.2307/1602514.7543353
Haddow, JE; Palomaki, GE; Allan, WC; Williams, JR; Knight, GJ; Gagnon, J; O’Heir, CE; Mitchell, ML; Hermos, RJ; Waisbren, SE; Faix, JD; Klein, RZ. (1999). Maternal thyroid deficiency during pregnancy and subsequent neuropsychological development of the child. N Engl J Med 341: 549–555. 10.1056/NEJM199908193410801.10451459
Hall, AP; Elcombe, CR; Foster, JR; Harada, T; Kaufmann, W; Knippel, A; Küttler, K; Malarkey, DE; Maronpot, RR; Nishikawa, A; Nolte, T; Schulte, A; Strauss, V; York, MJ. (2012). Liver hypertrophy: A review of adaptive (adverse and non-adverse) changes—Conclusions from the 3rd International ESTP Expert Workshop [Review]. Toxicol Pathol 40: 971–994. 10.1177/0192623312448935.22723046
Hall, CL; Guo, B; Valentine, AZ; Groom, MJ; Daley, D; Sayal, K; Hollis, C. (2019). The validity of the Strengths and Difficulties Questionnaire (SDQ) for children with ADHD symptoms. PLoS ONE 14: e0218518. 10.1371/journal.pone.0218518.31216327
Hallberg, L; Högdahl, AM; Nilsson, L; Rybo, G. (1966). Menstrual blood loss--a population study. Variation at different ages and attempts to define normality. Acta Obstet Gynecol Scand 45: 320–351. 10.3109/00016346609158455.5922481
Hamm, MP; Cherry, NM; Chan, E; Martin, JW; Burstyn, I. (2010). Maternal exposure to perfluorinated acids and fetal growth. J Expo Sci Environ Epidemiol 20: 589–597. 10.1038/jes.2009.57.19865074
Hammarstrand, S; Jakobsson, K; Andersson, E; Xu, Y; Li, Y; Olovsson, M; Andersson, EM. (2021). Perfluoroalkyl substances (PFAS) in drinking water and risk for polycystic ovarian syndrome, uterine leiomyoma, and endometriosis: A Swedish cohort study. Environ Int 157: 106819. 10.1016/j.envint.2021.106819.34391986
Hanssen, L; Dudarev, AA; Huber, S; Odland, JØ; Nieboer, E; Sandanger, TM. (2013). Partition of perfluoroalkyl substances (PFASs) in whole blood and plasma, assessed in maternal and umbilical cord samples from inhabitants of arctic Russia and Uzbekistan. Sci Total Environ 447: 430–437. 10.1016/j.scitotenv.2013.01.029.23410865
Harada, K; Inoue, K; Morikawa, A; Yoshinaga, T; Saito, N; Koizumi, A. (2005). Renal clearance of perfluorooctane sulfonate and perfluorooctanoate in humans and their species-specific excretion. Environ Res 99: 253–261. 10.1016/j.envres.2004.12.003.16194675
Harbison, RD; Bourgeois, MM; Johnson, GT. (2015). Hamilton & Hardy’s industrial toxicology (6th ed.). Hoboken, NJ: John Wiley & Sons, Inc. http://www.wiley.com/WileyCDA/WileyTitle/productCd-0470929731,subjectCd-CH50.html.
Hardell, E; Kärrman, A; van Bavel, B; Bao, J; Carlberg, M; Hardell, L. (2014). Case-control study on perfluorinated alkyl acids (PFAAs) and the risk of prostate cancer. Environ Int 63: 35–39. 10.1016/j.envint.2013.10.005.24246240
Harlow, SD; Hood, MM; Ding, N; Mukherjee, B; Calafat, AM; Randolph, JF, Jr; Gold, EB; Park, SK. (2021). Per- and polyfluoroalkyl substances and hormone levels during the menopausal transition. J Clin Endocrinol Metab 106: e4427–e4437. 10.1210/clinem/dgab476.34181018
Harris, MH; Oken, E; Rifas-Shiman, SL; Calafat, AM; Bellinger, DC; Webster, TF; White, RF; Sagiv, SK. (2021). Prenatal and childhood exposure to per- and polyfluoroalkyl substances (PFAS) and child executive function and behavioral problems. Environ Res 202: 111621. 10.1016/j.envres.2021.111621.34237332
Harris, MH; Oken, E; Rifas-Shiman, SL; Calafat, AM; Ye, X; Bellinger, DC; Webster, TF; White, RF; Sagiv, SK. (2018). Prenatal and childhood exposure to per- and polyfluoroalkyl substances (PFASs) and child cognition. Environ Int 115: 358–369. 10.1016/j.envint.2018.03.025.29705692
Harris, MH; Rifas-Shiman, SL; Calafat, AM; Ye, X; Mora, AM; Webster, TF; Oken, E; Sagiv, SK. (2017). Predictors of per- and polyfluoroalkyl substance (PFAS) plasma concentrations in 6-10 year old American children. Environ Sci Technol 51: 5193–5204. 10.1021/acs.est.6b05811.28325044
Harris, NS; Bazydlo, LAL; Winter, WE. (2012). Coagulation tests: a primer on hemostasis for clinical chemists. Clinical Laboratory News 2012.
Hartman, TJ; Calafat, AM; Holmes, AK; Marcus, M; Northstone, K; Flanders, WD; Kato, K; Taylor, EV. (2017). Prenatal exposure to perfluoroalkyl substances and body fatness in girls. Child Obes 13: 222–230. 10.1089/chi.2016.0126.28128969
Haug, LS; Thomsen, C; Becher, G. (2009). A sensitive method for determination of a broad range of perfluorinated compounds in serum suitable for large-scale human biomonitoring. J Chromatogr A 1216: 385–393. 10.1016/j.chroma.2008.10.113.19026423
Haug, LS; Thomsen, C; Brantsæter, AL; Kvalem, HE; Haugen, M; Becher, G; Alexander, J; Meltzer, HM; Knutsen, HK. (2010). Diet and particularly seafood are major sources of perfluorinated compounds in humans. Environ Int 36: 772–778. 10.1016/j.envint.2010.05.016.20579735
He, X; Jiang, J; Zhang, XX. (2022). Environmental exposure to low-dose perfluorohexanesulfonate promotes obesity and non-alcoholic fatty liver disease in mice fed a high-fat diet. Environ Sci Pollut Res Int 29: 49279–49290. 10.1007/s11356-022-19369-7.35217953
He, X; Liu, Y; Xu, B; Gu, L; Tang, W. (2018). PFOA is associated with diabetes and metabolic alteration in US men: National Health and Nutrition Examination Survey 2003-2012. Sci Total Environ 625: 566–574. 10.1016/j.scitotenv.2017.12.186.29291571
Heffernan, AL; Cunningham, TK; Drage, DS; Aylward, LL; Thompson, K; Vijayasarathy, S; Mueller, JF; Atkin, SL; Sathyapalan, T. (2018). Perfluorinated alkyl acids in the serum and follicular fluid of UK women with and without polycystic ovarian syndrome undergoing fertility treatment and associations with hormonal and metabolic parameters. Int J Hyg Environ Health 221: 1068–1075. 10.1016/j.ijheh.2018.07.009.30037723
Henrichs, J; Ghassabian, A; Peeters, RP; Tiemeier, H. (2013). Maternal hypothyroxinemia and effects on cognitive functioning in childhood: how and why? [Review]. Clin Endocrinol 79: 152162. 10.1111/cen.12227.
Heo, JJ; Lee, JW; Kim, SK; Oh, JE. (2014). Foodstuff analyses show that seafood and water are major perfluoroalkyl acids (PFAAs) sources to humans in Korea. J Hazard Mater 279: 402–409. 10.1016/j.jhazmat.2014.07.004.25093550
Hill, AB. (1965). The environment and disease: Association or causation? Proc R Soc Med 58: 295–300. 10.1177/003591576505800503.14283879
Hillard, PA. (2014). Menstrual suppression: current perspectives. International Journal of Women’s Health 6: 631–637. 10.2147/IJWH.S46680.
Hjermitslev, MH; Long, M; Wielsøe, M; Bonefeld-Jørgensen, EC. (2020). Persistent organic pollutants in Greenlandic pregnant women and indices of foetal growth: The ACCEPT study. Sci Total Environ 698: 134118. 10.1016/j.scitotenv.2019.134118.31494415
Hoffman, K; Webster, TF; Weisskopf, MG; Weinberg, J; Vieira, VM. (2010). Exposure to polyfluoroalkyl chemicals and attention deficit/hyperactivity disorder in U.S. children 12-15 years of age. Environ Health Perspect 118: 1762–1767. 10.1289/ehp.1001898.20551004
Højsager, FD; Sigvaldsen, A; Andersen, MS; Juul, A; Nielsen, F; Möller, S; Christesen, HBT; Grøntved, A; Grandjean, P; Jensen, TK. (2023). Prenatal and early postnatal exposure to perfluoroalkyl substances and bone mineral content and density in the Odense Child Cohort. Environ Int 181: 108264. 10.1016/j.envint.2023.108264.37864903
Honda-Kohmo, K; Hutcheson, R; Innes, KE; Conway, BN. (2019). Perfluoroalkyl substances are inversely associated with coronary heart disease in adults with diabetes. J Diabetes Complications 33: 407–412. 10.1016/j.jdiacomp.2019.02.004.30928231
Hood, A; Hashmi, R; Klaassen, CD. (1999a). Effects of microsomal enzyme inducers on thyroid-follicular cell proliferation, hyperplasia, and hypertrophy. Toxicol Appl Pharmacol 160: 163–170. 10.1006/taap.1999.8752.10527915
Hood, A; Klaassen, CD. (2000). Differential effects of microsomal enzyme inducers on in vitro thyroxine (T4) and triiodothyronine (T3) glucuronidation. Toxicol Sci 55: 78–84. 10.1093/toxsci/55.1.78.10788562
Hood, A; Liu, YP; Gattone, VH; Klaassen, CD. (1999b). Sensitivity of thyroid gland growth to thyroid stimulating hormone (TSH) in rats treated with antithyroid drugs. Toxicol Sci 49: 263–271. 10.1093/toxsci/49.2.263.10416271
Horn, CL; Morales, AL; Savard, C; Farrell, GC; Ioannou, GN. (2022). Role of cholesterol-associated steatohepatitis in the development of NASH [Review]. Hepatol Commun 6: 12–35. 10.1002/hep4.1801.34558856
Høyer, BB; Bonde, JP; Tøttenborg, SS; Ramlau-Hansen, CH; Lindh, C; Pedersen, HS; Toft, G. (2017). Exposure to perfluoroalkyl substances during pregnancy and child behaviour at 5 to 9 years of age. Horm Behav 101: 105–112. 10.1016/j.yhbeh.2017.11.007.29133180
Hu, Y; Liu, G; Rood, J; Liang, L; Bray, GA; de Jonge, L; Coull, B; Furtado, JD; Qi, L; Grandjean, P; Sun, Q. (2019). Perfluoroalkyl substances and changes in bone mineral density: A prospective analysis in the POUNDS-LOST study. Environ Res 179: 108775. 10.1016/j.envres.2019.108775.31593837
Huang, EJ; Reichardt, LF. (2001). Neurotrophins: Roles in neuronal development and function. Annu Rev Neurosci 24: 677–736. 10.1146/annurev.neuro.24.1.677.11520916
Huang, K; Zhou, W; Fu, J; Zhang, Q; Teng, Y; Gu, L; Fu, Y; Hu, B; Mei, Y; Zhang, H; Zhang, A; Fu, J; Jiang, G. (2023). Linking Transthyretin-Binding Chemicals and Free Thyroid Hormones: In Vitro to In Vivo Extrapolation Based on a Competitive Binding Model. Environ Sci Technol 57: 9130–9139. 10.1021/acs.est.3c01094.37261382
Huang, M; Jiao, J; Zhuang, P; Chen, X; Wang, J; Zhang, Y. (2018). Serum polyfluoroalkyl chemicals are associated with risk of cardiovascular diseases in national US population. Environ Int 119: 37–46. 10.1016/j.envint.2018.05.051.29933236
Huang, MC; Dzierlenga, AL; Robinson, VG; Waidyanatha, S; Devito, MJ; Eifrid, MA; Granville, CA; Gibbs, ST; Blystone, CR. (2019a). Toxicokinetics of perfluorobutane sulfonate (PFBS), perfluorohexane-1-sulphonic acid (PFHxS), and perfluorooctane sulfonic acid (PFOS) in male and female Hsd:Sprague Dawley SD rats after intravenous and gavage administration. Toxicol Rep 6: 645–655. 10.1016/j.toxrep.2019.06.016.31334035
Huang, Q; Liu, L; Wu, Y; Wang, X; Luo, L; Nan, B; Zhang, J; Tian, M; Shen, H. (2019b). Seminal plasma metabolites mediate the associations of multiple environmental pollutants with semen quality in Chinese men. Environ Int 132: 105066. 10.1016/j.envint.2019.105066.31394396
Huang, R; Chen, Q; Zhang, L; Luo, K; Chen, L; Zhao, S; Feng, L; Zhang, J. (2019c). Prenatal exposure to perfluoroalkyl and polyfluoroalkyl substances and the risk of hypertensive disorders of pregnancy. Environ Health 18: 5. 10.1186/s12940-018-0445-3.30626391
Humblet, O; Diaz-Ramirez, LG; Balmes, JR; Pinney, SM; Hiatt, RA. (2014). Perfluoroalkyl chemicals and asthma among children 12-19 years of age: NHANES (1999-2008). Environ Health Perspect 122: 1129–1133. 10.1289/ehp.1306606.24905661
Huo, X; Zhang, L; Huang, R; Feng, L; Wang, W; Zhang, J; Cohort, SB. (2020). Perfluoroalkyl substances exposure in early pregnancy and preterm birth in singleton pregnancies: a prospective cohort study. Environ Health 19: 60. 10.1186/s12940-020-00616-8.32493312
ICH Expert Working Group. (2005). Immunotoxicity studies for human pharmaceuticals S8 11. In ICH Harmonised Tripartite Guideline.
Idalsoaga, F; Kulkarni, AV; Mousa, OY; Arrese, M; Arab, JP. (2020). Non-alcoholic fatty liver disease and alcohol-related liver disease: Two intertwined entities. Front Med 7. 10.3389/fmed.2020.00448.
Impinen, A; Longnecker, MP; Nygaard, UC; London, SJ; Ferguson, KK; Haug, LS; Granum, B. (2019). Maternal levels of perfluoroalkyl substances (PFASs) during pregnancy and childhood allergy and asthma related outcomes and infections in the Norwegian Mother and Child (MoBa) Cohort. Environ Int 124: 462–472. 10.1016/j.envint.2018.12.041.30684804
Impinen, A; Nygaard, UC; Lødrup Carlsen, KC; Mowinckel, P; Carlsen, KH; Haug, LS; Granum, B. (2018). Prenatal exposure to perfluoralkyl substances (PFASs) associated with respiratory tract infections but not allergy- and asthma-related health outcomes in childhood. Environ Res 160: 518–523. 10.1016/j.envres.2017.10.012.29106950
Inoue, K; Ritz, B; Andersen, SL; Ramlau-Hansen, CH; Høyer, BB; Bech, BH; Henriksen, TB; Bonefeld-Jørgensen, EC; Olsen, J; Liew, Z. (2019). Perfluoroalkyl substances and maternal thyroid hormones in early pregnancy; findings in the Danish National Birth Cohort. Environ Health Perspect 127: 117002. 10.1289/EHP5482.31714155
Ioannou, GN. (2016). The Role of Cholesterol in the Pathogenesis of NASH [Review]. Trends Endocrinol Metab 27: 84–95. 10.1016/j.tem.2015.11.008.26703097
IPCS (International Programme on Chemical Safety). (1996). Principles and methods for assessing direct immunotoxicity associated with exposure to chemicals. Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc180.htm.
IPCS (International Programme on Chemical Safety). (2006). Principles for evaluating health risks in children associated with exposure to chemicals [WHO EHC]. (Environmental Health Criteria 225). Geneva, Switzerland: World Health Organization.
IPCS (International Programme on Chemical Safety). (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/330098.
Irizarry, L. (2014). Thyroid hormone toxicity [Supplemental Data]. Endocrinology n/a.
Itoh, S; Araki, A; Miyashita, C; Yamazaki, K; Goudarzi, H; Minatoya, M; Ait Bamai, Y; Kobayashi, S; Okada, E; Kashino, I; Yuasa, M; Baba, T; Kishi, R. (2019). Association between perfluoroalkyl substance exposure and thyroid hormone/thyroid antibody levels in maternal and cord blood: The Hokkaido Study. Environ Int 133: 105139. 10.1016/j.envint.2019.105139.31518930
Jackson-Browne, MS; Eliot, M; Patti, M; Spanier, AJ; Braun, JM. (2020). PFAS (per- and polyfluoroalkyl substances) and asthma in young children: NHANES 2013-2014. Int J Hyg Environ Health 229: 113565. 10.1016/j.ijheh.2020.113565.32485600
Jain, R. (2021a). Impact of kidney hyperfiltration on concentrations of selected perfluoroalkyl acids among US adults for various disease groups. Environ Sci Pollut Res Int 28: 21499–21515. 10.1007/s11356-020-11855-0.33411299
Jain, RB. (2013). Effect of pregnancy on the levels of selected perfluoroalkyl compounds for females aged 17-39 years: data from National Health and Nutrition Examination Survey 2003-2008. J Toxicol Environ Health A 76: 409–421. 10.1080/15287394.2013.771547.23611181
Jain, RB. (2014). Contribution of diet and other factors to the levels of selected polyfluorinated compounds: data from NHANES 2003-2008. Int J Hyg Environ Health 217: 52–61. 10.1016/j.ijheh.2013.03.008.23601780
Jain, RB. (2019). Synergistic impact of co-exposures to toxic metals cadmium, lead, and mercury along with perfluoroalkyl substances on the healthy kidney function. Environ Res 169: 342–347. 10.1016/j.envres.2018.11.037.30504076
Jain, RB. (2020). Impact of the co-occurrence of obesity with diabetes, anemia, hypertension, and albuminuria on concentrations of selected perfluoroalkyl acids. Environ Pollut 266 Pt. 2: 115207. 10.1016/j.envpol.2020.115207.
Jain, RB. (2021b). Perfluoroalkyl acids and their isomers, diabetes, anemia, and albuminuria: Variabilities with deteriorating kidney function. Ecotoxicol Environ Saf 208: 111625. 10.1016/j.ecoenv.2020.111625.33396145
Jain, RB; Ducatman, A. (2018). Associations between lipid/lipoprotein levels and perfluoroalkyl substances among US children aged 6-11 years. Environ Pollut 243: 1–8. 10.1016/j.envpol.2018.08.060.30170203
Jain, RB; Ducatman, A. (2019a). Dynamics of associations between perfluoroalkyl substances and uric acid across the various stages of glomerular function. Environ Sci Pollut Res Int 26: 12425–12434. 10.1007/s11356-019-04666-5.30847808
Jain, RB; Ducatman, A. (2019b). Perfluoroalkyl acids serum concentrations and their relationship to biomarkers of renal failure: Serum and urine albumin, creatinine, and albumin creatinine ratios across the spectrum of glomerular function among US adults. Environ Res 174: 143–151. 10.1016/j.envres.2019.04.034.31077989
Jain, RB; Ducatman, A. (2019c). Perfluoroalkyl substances follow inverted U-shaped distributions across various stages of glomerular function: Implications for future research. Environ Res 169: 476–482. 10.1016/j.envres.2018.11.033.30530087
Jain, RB; Ducatman, A. (2019d). Roles of gender and obesity in defining correlations between perfluoroalkyl substances and lipid/lipoproteins. Sci Total Environ 653: 74–81. 10.1016/j.scitotenv.2018.10.362.30408670
Jain, RB; Ducatman, A. (2019e). Selective associations of recent low concentrations of perfluoroalkyl substances with liver function biomarkers: nhanes 2011 to 2014 data on us adults aged ≥20 years. J Occup Environ Med 61: 293–302. 10.1097/JOM.0000000000001532.30589657
Jain, RB; Ducatman, A. (2022). Serum concentrations of selected perfluoroalkyl substances for US females compared to males as they age. Sci Total Environ 842: 156891. 10.1016/j.scitotenv.2022.156891.35753482
Jain, RB; Ducatman, A. (2023). Factors affecting serum PFAS concentrations among US females with surgically and naturally induced menopause: data from NHANES 2003-2018. Environ Sci Pollut Res Int 30: 84705–84724. 10.1007/s11356-023-28395-y.37369902
Janis, JA; Rifas-Shiman, SL; Seshasayee, SM; Sagiv, S; Calafat, AM; Gold, DR; Coull, BA; Rosen, CJ; Oken, E; Fleisch, AF. (2021). Plasma concentrations of per- and polyfluoroalkyl substances and body composition from mid-childhood to early adolescence. J Clin Endocrinol Metab 106: e3760–e3770. 10.1210/clinem/dgab187.33740056
Jeddy, Z; Hartman, TJ; Taylor, EV; Poteete, C; Kordas, K. (2017). Prenatal concentrations of perfluoroalkyl substances and early communication development in British girls. Early Hum Dev 109: 15–20. 10.1016/j.earlhumdev.2017.04.004.28411449
Jeddy, Z; Tobias, JH; Taylor, EV; Northstone, K; Flanders, WD; Hartman, TJ. (2018). Prenatal concentrations of perfluoroalkyl substances and bone health in British girls at age 17. Archives of Osteoporosis 13: 84. 10.1007/s11657-018-0498-5.30076472
Jensen, RC; Andersen, MS; Larsen, PV; Glintborg, D; Dalgård, C; Timmermann, CAG; Nielsen, F; Sandberg, MB; Andersen, HR; Christesen, HT; Grandjean, P; Jensen, TK. (2020a). Prenatal Exposures to Perfluoroalkyl Acids and Associations with Markers of Adiposity and Plasma Lipids in Infancy: An Odense Child Cohort Study. Environ Health Perspect 128: 77001. 10.1289/EHP5184.32628516
Jensen, RC; Glintborg, D; Gade Timmermann, CA; Nielsen, F; Kyhl, HB; Frederiksen, H; Andersson, AM; Juul, A; Sidelmann, JJ; Andersen, HR; Grandjean, P; Andersen, MS; Jensen, TK. (2020b). Prenatal exposure to perfluorodecanoic acid is associated with lower circulating concentration of adrenal steroid metabolites during mini puberty in human female infants. The odense child cohort. Environ Res 182: 109101. 10.1016/j.envres.2019.109101.32069767
Jensen, RC; Glintborg, D; Timmermann, CAG; Nielsen, F; Kyhl, HB; Andersen, HR; Grandjean, P; Jensen, TK; Andersen, M. (2018). Perfluoroalkyl substances and glycemic status in pregnant Danish women: The Odense Child Cohort. Environ Int 116: 101–107. 10.1016/j.envint.2018.04.010.29660612
Jensen, TK; Andersen, LB; Kyhl, HB; Nielsen, F; Christesen, HT; Grandjean, P. (2015). Association between perfluorinated compound exposure and miscarriage in Danish pregnant women. PLoS ONE 10: e0123496. 10.1371/journal.pone.0123496.25848775
Ji, K; Kim, S; Kho, Y; Paek, D; Sakong, J; Ha, J; Kim, S; Choi, K. (2012). Serum concentrations of major perfluorinated compounds among the general population in Korea: dietary sources and potential impact on thyroid hormones. Environ Int 45: 78–85. 10.1016/j.envint.2012.03.007.22580293
Jiang, W; Zhang, Y; Zhu, L; Deng, J. (2014). Serum levels of perfluoroalkyl acids (PFAAs) with isomer analysis and their associations with medical parameters in Chinese pregnant women. Environ Int 64: 40–47. 10.1016/j.envint.2013.12.001.24361923
Jin, H; Mao, L; Xie, J; Zhao, M; Bai, X; Wen, J; Shen, T; Wu, P. (2020a). Poly- and perfluoroalkyl substance concentrations in human breast milk and their associations with postnatal infant growth. Sci Total Environ 713: 136417. 10.1016/j.scitotenv.2019.136417.31955077
Jin, H; Zhang, Y; Jiang, W; Zhu, L; Martin, JW. (2016). Isomer-Specific Distribution of Perfluoroalkyl Substances in Blood. Environ Sci Technol 50: 7808–7815. 10.1021/acs.est.6b01698.27295125
Jin, R; Mcconnell, R; Catherine, C; Xu, S; Walker, DI; Stratakis, N; Jones, DP; Miller, GW; Peng, C; Conti, DV; Vos, MB; Chatzi, L. (2020b). Perfluoroalkyl substances and severity of nonalcoholic fatty liver in Children: An untargeted metabolomics approach. Environ Int 134: 105220. 10.1016/j.envint.2019.105220.31744629
Joensen, UN; Veyrand, B; Antignac, JP; Blomberg Jensen, M; Petersen, JH; Marchand, P; Skakkebæk, NE; Andersson, AM; Le Bizec, B; Jørgensen, N. (2013). PFOS (perfluorooctanesulfonate) in serum is negatively associated with testosterone levels, but not with semen quality, in healthy men. Hum Reprod 28: 599–608. 10.1093/humrep/des425.23250927
Jopling, J; Henry, E; Wiedmeier, SE; Christensen, RD. (2009). Reference ranges for hematocrit and blood hemoglobin concentration during the neonatal period: Data from a multihospital health care system. Pediatrics 123: E333–E337. 10.1542/peds.2008-2654.19171584
Jordan, CD; Flood, JG; Laposata, M; Lewandrowski, KB. (1992). Normal reference laboratory values. N Engl J Med 327: 718–724. 10.1056/NEJM199209033271009.1495525
Jørgensen, KT; Specht, IO; Lenters, V; Bach, CC; Rylander, L; Jönsson, BA; Lindh, CH; Giwercman, A; Heederik, D; Toft, G; Bonde, JP. (2014). Perfluoroalkyl substances and time to pregnancy in couples from Greenland, Poland and Ukraine. Environ Health 13: 116. 10.1186/1476-069X-13-116.25533644
Joshi-Barve, S; Kirpich, I; Cave, MC; Marsano, LS; McClain, CJ. (2015). Alcoholic, nonalcoholic, and toxicant-associated steatohepatitis: Mechanistic similarities and differences [Review]. CMGH 1: 356–367. 10.1016/j.jcmgh.2015.05.006.28210688
Joubert, L; Warme, A; Larson, A; Gronhaug, G; Michael, M; Schoffl, V; Burtscher, E; Meyer, N. (2022). Prevalence of amenorrhea in elite female competitive climbers. Front Sports Act Living 4: 895588. 10.3389/fspor.2022.895588.36032265
Kang, H; Kim, HS; Yoon, YS; Lee, J; Kho, Y; Lee, J; Chang, HJ; Cho, YH; Kim, YA. (2021). Placental transfer and composition of perfluoroalkyl substances (PFASs): A Korean birth panel of parent-infant triads. Toxics 9: 168. 10.3390/toxics9070168.34357911
Kang, H; Lee, HK; Moon, HB; Kim, S; Lee, J; Ha, M; Hong, S; Kim, S; Choi, K. (2018). Perfluoroalkyl acids in serum of Korean children: Occurrences, related sources, and associated health outcomes. Sci Total Environ 645: 958–965. 10.1016/j.scitotenv.2018.07.177.30032090
Kang, Q; Gao, F; Zhang, X; Wang, L; Liu, J; Fu, M; Zhang, S; Wan, Y; Shen, H; Hu, J. (2020). Nontargeted identification of per- and polyfluoroalkyl substances in human follicular fluid and their blood-follicle transfer. Environ Int 139: 105686. 10.1016/j.envint.2020.105686.32278886
Karlsen, M; Grandjean, P; Weihe, P; Steuerwald, U; Oulhote, Y; Valvi, D. (2017). Early-life exposures to persistent organic pollutants in relation to overweight in preschool children. Reprod Toxicol 68: 145–153. 10.1016/j.reprotox.2016.08.002.27496715
Kärrman, A; Domingo, JL; Llebaria, X; Nadal, M; Bigas, E; van Bavel, B; Lindström, G. (2010). Biomonitoring perfluorinated compounds in Catalonia, Spain: Concentrations and trends in human liver and milk samples. Environ Sci Pollut Res Int 17: 750–758. 10.1007/s11356-009-0178-5.19458971
Kärrman, A; Ericson, I; van Bavel, B; Darnerud, PO; Aune, M; Glynn, A; Lignell, S; Lindström, G. (2007). Exposure of perfluorinated chemicals through lactation: Levels of matched human milk and serum and a temporal trend, 1996-2004, in Sweden. Environ Health Perspect 115: 226–230. 10.1289/ehp.9491.17384769
Kashino, I; Sasaki, S; Okada, E; Matsuura, H; Goudarzi, H; Miyashita, C; Okada, E; Ito, YM; Araki, A; Kishi, R. (2020). Prenatal exposure to 11 perfluoroalkyl substances and fetal growth: A large-scale, prospective birth cohort study. Environ Int 136: 105355. 10.1016/j.envint.2019.105355.32029284
Kataria, A; Trachtman, H; Malaga-Dieguez, L; Trasande, L. (2015). Association between perfluoroalkyl acids and kidney function in a cross-sectional study of adolescents. Environ Health 14: 89. 10.1186/s12940-015-0077-9.26590127
Kato, K; Calafat, AM; Needham, LL. (2009). Polyfluoroalkyl chemicals in house dust. Environ Res 109: 518–523. 10.1016/j.envres.2009.01.005.19261270
Kawabata, K; Matsuzaki, H; Nukui, S; Okazaki, M; Sakai, A; Kawashima, Y; Kudo, N. (2017). Perfluorododecanoic acid induces cognitive deficit in adult rats. Toxicol Sci 157: 421–428. 10.1093/toxsci/kfx058.28402547
Khalil, N; Chen, A; Lee, M; Czerwinski, SA; Ebert, JR; Dewitt, JC; Kannan, K. (2016). Association of Perfluoroalkyl Substances, Bone Mineral Density, and Osteoporosis in the US Population in NHANES 2009-2010. Environ Health Perspect 124: 81–87. 10.1289/ehp.1307909.26058082
Khalil, N; Ducatman, AM; Sinari, S; Billheimer, D; Hu, C; Littau, S; Burgess, JL. (2020). Per- and polyfluoroalkyl substance and cardio metabolic markers in firefighters. J Occup Environ Med 62: 1076–1081. 10.1097/JOM.0000000000002062.33105404
Khalil, N; Ebert, JR; Honda, M; Lee, M; Nahhas, RW; Koskela, A; Hangartner, T; Kannan, K. (2018). Perfluoroalkyl substances, bone density, and cardio-metabolic risk factors in obese 8-12 year old children: A pilot study. Environ Res 160: 314–321. 10.1016/j.envres.2017.10.014.29040951
Khan, KNM; Hard, GC; Li, X; Alden, CL. (2018). Chapter 11 - Urinary system. In Fundamentals of Toxicologic Pathology (Third Edition). Cambridge, MA: Academic Press. 10.1016/B978-0-12-809841-7.00011-3.
Kielsen, K; Shamim, Z; Ryder, LP; Nielsen, F; Grandjean, P; Budtz-Jørgensen, E; Heilmann, C. (2016). Antibody response to booster vaccination with tetanus and diphtheria in adults exposed to perfluorinated alkylates. J Immunotoxicol 13: 270–273. 10.3109/1547691X.2015.1067259.26181512
Kim, DH; Kim, UJ; Kim, HY; Choi, SD; Oh, JE. (2016a). Perfluoroalkyl substances in serum from South Korean infants with congenital hypothyroidism and healthy infants - Its relationship with thyroid hormones. Environ Res 147: 399–404. 10.1016/j.envres.2016.02.037.26950028
Kim, HY; Kim, KN; Shin, CH; Lim, YH; Kim, JI; Kim, BN; Hong, YC; Lee, YA. (2020a). The relationship between perfluoroalkyl substances concentrations and thyroid function in early childhood: A prospective cohort study. Thyroid 30: 1556–1565. 10.1089/thy.2019.0436.32368952
Kim, K; Bennett, DH; Calafat, AM; Hertz-Picciotto, I; Shin, HM. (2020b). Temporal trends and determinants of serum concentrations of per- and polyfluoroalkyl substances among Northern California mothers with a young child, 2009-2016. Environ Res 186: 109491. 10.1016/j.envres.2020.109491.32361076
Kim, MJ; Moon, S; Oh, BC; Jung, D; Ji, K; Choi, K; Park, YJ. (2018a). Association between perfluoroalkyl substances exposure and thyroid function in adults: A meta-analysis. PLoS ONE 13: e0197244. 10.1371/journal.pone.0197244.29746532
Kim, OJ; Kim, S; Park, EY; Oh, JK; Jung, SK; Park, S; Hong, S; Jeon, HL; Kim, HJ; Park, B; Park, B; Kim, S; Kim, B. (2023). Exposure to serum perfluoroalkyl substances and biomarkers of liver function: The Korean national environmental health survey 2015-2017. Chemosphere 322: 138208. 10.1016/j.chemosphere.2023.138208.36822523
Kim, S; Choi, K; Ji, K; Seo, J; Kho, Y; Park, J; Kim, S; Park, S; Hwang, I; Jeon, J; Yang, H; Giesy, JP. (2011a). Trans-placental transfer of thirteen perfluorinated compounds and relations with fetal thyroid hormones. Environ Sci Technol 45: 7465–7472. 10.1021/es202408a.21805959
Kim, SJ; Heo, SH; Lee, DS; Hwang, IG; Lee, YB; Cho, HY. (2016b). Gender differences in pharmacokinetics and tissue distribution of 3 perfluoroalkyl and polyfluoroalkyl substances in rats. Food Chem Toxicol 97: 243–255. 10.1016/j.fct.2016.09.017.27637925
Kim, SJ; Shin, H; Lee, YB; Cho, HY. (2018b). Sex-specific risk assessment of PFHxS using a physiologically based pharmacokinetic model. Arch Toxicol 92: 1113–1131. 10.1007/s00204-017-2116-5.29143853
Kim, SK; Kannan, K. (2007). Perfluorinated acids in air, rain, snow, surface runoff, and lakes: Relative importance of pathways to contamination of urban lakes. Environ Sci Technol 41: 8328–8334. 10.1021/es072107t.18200859
Kim, SK; Lee, KT; Kang, CS; Tao, L; Kannan, K; Kim, KR; Kim, CK; Lee, JS; Park, PS; Yoo, YW; Ha, JY; Shin, YS; Lee, JH. (2011b). Distribution of perfluorochemicals between sera and milk from the same mothers and implications for prenatal and postnatal exposures. Environ Pollut 159: 169–174. 10.1016/j.envpol.2010.09.008.20932617
Kim, YR; White, N; Bräunig, J; Vijayasarathy, S; Mueller, JF; Knox, CL; Harden, FA; Pacella, R; Toms, LL. (2020c). Per- and poly-fluoroalkyl substances (PFASs) in follicular fluid from women experiencing infertility in Australia. Environ Res 190: 109963. 10.1016/j.envres.2020.109963.32745751
Kirk, AB; Destefano, A; Martin, A; Kirk, KC; Martin, CF. (2023). A New Interpretation of Relative Importance on an Analysis of Per and Polyfluorinated Alkyl Substances (PFAS) Exposures on Bone Mineral Density. Int J Environ Res Public Health 20: 4539. 10.3390/ijerph20054539.36901546
Kodavanti, UP; Russell, JC; Costa, DL. (2015). Rat models of cardiometabolic diseases: baseline clinical chemistries, and rationale for their use in examining air pollution health effects. Inhal Toxicol 27: 2–13. 10.3109/08958378.2014.954166.26667327
Koponen, J; Winkens, K; Airaksinen, R; Berger, U; Vestergren, R; Cousins, IT; Karvonen, AM; Pekkanen, J; Kiviranta, H. (2018). Longitudinal trends of per- and polyfluoroalkyl substances in children’s serum. Environ Int 121: 591–599. 10.1016/j.envint.2018.09.006.30308470
Korevaar, TIM; Muetzel, R; Medici, M; Chaker, L; Jaddoe, VWV; de Rijke, YB; Steegers, EAP; Visser, TJ; White, T; Tiemeier, H; Peeters, RP. (2016). Association of maternal thyroid function during early pregnancy with offspring IQ and brain morphology in childhood: A population-based prospective cohort study. Lancet Diabetes Endocrinol 4: 35–43. 10.1016/S2213-8587(15)00327-7.26497402
Koshy, TT; Attina, TM; Ghassabian, A; Gilbert, J; Burdine, LK; Marmor, M; Honda, M; Chu, DB; Han, X; Shao, Y; Kannan, K; Urbina, EM; Trasande, L. (2017). Serum perfluoroalkyl substances and cardiometabolic consequences in adolescents exposed to the World Trade Center disaster and a matched comparison group. Environ Int 109: 128–135. 10.1016/j.envint.2017.08.003.28890218
Koskela, A; Ducatman, A; Schousboe, JT; Nahhas, RW; Khalil, N. (2022). Perfluoroalkyl Substances and Abdominal Aortic Calcification. J Occup Environ Med 64: 287–294. 10.1097/JOM.0000000000002479.35001069
Kudo, N; Katakura, M; Sato, Y; Kawashima, Y. (2002). Sex hormone-regulated renal transport of perfluorooctanoic acid. Chem Biol Interact 139: 301–316. 10.1016/S0009-2797(02)00006-6.11879818
Kvalem, HE; Nygaard, UC; Lødrup Carlsen, KC; Carlsen, KH; Haug, LS; Granum, B. (2020). Perfluoroalkyl substances, airways infections, allergy and asthma related health outcomes - Implications of gender, exposure period and study design. Environ Int 134: 105259. 10.1016/j.envint.2019.105259.31733527
Kwon, EJ; Shin, JS; Kim, BM; Shah-Kulkarni, S; Park, H; Kho, YL; Park, EA; Kim, YJ; Ha, EH. (2016). Prenatal exposure to perfluorinated compounds affects birth weight through GSTM1 polymorphism. J Occup Environ Med 58: e198–e205. 10.1097/JOM.0000000000000739.27206125
Laitinen, JA; Koponen, J; Koikkalainen, J; Kiviranta, H. (2014). Firefighters’ exposure to perfluoroalkyl acids and 2-butoxyethanol present in firefighting foams. Toxicol Lett 231: 227–232. 10.1016/j.toxlet.2014.09.007.25447453
Lakind, JS; Naiman, J; Verner, MA; Lévêque, L; Fenton, S. (2023). Per- and polyfluoroalkyl substances (PFAS) in breast milk and infant formula: A global issue [Review]. Environ Res 219: 115042. 10.1016/j.envres.2022.115042.36529330
Lala, V; Zubair, M; Minter, DA. (2023). Liver function tests. [Updated 2023 Jul 30]. In StatPearls (pp. 1–13). Treasure Island, FL: StatPearls Publishing. https://www.ncbi.nlm.nih.gov/books/NBK482489/.
Lau, C; Anitole, K; Hodes, C; Lai, D; Pfahles-Hutchens, A; Seed, J. (2007). Perfluoroalkyl acids: a review of monitoring and toxicological findings [Review]. Toxicol Sci 99: 366–394. 10.1093/toxsci/kfm128.17519394
Lau, C; Thibodeaux, JR; Hanson, RG; Rogers, JM; Grey, BE; Stanton, ME; Butenhoff, JL; Stevenson, LA. (2003). Exposure to perfluorooctane sulfonate during pregnancy in rat and mouse. II: postnatal evaluation. Toxicol Sci 74: 382–392. 10.1093/toxsci/kfg122.12773772
Lebeaux, RM; Doherty, BT; Gallagher, LG; Zoeller, RT; Hoofnagle, AN; Calafat, AM; Karagas, MR; Yolton, K; Chen, A; Lanphear, BP; Braun, JM; Romano, ME. (2020). Maternal serum perfluoroalkyl substance mixtures and thyroid hormone concentrations in maternal and cord sera: The HOME Study. Environ Res 185: 109395. 10.1016/j.envres.2020.109395.32222633
Leboff, MS; Kaplan, MM; Silva, JE; Larsen, PR. (1982). Bioavailability of thyroid hormones from oral replacement preparations. Metabolism 31: 900–905. 10.1016/0026-0495(82)90179-2.7121261
Lee, ES; Han, S; Oh, JE. (2016). Association between perfluorinated compound concentrations in cord serum and birth weight using multiple regression models. Reprod Toxicol 59: 53–59. 10.1016/j.reprotox.2015.10.020.26562669
Lee, I; Viberg, H. (2013). A single neonatal exposure to perfluorohexane sulfonate (PFHxS) affects the levels of important neuroproteins in the developing mouse brain. Neurotoxicology 37: 190–196. 10.1016/j.neuro.2013.05.007.23701969
Lee, YA; Kim, JH; Jung, HW; Lim, YH; Bae, S; Kho, Y; Hong, YC; Shin, CH; Yang, SW. (2018). The serum concentrations of perfluoroalkyl compounds were inversely associated with growth parameters in 2-year old children. Sci Total Environ 628–629: 226–232. 10.1016/j.scitotenv.2018.02.050.
Lee, YJ; Kim, MK; Bae, J; Yang, JH. (2013). Concentrations of perfluoroalkyl compounds in maternal and umbilical cord sera and birth outcomes in Korea. Chemosphere 90: 1603–1609. 10.1016/j.chemosphere.2012.08.035.22990023
Lenters, V; Portengen, L; Rignell-Hydbom, A; Jönsson, BA; Lindh, CH; Piersma, AH; Toft, G; Bonde, JP; Heederik, D; Rylander, L; Vermeulen, R. (2016). Prenatal phthalate, perfluoroalkyl acid, and organochlorine exposures and term birth weight in three birth cohorts: multi-pollutant models based on elastic net regression. Environ Health Perspect 124: 365–372. 10.1289/ehp.1408933.26115335
Leter, G; Consales, C; Eleuteri, P; Uccelli, R; Specht, IO; Toft, G; Moccia, T; Budillon, A; Jönsson, BA; Lindh, CH; Giwercman, A; Pedersen, HS; Ludwicki, JK; Zviezdai, V; Heederik, D; Bonde, JP; Spanò, M. (2014). Exposure to perfluoroalkyl substances and sperm DNA global methylation in Arctic and European populations. Environ Mol Mutagen 55: 591–600. 10.1002/em.21874.24889506
Lewis, RC; Johns, LE; Meeker, JD. (2015). Serum biomarkers of exposure to perfluoroalkyl substances in relation to serum testosterone and measures of thyroid function among adults and adolescents from NHANES 2011-2012. Int J Environ Res Public Health 12: 6098–6114. 10.3390/ijerph120606098.26035660
Li, H; Hammarstrand, S; Midberg, B; Xu, Y; Li, Y; Olsson, DS; Fletcher, T; Jakobsson, K; Andersson, EM. (2022a). Cancer incidence in a Swedish cohort with high exposure to perfluoroalkyl substances in drinking water. Environ Res 204: 112217. 10.1016/j.envres.2021.112217.34662573
Li, J; Cai, D; Chu, C; Li, QQ; Zhou, Y; Hu, LW; Yang, BY; Dong, GH; Zeng, XW; Chen, D. (2020a). Transplacental Transfer of Per- and Polyfluoroalkyl Substances (PFASs): Differences between Preterm and Full-Term Deliveries and Associations with Placental Transporter mRNA Expression. Environ Sci Technol 54: 5062–5070. 10.1021/acs.est.0c00829.32208722
Li, K; Gao, P; Xiang, P; Zhang, X; Cui, X; Ma, LQ. (2017a). Molecular mechanisms of PFOA-induced toxicity in animals and humans: Implications for health risks [Review]. Environ Int 99: 43–54. 10.1016/j.envint.2016.11.014.27871799
Li, M; Zeng, XW; Qian, ZM; Vaughn, MG; Sauvé, S; Paul, G; Lin, S; Lu, L; Hu, LW; Yang, BY; Zhou, Y; Qin, XD; Xu, SL; Bao, WW; Zhang, YZ; Yuan, P; Wang, J; Zhang, C; Tian, YP; Nian, M; Xiao, X; Fu, C; Dong, GH. (2017b). Isomers of perfluorooctanesulfonate (PFOS) in cord serum and birth outcomes in China: Guangzhou Birth Cohort Study. Environ Int 102: 1–8. 10.1016/j.envint.2017.03.006.28297681
Li, N; Liu, Y; Papandonatos, GD; Calafat, AM; Eaton, CB; Kelsey, KT; Cecil, KM; Kalkwarf, HJ; Yolton, K; Lanphear, BP; Chen, A; Braun, JM. (2021a). Gestational and childhood exposure to per- and polyfluoroalkyl substances and cardiometabolic risk at age 12 years. Environ Int 147: 106344. 10.1016/j.envint.2020.106344.33418195
Li, Y; Andersson, A; Xu, Y; Pineda, D; Nilsson, CA; Lindh, CH; Jakobsson, K; Fletcher, T. (2022b). Determinants of serum half-lives for linear and branched perfluoroalkyl substances after long-term high exposure—A study in Ronneby, Sweden. Environ Int 163: 107198. 10.1016/j.envint.2022.107198.35447437
Li, Y; Barregard, L; Xu, Y; Scott, K; Pineda, D; Lindh, CH; Jakobsson, K; Fletcher, T. (2020b). Associations between perfluoroalkyl substances and serum lipids in a Swedish adult population with contaminated drinking water. Environ Health 19: 33. 10.1186/s12940-020-00588-9.32169067
Li, Y; Cheng, Y; Xie, Z; Zeng, F. (2017c). Perfluorinated alkyl substances in serum of the southern Chinese general population and potential impact on thyroid hormones. Sci Rep 7: 43380. 10.1038/srep43380.28240244
Li, Y; Fletcher, T; Mucs, D; Scott, K; Lindh, CH; Tallving, P; Jakobsson, K. (2018). Half-lives of PFOS, PFHxS and PFOA after end of exposure to contaminated drinking water. Occup Environ Med 75: 46–51. 10.1136/oemed-2017-104651.29133598
Li, Y; Shan, Z; Teng, W; Yu, X; Fan, C; Teng, X; Guo, R; Wang, H; Li, J; Chen, Y; Wang, W; Chawinga, M; Zhang, L; Yang, L; Zhao, Y; Hua, T. (2010). Abnormalities of maternal thyroid function during pregnancy affect neuropsychological development of their children at 25-30 months. Clin Endocrinol 72: 825–829. 10.1111/j.1365-2265.2009.03743.x.
Li, Y; Xu, Y; Fletcher, T; Scott, K; Nielsen, C; Pineda, D; Lindh, CH; Olsson, DS; Andersson, EM; Jakobsson, K. (2021b). Associations between perfluoroalkyl substances and thyroid hormones after high exposure through drinking water. Environ Res 194: 110647. 10.1016/j.envres.2020.110647.33358873
Liang, H; Wang, Z; Miao, M; Tian, Y; Zhou, Y; Wen, S; Chen, Y; Sun, X; Yuan, W. (2020). Prenatal exposure to perfluoroalkyl substances and thyroid hormone concentrations in cord plasma in a Chinese birth cohort. Environ Health 19: 127. 10.1186/s12940-020-00679-7.33243245
Liang, JL; Tiwari, T; Moro, P; Messonnier, NE; Reingold, A; Sawyer, M; Clark, TA. (2018). Prevention of pertussis, tetanus, and diphtheria with vaccines in the United States: Recommendations of the Advisory Committee on Immunization Practices (ACIP). MMWR Recomm Rep 67: 1–44. 10.15585/mmwr.rr6702a1.
Liao, Q; Tang, P; Fan, H; Song, Y; Liang, J; Huang, H; Pan, D; Mo, M; Leilei; Lin, M; Chen, J; Wei, H; Long, J; Shao, Y; Zeng, X; Liu, S; Huang, D; Qiu, X. (2023). Association between maternal exposure to per- and polyfluoroalkyl substances and serum markers of liver function during pregnancy in China: A mixture-based approach. Environ Pollut 323: 121348. 10.1016/j.envpol.2023.121348.36842621
Liao, S; Yao, W; Cheang, I; Tang, X; Yin, T; Lu, X; Zhou, Y; Zhang, H; Li, X. (2020). Association between perfluoroalkyl acids and the prevalence of hypertension among US adults. Ecotoxicol Environ Saf 196: 110589. 10.1016/j.ecoenv.2020.110589.32278136
Liew, Z; Luo, J; Nohr, EA; Bech, BH; Bossi, R; Arah, OA; Olsen, J. (2020). Maternal plasma perfluoroalkyl substances and miscarriage: a nested case-control study in the Danish National Birth Cohort. Environ Health Perspect 128: 47007. 10.1289/EHP6202.32319790
Liew, Z; Ritz, B; Bach, CC; Asarnow, RF; Bech, BH; Nohr, EA; Bossi, R; Henriksen, TB; Bonefeld-Jørgensen, EC; Olsen, J. (2018). Prenatal exposure to perfluoroalkyl substances and iq scores at age 5; a study in the danish national birth cohort. Environ Health Perspect 126: 067004. 10.1289/EHP2754.29897723
Liew, Z; Ritz, B; Bonefeld-Jørgensen, EC; Henriksen, TB; Nohr, EA; Bech, BH; Fei, C; Bossi, R; von Ehrenstein, OS; Streja, E; Uldall, P; Olsen, J. (2014). Prenatal exposure to perfluoroalkyl substances and the risk of congenital cerebral palsy in children. Am J Epidemiol 180: 574–581. 10.1093/aje/kwu179.25139206
Liew, Z; Ritz, B; von Ehrenstein, OS; Bech, BH; Nohr, EA; Fei, C; Bossi, R; Henriksen, TB; Bonefeld-Jørgensen, EC; Olsen, J. (2015). Attention deficit/hyperactivity disorder and childhood autism in association with prenatal exposure to perfluoroalkyl substances: A nested case-control study in the Danish National Birth Cohort. Environ Health Perspect 123: 367–373. 10.1289/ehp.1408412.25616253
Limei, E; Zhang, S; Jiang, X. (2023). Association between perfluoroalkyl substances exposure and the prevalence of nonalcoholic fatty liver disease in the different sexes: a study from the National Health and Nutrition Examination Survey 2005-2018. Environ Sci Pollut Res Int 30: 44292–44303. 10.1007/s11356-023-25258-4.36692718
Lin, AY; Panchangam, SC; Lo, CC. (2009a). The impact of semiconductor, electronics and optoelectronic industries on downstream perfluorinated chemical contamination in Taiwanese rivers. Environ Pollut 157: 1365–1372. 10.1016/j.envpol.2008.11.033.19117653
Lin, CY; Chen, PC; Lin, YC; Lin, LY. (2009b). Association among serum perfluoroalkyl chemicals, glucose homeostasis, and metabolic syndrome in adolescents and adults. Diabetes Care 32: 702–707. 10.2337/dc08-1816.19114613
Lin, CY; Lin, LY; Chiang, CK; Wang, WJ; Su, YN; Hung, KY; Chen, PC. (2010). Investigation of the Associations Between Low-Dose Serum Perfluorinated Chemicals and Liver Enzymes in US Adults. Am J Gastroenterol 105: 1354–1363. 10.1038/ajg.2009.707.20010922
Lin, HW; Feng, HX; Chen, L; Yuan, XJ; Tan, Z. (2020a). Maternal exposure to environmental endocrine disruptors during pregnancy is associated with pediatric germ cell tumors. Nagoya J Med Sci 82: 323–333. 10.18999/nagjms.82.2.323.32581411
Lin, P; Cardenas, A; Hauser, R; Gold, DR; Kleinman, K; Hivert, MF; Fleisch, AF; Calafat, AM; Webster, TF; Horton, ES; Oken, E. (2019). Per- and polyfluoroalkyl substances and blood lipid levels in pre-diabetic adults-longitudinal analysis of the diabetes prevention program outcomes study. Environ Int 129: 343–353. 10.1016/j.envint.2019.05.027.31150976
Lin, PD; Cardenas, A; Hauser, R; Gold, DR; Kleinman, KP; Hivert, MF; Calafat, AM; Webster, TF; Horton, ES; Oken, E. (2020b). Per- and polyfluoroalkyl substances and blood pressure in pre-diabetic adults-cross-sectional and longitudinal analyses of the diabetes prevention program outcomes study. Environ Int 137: 105573. 10.1016/j.envint.2020.105573.32088543
Lin, PD; Cardenas, A; Hauser, R; Gold, DR; Kleinman, KP; Hivert, MF; Calafat, AM; Webster, TF; Horton, ES; Oken, E. (2021). Per- and polyfluoroalkyl substances and kidney function: Follow-up results from the Diabetes Prevention Program trial. Environ Int 148: 106375. 10.1016/j.envint.2020.106375.33482440
Lin, TW; Chen, MK; Lin, CC; Chen, MH; Tsai, MS; Chan, DC; Hung, KY; Chen, PC. (2020c). Association between exposure to perfluoroalkyl substances and metabolic syndrome and related outcomes among older residents living near a Science Park in Taiwan. Int J Hyg Environ Health 230: 113607. 10.1016/j.ijheh.2020.113607.32919137
Lind, DV; Priskorn, L; Lassen, TH; Nielsen, F; Kyhl, HB; Kristensen, DM; Christesen, HT; Jørgensen, JS; Grandjean, P; Jensen, TK. (2017). Prenatal exposure to perfluoroalkyl substances and anogenital distance at 3 months of age in a Danish mother-child cohort. Reprod Toxicol 68: 200–206. 10.1016/j.reprotox.2016.08.019.27592399
Lind, L; Zethelius, B; Salihovic, S; van Bavel, B; Lind, PM. (2014). Circulating levels of perfluoroalkyl substances and prevalent diabetes in the elderly. Diabetologia 57: 473–479. 10.1007/s00125-013-3126-3.24337155
Lind, PM; Lind, L; Salihovic, S; Ahlström, H; Michaelsson, K; Kullberg, J; Strand, R. (2022). Serum levels of perfluoroalkyl substances (PFAS) and body composition - A cross-sectional study in a middle-aged population. Environ Res 209: 112677. 10.1016/j.envres.2022.112677.35074350
Linton, MRF; Yancey, PG; Davies, SS; Jerome, WG; Linton, EF; Song, WL; Doran, AC; Vickers, KC; Boyce, A; Chrousos, G; Corpas, E; de Herder, WW; Dhatariya, K; Dungan, K; Hofland, J; Kalra, S; Kaltsas, G; Kapoor, N; Koch, C, … Wilson, D. P. (2000). The role of lipids and lipoproteins in atherosclerosis. In LJ De Groot (Ed.), Endotext. South Dartmouth, MA: MDText.com, Inc. https://www.ncbi.nlm.nih.gov/books/NBK343489/.
Litvinov, RI; Weisel, JW. (2017). Role of red blood cells in haemostasis and thrombosis. 12: 176–183. 10.1111/voxs.12331.
Liu, B; Wei, B; Mo, M; Song, Y; Tang, C; Tang, P; Guo, X; Tan, C; Liu, S; Huang, D; Qiu, X. (2021a). Exposure to perfluoroalkyl substances in early pregnancy and the risk of hypertensive disorders of pregnancy: A nested case-control study in Guangxi, China. Chemosphere 288: 132468. 10.1016/j.chemosphere.2021.132468.34624345
Liu, C; Xu, X; Huo, X, ia. (2014). Anogenital distance and its application in environmental health research [Review]. Environ Sci Pollut Res Int 21: 5457–5464. 10.1007/s11356-014-2570-z.24474565
Liu, D; Tang, B; Nie, S; Zhao, N; He, L; Cui, J; Mao, W; Jin, H. (2023). Distribution of per- and poly-fluoroalkyl substances and their precursors in human blood. J Hazard Mater 441: 129908. 10.1016/j.jhazmat.2022.129908.36115093
Liu, G; Dhana, K; Furtado, JD; Rood, J; Zong, G; Liang, L; Qi, L; Bray, GA; Dejonge, L; Coull, B; Grandjean, P; Sun, Q. (2018). Perfluoroalkyl substances and changes in body weight and resting metabolic rate in response to weight-loss diets: A prospective study. PLoS Med 15: e1002502. 10.1371/journal.pmed.1002502.29438414
Liu, G; Zhang, B; Hu, Y; Rood, J; Liang, L; Qi, L; Bray, GA; Dejonge, L; Coull, B; Grandjean, P; Furtado, JD; Sun, Q. (2020a). Associations of Perfluoroalkyl substances with blood lipids and Apolipoproteins in lipoprotein subspecies: the POUNDS-lost study. Environ Health 19: 5. 10.1186/s12940-020-0561-8.31931806
Liu, H; Pan, Y; Jin, S; Li, Y; Zhao, L; Sun, X; Cui, Q; Zhang, B; Zheng, T; Xia, W; Zhou, A; Campana, AM; Dai, J; Xu, S. (2020b). Associations of per-/polyfluoroalkyl substances with glucocorticoids and progestogens in newborns. Environ Int 140: 105636. 10.1016/j.envint.2020.105636.32474218
Liu, J; Li, J; Liu, Y; Chan, HM; Zhao, Y; Cai, Z; Wu, Y. (2011). Comparison on gestation and lactation exposure of perfluorinated compounds for newborns. Environ Int 37: 1206–1212. 10.1016/j.envint.2011.05.001.21620474
Liu, JJ; Cui, XX; Tan, YW; Dong, PX; Ou, YQ; Li, QQ; Chu, C; Wu, LY; Liang, LX; Qin, SJ; Zeeshan, M; Zhou, Y; Hu, LW; Liu, RQ; Zeng, XW; Dong, GH; Zhao, XM. (2022a). Per- and perfluoroalkyl substances alternatives, mixtures and liver function in adults: A community-based population study in China. Environ Int 163: 107179. 10.1016/j.envint.2022.107179.35325771
Liu, M; Zhang, G; Meng, L; Han, X; Li, Y; Shi, Y; Li, A; Turyk, ME; Zhang, Q; Jiang, G. (2021b). Associations between novel and legacy per- and polyfluoroalkyl substances in human serum and thyroid cancer: A case and healthy population in Shandong Province, East China. Environ Sci Technol 56: 6144–6151. 10.1021/acs.est.1c02850.34618433
Liu, Y; Li, N; Papandonatos, GD; Calafat, AM; Eaton, CB; Kelsey, KT; Chen, A; Lanphear, BP; Cecil, KM; Kalkwarf, HJ; Yolton, K; Braun, JM. (2020c). Exposure to per- and polyfluoroalkyl substances and adiposity at age 12 years: Evaluating periods of susceptibility. Environ Sci Technol 54: 16039–16049. 10.1021/acs.est.0c06088.33269902
Liu, Y; Zhou, X; Wu, Y; Yang, X; Wang, Y; Li, S; Bai, X; Schlenk, D; Liu, W. (2022b). Exposure and Blood-Cerebrospinal Fluid Barrier Permeability of PFASs in Neonates. Environ Sci Technol Lett 9: 64–70. 10.1021/acs.estlett.1c00862.
Loccisano, AE; Campbell, JL, Jr; Andersen, ME; Clewell, HJ, III. (2011). Evaluation and prediction of pharmacokinetics of PFOA and PFOS in the monkey and human using a PBPK model. Regul Toxicol Pharmacol 59: 157–175. 10.1016/j.yrtph.2010.12.004.21168463
Long, M; Ghisari, M; Bonefeld-Jørgensen, EC. (2013). Effects of perfluoroalkyl acids on the function of the thyroid hormone and the aryl hydrocarbon receptor. Environ Sci Pollut Res Int 20: 8045–8056. 10.1007/s11356-013-1628-7.23539207
Lopez-Espinosa, MJ; Mondal, D; Armstrong, BG; Eskenazi, B; Fletcher, T. (2016). Perfluoroalkyl Substances, Sex Hormones, and Insulin-like Growth Factor-1 at 6-9 Years of Age: A Cross-Sectional Analysis within the C8 Health Project. Environ Health Perspect 124: 1269–1275. 10.1289/ehp.1509869.26794451
Lorber, M; Eaglesham, GE; Hobson, P; Toms, LM; Mueller, JF; Thompson, JS. (2015). The effect of ongoing blood loss on human serum concentrations of perfluorinated acids. Chemosphere 118: 170–177. 10.1016/j.chemosphere.2014.07.093.25180653
Lumley, T. (2004). Analysis of complex survey samples. J Stat Softw 9. 10.18637/jss.v009.i08.
Lumley, T. (2023). Survey: Analysis of complex survey samples (Version 4.2-1). Retrieved from https://cran.r-project.org/package=survey
Luo, D; Wu, WX; Pan, YA; Du, BB; Shen, MJ; Zeng, LX. (2021). Associations of prenatal exposure to per- and polyfluoroalkyl substances with the neonatal birth size and hormones in the growth hormone/insulin-like growth factor axis. Environ Sci Technol 55: 11859–11873. 10.1021/acs.est.1c02670.34378915
Luo, J; Xiao, J; Gao, Y; Ramlau-Hansen, CH; Toft, G; Li, J; Obel, C; Andersen, SL; Deziel, NC; Tseng, WL; Inoue, K; Bonefeld-Jørgensen, EC; Olsen, J; Liew, Z. (2020). Prenatal exposure to perfluoroalkyl substances and behavioral difficulties in childhood at 7 and 11 years. Environ Res 191: 110111. 10.1016/j.envres.2020.110111.32846178
Lyall, K; Yau, VM; Hansen, R; Kharrazi, M; Yoshida, CK; Calafat, AM; Windham, G; Croen, LA. (2018). Prenatal maternal serum concentrations of per- and polyfluoroalkyl substances in association with autism spectrum disorder and intellectual disability. Environ Health Perspect 126: 017001. 10.1289/EHP1830.29298162
M, B; S, A; S, Z; A, S. (2024). Management of metabolic-associated fatty liver disease/metabolic dysfunction-associated steatotic liver disease: from medication therapy to nutritional interventions. Nutrients 16. 10.3390/nu16142220.
Mackowiak, B; Hodge, J; Stern, S; Wang, H. (2018). The roles of xenobiotic receptors: Beyond chemical disposition [Review]. Drug Metab Dispos 46: 1361–1371. 10.1124/dmd.118.081042.29759961
Maekawa, R; Ito, R; Iwasaki, Y; Saito, K; Akutsu, K; Takatori, S; Ishii, R; Kondo, F; Arai, Y; Ohgane, J; Shiota, K; Makino, T; Sugino, N. (2017). Evidence of exposure to chemicals and heavy metals during pregnancy in Japanese women. Reproductive Medicine and Biology 16: 337–348. 10.1002/rmb2.12049.29259487
Maisonet, M; Calafat, AM; Marcus, M; Jaakkola, JJ; Lashen, H. (2015). Prenatal exposure to perfluoroalkyl acids and serum testosterone concentrations at 15 years of age in female ALSPAC study participants. Environ Health Perspect 123: 1325–1330. 10.1289/ehp.1408847.26034840
Maisonet, M; Terrell, ML; Mcgeehin, MA; Christensen, KY; Holmes, A; Calafat, AM; Marcus, M. (2012). Maternal concentrations of polyfluoroalkyl compounds during pregnancy and fetal and postnatal growth in British girls. Environ Health Perspect 120: 1432–1437. 10.1289/ehp.1003096.22935244
Makris, K; Mousa, C; Cavalier, E. (2022). Alkaline phosphatases: Biochemistry, functions, and measurement [Review]. Calcif Tissue Int 112: 233–242. 10.1007/s00223-022-01048-x.36571614
Mamsen, LS; Björvang, RD; Mucs, D; Vinnars, MT; Papadogiannakis, N; Lindh, CH; Andersen, CY; Damdimopoulou, P. (2019). Concentrations of perfluoroalkyl substances (PFASs) in human embryonic and fetal organs from first, second, and third trimester pregnancies. Environ Int 124: 482–492. 10.1016/j.envint.2019.01.010.30684806
Man, EB; Jones, WS; Holden, RH; Mellits, ED. (1971). Thyroid function in human pregnancy VIII Retardation of progency aged 7 years, relationships to maternal age and maternal thyroid function. Am J Obstet Gynecol 111: 905–916.4107381
Manz, MG; Akashi, K; Weissman, IL. (2004). Biology of hematopoietic stem and progenitor cells. In KG Blume; SJ Forman; FR Appelbaum (Eds.), Thomas’ Hematopoietic Cell Transplantation (3 ed.). Malden, MA: Blackwell Publishing.
Manzano-Salgado, CB; Casas, M; Lopez-Espinosa, MJ; Ballester, F; Iñiguez, C; Martinez, D; Costa, O; Santa-Marina, L; Pereda-Pereda, E; Schettgen, T; Sunyer, J; Vrijheid, M. (2017a). Prenatal exposure to perfluoroalkyl substances and birth outcomes in a Spanish birth cohort. Environ Int 108: 278–284. 10.1016/j.envint.2017.09.006.28917208
Manzano-Salgado, CB; Casas, M; Lopez-Espinosa, MJ; Ballester, F; Iñiguez, C; Martinez, D; Romaguera, D; Fernández-Barrés, S; Santa-Marina, L; Basterretxea, M; Schettgen, T; Valvi, D; Vioque, J; Sunyer, J; Vrijheid, M. (2017b). Prenatal exposure to perfluoroalkyl substances and cardiometabolic risk in children from the Spanish INMA birth cohort study. Environ Health Perspect 125: 097018. 10.1289/EHP1330.28934720
Manzano-Salgado, CB; Granum, B; Lopez-Espinosa, MJ; Ballester, F; Iñiguez, C; Gascón, M; Martínez, D; Guxens, M; Basterretxea, M; Zabaleta, C; Schettgen, T; Sunyer, J; Vrijheid, M; Casas, M. (2019). Prenatal exposure to perfluoroalkyl substances, immune-related outcomes, and lung function in children from a Spanish birth cohort study. Int J Hyg Environ Health 222: 945–954. 10.1016/j.ijheh.2019.06.005.31262703
Mao, W; Hu, Q; Chen, S; Chen, Y; Luo, M; Zhang, Z; Geng, J; Wu, J; Xu, B; Chen, M. (2020). Polyfluoroalkyl chemicals and the risk of kidney stones in US adults: A population-based study. Ecotoxicol Environ Saf 208: 111497. 10.1016/j.ecoenv.2020.111497.33091773
Marks, KJ; Cutler, AJ; Jeddy, Z; Northstone, K; Kato, K; Hartman, TJ. (2019a). Maternal serum concentrations of perfluoroalkyl substances and birth size in British boys. Int J Hyg Environ Health 222: 889–895. 10.1016/j.ijheh.2019.03.008.30975573
Marks, KJ; Jeddy, Z; Flanders, WD; Northstone, K; Fraser, A; Calafat, AM; Kato, K; Hartman, TJ. (2019b). Maternal serum concentrations of perfluoroalkyl substances during pregnancy and gestational weight gain: The Avon Longitudinal Study of Parents and Children. Reprod Toxicol 90: 8–14. 10.1016/j.reprotox.2019.08.003.31415809
Maronpot, RR. (2014). Liver, hepatocyte - hypertrophy. In National Toxicology Program Nonneoplastic Lesion Atlas. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/atlas/nnl/hepatobiliary-system/liver/Hepatocyte-Hypertrophy.
Marques, ES; Agudelo, J; Kaye, EM; Modaresi, SMS; Pfohl, M; Bečanová, J; Wei, W; Polunas, M; Goedken, M; Slitt, AL. (2021). The role of maternal high fat diet on mouse pup metabolic endpoints following perinatal PFAS and PFAS mixture exposure. Toxicology 462: 152921. 10.1016/j.tox.2021.152921.34464680
Martin, CM. (1978). Verbal and spatial encoding of visual stimuli: the effects of sex, hemisphere and yes-no judgements. Cortex 14: 227–233. 10.1016/s0010-9452(78)80048-3.679703
Martinsson, M; Nielsen, C; Björk, J; Rylander, L; Malmqvist, E; Lindh, C; Rignell-Hydbom, A. (2020). Intrauterine exposure to perfluorinated compounds and overweight at age 4: A case-control study. PLoS ONE 15: e0230137. 10.1371/journal.pone.0230137.32176721
Matilla-Santander, N; Valvi, D; Lopez-Espinosa, MJ; Manzano-Salgado, CB; Ballester, F; Ibarluzea, J; Santa-Marina, L; Schettgen, T; Guxens, M; Sunyer, J; Vrijheid, M. (2017). Exposure to Perfluoroalkyl Substances and Metabolic Outcomes in Pregnant Women: Evidence from the Spanish INMA Birth Cohorts. Environ Health Perspect 125: 117004. 10.1289/EHP1062.29135438
Matthews, DR; Hosker, JP; Rudenski, AS; Naylor, BA; Treacher, DF; Turner, RC. (1985). Homeostasis model assessment: Insulin resistance and beta-cell function from fasting plasma glucose and insulin concentrations in man. Diabetologia 28: 412–419. 10.1007/BF00280883.3899825
Mattsson, K; Rignell-Hydbom, A; Holmberg, S; Thelin, A; Jönsson, BA; Lindh, CH; Sehlstedt, A; Rylander, L. (2015). Levels of perfluoroalkyl substances and risk of coronary heart disease: Findings from a population-based longitudinal study. Environ Res 142: 148–154. 10.1016/j.envres.2015.06.033.26142720
McCoy, JA; Bangma, JT; Reiner, JL; Bowden, JA; Schnorr, J; Slowey, M; O’Leary, T; Guillette, LJ; Parrott, BB. (2017). Associations between perfluorinated alkyl acids in blood and ovarian follicular fluid and ovarian function in women undergoing assisted reproductive treatment. Sci Total Environ 605–606: 9–17. 10.1016/j.scitotenv.2017.06.137.
Mcmahon, HT; Bolshakov, VY; Janz, R; Hammer, RE; Siegelbaum, SA; Sudhof, TC. (1996). Synaptophysin, a major synaptic vesicle protein, is not essential for neurotransmitter release. Proc Natl Acad Sci USA 93: 4760–4764. 10.1073/pnas.93.10.4760.8643476
MDH (Minnesota Department of Health). (2019). Health Based Guidance for Water: Toxicological Summary for: Perfluorohexane sulfonate (PFHxS). https://www.health.state.mn.us/communities/environment/risk/docs/guidance/gw/pfhxs.pdf.
Mellor, CL; Steinmetz, FP; Cronin, MT. (2016). The identification of nuclear receptors associated with hepatic steatosis to develop and extend adverse outcome pathways [Review]. Crit Rev Toxicol 46: 138–152. 10.3109/10408444.2015.1089471.26451809
Mendez-Sanchez, N; Cruz-Ramon, VC; Ramirez-Perez, OL; Hwang, JP; Barranco-Fragoso, B; Cordova-Gallardo, J. (2018). New aspects of lipotoxicity in nonalcoholic steatohepatitis. INTERNATIONAL JOURNAL OF MOLECULAR SCIENCES 19: 2034. 10.3390/ijms19072034.30011790
Meng, Q; Inoue, K; Ritz, B; Olsen, J; Liew, Z. (2018). Prenatal exposure to perfluoroalkyl substances and birth outcomes; An updated analysis from the Danish national birth cohort. Int J Environ Res Public Health 15: 1832. 10.3390/ijerph15091832.30149566
Mi, X; Lin, SQ; Zhang, XF; Li, JJ; Pei, LJ; Jin, F; Liao, Q; Xie, LM; Wei, LC; Hao, CJ; Zhang, YW; Li, W. (2022). Maternal perfluorinated compound exposure and risk of early pregnancy loss: A nested case-control study [Letter]. Biomed Environ Sci 35: 174–179. 10.3967/bes2022.026.35197186
Miller, M; Stone, NJ; Ballantyne, C; Bittner, V; Criqui, MH; Ginsberg, HN; Goldberg, AC; Howard, WJ; Jacobson, MS; Kris-Etherton, PM; Lennie, TA; Levi, M; Mazzone, T; Pennathur, S. (2011). Triglycerides and cardiovascular disease: A scientific statement from the American Heart Association. Circulation 123: 2292–2333. 10.1161/CIR.0b013e3182160726.21502576
Mobacke, I; Lind, L; Dunder, L; Salihovic, S; Lind, PM. (2018). Circulating levels of perfluoroalkyl substances and left ventricular geometry of the heart in the elderly. Environ Int 115: 295–300. 10.1016/j.envint.2018.03.033.29621717
Mochizuki, K; Yagi, E; Sakaguchi, N; Mochizuki, H; Takabe, S; Kuranuki, S; Suzuki, T; Shimada, M; Goda, T. (2007). The critical period for thyroid hormone responsiveness through thyroid hormone receptor isoform alpha in the postnatal small intestine. Biochim Biophys Acta 1770: 609–616. 10.1016/j.bbagen.2006.12.011.17292555
Mondal, D; Weldon, RH; Armstrong, BG; Gibson, LJ; Lopez-Espinosa, MJ; Shin, HM; Fletcher, T. (2014). Breastfeeding: a potential excretion route for mothers and implications for infant exposure to perfluoroalkyl acids. Environ Health Perspect 122: 187–192. 10.1289/ehp.1306613.24280536
Monroy, R; Morrison, K; Teo, K; Atkinson, S; Kubwabo, C; Stewart, B; Foster, WG. (2008). Serum levels of perfluoroalkyl compounds in human maternal and umbilical cord blood samples. Environ Res 108: 56–62. 10.1016/j.envres.2008.06.001.18649879
Montesinos, MM; Pellizas, CG. (2019). Thyroid Hormone Action on Innate Immunity. Front Endocrinol (Lausanne) 10: 350. 10.3389/fendo.2019.00350.31214123
Moog, NK; Entringer, S; Heim, C; Wadhwa, PD; Kathmann, N; Buss, C. (2017). Influence of maternal thyroid hormones during gestation on fetal brain development [Review]. Neuroscience 342: 68–100. 10.1016/j.neuroscience.2015.09.070.26434624
Moon, J. (2021). Perfluoroalkyl substances (PFASs) exposure and kidney damage: Causal interpretation using the US 2003-2018 National Health and Nutrition Examination Survey (NHANES) datasets. Environ Pollut 288: 117707. 10.1016/j.envpol.2021.117707.34252714
Mora, AM; Fleisch, AF; Rifas-Shiman, SL; Woo Baidal, JA; Pardo, L; Webster, TF; Calafat, AM; Ye, X; Oken, E; Sagiv, SK. (2018). Early life exposure to per- and polyfluoroalkyl substances and mid-childhood lipid and alanine aminotransferase levels. Environ Int 111: 1–13. 10.1016/j.envint.2017.11.008.29156323
Mora, AM; Oken, E; Rifas-Shiman, SL; Webster, TF; Gillman, MW; Calafat, AM; Ye, X; Sagiv, SK. (2017). Prenatal exposure to perfluoroalkyl substances and adiposity in early and mid-childhood. Environ Health Perspect 125: 467–473. 10.1289/EHP246.27352404
Moreta, C; Tena, MT. (2014). Determination of perfluorinated alkyl acids in corn, popcorn and popcorn bags before and after cooking by focused ultrasound solid-liquid extraction, liquid chromatography and quadrupole-time of flight mass spectrometry. J Chromatogr A 1355: 211–218. 10.1016/j.chroma.2014.06.018.24986069
Morgan, RL; Thayer, KA; Bero, L; Bruce, N; Falck-Ytter, Y; Ghersi, D; Guyatt, G; Hooijmans, C; Langendam, M; Mandrioli, D; Mustafa, RA; Rehfuess, EA; Rooney, AA; Shea, B; Silbergeld, EK; Sutton, P; Wolfe, MS; Woodruff, TJ; Verbeek, JH; Holloway, AC; Santesso, N; Schünemann, HJ. (2016). GRADE: Assessing the quality of evidence in environmental and occupational health. Environ Int 92–93: 611–616. 10.1016/j.envint.2016.01.004.
Morreale de Escobar, G; Ares, S; Berbel, P; Obregón, MJ; Escobar del Rey, F. (2008). The changing role of maternal thyroid hormone in fetal brain development [Review]. Semin Perinatol 32: 380–386. 10.1053/j.semperi.2008.09.002.19007674
Mullur, R; Liu, YY; Brent, GA. (2014). Thyroid hormone regulation of metabolism [Review]. Physiol Rev 94: 355–382. 10.1152/physrev.00030.2013.24692351
Murray, M. (2017). Trafficking and other regulatory mechanisms for organic anion transporting polypeptides and organic anion transporters that modulate cellular drug and xenobiotic influx and that are dysregulated in disease. Br J Pharmacol 174: 1908–1924. 10.1111/bph.13785.28299773
Natarajan, S; Lipsitz, S. R.; Nietert, PJ. (2002). Self-report of high cholesterol - Determinants of validity in US adults. Am J Prev Med 23: 13–21. 10.1016/s0749-3797(02)00446-4.
Navarro, D; Alvarado, M; Morte, B; Berbel, D; Sesma, J; Pacheco, P; Morreale de Escobar, G; Bernal, J; Berbel, P. (2014). Late maternal hypothyroidism alters the expression of Camk4 in neocortical subplate neurons: a comparison with Nurr1 labeling. Cereb Cortex 24: 2694–2706. 10.1093/cercor/bht129.23680840
Nelson, JW; Hatch, EE; Webster, TF. (2010). Exposure to Polyfluoroalkyl Chemicals and Cholesterol, Body Weight, and Insulin Resistance in the General US Population. Environ Health Perspect 118: 197–202. 10.1289/ehp.0901165.20123614
Nian, M; Li, QQ; Bloom, M; Qian, ZM; Syberg, KM; Vaughn, MG; Wang, SQ; Wei, Q; Zeeshan, M; Gurram, N; Chu, C; Wang, J; Tian, YP; Hu, LW; Liu, KK; Yang, BY; Liu, RQ; Feng, D; Zeng, XW; Dong, GH. (2019). Liver function biomarkers disorder is associated with exposure to perfluoroalkyl acids in adults: Isomers of C8 Health Project in China. Environ Res 172: 81–88. 10.1016/j.envres.2019.02.013.30776734
Nigam, PK. (2011). Serum lipid profile: fasting or non-fasting? Indian J Clin Biochem 26: 96–97. 10.1007/s12291-010-0095-x.22211025
NIH (National Institutes of Health). (2020). The PhenX Toolkit: protocol - lipid profile. Available online at https://www.phenxtoolkit.org/protocols/view/40201
Nilsson, S; Smurthwaite, K; Aylward, LL; Kay, M; Toms, LM; King, L; Marrington, S; Barnes, C; Kirk, MD; Mueller, JF; Bräunig, J. (2022a). Serum concentration trends and apparent half-lives of per- and polyfluoroalkyl substances (PFAS) in Australian firefighters. Int J Hyg Environ Health 246: 114040. 10.1016/j.ijheh.2022.114040.36162311
Nilsson, S; Smurthwaite, K; Aylward, LL; Kay, M; Toms, LM; King, L; Marrington, S; Kirk, MD; Mueller, JF; Bräunig, J. (2022b). Associations between serum perfluoroalkyl acid (PFAA) concentrations and health related biomarkers in firefighters. Environ Res 215: 114370. 10.1016/j.envres.2022.114370.36174755
Nirogi, R; Goyal, VK; Jana, S; Pandey, SK; Gothi, A. (2014). What suits best for organ weight analysis: Review of relationship between organ weight and body / brain weight for rodent toxicity studies. Int J Pharm Sci Res 5: 1525–1532. 10.13040/IJPSR.0975-8232.5(4).1525-32.
Niu, J; Liang, H; Tian, Y; Yuan, W; Xiao, H; Hu, H; Sun, X; Song, X; Wen, S; Yang, L; Ren, Y; Miao, M. (2019). Prenatal plasma concentrations of Perfluoroalkyl and polyfluoroalkyl substances and neuropsychological development in children at four years of age. Environ Health 18: 53. 10.1186/s12940-019-0493-3.31196101
NJDWQI (New Jersey Drinking Water Quality Institute). (2017). Public review draft: Health-based maximum contaminant level support document: Perfluorooctane sulfonate (PFOS) (CAS #: 1763-23-1; Chemical Formula: C8HF17O3S). NJDWQI Health Effects Subcommittee. https://cswab.org/wp-content/uploads/2018/09/New-Jersey-Scientific-Documentation-Supporting-PFOS-13-ppt.pdf.
NLM (National Library of Medicine). (2013). HSDB: Perfluoro-n-nonanoic acid. Available online at https://pubchem.ncbi.nlm.nih.gov/source/hsdb/8040
NLM (National Library of Medicine). (2016). HSDB: Perfluorohexanoic acid. Available online at https://pubchem.ncbi.nlm.nih.gov/source/hsdb/8299
NLM (National Library of Medicine). (2017). HSDB: Perfluorohexanesulfonic acid. Available online at https://pubchem.ncbi.nlm.nih.gov/source/hsdb/8274
Norwegian Environment Agency. (2018). Investigation of sources to PFHxS in the environment. Munich, Germany: BiPRO GmbH. https://www.miljodirektoratet.no/globalassets/publikasjoner/M961/M961.pdf.
Noyes, PD; Paul-Friedman, KP; Haselman, JT; Barone Jr., S; Crofton, KM; Gilbert, ME; Hornung, MW; Laws, SC; Simmons, SO; Stoker, TE; Tietge, JE; Degitz, SJ. (2019). Evaluating chemicals for thyroid disruption: Opportunities and challenges with in vitro testing and adverse outcome pathway approaches. Environ Health Perspect 127: 95001. 10.1289/EHP5297.31487205
NTP (National Toxicology Program). (2018a). 28-day evaluation of the toxicity (C06100) of perfluorohexane sulfonate potassium salt (PFHSKslt) (3871-99-6) on Harlan Sprague-Dawley rats exposed via gavage. Available online at 10.22427/NTP-DATA-002-03267-0002-0000-2 (accessed October 13, 2020).
NTP (National Toxicology Program). (2018b). 28-day evaluation of the toxicity (C20615) of perfluorodecanoic acid (PFDA) (335-76-2) on Harlan Sprague-Dawley rats exposed via gavage [NTP]. U.S. Department of Health and Human Services. 10.22427/NTP-DATA-002-02652-0004-0000-1.
NTP (National Toxicology Program). (2018c). TOX-96: 1-Perfluorobutanesulfonic acid (375-73-5), potassium perfluorohexanesulfonate (3871-99-6), perfluorooctane sulfonate (1763-23-1), WY-14643 (50892-23-4). Chemical Effects in Biological Systems (CEBS). Available online at https://manticore.niehs.nih.gov/cebssearch/publication/TOX-96 (accessed August 6, 2018).
NTP (National Toxicology Program). (2019). NTP technical report on the toxicity studies of perfluoroalkyl sulfonates (perfluorobutane sulfonic acid, perfluorohexane sulfonate potassium salt, and perfluorooctane sulfonic acid) administered by gavage to Sprague Dawley (Hsd:Sprague Dawley SD) rats. (Toxicity Report 96). Research Triangle Park, NC. https://ntp.niehs.nih.gov/ntp/htdocs/st_rpts/tox096_508.pdf.
OECD (Organisation for Economic Co-operation and Development). (2015). Working towards a global emission inventory of PFASS: focus on PFCAS - status quo and the way forward. Paris, France. http://www.oecd.org/chemicalsafety/Working%20Towards%20a%20Global%20Emission%20Inventory%20of%20PFASS.pdf.
OECD (Organisation for Economic Co-operation and Development). (2016). Test no. 422: Combined repeated dose toxicity study with the reproduction/developmental toxicity screening test: 2016 version. In OECD guidelines for the testing of chemicals, Section 4: Health effects. Paris, France. 10.1787/9789264264403-en.
Oh, J; Bennett, DH; Calafat, AM; Tancredi, D; Roa, DL; Schmidt, RJ; Hertz-Picciotto, I; Shin, HM. (2021). Prenatal exposure to per- and polyfluoroalkyl substances in association with autism spectrum disorder in the MARBLES study. Environ Int 147: 106328. 10.1016/j.envint.2020.106328.33387879
Oh, J; Bennett, DH; Tancredi, DJ; Calafat, AM; Schmidt, RJ; Hertz-Picciotto, I; Shin, HM. (2022). Longitudinal Changes in Maternal Serum Concentrations of Per- and Polyfluoroalkyl Substances from Pregnancy to Two Years Postpartum. Environ Sci Technol 56: 11449–11459. 10.1021/acs.est.1c07970.35904360
Oh, RC; Hustead, TR; Ali, SM; Pantsari, MW. (2017). Mildly elevated liver transaminase levels: Causes and evaluation. Am Fam Physician 96: 709–715.29431403
Ojo, AF; Peng, C; Ng, JC. (2020). Combined effects and toxicological interactions of perfluoroalkyl and polyfluoroalkyl substances mixtures in human liver cells (HepG2). Environ Pollut 263: 114182. 10.1016/j.envpol.2020.114182.32247900
Ojo, AF; Xia, Q; Peng, C; Ng, JC. (2021). Evaluation of the individual and combined toxicity of perfluoroalkyl substances to human liver cells using biomarkers of oxidative stress. Chemosphere 281: 130808. 10.1016/j.chemosphere.2021.130808.34022600
Okada, E; Sasaki, S; Kashino, I; Matsuura, H; Miyashita, C; Kobayashi, S; Itoh, K; Ikeno, T; Tamakoshi, A; Kishi, R. (2014). Prenatal exposure to perfluoroalkyl acids and allergic diseases in early childhood. Environ Int 65: 127–134. 10.1016/j.envint.2014.01.007.24486970
Olsen, GW; Burris, JM; Ehresman, DJ; Froehlich, JW; Seacat, AM; Butenhoff, JL; Zobel, LR. (2007). Half-life of serum elimination of perfluorooctanesulfonate,perfluorohexanesulfonate, and perfluorooctanoate in retired fluorochemical production workers. Environ Health Perspect 115: 1298–1305. 10.1289/ehp.10009.17805419
Omoike, OE; Pack, RP; Mamudu, HM; Liu, Y; Strasser, S; Zheng, S; Okoro, J; Wang, L. (2020). Association between per and polyfluoroalkyl substances and markers of inflammation and oxidative stress. Environ Res 196: 110361. 10.1016/j.envres.2020.110361.33131681
Omoike, OE; Pack, RP; Mamudu, HM; Liu, Y; Wang, L. (2021). A cross-sectional study of the association between perfluorinated chemical exposure and cancers related to deregulation of estrogen receptors. Environ Res 196: 110329. 10.1016/j.envres.2020.110329.33068574
Oppi, S; Lüscher, TF; Stein, S. (2019). Mouse models for atherosclerosis research- Which is my line? [Review]. Front Cardiovasc Med 6: 46. 10.3389/fcvm.2019.00046.31032262
Osmond, C; Barker, DJ. (2000). Fetal, infant, and childhood growth are predictors of coronary heart disease, diabetes, and hypertension in adult men and women [Review]. Environ Health Perspect 108: 545–553. 10.2307/3454545.
Osterman, LE; Poore, RZ; Swarzenski, PW. (2008). The last 1000 years of natural and anthropogenic low-oxygen bottom-water on the Louisiana shelf, Gulf of Mexico. Marine Micropaleontology 66: 291–303. 10.1016/j.marmicro.2007.10.005.
Ou, Y; Zeng, X; Lin, S; Bloom, MS; Han, F; Xiao, X; Wang, H; Matala, R; Li, X; Qu, Y; Nie, Z; Dong, G; Liu, X. (2021). Gestational exposure to perfluoroalkyl substances and congenital heart defects: A nested case-control pilot study. Environ Int 154: 106567. 10.1016/j.envint.2021.106567.33882431
Oulhote, Y; Steuerwald, U; Debes, F; Weihe, P; Grandjean, P. (2016). Behavioral difficulties in 7-year old children in relation to developmental exposure to perfluorinated alkyl substances [Review]. Environ Int 97: 237–245. 10.1016/j.envint.2016.09.015.27692925
Palha, JA. (2002). Transthyretin as a thyroid hormone carrier: Function revisited [Review]. Clin Chem Lab Med 40: 1292–1300. 10.1515/CCLM.2002.223.12553433
Papadopoulou, E; Sabaredzovic, A; Namork, E; Nygaard, UC; Granum, B; Haug, LS. (2016). Exposure of Norwegian toddlers to perfluoroalkyl substances (PFAS): The association with breastfeeding and maternal PFAS concentrations. Environ Int 94: 687–694. 10.1016/j.envint.2016.07.006.27453094
Papadopoulou, E; Stratakis, N; Basagaña, X; Brantsæter, AL; Casas, M; Fossati, S; Gražulevičienė, R; Småstuen Haug, L; Heude, B; Maitre, L; Mceachan, RRC; Robinson, O; Roumeliotaki, T; Sabidó, E; Borràs, E; Urquiza, J; Vafeiadi, M; Zhao, Y; Slama, R; Wright, J; Conti, DV; Vrijheid, M; Chatzi, L. (2021). Prenatal and postnatal exposure to PFAS and cardiometabolic factors and inflammation status in children from six European cohorts. Environ Int 157: 106853. 10.1016/j.envint.2021.106853.34500361
Pappan, N; Awosika, AO; Rehman, A. (2024). Dyslipidemia. In B Abai (Ed.), StatPearls. Treasure Island, FL: StatPearls Publishing LLC. https://www.ncbi.nlm.nih.gov/books/NBK560891/.
Park, JH; Choi, J; Jun, DW; Han, SW; Yeo, YH; Nguyen, MH. (2019). Low Alanine Aminotransferase Cut-Off for Predicting Liver Outcomes; A Nationwide Population-Based Longitudinal Cohort Study. J Clin Med 8. 10.3390/jcm8091445.
Patel, J; Landers, K; Li, H; Mortimer, RH; Richard, K. (2011). Thyroid hormones and fetal neurological development [Review]. J Endocrinol 209: 1–8. 10.1530/JOE-10-0444.21212091
Pearce, RG; Setzer, RW; Strope, CL; Sipes, NS; Wambaugh, JF. (2017). Httk: R package for high-throughput toxicokinetics. J Stat Softw 79: 1–26. 10.18637/jss.v079.i04.30220889
Pelch, KE; Reade, A; Kwiatkowski, CF; Merced-Nieves, FM; Cavalier, H; Schultz, K; Wolffe, T; Varshavsky, J. (2022). The PFAS-Tox Database: A systematic evidence map of health studies on 29 per- and polyfluoroalkyl substances. Environ Int 167: 107408. 10.1016/j.envint.2022.107408.35908389
Pennings, JLA; Jennen, DGJ; Nygaard, UC; Namork, E; Haug, LS; van Loveren, H; Granum, B. (2016). Cord blood gene expression supports that prenatal exposure to perfluoroalkyl substances causes depressed immune functionality in early childhood. J Immunotoxicol 13: 173–180. 10.3109/1547691X.2015.1029147.25812627
Pérez, F; Llorca, M; Köck-Schulmeyer, M; Škrbić, B; Oliveira, LS; da Boit Martinello, K; Al-Dhabi, NA; Antić, I; Farré, M; Barceló, D. (2014). Assessment of perfluoroalkyl substances in food items at global scale. Environ Res 135: 181–189. 10.1016/j.envres.2014.08.004.25282275
Pérez, F; Nadal, M; Navarro-Ortega, A; Fàbrega, F; Domingo, JL; Barceló, D; Farré, M. (2013). Accumulation of perfluoroalkyl substances in human tissues. Environ Int 59: 354–362. 10.1016/j.envint.2013.06.004.23892228
Perng, W, ei; Rifas-Shiman, SL; Kramer, MS; Haugaard, LK; Oken, E; Gillman, MW; Belfort, MB. (2016). Early Weight Gain, Linear Growth, and Mid-Childhood Blood Pressure A Prospective Study in Project Viva. Hypertension 67: 301–308. 10.1161/HYPERTENSIONAHA.115.06635.26644238
Petersen, KU; Hærvig, KK; Flachs, EM; Bonde, JP; Lindh, C; Hougaard, KS; Toft, G; Ramlau-Hansen, CH; Tøttenborg, SS. (2022). Per- and polyfluoroalkyl substances (PFAS) and male reproductive function in young adulthood; a cross-sectional study. Environ Res 212: 113157. 10.1016/j.envres.2022.113157.35318009
Pettersson, F; Fries, H; Nillius, SJ. (1973). Epidemiology of secondary amenorrhea. I. Incidence and prevalence rates. Am J Obstet Gynecol 117: 80–86.4722382
Pfohl, M; Ingram, L; Marques, E; Auclair, A; Barlock, B; Jamwal, R; Anderson, D; Cummings, BS; Slitt, AL. (2020). Perfluorooctanesulfonic acid and perfluorohexanesulfonic acid alter the blood lipidome and the hepatic proteome in a murine model of diet-induced obesity. Toxicol Sci 178: 311–324. 10.1093/toxsci/kfaa148.32991729
Pilo, A; Iervasi, G; Vitek, F; Ferdeghini, M; Cazzuola, F; Bianchi, R. (1990). Thyroidal and peripheral production of 3,5,3’-triiodothyronine in humans by multicompartmental analysis. Am J Physiol 258: E715–E726. 10.1152/ajpendo.1990.258.4.E715.2333963
Pirard, C; Dufour, P; Charlier, C. (2020). Background contamination of perfluoralkyl substances in a Belgian general population. Toxicol Lett 333: 13–21. 10.1016/j.toxlet.2020.07.015.32659468
Pitter, G; Zare Jeddi, M; Barbieri, G; Gion, M; Fabricio, ASC; Daprà, F; Russo, F; Fletcher, T; Canova, C. (2020). Perfluoroalkyl substances are associated with elevated blood pressure and hypertension in highly exposed young adults. Environ Health 19: 102. 10.1186/s12940-020-00656-0.32958007
Poothong, S; Thomsen, C; Padilla-Sanchez, JA; Papadopoulou, E; Haug, LS. (2017). Distribution of novel and well-known poly- and perfluoroalkyl substances (PFASs) in human serum, plasma, and whole blood. Environ Sci Technol 51: 13388–13396. 10.1021/acs.est.7b03299.29056041
Preston, EV; Webster, TF; Claus Henn, B; Mcclean, MD; Gennings, C; Oken, E; Rifas-Shiman, SL; Pearce, EN; Calafat, AM; Fleisch, AF; Sagiv, SK. (2020). Prenatal exposure to per- and polyfluoroalkyl substances and maternal and neonatal thyroid function in the Project Viva Cohort: A mixtures approach. Environ Int 139: 105728. 10.1016/j.envint.2020.105728.32311629
Preston, EV; Webster, TF; Oken, E; Claus Henn, B; Mcclean, MD; Rifas-Shiman, SL; Pearce, EN; Braverman, LE; Calafat, AM; Ye, X; Sagiv, SK. (2018). Maternal plasma per- and polyfluoroalkyl substance concentrations in early pregnancy and maternal and neonatal thyroid function in a prospective birth cohort: Project Viva (USA). Environ Health Perspect 126: 027013. 10.1289/EHP2534.29488882
Pritchard, A. (2012). The Strengths and Difficulties Questionnaire hyperactivity-inattention subscale is more sensitive for the ADHD-combined subtype than other subtypes in 7-9-year-old school children. Evid Based Ment Health 15: 34. 10.1136/ebmental-2011-100482.22293441
Prol, B; Klein, S; Rennie, C; Andelija, S. (2024). Respondent Demographics and Contraceptive Use Patterns in the United States: A National Survey of Family Growth Analysis. Cureus 16: e53121. 10.7759/cureus.53121.38420091
Qin, XD; Qian, Z; Vaughn, MG; Huang, J; Ward, P; Zeng, XW; Zhou, Y; Zhu, Y; Yuan, P; Li, M; Bai, Z; Paul, G; Hao, YT; Chen, W; Chen, PC; Dong, GH; Lee, YL. (2016). Positive associations of serum perfluoroalkyl substances with uric acid and hyperuricemia in children from Taiwan. Environ Pollut 212: 519–524. 10.1016/j.envpol.2016.02.050.26970855
Quispe, R; Sweeney, T; Varma, B; Agarwala, A; Michos, ED. (2022). Recent updates in hypertriglyceridemia management for cardiovascular disease prevention. Curr Atheroscler Rep 24: 767–778. 10.1007/s11883-022-01052-4.35895246
Radke, E; Wright, MJ; Christensen, K; Lin, CJ; Goldstone, AE; Glenn, B; Thayer, K. (2022). Epidemiology evidence for health effects of 150 per- and polyfluoroalkyl substances: A systematic evidence map [Review]. Environ Health Perspect 130: 96003. 10.1289/EHP11185.36178797
Radke, EG; Glenn, B; Galizia, A; Persad, A; Nachman, R; Bateson, T; Wright, JM; Navas-Acien, A; Arroyave, WD; Puett, RC; Harville, EW; Pollack, AZ; Burns, JS; Lynch, CD; Sagiv, SK; Stein, C; Cooper, GS. (2019). Development of outcome-specific criteria for study evaluation in systematic reviews of epidemiology studies. Environ Int 130: 104884. 10.1016/j.envint.2019.05.078.31299560
Rahman, ML; Zhang, C; Smarr, MM; Lee, S; Honda, M; Kannan, K; Tekola-Ayele, F; Buck Louis, GM. (2019). Persistent organic pollutants and gestational diabetes: A multi-center prospective cohort study of healthy US women. Environ Int 124: 249–258. 10.1016/j.envint.2019.01.027.30660025
Ramhøj, L; Hass, U; Boberg, J; Scholze, M; Christiansen, S; Nielsen, F; Axelstad, M. (2018). Perfluorohexane sulfonate (PFHxS) and a mixture of endocrine disrupters reduce thyroxine levels and cause anti-androgenic effects in rats. Toxicol Sci 163: 579–591. 10.1093/toxsci/kfy055.29518214
Ramhøj, L; Hass, U; Gilbert, ME; Wood, C; Svingen, T; Usai, D; Vinggaard, AM; Mandrup, K; Axelstad, M. (2020). Evaluating thyroid hormone disruption: investigations of long-term neurodevelopmental effects in rats after perinatal exposure to perfluorohexane sulfonate (PFHxS). Sci Rep 10: 2672. 10.1038/s41598-020-59354-z.32060323
Rantakokko, P; Männistö, V; Airaksinen, R; Koponen, J; Viluksela, M; Kiviranta, H; Pihlajamäki, J. (2015). Persistent organic pollutants and non-alcoholic fatty liver disease in morbidly obese patients: A cohort study. Environ Health 14: 79. 10.1186/s12940-015-0066-z.26420011
Reardon, AJF; Khodayari Moez, E; Dinu, I; Goruk, S; Field, CJ; Kinniburgh, DW; Macdonald, AM; Martin, JW; Study, A. (2019). Longitudinal analysis reveals early-pregnancy associations between perfluoroalkyl sulfonates and thyroid hormone status in a Canadian prospective birth cohort. Environ Int 129: 389–399. 10.1016/j.envint.2019.04.023.31150980
Refetoff, S. (2015). Thyroid hormone serum transport proteins. In KR Feingold; B Anawalt; A Boyce; G Chrousos; WW de Herder; K Dhatariya; K Dungan; JM Hershman; J Hofland; S Kalra; G Kaltsas; C Koch; P Kopp; M Korbonits; CS Kovacs; W Kuohung; B Laferrère; M Levy; EA McGee; R McLachlan; JE Morley; M New; J Purnell; R Sahay; F Singer; MA Sperling; CA Stratakis; DL Trence; DP Wilson (Eds.), Endotext. South Dartmouth, MA: MDtext.com Inc. https://www.ncbi.nlm.nih.gov/books/NBK285566/.
Ren, XM; Qin, WP; Cao, LY; Zhang, J; Yang, Y; Wan, B; Guo, LH. (2016). Binding interactions of perfluoroalkyl substances with thyroid hormone transport proteins and potential toxicological implications. Toxicology 366–367: 32–42. 10.1016/j.tox.2016.08.011.
Ren, XM; Zhang, YF; Guo, LH; Qin, ZF; Lv, QY; Zhang, LY. (2015). Structure-activity relations in binding of perfluoroalkyl compounds to human thyroid hormone T3 receptor. Arch Toxicol 89: 233–242. 10.1007/s00204-014-1258-y.24819616
Ren, Y; Jin, L; Yang, F; Liang, H; Zhang, Z; Du, J; Song, X; Miao, M; Yuan, W. (2020). Concentrations of perfluoroalkyl and polyfluoroalkyl substances and blood glucose in pregnant women. Environ Health 19: 88. 10.1186/s12940-020-00640-8.32807188
Reyes, L; Mañalich, R. (2005). Long-term consequences of low birth weight [Review]. Kidney Int Suppl 68: S107–S111. 10.1111/j.1523-1755.2005.09718.x.
Rivera, JC; Opazo, MC; Hernández-Armengol, R; Alvarez, O; Mendoza-León, MJ; Caamaño, E; Gatica, S; Bohmwald, K; Bueno, SM; González, PA; Neunlist, M; Boudin, H; Kalergis, AM; Riedel, CA. (2024). Transient gestational hypothyroxinemia accelerates and enhances ulcerative colitis-like disorder in the male offspring. Front Endocrinol (Lausanne) 14: 1269121. 10.3389/fendo.2023.1269121.38239991
Robinson, PJ; Rapoport, SI. (1986). Kinetics of protein binding determine rates of uptake of drugs by brain. Am J Physiol Regul Integr Comp Physiol 251: R1212–R1220. 10.1152/ajpregu.1986.251.6.R1212.
Romano, ME; Gallagher, LG; Eliot, MN; Calafat, AM; Chen, A; Yolton, K; Lanphear, B; Braun, JM. (2020). Per- and polyfluoroalkyl substance mixtures and gestational weight gain among mothers in the health outcomes and measures of the environment study. Int J Hyg Environ Health 231: 113660. 10.1016/j.ijheh.2020.113660.33181449
Romano, ME; Xu, Y; Calafat, AM; Yolton, K; Chen, A; Webster, GM; Eliot, MN; Howard, CR; Lanphear, BP; Braun, JM. (2016). Maternal serum perfluoroalkyl substances during pregnancy and duration of breastfeeding. Environ Res 149: 239–246. 10.1016/j.envres.2016.04.034.27179585
Rosen, EM; Brantsæter, AL; Carroll, R; Haug, L; Singer, AB; Zhao, S; Ferguson, KK. (2018). Maternal Plasma Concentrations of Per- and polyfluoroalkyl Substances and Breastfeeding Duration in the Norwegian Mother and Child Cohort. Environmental Epidemiology 2: e027. 10.1097/EE9.0000000000000027.30298140
Rosen, MB; Das, KP; Rooney, J; Abbott, B; Lau, C; Corton, JC. (2017). PPARα-independent transcriptional targets of perfluoroalkyl acids revealed by transcript profiling. Toxicology 387: 95–107. 10.1016/j.tox.2017.05.013.28558994
Rosen, MB; Das, KP; Wood, CR; Wolf, CJ; Abbott, BD; Lau, C. (2013). Evaluation of perfluoroalkyl acid activity using primary mouse and human hepatocytes. Toxicology 308: 129–137. 10.1016/j.tox.2013.03.011.23567314
Rosenmai, AK; Ahrens, L; le Godec, T; Lundqvist, J; Oskarsson, A. (2018). Relationship between peroxisome proliferator-activated receptor alpha activity and cellular concentration of 14 perfluoroalkyl substances in HepG2 cells. J Appl Toxicol 38: 219–226. 10.1002/jat.3515.28857218
Rosskothen-Kuhl, N; Illing, RB. (2014). Gap43 transcription modulation in the adult brain depends on sensory activity and synaptic cooperation. PLoS ONE 9: e92624. 10.1371/journal.pone.0092624.24647228
Rotander, A; Kärrman, A; Toms, LM; Kay, M; Mueller, JF; Gómez Ramos, MJ. (2015a). Novel fluorinated surfactants tentatively identified in firefighters using liquid chromatography quadrupole time-of-flight tandem mass spectrometry and a case-control approach. Environ Sci Technol 49: 2434–2442. 10.1021/es503653n.25611076
Rotander, A; Toms, LM; Aylward, L; Kay, M; Mueller, JF. (2015b). Elevated levels of PFOS and PFHxS in firefighters exposed to aqueous film forming foam (AFFF). Environ Int 82: 28–34. 10.1016/j.envint.2015.05.005.26001497
Roth, K; Yang, Z; Agarwal, M; Birbeck, J; Westrick, J; Lydic, T; Gurdziel, K; Petriello, MC. (2024). Exposure of Environ Health Perspect 132: 087007. 10.1289/EHP14339.39177951
Roth, RA; Jaeschke, H; Luyendyk, JP. (2019). Chapter 13: Toxic responses of the liver. In CD Klaassen (Ed.), Casarett & Doull’s toxicology: The basic science of poisons (9th ed., pp. 719–766). New York, NY: McGraw Hill.
Rovet, JF. (2005). Children with congenital hypothyroidism and their siblings: Do they really differ? Pediatrics 115: e52–e57. 10.1542/peds.2004-1492.15629966
Rovet, JF. (2014). The role of thyroid hormones for brain development and cognitive function [Review]. In G Szinnai (Ed.), Paediatric thyroidology (pp. 26–43). Basel, Switzerland: Karger. 10.1159/000363153.
Ruark, CD; Song, G; Yoon, M; Verner, MA; Andersen, ME; Clewell, HJ; Longnecker, MP. (2017). Quantitative bias analysis for epidemiological associations of perfluoroalkyl substance serum concentrations and early onset of menopause. Environ Int 99: 245–254. 10.1016/j.envint.2016.11.030.27927583
Ruffle, B; Vedagiri, U; Bogdan, D; Maier, M; Schwach, C; Murphy-Hagan, C. (2020). Perfluoroalkyl Substances in U.S. market basket fish and shellfish. Environ Res 190: 9932–9932. 10.1016/j.envres.2020.109932.
Rylander, C; Brustad, M; Falk, H; Sandanger, TM. (2009). Dietary predictors and plasma concentrations of perfluorinated compounds in a coastal population from northern Norway. J Environ Public Health 2009: 268219. 10.1155/2009/268219.20111729
S, N; MR, B; S, R; R, C; M, S; R, B; F, C; C, L; M, M; F, C; G, S; V, M; E, P. (2023). Natural Products for the Treatment of Non-Alcoholic Fatty Liver Disease: A Comprehensive Review. Scientia Pharmaceutica 91. 10.3390/scipharm91040053.
Sagiv, SK; Rifas-Shiman, SL; Fleisch, AF; Webster, TF; Calafat, AM; Ye, X; Gillman, MW; Oken, E. (2018). Early Pregnancy Perfluoroalkyl Substance Plasma Concentrations and Birth Outcomes in Project Viva: Confounded by Pregnancy Hemodynamics? Am J Epidemiol 187: 793–802. 10.1093/aje/kwx332.29155920
Sagiv, SK; Rifas-Shiman, SL; Webster, TF; Mora, AM; Harris, MH; Calafat, AM; Ye, X; Gillman, MW; Oken, E. (2015). Sociodemographic and perinatal predictors of early pregnancy per- and polyfluoroalkyl substance (PFAS) concentrations. Environ Sci Technol 49: 11849–11858. 10.1021/acs.est.5b02489.26333069
Salazar-Martinez, E; Romano-Riquer, P; Yanez-Marquez, E; Longnecker, MP; Hernandez-Avila, M. (2004). Anogenital distance in human male and female newborns: a descriptive, cross-sectional study. Environ Health 3: 8–13. 10.1186/1476-069x-3-8.15363098
Salgado, R; López-Doval, S; Pereiro, N; Lafuente, A. (2016). Perfluorooctane sulfonate (PFOS) exposure could modify the dopaminergic system in several limbic brain regions. Toxicol Lett 240: 226–235. 10.1016/j.toxlet.2015.10.023.26529483
Salihovic, S; Stubleski, J; Kärrman, A; Larsson, A; Fall, T; Lind, L; Lind, PM. (2018). Changes in markers of liver function in relation to changes in perfluoroalkyl substances - A longitudinal study. Environ Int 117: 196–203. 10.1016/j.envint.2018.04.052.29754000
Sanders, JE; Eigenberg, DA; Bracht, LJ; Wang, WR; van Zwieten, MJ. (1988). Thyroid and liver trophic changes in rats secondary to liver microsomal enzyme induction caused by an experimental leukotriene antagonist (L-649,923). Toxicol Appl Pharmacol 95: 378–387. 10.1016/0041-008x(88)90356-0.3142097
Sarzo, B; Ballesteros, V; Iñiguez, C; Manzano-Salgado, CB; Casas, M; Llop, S; Murcia, M; Guxens, M; Vrijheid, M; Marina, LS; Schettgen, T; Espada, M; Irizar, A; Fernandez-Jimenez, N; Ballester, F; Lopez-Espinosa, MJ. (2021). Maternal perfluoroalkyl substances, thyroid hormones, and DIO genes: A Spanish cross-sectional study. Environ Sci Technol 55: 11144–11154. 10.1021/acs.est.1c01452.34314170
Sathyanarayana, S; Beard, L; Zhou, C; Grady, R. (2010). Measurement and correlates of ano-genital distance in healthy, newborn infants. Int J Androl 33: 317–323. 10.1111/j.1365-2605.2009.01044.x.20132349
Schecter, A; Malik-Bass, N; Calafat, AM; Kato, K; Colacino, JA; Gent, TL; Hynan, LS; Harris, TR; Malla, S; Birnbaum, L. (2012). Polyfluoroalkyl compounds in Texas children from birth through 12 years of age. Environ Health Perspect 120: 590–594. 10.1289/ehp.1104325.22182702
Schünemann, H; Hill, S; Guyatt, G; Akl, EA; Ahmed, F. (2011). The GRADE approach and Bradford Hill’s criteria for causation. J Epidemiol Community Health 65: 392–395. 10.1136/jech.2010.119933.20947872
Scinicariello, F; Buser, MC; Abadin, HG; Attanasio, R. (2020a). Perfluoroalkyl substances and anthropomorphic measures in children (ages 3-11 years), NHANES 2013-2014. Environ Res 186: 109518. 10.1016/j.envres.2020.109518.32315828
Scinicariello, F; Buser, MC; Balluz, L; Gehle, K; Murray, HE; Abadin, HG; Attanasio, R. (2020b). Perfluoroalkyl acids, hyperuricemia and gout in adults: Analyses of NHANES 2009-2014. Chemosphere 259: 127446. 10.1016/j.chemosphere.2020.127446.32590180
Sellers, RS; Mortan, D; Michael, B; Roome, N; Johnson, JK; Yano, BL; Perry, R; Schafer, K. (2007). Society of toxicologic pathology position paper: Organ weight recommendations for toxicology studies [Review]. Toxicol Pathol 35: 751–755. 10.1080/01926230701595300.17849358
Seo, SH; Son, MH; Choi, SD; Lee, DH; Chang, YS. (2018). Influence of exposure to perfluoroalkyl substances (PFASs) on the Korean general population: 10-year trend and health effects. Environ Int 113: 149–161. 10.1016/j.envint.2018.01.025.29425899
Shah-Kulkarni, S; Kim, BM; Hong, YC; Kim, HS; Kwon, EJ; Park, H; Kim, YJ; Ha, EH. (2016). Prenatal exposure to perfluorinated compounds affects thyroid hormone levels in newborn girls. Environ Int 94: 607–613. 10.1016/j.envint.2016.06.024.27395336
Shapiro, GD; Dodds, L; Arbuckle, TE; Ashley-Martin, J; Ettinger, AS; Fisher, M; Taback, S; Bouchard, MF; Monnier, P; Dallaire, R; Morisset, AS; Fraser, W. (2016). Exposure to organophosphorus and organochlorine pesticides, perfluoroalkyl substances, and polychlorinated biphenyls in pregnancy and the association with impaired glucose tolerance and gestational diabetes mellitus: The MIREC Study. Environ Res 147: 71–81. 10.1016/j.envres.2016.01.040.26852007
Sheng, N; Li, J; Liu, H; Zhang, A; Dai, J. (2016). Interaction of perfluoroalkyl acids with human liver fatty acid-binding protein. Arch Toxicol 90: 217–227. 10.1007/s00204-014-1391-7.25370009
Shi, Y; Yang, L; Li, J; Lai, J; Wang, Y; Zhao, Y; Wu, Y. (2017). Occurrence of perfluoroalkyl substances in cord serum and association with growth indicators in newborns from Beijing. Chemosphere 169: 396–402. 10.1016/j.chemosphere.2016.11.050.27886542
Shih, YH; Blomberg, AJ; Bind, MA; Holm, D; Nielsen, F; Heilmann, C; Weihe, P; Grandjean, P. (2021). Serum vaccine antibody concentrations in adults exposed to per- and polyfluoroalkyl substances: A birth cohort in the Faroe Islands. J Immunotoxicol 18: 85–92. 10.1080/1547691X.2021.1922957.34143710
Shin, HM; Bennett, DH; Calafat, AM; Tancredi, D; Hertz-Picciotto, I. (2020). Modeled prenatal exposure to per- and polyfluoroalkyl substances in association with child autism spectrum disorder: A case-control study. Environ Res 186: 109514. 10.1016/j.envres.2020.109514.32353786
Shinwell, ES; Shlomo, M. (2003). Measured length of normal term infants changes over the first two days of life. J Pediatr Endocrinol Metab 16: 537–540. 10.1515/jpem.2003.16.4.537.12793605
Shoaff, J; Papandonatos, GD; Calafat, AM; Chen, A; Lanphear, BP; Ehrlich, S; Kelsey, KT; Braun, JM. (2018). Prenatal exposure to perfluoroalkyl substances: Infant birth weight and early life growth. Environmental Epidemiology 2: e010. 10.1097/EE9.0000000000000010.30272047
Shrestha, S; Bloom, MS; Yucel, R; Seegal, RF; Rej, R; Mccaffrey, RJ; Wu, Q; Kannan, K; Fitzgerald, EF. (2017). Perfluoroalkyl substances, thyroid hormones, and neuropsychological status in older adults. Int J Hyg Environ Health 220: 679–685. 10.1016/j.ijheh.2016.12.013.28065522
Singer, AB; Whitworth, KW; Haug, LS; Sabaredzovic, A; Impinen, A; Papadopoulou, E; Longnecker, MP. (2018). Menstrual cycle characteristics as determinants of plasma concentrations of perfluoroalkyl substances (PFASs) in the Norwegian Mother and Child Cohort (MoBa study). Environ Res 166: 78–85. 10.1016/j.envres.2018.05.019.29879567
Sinisalu, L; Yeung, LWY; Wang, J; Pan, Y; Dai, J; Hyötyläinen, T. (2021). Prenatal exposure to poly-/per-fluoroalkyl substances is associated with alteration of lipid profiles in cord-blood. Metabolomics 17: 103. 10.1007/s11306-021-01853-9.34816353
Skogheim, TS; Villanger, GD; Weyde, KVF; Engel, SM; Surén, P; Øie, MG; Skogan, AH; Biele, G; Zeiner, P; Øvergaard, KR; Haug, LS; Sabaredzovic, A; Aase, H. (2020). Prenatal exposure to perfluoroalkyl substances and associations with symptoms of attention-deficit/hyperactivity disorder and cognitive functions in preschool children. Int J Hyg Environ Health 223: 80–92. 10.1016/j.ijheh.2019.10.003.31653559
Skogheim, TS; Weyde, K, jell Vegard F; Aase, H; Engel, SM; Suren, P; Oie, MG; Biele, G; Reichborn-Kjennerud, T; Brantsaeter, AL; Haug, LS; Sabaredzovic, A; Auyeung, B; Villanger, GD. (2021). Prenatal exposure to per- and polyfluoroalkyl substances (PFAS) and associations with attention-deficit/hyperactivity disorder and autism spectrum disorder in children. Environ Res 202: 111692. 10.1016/j.envres.2021.111692.34293314
Smeltz, M; Wambaugh, JF; Wetmore, BA. (2023). Plasma protein binding evaluations of per- and polyfluoroalkyl substances for category-based toxicokinetic assessment. Chem Res Toxicol 36: 870–881. 10.1021/acs.chemrestox.3c00003.37184865
Smit, LAM; Lenters, V; Høyer, BB; Lindh, CH; Pedersen, HS; Liermontova, I; Jönsson, BAG; Piersma, AH; Bonde, JP; Toft, G; Vermeulen, R; Heederik, D. (2015). Prenatal exposure to environmental chemical contaminants and asthma and eczema in school-age children. Allergy 70: 653–660. 10.1111/all.12605.25753462
Song, X; Tang, S; Zhu, H; Chen, Z; Zang, Z; Zhang, Y; Niu, X; Wang, X; Yin, H; Zeng, F; He, C. (2018). Biomonitoring PFAAs in blood and semen samples: Investigation of a potential link between PFAAs exposure and semen mobility in China. Environ Int 113: 50–54. 10.1016/j.envint.2018.01.010.29421407
Specht, IO; Hougaard, KS; Spanò, M; Bizzaro, D; Manicardi, GC; Lindh, CH; Toft, G; Jönsson, BA; Giwercman, A; Bonde, JP. (2012). Sperm DNA integrity in relation to exposure to environmental perfluoroalkyl substances - a study of spouses of pregnant women in three geographical regions. Reprod Toxicol 33: 577–583. 10.1016/j.reprotox.2012.02.008.22449571
Spratlen, MJ; Perera, FP; Lederman, SA; Rauh, VA; Robinson, M; Kannan, K; Trasande, L; Herbstman, J. (2020a). The association between prenatal exposure to perfluoroalkyl substances and childhood neurodevelopment. Environ Pollut 263: 114444. 10.1016/j.envpol.2020.114444.32272335
Spratlen, MJ; Perera, FP; Lederman, SA; Robinson, M; Kannan, K; Herbstman, J; Trasande, L. (2020b). The association between perfluoroalkyl substances and lipids in cord blood. J Clin Endocrinol Metab 105: 43–54. 10.1210/clinem/dgz024.31536623
Stagnaro-Green, A; Rovet, J. (2016). Pregnancy: Maternal thyroid function in pregnancy - A tale of two tails [Comment]. Nat Rev Endocrinol 12: 10–11. 10.1038/nrendo.2015.212.26635112
Stahl, LL; Snyder, BD; Olsen, AR; Kincaid, TM; Wathen, JB; Mccarty, HB. (2014). Perfluorinated compounds in fish from U.S. urban rivers and the Great Lakes. Sci Total Environ 499: 185–195. 10.1016/j.scitotenv.2014.07.126.25190044
Starling, AP; Adgate, JL; Hamman, RF; Kechris, K; Calafat, AM; Dabelea, D. (2019). Prenatal exposure to per- and polyfluoroalkyl substances and infant growth and adiposity: The healthy start study. Environ Int 131: 104983. 10.1016/j.envint.2019.104983.31284113
Starling, AP; Adgate, JL; Hamman, RF; Kechris, K; Calafat, AM; Ye, X; Dabelea, D. (2017). Perfluoroalkyl substances during pregnancy and offspring weight and adiposity at birth: Examining mediation by maternal fasting glucose in the healthy start study. Environ Health Perspect 125: 067016. 10.1289/EHP641.28669937
Starling, AP; Engel, SM; Richardson, DB; Baird, DD; Haug, LS; Stuebe, AM; Klungsoyr, K; Harmon, Q; Becher, G; Thomsen, C; Sabaredzovic, A; Eggesbo, M; Hoppin, JA; Travlos, GS; Wilson, RE; Trogstad, LI; Magnus, P, er; Longnecker, MP. (2014a). Perfluoroalkyl Substances During Pregnancy and Validated Preeclampsia Among Nulliparous Women in the Norwegian Mother and Child Cohort Study. Am J Epidemiol 179: 824–833. 10.1093/aje/kwt432.24557813
Starling, AP; Engel, SM; Whitworth, KW; Richardson, DB; Stuebe, AM; Daniels, JL; Haug, LS; Eggesbø, M; Becher, G; Sabaredzovic, A; Thomsen, C; Wilson, RE; Travlos, GS; Hoppin, JA; Baird, DD; Longnecker, MP. (2014b). Perfluoroalkyl substances and lipid concentrations in plasma during pregnancy among women in the Norwegian Mother and Child Cohort Study. Environ Int 62: 104–112. 10.1016/j.envint.2013.10.004.24189199
Steenland, K; Barry, V; Savitz, D. (2018). Serum perfluorooctanoic acid and birthweight: an updated meta-analysis with bias analysis. Epidemiology 29: 765–776. 10.1097/EDE.0000000000000903.30063543
Stein, CR; Ge, Y; Wolff, MS; Ye, X; Calafat, AM; Kraus, T; Moran, TM. (2016a). Perfluoroalkyl substance serum concentrations and immune response to FluMist vaccination among healthy adults. Environ Res 149: 171–178. 10.1016/j.envres.2016.05.020.27208468
Stein, CR; Mcgovern, KJ; Pajak, AM; Maglione, PJ; Wolff, M. (2016b). Perfluoroalkyl and polyfluoroalkyl substances and indicators of immune function in children aged 12-19 y: National Health and Nutrition Examination Survey. Pediatr Res 79: 348–357. 10.1038/pr.2015.213.26492286
Stein, CR; Savitz, DA. (2011). Serum perfluorinated compound concentration and attention deficit/hyperactivity disorder in children 5-18 years of age. Environ Health Perspect 119: 1466–1471. 10.1289/ehp.1003538.21665566
Stoker, TE; Ferrell, JM; Laws, SC; Cooper, RL; Buckalew, A. (2006). Evaluation of ammonium perchlorate in the endocrine disruptor screening and testing program’s male pubertal protocol: Ability to detect effects on thyroid endpoints. Toxicology 228: 58–65. 10.1016/j.tox.2006.08.026.17011691
Stratakis, N; Conti, DV; Jin, R; Margetaki, K; Valvi, D; Siskos, AP; Maitre, L; Garcia, E; Varo, N; Zhao, Y; Roumeliotaki, T; Vafeiadi, M; Urquiza, J; Fernández-Barrés, S; Heude, B; Basagana, X; Casas, M; Fossati, S; Gražulevičienė, R; Andrušaitytė, S; Uppal, K; Mceachan, RR; Papadopoulou, E; Robinson, O; Haug, LS; Wright, J; Vos, MB; Keun, HC; Vrijheid, M; Berhane, KT; Mcconnell, R; Chatzi, L. (2020). Prenatal exposure to perfluoroalkyl substances associated with increased susceptibility to liver injury in children. Hepatology 72: 1758–1770. 10.1002/hep.31483.32738061
Street, ME; Shulhai, AM; Petraroli, M; Patianna, V; Donini, V; Giudice, A; Gnocchi, M; Masetti, M; Montani, AG; Rotondo, R; Bernasconi, S; Iughetti, L; Esposito, SM; Predieri, B. (2024). The impact of environmental factors and contaminants on thyroid function and disease from fetal to adult life: current evidence and future directions [Review]. Front Endocrinol (Lausanne) 15: 1429884. 10.3389/fendo.2024.1429884.38962683
Stubleski, J; Salihovic, S; Lind, L; Lind, PM; van Bavel, B; Kärrman, A. (2016). Changes in serum levels of perfluoroalkyl substances during a 10-year follow-up period in a large population-based cohort. Environ Int 95: 86–92. 10.1016/j.envint.2016.08.002.27542758
Sultan, M; Ben-Ari, Z; Masoud, R; Pappo, O; Kamari, Y; Safran, M. (2017). Interleukin-1α and Interleukin-1β play a central role in the pathogenesis of fulminant hepatic failure in mice. PLoS ONE 12: e0184084. 10.1371/journal.pone.0184084.28953903
Sun, Q; Zong, G; Valvi, D; Nielsen, F; Coull, B; Grandjean, P. (2018). Plasma concentrations of perfluoroalkyl substances and risk of Type 2 diabetes: A prospective investigation among U.S. women. Environ Health Perspect 126: 037001. 10.1289/EHP2619.29498927
Sunderland, EM; Hu, XC; Dassuncao, C; Tokranov, AK; Wagner, CC; Allen, JG. (2019). A review of the pathways of human exposure to poly- and perfluoroalkyl substances (PFASs) and present understanding of health effects [Review]. J Expo Sci Environ Epidemiol 29: 131–147. 10.1038/s41370-018-0094-1.30470793
Sundström, M; Chang, SC; Noker, PE; Gorman, GS; Hart, JA; Ehresman, DJ; Bergman, A; Butenhoff, JL. (2012). Comparative pharmacokinetics of perfluorohexanesulfonate (PFHxS) in rats, mice, and monkeys. Reprod Toxicol 33: 441–451. 10.1016/j.reprotox.2011.07.004.21856411
Surma, M; Piskula, M; Wiczkowski, W; Zieliński, H. (2017). The perfluoroalkyl carboxylic acids (PFCAs) and perfluoroalkane sulfonates (PFSAs) contamination level in spices. European Food Research and Technology 243: 297–307. 10.1007/s00217-016-2744-7.
Sweeney, M. (2022). Physiologically based pharmacokinetic (PBPK) modeling of perfluorohexane sulfonate (PFHxS) in humans. Regul Toxicol Pharmacol 129: 1–10.
Tamber, SS; Bansal, P; Sharma, S; Singh, RB; Sharma, R. (2023). Biomarkers of liver diseases [Review]. Mol Biol Rep 50: 7815–7823. 10.1007/s11033-023-08666-0.37482588
Tao, L, in; Kannan, K; Aldous, KM; Mauer, MP; Eadon, GA. (2008). Biomonitoring of perfluorochemicals in plasma of New York state personnel responding to the World Trade Center disaster. Environ Sci Technol 42: 3472–3478. 10.1021/es8000079.18522136
Tetzlaff, CNR; Ramhøj, L; Lardenois, A; Axelstad, M; Evrard, B; Chalmel, F; Taxvig, C; Svingen, T. (2021). Adult female rats perinatally exposed to perfluorohexane sulfonate (PFHxS) and a mixture of endocrine disruptors display increased body/fat weights without a transcriptional footprint in fat cells. Toxicol Lett 339: 78–87. 10.1016/j.toxlet.2020.12.018.33387635
Thankamony, A; Pasterski, V; Ong, KK; Acerini, CL; Hughes, IA. (2016). Anogenital distance as a marker of androgen exposure in humans. Andrology 0: 1–10. 10.1111/andr.12156.
Thomsen, ML; Henriksen, LS; Tinggaard, J; Nielsen, F; Jensen, TK; Main, KM. (2021). Associations between exposure to perfluoroalkyl substances and body fat evaluated by DXA and MRI in 109 adolescent boys. Environ Health 20: 73. 10.1186/s12940-021-00758-3.34187491
Thoolen, B; Maronpot, RR; Harada, T; Nyska, A; Rousseaux, C; Nolte, T; Malarkey, DE; Kaufmann, W; Küttler, K; Deschl, U; Nakae, D; Gregson, R; Vinlove, MP; Brix, AE; Singh, B; Belpoggi, F; Ward, JM. (2010). Proliferative and nonproliferative lesions of the rat and mouse hepatobiliary system [Review]. Toxicol Pathol 38: 5S–81S. 10.1177/0192623310386499.21191096
Tian, M, .; Reichetzeder, C, .; Li, J, .; Hocher, B, . (2019a). Low birth weight, a risk factor for diseases in later life, is a surrogate of insulin resistance at birth. J Hypertens 37: 2123–2134. 10.1097/HJH.0000000000002156.31157747
Tian, Y; Liang, H; Miao, M; Yang, F; Ji, H; Cao, W; Liu, X; Zhang, X; Chen, A; Xiao, H; Hu, H; Yuan, W. (2019b). Maternal plasma concentrations of perfluoroalkyl and polyfluoroalkyl substances during pregnancy and anogenital distance in male infants. Hum Reprod 34: 1356–1368. 10.1093/humrep/dez058.31242507
Tian, Y; Miao, M; Ji, H; Zhang, X; Chen, A; Wang, Z; Yuan, W; Liang, H. (2021). Prenatal exposure to perfluoroalkyl substances and cord plasma lipid concentrations. Environ Pollut 268: 115426. 10.1016/j.envpol.2020.115426.33152632
Tian, Z; Peter, KT; Gipe, AD; Zhao, H; Hou, F; Wark, DA; Khangaonkar, T; Kolodziej, EP; James, CA. (2020). Suspect and Nontarget Screening for Contaminants of Emerging Concern in an Urban Estuary. Environ Sci Technol 54: 889–901. 10.1021/acs.est.9b06126.31887037
Timmermann, CA; Budtz-Jørgensen, E; Jensen, TK; Osuna, CE; Petersen, MS; Steuerwald, U; Nielsen, F; Poulsen, LK; Weihe, P; Grandjean, P. (2017a). Association between perfluoroalkyl substance exposure and asthma and allergic disease in children as modified by MMR vaccination. J Immunotoxicol 14: 39–49. 10.1080/1547691X.2016.1254306.28091126
Timmermann, CA; Budtz-Jørgensen, E; Petersen, MS; Weihe, P; Steuerwald, U; Nielsen, F; Jensen, TK; Grandjean, P. (2017b). Shorter duration of breastfeeding at elevated exposures to perfluoroalkyl substances. Reprod Toxicol 68: 164–170. 10.1016/j.reprotox.2016.07.010.27421579
Timmermann, CAG; Andersen, MS; Budtz-Jørgensen, E; Boye, H; Nielsen, F; Jensen, RC; Bruun, S; Husby, S; Grandjean, P; Jensen, TK. (2022). Pregnancy exposure to perfluoroalkyl substances and associations with prolactin concentrations and breastfeeding in the Odense Child Cohort. J Clin Endocrinol Metab 107: e631–e642. 10.1210/clinem/dgab638.34529060
Timmermann, CAG; Jensen, KJ; Nielsen, F; Budtz-Jørgensen, E; van Der Klis, F; Benn, CS; Grandjean, P; Fisker, AB. (2020). Serum Perfluoroalkyl Substances, Vaccine Responses, and Morbidity in a Cohort of Guinea-Bissau Children. Environ Health Perspect 128: 87002. 10.1289/EHP6517.32772733
Timmermann, CAG; Pedersen, HS; Weihe, P; Bjerregaard, P; Nielsen, F; Heilmann, C; Grandjean, P. (2021). Concentrations of tetanus and diphtheria antibodies in vaccinated Greenlandic children aged 7-12 years exposed to marine pollutants, a cross sectional study. Environ Res 203: 111712. 10.1016/j.envres.2021.111712.34343554
Toft, G; Jönsson, BAG; Lindh, CH; Giwercman, A; Spano, M; Heederik, D; Lenters, V; Vermeulen, R; Rylander, L; Pedersen, HS; Ludwicki, JK; Zviezdai, V; Bonde, JP. (2012). Exposure to perfluorinated compounds and human semen quality in arctic and European populations. Hum Reprod 27: 2532–2540. 10.1093/humrep/des185.22647447
Tsai, MS; Chang, SH; Kuo, WH; Kuo, CH; Li, SY; Wang, MY; Chang, DY; Lu, YS; Huang, CS; Cheng, AL; Lin, CH; Chen, PC. (2020). A case-control study of perfluoroalkyl substances and the risk of breast cancer in Taiwanese women. Environ Int 142: 105850. 10.1016/j.envint.2020.105850.32580117
U.S. EPA (U.S. Environmental Protection Agency). (1991). Guidelines for developmental toxicity risk assessment. Fed Reg 56: 63798–63826.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (1996). Guidelines for reproductive toxicity risk assessment. Fed Reg 61: 56274–56322.
U.S. EPA (U.S. Environmental Protection Agency). (1998). Health effects test guidelines OPPTS 870.7800 immunotoxicity. (EPA 712-C-98-351). Washington, DC: Prevention, Pesticides and Toxic Substances, U.S. Environmental Protection Agency. http://www.epa.gov/ocspp/pubs/frs/publications/Test_Guidelines/series870.htm.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes [EPA Report]. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2005). Guidelines for carcinogen risk assessment [EPA Report]. (EPA630P03001F). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/cancer_guidelines_final_3-25-05.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2006). A framework for assessing health risk of environmental exposures to children. (EPA/600/R-05/093F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=158363.
U.S. EPA (U.S. Environmental Protection Agency). (2011a). Exposure factors handbook: 2011 edition [EPA Report]. (EPA/600/R-090/052F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Environmental Assessment. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100F2OS.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2011b). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2014a). Estimated fish consumption rates for the U.S. population and selected subpopulations (NHANES 2003-2010) [EPA Report]. (EPA-820-R-14-002). Washington, DC. https://www.epa.gov/sites/production/files/2015-01/documents/fish-consumption-rates-2014.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2014b). Guidance for applying quantitative data to develop data-derived extrapolation factors for interspecies and intraspecies extrapolation [EPA Report]. (EPA/100/R-14/002F). Washington, DC: Risk Assessment Forum, Office of the Science Advisor. https://www.epa.gov/sites/production/files/2015-01/documents/ddef-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016a). Health effects support document for perfluorooctane sulfonate (PFOS) [EPA Report]. (EPA 822-R-16-002). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://www.epa.gov/sites/production/files/2016-05/documents/pfos_hesd_final_508.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016b). Health effects support document for perfluorooctanoic acid (PFOA) [EPA Report]. (EPA 822-R-16-003). Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division. https://www.epa.gov/sites/production/files/2016-05/documents/pfoa_hesd_final-plain.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2016c). The Third Unregulated Contaminant Monitoring Rule. Available online at https://www.epa.gov/dwucmr/third-unregulated-contaminant-monitoring-rule
U.S. EPA (U.S. Environmental Protection Agency). (2018a). Chemistry Dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2018b). An umbrella Quality Assurance Project Plan (QAPP) for PBPK models [EPA Report]. (ORD QAPP ID No: B-0030740-QP-1-1). Research Triangle Park, NC.
U.S. EPA (U.S. Environmental Protection Agency). (2019a). ChemView [Database]. Retrieved from https://chemview.epa.gov/chemview
U.S. EPA (U.S. Environmental Protection Agency). (2019b). CompTox Chemicals Dashboard [Database]. Research Triangle Park, NC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2019c). Systematic review protocol for the PFBA, PFHxA, PFHxS, PFNA, and PFDA IRIS assessments [EPA Report]. (EPA635R19050). Integrated Risk Information System. Center for Public Health and Environmental Assessment. Office of Research and Development. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=345065.
U.S. EPA (U.S. Environmental Protection Agency). (2020). ORD staff handbook for developing IRIS assessments (public comment draft) [EPA Report]. (EPA600R20137). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=350086.
U.S. EPA (U.S. Environmental Protection Agency). (2021a). Human health toxicity values for hexafluoropropylene oxide (HFPO) dimer acid and its ammonium salt (CASRN 13252-13-6 and CASRN 62037-80-3). Also known as “GenX chemicals.” Final report [EPA Report]. (EPA-822R-21-010). Washington, DC: U.S. Environmental Protection Agency, Office of Water.
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Human health toxicity values for perfluorobutane sulfonic acid (CASRN 375-73-5) and related compound potassium perfluorobutane sulfonate (CASRN 29420-49-3) [EPA Report]. (EPA/600/R-20/345F). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=350888.
U.S. EPA (U.S. Environmental Protection Agency). (2021c). Systematic Review Protocol for the PFBA, PFHxA, PFHxS, PFNA, and PFDA (anionic and acid forms) IRIS Assessments: Supplemental Information―Appendix A. (EPA/635/R-19/050). https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=345065.
U.S. EPA (U.S. Environmental Protection Agency). (2021d). Toxicological review of perfluorobutanoic acid (PFBA) and related compound ammonium perfluorobutanoic acid (public comment and external review draft, Aug 2021) [EPA Report]. (EPA/635/R-20/424a). Washington, DC: U.S. Environmental Protection Agency, Integrated Risk Information System. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1014IBF.txt.
U.S. EPA (U.S. Environmental Protection Agency). (2022a). DRAFT: Toxicological review of perfluorohexanoic acid [CASRN 307244] and related salts. (EPA/635/R-21/312a).
U.S. EPA (U.S. Environmental Protection Agency). (2022b). IRIS toxicological review of perfluorobutanoic acid and related salts [EPA Report]. (EPA/635/R-22/277Fa). Washington, D.C.: U.S. Environmental Protection Agency :: U.S. EPA. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0701tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2022c). Review of EPA’s Analysis to Support EPA’s National Primary Drinking Water Rulemaking for PFAS. (EPA-SAB-22-008). U.S. Environmental Protection Agency, Science Advisory Board.
U.S. EPA (U.S. Environmental Protection Agency). (2023a). IRIS toxicological review of perfluorodecanoic acid (PFDA) and related salts (public comment and external review draft). (EPA/635/R-23/056a). https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=354408.
U.S. EPA (U.S. Environmental Protection Agency). (2023b). Toxicological Review of Perfluorohexanoic Acid (PFHxA) and Related Salts (Final Report, 2023) [EPA Report]. (EPA/635/R-23/027F). https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=357314.
U.S. EPA (U.S. Environmental Protection Agency). (2024a). Final Human health toxicity assessment for perfluorooctane sulfonic acid (PFOS) and related salts [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division.
U.S. EPA (U.S. Environmental Protection Agency). (2024b). Final human health toxicity assessment for perfluorooctanoic acid (PFOA) and related salts [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division.
Ullebo, AK; Posserud, M; Heiervang, E; Gillberg, C; Obel, C. (2011). Screening for the attention deficit hyperactivity disorder phenotype using the strength and difficulties questionnaire. Eur Child Adolesc Psychiatry 20: 451–458. 10.1007/s00787-011-0198-9.21833627
Vagi, SJ; Azziz-Baumgartner, E; Sjödin, A; Calafat, AM; Dumesic, D; Gonzalez, L; Kato, K; Silva, MJ; Ye, X; Azziz, R. (2014). Exploring the potential association between brominated diphenyl ethers, polychlorinated biphenyls, organochlorine pesticides, perfluorinated compounds, phthalates, and bisphenol a in polycystic ovary syndrome: a case-control study. BMC Endocrine Disorders 14: 86. 10.1186/1472-6823-14-86.25348326
Valenti, L, . Pelusi, S.,. Bianco, C.,. Ceriotti, F.,. Berzuini, A.,. Iogna Prat, L.,. Trotti, R.,. Malvestiti, F.,. D’Ambrosio, R.,. Lampertico, P.,. Colli, A.,. Colombo, M.,. Tsochatzis, E.,. A. Fraquelli, M.,. Prati, D.,. (2021). Definition of Healthy Ranges for Alanine Aminotransferase Levels: A 2021 Update. Hematology 5: 1824–1832. 10.1002/hep4.1794.
Valvi, D; Højlund, K; Coull, BA; Nielsen, F; Weihe, P; Grandjean, P. (2021). Life-course Exposure to Perfluoroalkyl Substances in Relation to Markers of Glucose Homeostasis in Early Adulthood. J Clin Endocrinol Metab 106: 2495–2504. 10.1210/clinem/dgab267.33890111
Valvi, D; Oulhote, Y; Weihe, P; Dalgård, C; Bjerve, KS; Steuerwald, U; Grandjean, P. (2017). Gestational diabetes and offspring birth size at elevated environmental pollutant exposures. Environ Int 107: 205–215. 10.1016/j.envint.2017.07.016.28753482
van Kerkhof, LWM; Van Dycke, KCG; Jansen, EHJ, M; Beekhof, PK; van Oostrom, CTM; Ruskovska, T; Velickova, N; Kamcev, N; Pennings, JLA; van Steeg, H; Rodenburg, W. (2015). Diurnal variation of hormonal and lipid biomarkers in a molecular epidemiology-like setting. PLoS ONE 10: e0135652. 10.1371/journal.pone.0135652.26285127
Vanden Heuvel, JP; Kuslikis, BI; Van Rafelghem, MJ; Peterson, RE. (1991a). Disposition of perfluorodecanoic acid in male and female rats. Toxicol Appl Pharmacol 107: 450–459. 10.1016/0041-008X(91)90308-2.2000633
Vanden Heuvel, JP; Kuslikis, BI; Van Rafelghem, MJ; Peterson, RE. (1991b). Tissue distribution, metabolism, and elimination of perfluorooctanoic acid in male and female rats. J Biochem Toxicol 6: 83–92. 10.1002/jbt.2570060202.1941903
Vansell, NR. (2022). Mechanisms by Which Inducers of Drug Metabolizing Enzymes Alter Thyroid Hormones in Rats. Drug Metab Dispos 50: 508–517. 10.1124/dmd.121.000498.35046065
Varshavsky, JR; Robinson, JF; Zhou, Y; Puckett, KA; Kwan, E; Buarpung, S; Aburajab, R; Gaw, SL; Sen, S; Gao, SM; Smith, SC; Park, JS; Zakharevich, I; Gerona, RR; Fisher, SJ; Woodruff, TJ. (2021). Organophosphate flame retardants, highly fluorinated chemicals, and biomarkers of placental development and disease during mid-gestation. Toxicol Sci 181: 215–228. 10.1093/toxsci/kfab028.33677611
Varsi, K; Huber, S; Averina, M; Brox, J; Bjørke-Monsen, AL. (2022). Quantitation of linear and branched perfluoroalkane sulfonic acids (PFSAs) in women and infants during pregnancy and lactation. Environ Int 160: 107065. 10.1016/j.envint.2021.107065.34959199
Velarde, MC; Chan, AFO; Sajo, MEJ, V; Zakharevich, I; Melamed, J; Uy, GLB; Teves, JMY; Corachea, AJM; Valparaiso, AP; Macalindong, SS; Cabaluna, ND; Dofitas, RB; Giudice, LC; Gerona, RR. (2022). Elevated levels of perfluoroalkyl substances in breast cancer patients within the Greater Manila Area. Chemosphere 286 Pt 1: 131545. 10.1016/j.chemosphere.2021.131545.
Vélez, MP; Arbuckle, TE; Fraser, WD. (2015). Maternal exposure to perfluorinated chemicals and reduced fecundity: the MIREC study. Hum Reprod 30: 701–709. 10.1093/humrep/deu350.25567616
Verner, MA; Longnecker, MP. (2015). Comment on “enhanced elimination of perfluorooctanesulfonic acid by menstruating women: evidence from population-based pharmacokinetic modeling” [Letter]. Environ Sci Technol 49: 5836–5837. 10.1021/acs.est.5b00187.25871968
Verner, MA; Ngueta, G; Jensen, ET; Fromme, H; Vöelkel, W; Nygaard, UC; Granum, B; Longnecker, MP. (2016). A simple pharmacokinetic model of prenatal and postnatal exposure to perfluoroalkyl substances (PFASs). Environ Sci Technol 50: 978–986. 10.1021/acs.est.5b04399.26691063
Veseli, BE; Perrotta, P; De Meyer, GRA; Roth, L; Van der Donckt, C; Martinet, W; De Meyer, GRY. (2017). Animal models of atherosclerosis. Eur J Pharmacol 816: 3–13. 10.1016/j.ejphar.2017.05.010.28483459
Vesković, M; Pejović, M; Šutulović, N; Hrnčić, D; Rašić-Marković, A; Stanojlović, O; Mladenović, D. (2024). Exploring fibrosis pathophysiology in lean and obese metabolic-associated fatty liver disease: An in-depth comparison. INTERNATIONAL JOURNAL OF MOLECULAR SCIENCES 25. 10.3390/ijms25137405.
Vestergaard, S; Nielsen, F; Andersson, AM; Hjøllund, NH; Grandjean, P; Andersen, HR; Jensen, TK. (2012). Association between perfluorinated compounds and time to pregnancy in a prospective cohort of Danish couples attempting to conceive. Hum Reprod 27: 873–880. 10.1093/humrep/der450.22246448
Viberg, H; Lee, I; Eriksson, P. (2013). Adult dose-dependent behavioral and cognitive disturbances after a single neonatal PFHxS dose. Toxicology 304: 185–191. 10.1016/j.tox.2012.12.013.23287389
Vongphachan, V; Cassone, CG; Wu, DM; Chiu, SZ; Crump, D; Kennedy, SW. (2011). Effects of perfluoroalkyl compounds on mRNA expression levels of thyroid hormone-responsive genes in primary cultures of avian neuronal cells. Toxicol Sci 120: 392–402. 10.1093/toxsci/kfq395.21212296
Vuong, A; Yolton, K; Webster, GM; Sjodin, A; Calafat, AM; Braun, JM; Dietrich, K; Lanphear, BP; Chen, A. (2016). Prenatal polybrominated diphenyl ether and perfluoroalkyl substance exposures and executive function in school-age children. Environ Res 147: 556–564. 10.1016/j.envres.2016.01.008.26832761
Vuong, AM; Braun, JM; Yolton, K; Wang, Z; Xie, C; Webster, GM; Ye, X; Calafat, AM; Dietrich, KN; Lanphear, BP; Chen, A. (2018a). Prenatal and childhood exposure to perfluoroalkyl substances (PFAS) and measures of attention, impulse control, and visual spatial abilities. Environ Int 119: 413–420. 10.1016/j.envint.2018.07.013.30015313
Vuong, AM; Webster, GM; Yolton, K; Calafat, AM; Muckle, G; Lanphear, BP; Chen, A. (2021a). Prenatal exposure to per- and polyfluoroalkyl substances (PFAS) and neurobehavior in US children through 8 years of age: The HOME study. Environ Res 195: 110825. 10.1016/j.envres.2021.110825.33545124
Vuong, AM; Xie, C; Jandarov, R; Dietrich, KN; Zhang, H; Sjödin, A; Calafat, AM; Lanphear, BP; Mccandless, L; Braun, JM; Yolton, K; Chen, A. (2020). Prenatal exposure to a mixture of persistent organic pollutants (POPs) and child reading skills at school age. Int J Hyg Environ Health 228: 113527. 10.1016/j.ijheh.2020.113527.32521479
Vuong, AM; Yolton, K; Wang, Z; Xie, C; Webster, GM; Ye, X; Calafat, AM; Braun, JM; Dietrich, KN; Lanphear, BP; Chen, A. (2018b). Childhood perfluoroalkyl substance exposure and executive function in children at 8 years. Environ Int 119: 212–219. 10.1016/j.envint.2018.06.028.29980044
Vuong, AM; Yolton, K; Xie, C; Dietrich, KN; Braun, JM; Webster, GM; Calafat, AM; Lanphear, BP; Chen, A. (2019). Prenatal and childhood exposure to poly- and perfluoroalkyl substances (PFAS) and cognitive development in children at age 8 years. Environ Res 172: 242–248. 10.1016/j.envres.2019.02.025.30818233
Vuong, AM; Yolton, K; Xie, C; Dietrich, KN; Braun, JM; Webster, GM; Calafat, AM; Lanphear, BP; Chen, A. (2021b). Childhood exposure to per- and polyfluoroalkyl substances (PFAS) and neurobehavioral domains in children at age 8 years. Neurotoxicol Teratol 88: 107022. 10.1016/j.ntt.2021.107022.34438039
Wahlang, B; Beier, JI; Clair, HB; Bellis-Jones, HJ; Falkner, K; Mcclain, CJ; Cave, MC. (2013). Toxicant-associated steatohepatitis [Review]. Toxicol Pathol 41: 343–360. 10.1177/0192623312468517.23262638
Wahlang, B; Jin, J; Beier, JI; Hardesty, JE; Daly, EF; Schnegelberger, RD; Falkner, KC; Prough, RA; Kirpich, IA; Cave, MC. (2019). Mechanisms of environmental contributions to fatty liver disease [Review]. Curr Environ Health Rep 6: 80–94. 10.1007/s40572-019-00232-w.31134516
Wang, B; Fu, J; Gao, K; Liu, Q; Zhuang, L; Zhang, G; Long, M; Na, J; Ren, M; Wang, A; Liang, R; Shen, G; Li, Z; Lu, Q. (2021a). Early pregnancy loss: Do Per- and polyfluoroalkyl substances matter? Environ Int 157: 106837. 10.1016/j.envint.2021.106837.34454360
Wang, B; Zhang, R; Jin, F; Lou, H; Mao, Y; Zhu, W; Zhou, W; Zhang, P; Zhang, J. (2017). Perfluoroalkyl substances and endometriosis-related infertility in Chinese women. Environ Int 102: 207–212. 10.1016/j.envint.2017.03.003.28283302
Wang, F; Zhao, C; Gao, Y; Fu, J; Gao, K; Lv, K; Wang, K; Yue, H; Lan, X; Liang, Y; Wang, Y; Jiang, G. (2019a). Protein-specific distribution patterns of perfluoroalkyl acids in egg yolk and albumen samples around a fluorochemical facility. Sci Total Environ 650: 2697–2704. 10.1016/j.scitotenv.2018.10.006.30296776
Wang, J; Zeng, XW; Bloom, MS; Qian, Z; Hinyard, LJ; Belue, R; Lin, S; Wang, SQ; Tian, YP; Yang, M; Chu, C; Gurram, N; Hu, LW; Liu, KK; Yang, BY; Feng, D; Liu, RQ; Dong, GH. (2019b). Renal function and isomers of perfluorooctanoate (PFOA) and perfluorooctanesulfonate (PFOS): Isomers of C8 Health Project in China. Chemosphere 218: 1042–1049. 10.1016/j.chemosphere.2018.11.191.30609483
Wang, L; Zhang, QM; Wu, ZY; Huang, XW. (2024). A significant presence in atherosclerotic cardiovascular disease: Remnant cholesterol: A review. Medicine (Baltimore) 103: e38754. 10.1097/MD.0000000000038754.38968507
Wang, Y; Aimuzi, R; Nian, M; Zhang, Y; Luo, K; Zhang, J. (2021b). Perfluoroalkyl substances and sex hormones in postmenopausal women: NHANES 2013-2016. Environ Int 149: 106408. 10.1016/j.envint.2021.106408.33548847
Wang, Y; Rogan, WJ; Chen, HY; Chen, PC; Su, PH; Chen, HY; Wang, SL. (2015). Prenatal exposure to perfluroalkyl substances and children’s IQ: The Taiwan maternal and infant cohort study. Int J Hyg Environ Health 218: 639–644. 10.1016/j.ijheh.2015.07.002.26205657
Wang, Y; Rogan, WJ; Chen, PC; Lien, GW; Chen, HY; Tseng, YC; Longnecker, MP; Wang, SL. (2014a). Association between maternal serum perfluoroalkyl substances during pregnancy and maternal and cord thyroid hormones: Taiwan maternal and infant cohort study. Environ Health Perspect 122: 529–534. 10.1289/ehp.1306925.24577800
Wang, Y; Starling, AP; Haug, LS; Eggesbo, M; Becher, G; Thomsen, C; Travlos, G; King, D; Hoppin, JA; Rogan, WJ; Longnecker, MP. (2013). Association between perfluoroalkyl substances and thyroid stimulating hormone among pregnant women: a cross-sectional study. Environ Health 12: 76. 10.1186/1476-069X-12-76.24010716
Wang, Y; Wang, L; Chang, W; Zhang, Y; Zhang, Y; Liu, W. (2019c). Neurotoxic effects of perfluoroalkyl acids: Neurobehavioral deficit and its molecular mechanism. Toxicol Lett 305: 65–72. 10.1016/j.toxlet.2019.01.012.30711673
Wang, Y; Zhang, L; Teng, Y; Zhang, J; Yang, L; Li, J; Lai, J; Zhao, Y; Wu, Y. (2018). Association of serum levels of perfluoroalkyl substances with gestational diabetes mellitus and postpartum blood glucose. J Environ Sci 69: 5–11. 10.1016/j.jes.2018.03.016.
Wang, YM; Chai, SC; Brewer, CT; Chen, T. (2014b). Pregnane X receptor and drug-induced liver injury [Review]. Expert Opin Drug Metab Toxicol 10: 1521–1532. 10.1517/17425255.2014.963555.25252616
Wang, Z; Shi, R; Ding, G; Yao, Q; Pan, C; Gao, Y; Tian, Y. (2022). Association between maternal serum concentration of perfluoroalkyl substances (PFASs) at delivery and acute infectious diseases in infancy. Chemosphere 289: 133235. 10.1016/j.chemosphere.2021.133235.34896425
Watkins, DJ; Josson, J; Elston, B; Bartell, SM; Shin, HM; Vieira, VM; Savitz, DA; Fletcher, T; Wellenius, GA. (2013). Exposure to perfluoroalkyl acids and markers of kidney function among children and adolescents living near a chemical plant. Environ Health Perspect 121: 625–630. 10.1289/ehp.1205838.23482063
Weaver, YM; Ehresman, DJ; Butenhoff, JL; Hagenbuch, B. (2010). Roles of rat renal organic anion transporters in transporting perfluorinated carboxylates with different chain lengths. Toxicol Sci 113: 305–314. 10.1093/toxsci/kfp275.19915082
Webster, GM; Venners, SA; Mattman, A; Martin, JW. (2014). Associations between perfluoroalkyl acids (PFASs) and maternal thyroid hormones in early pregnancy: a population-based cohort study. Environ Res 133: 338–347. 10.1016/j.envres.2014.06.012.25019470
Weiss, JM; Andersson, PL; Lamoree, MH; Leonards, PEG; van Leeuwen, SPJ; Hamers, T. (2009). Competitive Binding of Poly- and Perfluorinated Compounds to the Thyroid Hormone Transport Protein Transthyretin. Toxicol Sci 109: 206–216. 10.1093/toxsci/kfp055.19293372
Weisskopf, MG; Seals, RM; Webster, TF. (2018). Bias amplification in epidemiologic analysis of exposure to mixtures. Environ Health Perspect 126. 10.1289/EHP2450.
Wen, LL; Lin, LY; Su, TC; Chen, PC; Lin, CY. (2013). Association between serum perfluorinated chemicals and thyroid function in U.S. adults: the National Health and Nutrition Examination Survey 2007-2010. J Clin Endocrinol Metab 98: E1456–E1464. 10.1210/jc.2013-1282.23864701
Wexler, JA; Sharretts, J. (2007). Thyroid and bone [Review]. Endocrinol Metab Clin North Am 36: 673–705, vi. 10.1016/j.ecl.2007.04.005.17673124
Whalan, JE. (2015). A toxicologist’s guide to clinical pathology in animals: Hematology, clinical chemistry, urinalysis. Switzerland: Springer International Publishing. 10.1007/978-3-319-15853-2.
WHO (World Health Organization). (2010). WHO laboratory manual for the examination and processing of human semen. In WHO laboratory manual for the examination and processing of human semen (5th ed.). Geneva, Switzerland.
Wielsøe, M; Kern, P; Bonefeld-Jørgensen, EC. (2017). Serum levels of environmental pollutants is a risk factor for breast cancer in Inuit: a case control study. Environ Health 16: 56. 10.1186/s12940-017-0269-6.28610584
Wielsøe, M; Long, M; Ghisari, M; Bonefeld-Jørgensen, EC. (2015). Perfluoroalkylated substances (PFAS) affect oxidative stress biomarkers in vitro. Chemosphere 129: 239–245. 10.1016/j.chemosphere.2014.10.014.25455676
Wikström, S; Hussein, G; Lingroth Karlsson, A; Lindh, CH; Bornehag, CG. (2021). Exposure to perfluoroalkyl substances in early pregnancy and risk of sporadic first trimester miscarriage. Sci Rep 11: 3568. 10.1038/s41598-021-82748-6.33574373
Wikström, S; Lin, PI; Lindh, CH; Shu, H; Bornehag, CG. (2020). Maternal serum levels of perfluoroalkyl substances in early pregnancy and offspring birth weight. Pediatr Res 87: 1093–1099. 10.1038/s41390-019-0720-1.31835271
Wise, LA; Wesselink, AK; Schildroth, S; Calafat, AM; Bethea, TN; Geller, RJ; Coleman, CM; Fruh, V; Claus Henn, B; Botelho, JC; Harmon, QE; Thirkill, M; Wegienka, GR; Baird, DD. (2022). Correlates of plasma concentrations of per- and poly-fluoroalkyl substances among reproductive-aged Black women. Environ Res 203: 111860. 10.1016/j.envres.2021.111860.34403666
Woods, MM; Lanphear, BP; Braun, JM; McCandless, LC. (2017). Gestational exposure to endocrine disrupting chemicals in relation to infant birth weight: A Bayesian analysis of the HOME Study. Environ Health 16: 115. 10.1186/s12940-017-0332-3.29078782
Workman, CE; Becker, AB; Azad, MB; Moraes, TJ; Mandhane, PJ; Turvey, SE; Subbarao, P; Brook, JR; Sears, MR; Wong, CS. (2019). Associations between concentrations of perfluoroalkyl substances in human plasma and maternal, infant, and home characteristics in Winnipeg, Canada. Environ Pollut 249: 758–766. 10.1016/j.envpol.2019.03.054.30933773
Worley, RR; Moore, SM; Tierney, BC; Ye, X; Calafat, AM; Campbell, S; Woudneh, MB; Fisher, J. (2017). Per- and polyfluoroalkyl substances in human serum and urine samples from a residentially exposed community. Environ Int 106: 135–143. 10.1016/j.envint.2017.06.007.28645013
Wright, JM; Larsen, A; Rappazzo, K; Ru, H; Radke, EG; Bateson, TF. (2023). Systematic review and meta-analysis of birthweight and PFNA exposures [Review]. Environ Res 222: 115357. 10.1016/j.envres.2023.115357.36706898
WS (Weston Solutions Inc). (2007). Remedial investigation report. Phase 2. Fluorochemical (FC) data assessment report for the Cottage Grove, MN site. St. Paul, MN: 3M Corporate Toxicology. https://www.pca.state.mn.us/sites/default/files/pfc-cottagegrove-remedialinvestigationreport.pdf.
Xiao, C; Grandjean, P; Valvi, D; Nielsen, F; Jensen, TK; Weihe, P; Oulhote, Y. (2019). Associations of exposure to perfluoroalkyl substances with thyroid hormone concentrations and birth size. J Clin Endocrinol Metab 105: 735–745. 10.1210/clinem/dgz147.
Xiong, X; Chen, B; Wang, Z; Ma, L; Li, S; Gao, Y. (2022). Association between perfluoroalkyl substances concentration and bone mineral density in the US adolescents aged 12-19 years in NHANES 2005-2010. Front Endocrinol (Lausanne) 13: 980608. 10.3389/fendo.2022.980608.36277702
Xu, C; Yin, S; Liu, Y; Chen, F; Zhong, Z; Li, F; Liu, K; Liu, W. (2019). Prenatal exposure to chlorinated polyfluoroalkyl ether sulfonic acids and perfluoroalkyl acids: Potential role of maternal determinants and associations with birth outcomes. J Hazard Mater 380: 120867. 10.1016/j.jhazmat.2019.120867.31330388
Y, A; SC, F; E, R. (2024). Recent insights into the role of hormones during development and their functional regulation. Front Endocrinol (Lausanne) 15. 10.3389/fendo.2024.1340432.
Y, L; X, C; L, Z; X, W; Y, X; Z, Q; G, L; Q, W; K, T; KS, L; CJ, C; J, Z; J., T. (2022). The functional role of lipoproteins in atherosclerosis: novel directions for diagnosis and targeting therapy. 13: 491–520. 10.14336/AD.2021.0929.
Yamauchi, T. (2005). Neuronal Ca2+/calmodulin-dependent protein kinase II - Discovery, progress in a quarter of a century, and perspective: Implication for learning and memory. Biol Pharm Bull 28: 1342–1354. 10.1248/bpb.28.1342.16079472
Yang, A; Chen, L; Xie, Z; Feng, H; Sun, F. (2016a). Constructal heat transfer rate maximization for cylindrical pin-fin heat sinks. Applied Thermal Engineering 108: 427–435. 10.1016/j.applthermaleng.2016.07.150.
Yang, BY; Wu, J; Niu, XL; He, CJ; Bloom, MS; Abudoukade, M; Abulizi, M; Xu, AM; Li, BB; Li, L; Zhong, XM; Wu, QZ; Chu, C; Luo, YN; Liu, XX; Zeng, XW; Yu, YJ; Dong, GH; Zou, XG; Liu, T. (2022a). Low-level environmental per- and polyfluoroalkyl substances and preterm birth: A nested case-control study among a Uyghur population in northwestern China. Exposure and Health 14: 793–805. 10.1007/s12403-021-00454-0.
Yang, CH; Glover, KP; Han, X. (2009). Organic anion transporting polypeptide (Oatp) 1a1-mediated perfluorooctanoate transport and evidence for a renal reabsorption mechanism of Oatp1a1 in renal elimination of perfluorocarboxylates in rats. Toxicol Lett 190: 163–171. 10.1016/j.toxlet.2009.07.011.19616083
Yang, D; Han, J; Hall, DR; Sun, J; Fu, J; Kutarna, S; Houck, KA; Lalone, CA; Doering, JA; Ng, CA; Peng, H. (2020a). Nontarget screening of per- and polyfluoroalkyl substances binding to human liver fatty acid binding protein. Environ Sci Technol 54: 5676–5686. 10.1021/acs.est.0c00049.32249562
Yang, J; Wang, H; Du, H; Fang, H; Han, M; Wang, Y; Xu, L; Liu, S; Yi, J; Chen, Y; Jiang, Q; He, G. (2022b). Exposure to perfluoroalkyl substances was associated with estrogen homeostasis in pregnant women. Sci Total Environ 805: 150360. 10.1016/j.scitotenv.2021.150360.34818773
Yang, J; Wang, H; Du, H; Fang, H; Han, M; Xu, L; Liu, S; Yi, J; Chen, Y; Jiang, Q; He, G. (2020b). Serum perfluoroalkyl substances in relation to lipid metabolism in Chinese pregnant women. Chemosphere 273: 128566. 10.1016/j.chemosphere.2020.128566.33097232
Yang, L; Li, J; Lai, J; Luan, H; Cai, Z; Wang, Y; Zhao, Y; Wu, Y. (2016b). Placental transfer of perfluoroalkyl substances and associations with thyroid hormones: Beijing prenatal exposure study. Sci Rep 6: 21699. 10.1038/srep21699.26898235
Yang, L; Wang, Z; Shi, Y; Li, J; Wang, Y; Zhao, Y; Wu, Y; Cai, Z. (2016c). Human placental transfer of perfluoroalkyl acid precursors: Levels and profiles in paired maternal and cord serum. Chemosphere 144: 1631–1638. 10.1016/j.chemosphere.2015.10.063.26517392
Yang, Q; Guo, X; Sun, P; Chen, Y; Zhang, W; Gao, A. (2018). Association of serum levels of perfluoroalkyl substances (PFASs) with the metabolic syndrome (MetS) in Chinese male adults: A cross-sectional study. Sci Total Environ 621: 1542–1549. 10.1016/j.scitotenv.2017.10.074.29054655
Yang, X; Schnakenberg, LK; Shi, Q; Salminen, WF. (2014). Hepatic toxicity biomarkers. In RC Gupta (Ed.), Biomarkers in Toxicology (pp. 241–259). New York, NY: Academic Press. 10.1016/B978-0-12-404630-6.00013-0.
Yao, J; Dong, Z; Jiang, L; Pan, Y; Zhao, M; Bai, X; Dai, J. (2023a). Emerging and Legacy Perfluoroalkyl Substances in Breastfed Chinese Infants: Renal Clearance, Body Burden, and Implications. Environ Health Perspect 131: 37003–37003. 10.1289/EHP11403.36862174
Yao, J; Pan, Y; Sheng, N; Su, Z; Guo, Y; Wang, J; Dai, J. (2020). Novel perfluoroalkyl ether carboxylic acids (PFECAs) and sulfonic acids (PFESAs): Occurrence and association with serum biochemical parameters in residents living near a fluorochemical plant in China. Environ Sci Technol 54: 13389–13398. 10.1021/acs.est.0c02888.33047597
Yao, Q; Gao, Y; Zhang, Y; Qin, K; Liew, Z; Tian, Y. (2021). Associations of paternal and maternal per- and polyfluoroalkyl substances exposure with cord serum reproductive hormones, placental steroidogenic enzyme and birth weight. Chemosphere 285: 131521. 10.1016/j.chemosphere.2021.131521.34273704
Yao, Q; Shi, R; Wang, C; Han, W; Gao, Y; Zhang, Y; Zhou, Y; Ding, G; Tian, Y. (2019). Cord blood per- and polyfluoroalkyl substances, placental steroidogenic enzyme, and cord blood reproductive hormone. Environ Int 129: 573–582. 10.1016/j.envint.2019.03.047.31174145
Yao, Q; Vinturache, A; Lei, X; Wang, Z; Pan, C; Shi, R; Yuan, T; Gao, Y; Tian, Y. (2022). Prenatal exposure to per- and polyfluoroalkyl substances, fetal thyroid hormones, and infant neurodevelopment. Environ Res 206: 112561. 10.1016/j.envres.2021.112561.34954147
Yao, W; Xu, J; Tang, W; Gao, C; Tao, L; Yu, J; Lv, J; Wang, H; Fan, Y; Xu, DX; Huang, Y. (2023b). Developmental toxicity of perfluorohexane sulfonate at human relevant dose during pregnancy via disruption in placental lipid homeostasis. Environ Int 177: 108014. 10.1016/j.envint.2023.108014.37315490
Yeung, LW; Guruge, KS; Taniyasu, S; Yamashita, N; Angus, PW; Herath, CB. (2013). Profiles of perfluoroalkyl substances in the liver and serum of patients with liver cancer and cirrhosis in Australia. Ecotoxicol Environ Saf 96: 139–146. 10.1016/j.ecoenv.2013.06.006.23849467
Yin, X; Di, T; Cao, X; Liu, Z; Xie, J; Zhang, S. (2021). Chronic exposure to perfluorohexane sulfonate leads to a reproduction deficit by suppressing hypothalamic kisspeptin expression in mice. Journal of Ovarian Research 14: 141. 10.1186/s13048-021-00903-z.34706750
Younossi, ZM; Henry, L. (2024). Understanding the Burden of Nonalcoholic Fatty Liver Disease: Time for Action. Diabetes Spectrum 37: 9–19. 10.2337/dsi23-0010.38385101
Yu, G; Jin, M; Huang, Y; Aimuzi, R; Zheng, T; Nian, M; Tian, Y; Wang, W; Luo, Z; Shen, L; Wang, X; Du, Q; Xu, W; Zhang, J. (2021). Environmental exposure to perfluoroalkyl substances in early pregnancy, maternal glucose homeostasis and the risk of gestational diabetes: A prospective cohort study. Environ Int 156: 106621. 10.1016/j.envint.2021.106621.33984575
Zare Jeddi, M; Dalla Zuanna, T; Barbieri, G; Fabricio, ASC; Daprà, F; Fletcher, T; Russo, F; Pitter, G; Canova, C. (2021). Associations of Perfluoroalkyl Substances with Prevalence of Metabolic Syndrome in Highly Exposed Young Adult Community Residents-A Cross-Sectional Study in Veneto Region, Italy. Int J Environ Res Public Health 18: 1194. 10.3390/ijerph18031194.33572770
Zeng, X; Chen, Q; Zhang, X; Li, H; Liu, Q; Li, C; Ma, M; Zhang, J; Zhang, W; Zhang, J; Huang, L. (2019a). Association between prenatal exposure to perfluoroalkyl substances and asthma-related diseases in preschool children. Environ Sci Pollut Res Int 26: 29639–29648. 10.1007/s11356-019-05864-x.31399834
Zeng, XW; Bloom, MS; Dharmage, SC; Lodge, CJ; Chen, D; Li, S; Guo, Y; Roponen, M; Jalava, P; Hirvonen, MR; Ma, H; Hao, YT; Chen, W; Yang, M; Chu, C; Li, QQ; Hu, LW; Liu, KK; Yang, BY; Liu, S; Fu, C; Dong, GH. (2019b). Prenatal exposure to perfluoroalkyl substances is associated with lower hand, foot and mouth disease viruses antibody response in infancy: Findings from the Guangzhou Birth Cohort Study. Sci Total Environ 663: 60–67. 10.1016/j.scitotenv.2019.01.325.30708217
Zeng, XW; Lodge, CJ; Dharmage, SC; Bloom, MS; Yu, Y; Yang, M; Chu, C; Li, QQ; Hu, LW; Liu, KK; Yang, BY; Dong, GH. (2019c). Isomers of per- and polyfluoroalkyl substances and uric acid in adults: Isomers of C8 Health Project in China. Environ Int 133: 105160. 10.1016/j.envint.2019.105160.31518937
Zeng, XW; Qian, Z; Emo, B; Vaughn, M; Bao, J; Qin, XD; Zhu, Y; Li, J; Lee, YL; Dong, GH. (2015). Association of polyfluoroalkyl chemical exposure with serum lipids in children. Sci Total Environ 512–513: 364–370. 10.1016/j.scitotenv.2015.01.042.
Zhang, BH; Yin, F; Qiao, YN; Guo, SD. (2022a). Triglyceride and triglyceride-rich lipoproteins in atherosclerosis [Review]. Front Mol Biosci 9: 909151. 10.3389/fmolb.2022.909151.35693558
Zhang, H; Yolton, K; Webster, GM; Ye, X; Calafat, AM; Dietrich, KN; Xu, Y; Xie, C; Braun, JM; Lanphear, BP; Chen, A. (2018a). Prenatal and childhood perfluoroalkyl substances exposures and children’s reading skills at ages 5 and 8 years. Environ Int 111: 224–231. 10.1016/j.envint.2017.11.031.29241079
Zhang, JF; Hu, LH; Xu, HY. (2024). Dietary exposure to per- and polyfluoroalkyl substances: Potential health impacts on human liver [Review]. Sci Total Environ 907: 167945. 10.1016/j.scitotenv.2023.167945.37871818
Zhang, Q; Liu, W; Niu, Q; Wang, Y; Zhao, H; Zhang, H; Song, J; Tsuda, S; Saito, N. (2016a). Effects of perfluorooctane sulfonate and its alternatives on long-term potentiation in the hippocampus CA1 region of adult rats in vivo. Toxicology Research 5: 539–546. 10.1039/c5tx00184f.30090368
Zhang, Q; Zhao, H; Liu, W; Zhang, Z; Qin, H; Luo, F; Leng, S. (2016b). Developmental perfluorooctane sulfonate exposure results in tau hyperphosphorylation and β-amyloid aggregation in adults rats: Incidence for link to Alzheimer’s disease. Toxicology 347–349: 40–46. 10.1016/j.tox.2016.03.003.
Zhang, S; Tan, R; Pan, R; Xiong, J; Tian, Y; Wu, J; Chen, L. (2018b). Association of perfluoroalkyl and polyfluoroalkyl substances with premature ovarian insufficiency in Chinese women. J Clin Endocrinol Metab 103: 2543–2551. 10.1210/jc.2017-02783.29986037
Zhang, T; Sun, H; Lin, Y; Qin, X; Zhang, Y; Geng, X; Kannan, K. (2013a). Distribution of poly- and perfluoroalkyl substances in matched samples from pregnant women and carbon chain length related maternal transfer. Environ Sci Technol 47: 7974–7981. 10.1021/es400937y.23777259
Zhang, T; Zhang, B; Bai, X; Yao, Y; Wang, L; Shu, Y; Kannan, K; Huang, X; Sun, H. (2019a). Health status of elderly people living near e-waste recycling sites: association of e-waste dismantling activities with legacy perfluoroalkyl substances (PFASs). Environ Sci Technol Lett 6: 133–140. 10.1021/acs.estlett.9b00085.
Zhang, W; Zhang, D; Zagorevski, DV; Liang, Y. (2019b). Exposure of Juncus effusus to seven perfluoroalkyl acids: Uptake, accumulation and phytotoxicity. Chemosphere 233: 300–308. 10.1016/j.chemosphere.2019.05.258.31176131
Zhang, Y; Beesoon, S; Zhu, L; Martin, JW. (2013b). Biomonitoring of perfluoroalkyl acids in human urine and estimates of biological half-life. Environ Sci Technol 47: 10619–10627. 10.1021/es401905e.23980546
Zhang, Y; Pan, C; Ren, Y; Wang, Z; Luo, J; Ding, G; Vinturache, A; Wang, X; Shi, R; Ouyang, F; Zhang, J; Li, J; Gao, Y; Tian, Y. (2022b). Association of maternal exposure to perfluoroalkyl and polyfluroalkyl substances with infant growth from birth to 12 months: A prospective cohort study. Sci Total Environ 806: 151303. 10.1016/j.scitotenv.2021.151303.34749968
Zhang, YH; Lv, J; Fan, YJ; Tao, L; Xu, JJ; Tang, WT; Sun, N; Zhao, LL; Xu, DX; Huang, YC. (2023). Evaluating the effect of gestational exposure to perfluorohexane sulfonate on placental development in mice combining alternative splicing and gene expression analyses. Environ Health Perspect 131: 117011. 10.1289/EHP13217.37995155
Zhao, W; Zitzow, JD; Ehresman, DJ; Chang, SC; Butenhoff, JL; Forster, J; Hagenbuch, B. (2015). Na+/taurocholate cotransporting polypeptide and apical sodium-dependent bile acid transporter are involved in the disposition of perfluoroalkyl sulfonates in humans and rats. Toxicol Sci 146: 363–373. 10.1093/toxsci/kfv102.26001962
Zhao, W; Zitzow, JD; Weaver, Y; Ehresman, DJ; Chang, SC; Butenhoff, JL; Hagenbuch, B. (2017). Organic anion transporting polypeptides contribute to the disposition of perfluoroalkyl acids in humans and rats. Toxicol Sci 156: 84–95. 10.1093/toxsci/kfw236.28013215
Zhao, X; Lin, JY; Dong, WW; Tang, ML; Yan, SG. (2022). Per- and polyfluoroalkyl substances exposure and bone mineral density in the U.S. population from NHANES 2005-2014. J Expo Sci Environ Epidemiol. 10.1038/s41370-022-00452-7.
Zhou, W; Zhang, L; Tong, C; Fang, F; Zhao, S; Tian, Y; Tao, Y; Zhang, J. (2017a). Plasma perfluoroalkyl and polyfluoroalkyl substances concentration and menstrual cycle characteristics in preconception women. Environ Health Perspect 125: 067012. 10.1289/EHP1203.28657892
Zhou, Y; Hu, LW; Qian, ZM; Chang, JJ; King, C; Paul, G; Lin, S; Chen, PC; Lee, YL; Dong, GH. (2016). Association of perfluoroalkyl substances exposure with reproductive hormone levels in adolescents: By sex status. Environ Int 94: 189–195. 10.1016/j.envint.2016.05.018.27258660
Zhou, Y; Hu, LW; Qian, ZM; Geiger, SD; Parrish, KL; Dharmage, SC; Campbell, B; Roponen, M; Jalava, P; Hirvonen, MR; Heinrich, J; Zeng, XW; Yang, BY; Qin, XD; Lee, YL; Dong, GH. (2017b). Interaction effects of polyfluoroalkyl substances and sex steroid hormones on asthma among children. Sci Rep 7: 899. 10.1038/s41598-017-01140-5.28420867
Zhou, Z; Shi, YL; Vestergren, R; Wang, T; Liang, Y; Cai, YQ. (2014). Highly elevated serum concentrations of perfluoroalkyl substances in fishery employees from Tangxun lake, china. Environ Sci Technol 48: 3864–3874. 10.1021/es4057467.24588690
Zhu, Y; Qin, XD; Zeng, XW; Paul, G; Morawska, L; Su, MW; Tsai, CH; Wang, SQ; Lee, YL; Dong, GH. (2016). Associations of serum perfluoroalkyl acid levels with T-helper cell-specific cytokines in children: By gender and asthma status. Sci Total Environ 559: 166–173. 10.1016/j.scitotenv.2016.03.187.27060656
Zoeller, RT; Crofton, KM. (2005). Mode of action: developmental thyroid hormone insufficiency--neurological abnormalities resulting from exposure to propylthiouracil [Review]. Crit Rev Toxicol 35: 771–781. 10.1080/10408440591007313.16417044
Zoeller, RT; Rovet, J. (2004). Timing of thyroid hormone action in the developing brain: Clinical observations and experimental findings [Review]. J Neuroendocrinol 16: 809–818. 10.1111/j.1365-2826.2004.01243.x.15500540